# Appendix A Detailed Methods

## Appendix A1 Search Strategy

### Ovid MEDLINE® Database Searches for Key Questions 1, 2, and 4

Search Strategy:

1. exp Chlamydia Infections/ or exp Chlamydia
2. Neisseria gonorrhoeae
3. Gonorrhea
4. chlamydi*.ti,ab,kf.
5. (gonorrhe* or gonorrhoe*).ti,ab,kf.
6. or/1-5
7. *Mass Screening
8. (screen* or test*).ti,ab,kf.
9. 7 or 8
10. 6 and 9
11. (random* or control* or group* or cohort or placebo or sham or trial).ti,ab,kw
12. exp cohort studies
13. cohort$.tw.
14. controlled clinical trial.pt.
15. epidemiologic methods
16. limit 15 to yr=1966-1989
17. exp case-control studies
18. (case$ and control$).tw.
19. or/12-14,16-18
20. 11 or 19
21. 10 and 20
22. limit 21 to yr=“2014 -Current”
23. limit 22 to english language

### EBM Reviews - Cochrane Central Register of Controlled Trials for Key Questions 1, 2, and 4

Search Strategy:

1. exp Chlamydia Infections/ or exp Chlamydia
2. Neisseria gonorrhoeae
3. Gonorrhea
4. chlamydi*.ti,ab.
5. (gonorrhe* or gonorrhoe*).ti,ab.
6. or/1-5
7. (screen* or test*).ti,ab.
8. 6 and 7
9. limit 8 to yr=“2014 -Current”
10. limit 9 to english language

### Ovid MEDLINE® Database Searches for Key Questions 3

Search Strategy:

1. exp Chlamydia Infections/ or exp Chlamydia/
2. Neisseria gonorrhoeae/
3. Gonorrhea/
4. chlamydi*.ti,ab,kf.
5. gonorrhe*.ti,ab,kf.
6. or/1-5
7. exp “Sensitivity and Specificity”/
8. (sensitiv* or “predictive value” or accuracy).ti,ab,kf.
9. 7 or 8
10. 6 and 9
11. limit 10 to yr=“2014 - 2019”

### EBM Reviews - Cochrane Central Register of Controlled Trials for Key Questions 3

Search Strategy:

1. exp Chlamydia Infections/ or exp Chlamydia/
2. Neisseria gonorrhoeae/
3. Gonorrhea/
4. chlamydi*.ti,ab,kf.
5. gonorrhe*.ti,ab,kf.
6. or/1-5
7. exp “Sensitivity and Specificity”/
8. (sensitiv* or “predictive value” or accuracy).ti,ab,kf.
9. 7 or 8
10. 6 and 9
11. limit 10 to yr=“2014 - 2019”

### EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

1. chlamydi*.ti,ab,kf.
2. gonorrhoe*.ti,ab.
3. 1 or 2
4. limit 3 to full systematic reviews

## Appendix A2 Inclusion and Exclusion Criteria

| Included | Excluded
Populations | Asymptomatic adults (age ≥18 years) and adolescents (ages 13 to <18 years); pregnant persons | Patients with symptoms of chlamydial or gonococcal infections; patients with current or recent diagnosis of any acute sexually transmitted infection; patients undergoing management for HIV infection; children (age <13 years); studies in which the majority of participants is comprised of persons infected with HIV or persons not infected with HIV and currently using pre-exposure prophylaxis
Interventions | KQs 1, 4: Screening for chlamydial or gonococcal infections; KQ 2: Screening strategies to detect infection, including selective screening of high-risk groups (such as younger persons, men who have sex with men, persons with high-risk sexual behaviors, or persons with high-risk sexual partners); testing for concurrent sexually transmitted infections, including HIV; using defined screening intervals; KQ 3: Test methods and approaches (such as self- vs. clinician-collected) to detect chlamydial or gonococcal infections in biological specimens from various anatomical sites (such as urine specimens and samples from the endocervix, urethra, vagina, anus, or pharynx) | No intervention; no screening
Comparisons | KQs 1, 2: Screening vs. no screening or alternate screening strategies or methods; KQ 3: Gold standard (nucleic acid amplification testing) or other reference standard (if study does not use nucleic acid amplification testing), specific to anatomic site or sites where gold standard sample is collected, when reported | No comparison; testing methods not cleared or approved by the U.S. Food and Drug Administration
Outcomes | KQ 1: Complications of infection (such as pelvic inflammatory disease, ectopic pregnancy, infertility, chronic pelvic pain, or epididymitis); infection transmission or acquisition, including gonorrhea, chlamydia, and HIV; reproductive, pregnancy-related, and perinatal outcomes; KQ 2: Accuracy of screening strategies; KQ 3: Diagnostic accuracy of testing at a specific anatomic site; accuracy of self- vs. clinician-collected specimens; KQ 4: Harms from screening or not screening (such as labeling, false-negative results, false-positive results, or changes in risk perception or risk behaviors) | Intermediate outcomes (outcomes that are not health outcomes, such as eradication of infection or laboratory studies)
Settings | U.S.-relevant primary care and primary care–referable settings (such as correctional settings, community care, schools, sexually transmitted infection clinics, and family planning settings); emergency departments; military or college intake or entrance settings | Other settings not relevant or referable to primary care in the United States
Study Design | All KQs: Good-quality systematic reviews; Benefits: Randomized, controlled trials; controlled observational trials; Harms: Randomized, controlled trials; controlled observational trials; uncontrolled observational trials | Uncontrolled observational trials (except for evidence on screening harms), case reports, small uncontrolled observational trials, and case studies
Study Quality | Fair- and good-quality studies based on USPSTF criteria | Poor-quality studies

Abbreviations: HIV = human immunodeficiency virus, KQ = key question, USPSTF = U.S. Preventive Services Task Force.

## Appendix A3 Literature Flow Diagram

*Included publications may be included for multiple key questions.

Appendix A3 is a literature flow diagram depicting the number of articles screened at each level of the review. After duplicates were removed, 2,356 records were identified through database searching and other sources. In total, 2,356 records were screened at the abstract level for inclusion. 1,866 abstracts were excluded, leaving 490 articles to be assessed at the full-text level. Of these 490 full-text articles, 104 were excluded but used for background and contextual questions and 366 were excluded for not meeting inclusion criteria. The remaining 20 articles were included in the review. For Key Question 1 there were 4 studies included in 4 publications. In Key Question 2, there were 7 studies in 7 publications included. In Key Question 3, there were 9 studies included in 9 publications included. In Key Question 4, there were 8 studies in 8 publications included. The footnote indicates some publications are counted in multiple key questions.

## Appendix A4 List of Included Studies

1 Berry L, Stanley B. Comparison of self-collected meatal swabs with urine specimens for the diagnosis of Chlamydia trachomatis and Neisseria gonorrhoeae in men. J Med Microbiol. 2017 Feb;66(2):134–6. doi: 10.1099/jmm.0.000428. PMID: 28068218.28068218
2 Falasinnu T, Gilbert M, Gustafson P, . Deriving and validating a risk estimation tool for screening asymptomatic chlamydia and gonorrhea. Sex Transm Dis. 2014 Dec;41(12):706–12. doi: 10.1097/OLQ.0000000000000205. PMID: 25581805.25581805
3 Falasinnu T, Gilbert M, Gustafson P, . A validation study of a clinical prediction rule for screening asymptomatic chlamydia and gonorrhoea infections among heterosexuals in British Columbia. Sex Transm Infect. 2016a Feb;92(1):12–8. doi: 10.1136/sextrans-2014-051992. PMID: 25933609.25933609
4 Falasinnu T, Gilbert M, Gustafson P, . An assessment of population-based screening guidelines versus clinical prediction rules for chlamydia and gonorrhea case finding. Prev Med. 2016b Aug;89:51–6. doi: 10.1016/j.ypmed.2016.04.001. PMID: 27143496.27143496
5 Fang J, Husman C, DeSilva L, . Evaluation of self-collected vaginal swab, first void urine, and endocervical swab specimens for the detection of Chlamydia trachomatis and Neisseria gonorrhoeae in adolescent females. J Pediatr Adolesc Gynecol. 2008;21(6):355–60. doi: 10.1016/j.jpag.2008.03.010. PMID: 19064231.19064231
6 Grentzer JM, Peipert JF, Zhao Q, . Risk-based screening for Chlamydia trachomatis and Neisseria gonorrhoeae prior to intrauterine device insertion. Contracept. 2015 Oct;92(4):313–8. doi: 10.1016/j.contraception.2015.06.012. PMID: 26093189.26093189
7 Hocking JS, Temple-Smith M, Guy R, . Population effectiveness of opportunistic chlamydia testing in primary care in Australia: a cluster-randomised controlled trial. Lancet. 2018 Oct 20;392(10156):1413–22. doi: 10.1016/S0140-6736(18)31816-6. PMID: 30343857.30343857
8 Javanbakht M, Westmoreland D, Gorbach P. Factors associated with pharyngeal gonorrhea in young people: implications for prevention. Sex Transm Dis. 2018 Sep;45(9):588–93. doi: 10.1097/OLQ.0000000000000822. PMID: 29485543.29485543
9 Lavoue V, Morcel K, Voltzenlogel MC, . Scoring system avoids Chlamydia trachomatis overscreening in women seeking surgical abortions. Sex Transm Dis. 2014 Aug;41(8):470–4. doi: 10.1097/OLQ.0000000000000153. PMID: 25013973.25013973
10 Miller WC, Hoffman IF, Owen-O’Dowd J, . Selective screening for chlamydial infection: which criteria to use? Am J Prev Med. 2000 Feb;18(2):115–22. doi: 10.1016/s0749-3797(99)00146-4. PMID: 10698241.10698241
11 Nye MB, Osiecki J, Lewinski M, . Detection of Chlamydia trachomatis and Neisseria gonorrhoeae with the cobas CT/NG v2.0 test: performance compared with the BD probetec CT Q and GC Q amplified DNA and aptima AC2 assays. Sex Transm Infect. 2019 03;95(2):87–93. doi: 10.1136/sextrans-2018-053545. PMID: 30126947.30126947
12 Oakeshott P, Kerry S, Aghaizu A, . Randomised controlled trial of screening for Chlamydia trachomatis to prevent pelvic inflammatory disease: the POPI (prevention of pelvic infection) trial. BMJ (Clinical research ed.). 2010 Apr 8;340:c1642. doi: 10.1136/bmj.c1642. PMID: 20378636.20378636
13 Østergaard L, Andersen B, Moller JK, . Home sampling versus conventional swab sampling for screening of Chlamydia trachomatis in women: a cluster-randomized 1-year follow-up study. Clin Infect Dis. 2000 Oct;31(4):951–7. doi: 10.1086/318139. PMID: 11049776.11049776
14 Schachter J, McCormack WM, Chernesky MA, . Vaginal swabs are appropriate specimens for diagnosis of genital tract infection with Chlamydia trachomatis. J Clin Microbiol. 2003 Aug;41(8):3784–9. doi: 10.1128/jcm.41.8.3784-3789.2003. PMID: 12904390.12904390
15 Schoeman SA, Stewart CM, Booth RA, . Assessment of best single sample for finding chlamydia in women with and without symptoms: a diagnostic test study. BMJ (Clinical research ed.). 2012 Dec 12;345:e8013. doi: 10.1136/bmj.e8013. PMID: 23236032.23236032
16 Scholes D, Stergachis A, Heidrich FE, . Prevention of pelvic inflammatory disease by screening for cervical chlamydial infection. N Engl J Med. 1996 May 23;334(21):1362–6. doi: 10.1056/nejm199605233342103. PMID: 8614421.8614421
17 Shrier LA, Dean D, Klein E, . Limitations of screening tests for the detection of Chlamydia trachomatis in asymptomatic adolescent and young adult women. Am J Obstet Gynecol. 2004 Mar;190(3):654–62. doi: 10.1016/j.ajog.2003.09.063. PMID: 15041995.15041995
18 Skidmore S, Kaye M, Bayliss D, . Validation of COBAS Taqman CT for the detection of Chlamydia trachomatis in vulvo-vaginal swabs. Sex Transm Infect. 2008 Aug;84(4):277–8; discussion 8-9. doi: 10.1136/sti.2007.029587. PMID: 18305120.18305120
19 Stewart CM, Schoeman SA, Booth RA, . Assessment of self taken swabs versus clinician taken swab cultures for diagnosing gonorrhoea in women: single centre, diagnostic accuracy study. BMJ (Clinical research ed.). 2012 Dec 12;345:e8107. doi: 10.1136/bmj.e8107. PMID: 23236033.23236033
20 Sultan B, White JA, Fish R, . The “3 in 1” study: pooling self-taken pharyngeal, urethral, and rectal samples into a single sample for analysis for detection of Neisseria gonorrhoeae and Chlamydia trachomatis in men who have sex with men. J Clin Microbiol. 2016 Mar;54(3):650–6. doi: 10.1128/JCM.02460-15. PMID: 26719439.26719439

## Appendix A5 List of Excluded Studies With Reasons for Exclusion

1 Abara WE, Llata EL, Schumacher C, . Extragenital gonorrhea and chlamydia positivity and the potential for missed extragenital gonorrhea with concurrent urethral chlamydia among men who have sex with men attending sexually transmitted disease clinics-Sexually Transmitted Disease Surveillance Network, 2015-2019. Sexually Transmitted Diseases. 2020;47(6):361–8. doi: 10.1097/OLQ.0000000000001170. PMID: 32413018. Exclusion: Wrong outcome.32413018
2 Abbai NS, Moodley P, Reddy T, . Clinical evaluation of the OneStep Gonorrhea RapiCard InstaTest for detection of Neisseria gonorrhoeae in symptomatic patients from KwaZulu-Natal, South Africa. J Clin Microbiol. 2015;53(4):1348–50. doi: 10.1128/JCM.03603-14. PMID: 25609726. Exclusion: Wrong population.25609726
3 Abbai-Shaik NS, Reddy T, Govender S, . Poor performance of the chlamydia rapid test device for the detection of asymptomatic infections in South African men: a pilot study. Sex Transm Dis. 2016;2016:8695146. doi: 10.1155/2016/8695146. PMID: 27195171. Exclusion: Wrong country.27195171
4 Abou Tayoun AN, Burchard PR, Caliendo AM, . A multiplex PCR assay for the simultaneous detection of Chlamydia trachomatis, Neisseria gonorrhoeae, and Trichomonas vaginalis. Exp Mol Pathol. 2015;98(2):214–8. doi: 10.1016/j.yexmp.2015.01.011. PMID: 25595915. Exclusion: Wrong intervention.25595915
5 Adachi K, Klausner JD, Bristow CC, . Chlamydia and gonorrhea in HIV-infected pregnant women and infant HIV transmission. Sex Transm Dis. 2015;42(10):554–65. doi: 10.1097/OLQ.0000000000000340. PMID: 26372927. Exclusion: Wrong population.26372927
6 Adachi K, Klausner JD, Xu J, . Chlamydia trachomatis and Neisseria gonorrhoeae in HIV-infected pregnant women and adverse infant outcomes. Pediatr Infect Dis J. 2016;35(8):894–900. doi: 10.1097/INF.0000000000001199. PMID: 27164464. Exclusion: Wrong population.27164464
7 Adachi K, Xu J, Yeganeh N, . Combined evaluation of sexually transmitted infections in HIV-infected pregnant women and infant HIV transmission. PLoS One. 2018;13(1):e0189851. doi: 10.1371/journal.pone.0189851. PMID: 29304083. Exclusion: Wrong population.29304083
8 Aghaizu A, Reid F, Kerry S, . Frequency and risk factors for incident and redetected Chlamydia trachomatis infection in sexually active, young, multi-ethnic women: a community based cohort study. Sexually Transmitted Infections. 2014;90(7):524–8. doi: 10.1136/sextrans-2014-051607. PMID: 25100744. Exclusion: Wrong outcome.25100744
9 Ahmadi A, Khodabandehloo M, Ramazanzadeh R, . The relationship between Chlamydia trachomatis genital infection and spontaneous abortion. J Reprod Health Med 2016;17(2):110–6. PMID: 27141466. Exclusion: Wrong outcome.27141466
10 Ahmadi MH, Mirsalehian A, Bahador A. Association of Chlamydia trachomatis with infertility and clinical manifestations: a systematic review and meta-analysis of case-control studies. Infect Dis. 2016;48(7):517–23. doi: 10.3109/23744235.2016.1160421. PMID: 27064452. Exclusion: Wrong outcome.27064452
11 Ako MC, Lewis M, Peterson S, . The clinical impact of rapid diagnostics on improving appropriate treatment of STIs in women in the emergency department. Sex Transm Dis. 2016;43(10):S136-. Exclusion: Wrong publication type.
12 Akoh CC, Pressman EK, Cooper E, . Prevalence and risk factors for infections in a pregnant adolescent population. J Pediatr Adolesc Gynecol. 2017;30(1):71–5. doi: 10.1016/j.jpag.2016.08.001. PMID: 27521899. Exclusion: Wrong study design for Key Question.27521899
13 Ampt FH, El Hayek C, Agius PA, . Anorectal swabs as a marker of male-to-male sexual exposure in STI surveillance systems. Epidemiol Infect. 2017;145(12):2530–5. doi: 10.1017/S095026881700098X. PMID: 28528588. Exclusion: Wrong outcome.28528588
14 Anaene M, Soyemi K, Caskey R. Factors associated with the over-treatment and under-treatment of gonorrhea and chlamydia in adolescents presenting to a public hospital emergency department. Int J Infect Dis. 2016;53:34–8. doi: 10.1016/j.ijid.2016.10.009. PMID: 27771470. Exclusion: Wrong outcome.27771470
15 Andreatos N, Grigoras C, Shehadeh F, . The impact of HIV infection and socioeconomic factors on the incidence of gonorrhea: a county-level, US-wide analysis. PLoS One. 2017;12(9):e0183938. doi: 10.1371/journal.pone.0183938. PMID: 28863154. Exclusion: Wrong outcome.28863154
16 Atkinson LM, Vijeratnam D, Mani R, . ‘The waiting game’: are current chlamydia and gonorrhoea near-patient/point-of-care tests acceptable to service users and will they impact on treatment? Int J STD AIDS. 2016;27(8):650–5. doi: 10.1177/0956462415591414. PMID: 26092579. Exclusion: Wrong intervention.26092579
17 August EM, Daley E, Kromrey J, . Age-related variation in sexual behaviours among heterosexual men residing in Brazil, Mexico and the USA. J Fam Plann Reprod Health Care. 2014;40(4):261–9. doi: 10.1136/jfprhc-2012-100564. PMID: 24099979. Exclusion: Wrong comparator.24099979
18 Badman SG, Willie B, Narokobi R, . A diagnostic evaluation of a molecular assay used for testing and treating anorectal chlamydia and gonorrhoea infections at the point-of-care in Papua New Guinea. Clin Microbiol Infect. 2019;25(5):623–7. doi: 10.1016/j.cmi.2018.08.001. PMID: 30107282. Exclusion: Wrong country.30107282
19 Badolato GM, Goyal MK. Refining a computerized sexual health screening tool among adolescents presenting to the emergency department. Journal of Adolescent Health. 2019;64(2):S41-. Exclusion: Wrong publication type.
20 Baird J, Merchant RC. A randomized controlled trial of the effects of a brief intervention to increase chlamydia and gonorrhea testing uptake among young adult female emergency department patients. Acad Emerg Med. 2014;21(12):1512–20. doi: 10.1111/acem.12539. PMID: 25491714. Exclusion: Wrong outcome.25491714
21 Balendra A, Cousins E, Lamplough H, . Pilot study for the ‘test n treat’ trial of on-site rapid chlamydia/gonorrhoea tests and same day treatment. Sex Transm Infect. 2017;93(4):283. doi: 10.1136/sextrans-2016-053084. PMID: 28576786. Exclusion: Wrong comparator.28576786
22 Banerjee P, Thorley N, Radcliffe K. A service evaluation comparing home-based testing to clinic-based testing for chlamydia and gonorrhoea in Birmingham and Solihull. International Journal of STD & AIDS. 2018;29(10):974–9. doi: 10.1177/0956462418767180. PMID: 29690825. Exclusion: Wrong intervention.29690825
23 Barbee LA, Dombrowski JC, Kerani R, . Effect of nucleic acid amplification testing on detection of extragenital gonorrhea and chlamydial infections in men who have sex with men sexually transmitted disease clinic patients. Sex Transm Dis. 2014;41(3):168–72. doi: 10.1097/OLQ.0000000000000093. PMID: 24521722. Exclusion: Wrong outcome.24521722
24 Barbee LA, Khosropour CM, Dombrowksi JC, . New Human Immunodeficiency Virus Diagnosis Independently Associated With Rectal Gonorrhea and Chlamydia in Men Who Have Sex With Men. Sexually Transmitted Diseases. 2017;44(7):385–9. doi: 10.1097/OLQ.0000000000000614. PMID: 28608786. Exclusion: Wrong intervention.28608786
25 Barbee LA, Khosropour CM, Dombrowski JC, . An estimate of the proportion of symptomatic gonococcal, chlamydial and non-gonococcal non-chlamydial urethritis attributable to oral sex among men who have sex with men: a case-control study. Sex Transm Infect. 2016;92(2):155–60. doi: 10.1136/sextrans-2015-052214. PMID: 26297719. Exclusion: Wrong population.26297719
26 Barnard S, Free C, Bakolis I, . Comparing the characteristics of users of an online service for STI self-sampling with clinic service users: a cross-sectional analysis. Sex Transm Infect. 2018;94(5):377–83. doi: 10.1136/sextrans-2017-053302. PMID: 29437985. Exclusion: Wrong outcome.29437985
27 Bartelsman M, Straetemans M, Vaughan K, . Comparison of two gram stain point-of-care systems for urogenital gonorrhoea among high-risk patients: diagnostic accuracy and cost-effectiveness before and after changing the screening algorithm at an STI clinic in Amsterdam. Sex Transm Infect. 2014;90(5):358–62. doi: 10.1136/sextrans-2013-051500. PMID: 24860102. Exclusion: Wrong comparator.24860102
28 Bartelsman M, van Rooijen MS, Alba S, . Point-of-care management of urogenital Chlamydia trachomatis via gram-stained smear analysis in male high-risk patients. Diagnostic accuracy and cost-effectiveness before and after changing the screening indication at the STI clinic in Amsterdam. Sex Transm Infect. 2015;91(7):479–84. doi: 10.1136/sextrans-2014-051941. PMID: 25855625. Exclusion: Wrong study design for Key Question.25855625
29 Batteiger TA, Dixon BE, Wang J, . Where do people go for gonorrhea and chlamydia tests: a cross-sectional view of the central Indiana population, 2003-2014. Sex Transm Infect. 2019;46(2):132–6. doi: 10.1097/OLQ.0000000000000928. PMID: 30334869. Exclusion: Wrong study design for Key Question.30334869
30 Baud D, Zufferey J, Hohlfeld P, . Performance of an automated multiplex immunofluorescence assay for detection of Chlamydia trachomatis immunoglobulin G. Diagn Microbiol Infect Dis. 2014;78(3):217–9. doi: 10.1016/j.diagmicrobio.2013.11.022. PMID: 24365033. Exclusion: Wrong outcome.24365033
31 Bazan JA, Carr Reese P, Esber A, . High prevalence of rectal gonorrhea and chlamydia infection in women attending a sexually transmitted disease clinic. J Womens Health. 2015;24(3):182–9. doi: 10.1089/jwh.2014.4948. PMID: 25692800. Exclusion: Wrong outcome.25692800
32 Beanland F, Schoeman S, Davis P, . A year of ‘sex, steam and stis’. Sex Transm Infect. Conference: BASHH Spring Conference. 2015;91. Exclusion: Wrong comparator.
33 Bellaminutti S, Seraceni S, De Seta F, . HPV and Chlamydia trachomatis co-detection in young asymptomatic women from high incidence area for cervical cancer. J Med Virol. 2014;86(11):1920–5. doi: 10.1002/jmv.24041. PMID: 25132162. Exclusion: Wrong comparator.25132162
34 Bercot B, Amarsy R, Goubard A, . Assessment of coinfection of sexually transmitted pathogen microbes by use of the anyplex II STI-7 molecular kit. J Clin Microbiol. 2015;53(3):991–3. doi: 10.1128/JCM.03370-14. PMID: 25540390. Exclusion: Wrong intervention.25540390
35 Beymer MR, Bolan RK, Flynn RP, . Uptake and repeat use of postexposure prophylaxis in a community-based clinic in Los Angeles, California. AIDS Res Hum Retroviruses. 2014;30(9):848–55. doi: 10.1089/AID.2014.0017. PMID: 24970113. Exclusion: Wrong outcome.24970113
36 Beymer MR, Llata E, Stirland AM, . Evaluation of gonorrhea test of cure at 1 week in a Los Angeles community-based clinic serving men who have sex with men. Sex Transm Dis. 2014;41(10):595–600. doi: 10.1097/OLQ.0000000000000190. PMID: 25211254. Exclusion: Wrong population.25211254
37 Bilder CR, Tebbs JM, McMahan CS. Informative group testing for multiplex assays. Biometrics. 2019;75(1):278–88. doi: 10.1111/biom.12988. PMID: 30353548. Exclusion: Wrong comparator.30353548
38 Booth AR, Norman P, Goyder E, . Pilot study of a brief intervention based on the theory of planned behaviour and self-identity to increase chlamydia testing among young people living in deprived areas. Br J Health Psychol. 2014;19(3):636–51. doi: 10.1111/bjhp.12065. PMID: 24103040. Exclusion: Wrong outcome.24103040
39 Borchardt LN, Pickett ML, Tan KT, . Expedited partner therapy: pharmacist refusal of legal prescriptions. Sexually Transmitted Diseases. 2018;45(5):350–3. doi: 10.1097/OLQ.0000000000000751. PMID: 29465689. Exclusion: Wrong outcome.29465689
40 Bosmans LJ. Conquering chlamydia. Creat Nurs. 2014;20(4):248–53. PMID: 26050420. Exclusion: Wrong publication type.26050420
41 Bourgeois-Nicolaos N, Jaureguy F, Pozzi-Gaudin S, . Benefits of rapid molecular diagnosis of Chlamydia trachomatis and Neisseria gonorrhoeae infections in women attending family planning clinics. Sex Transm Dis. 2015;42(11):652–3. doi: 10.1097/OLQ.0000000000000351. PMID: 26462191. Exclusion: Wrong outcome.26462191
42 Boyajian AJ, Murray M, Tucker M, . Identifying variations in adherence to the CDC sexually transmitted disease treatment guidelines of Neisseria gonorrhoeae. Public Health. 2016;136:161–5. doi: 10.1016/j.puhe.2016.04.004. PMID: 27179879. Exclusion: Wrong study design for Key Question.27179879
43 Breslin K, Tuchman L, Hayes KL, . Sensitivity and specificity of empiric treatment for sexually transmitted infections in a pediatric emergency department. J Pediatr. 2017;189:48–53. doi: 10.1016/j.jpeds.2017.05.050. PMID: 28629687. Exclusion: Wrong study design for Key Question.28629687
44 Bristow CC, Mathelier P, Ocheretina O, . Chlamydia trachomatis, Neisseria gonorrhoeae, and Trichomonas vaginalis screening and treatment of pregnant women in Port-au-Prince, Haiti. Int J STD AIDS. 2017;28(11):1130–4. doi: 10.1177/0956462416689755. PMID: 28134005. Exclusion: Wrong outcome.28134005
45 Brook G. The performance of non-NAAT point-of-care (POC) tests and rapid NAAT tests for chlamydia and gonorrhoea infections. An assessment of currently available assays. Sex Transm Infect. 2015;91(8):539–44. doi: 10.1136/sextrans-2014-051997. PMID: 25935930. Exclusion: Wrong publication type.25935930
46 Brown B, Davtyan M, Leon SR, . A prospective cohort study characterising the role of anogenital warts in HIV acquisition among men who have sex with men: a study protocol. BMJ Open. 2014;4(9):e005687. doi: 10.1136/bmjopen-2014-005687. PMID: 25227629. Exclusion: Wrong study design for Key Question.25227629
47 Brown S, Paterson C, Dougall N, . Understanding the attitudes and acceptability of extra-genital chlamydia testing in young women: evaluation of a feasibility study. BMC Public Health. 2019;19(1):992. doi: 10.1186/s12889-019-7313-0. PMID: 31340797. Exclusion: Wrong intervention.31340797
48 Browne FA, Wechsberg WM, Kizakevich PN, . mHealth versus face-to-face: study protocol for a randomized trial to test a gender-focused intervention for young African American women at risk for HIV in North Carolina. BMC Public Health. 2018;18(1):982. doi: 10.1186/s12889-018-5796-8. PMID: 30081868. Exclusion: Wrong study design for Key Question.30081868
49 Burchell AN, Grewal R, Allen VG, . Modest rise in chlamydia and gonorrhoea testing did not increase case detection in a clinical HIV cohort in Ontario, Canada. Sex Transm Infect. 2014;90(8):608–14. doi: 10.1136/sextrans-2014-051647. PMID: 25178285. Exclusion: Wrong population.25178285
50 Burgess S, Beltrami J, Kearns L, . The Louisiana Wellness Centers Program for HIV/STD prevention among gay and bisexual men and transgender persons. J Public Health Manag Pract. 2019;22:22. doi: 10.1097/PHH.0000000000000959. PMID: 30807464. Exclusion: Wrong outcome.30807464
51 Butzler MA, Reed JL, McFall SM. A simple and rapid DNA extraction method for Chlamydia trachomatis detection from urogenital swabs. Diagn Microbiol Infect Dis. 2017;89(3):182–4. doi: 10.1016/j.diagmicrobio.2017.08.007. PMID: 28918068. Exclusion: Wrong intervention.28918068
52 Byrne R, Cooper F, Appleby T, . Can express treatment reduce onward transmission? Sexually Transmitted Infections. Conference: BASHH Spring Conference. 2015;91. Exclusion: Wrong publication type.
53 Callander D, Cook T, Read P, . Sexually transmissible infections among transgender men and women attending Australian sexual health clinics. Medical Journal of Australia. 2019;211(9):406–11. doi: 10.5694/mja2.50322. PMID: 31468530. Exclusion: Wrong intervention.31468530
54 Callander D, Guy R, Fairley CK, . Gonorrhoea gone wild: rising incidence of gonorrhoea and associated risk factors among gay and bisexual men attending Australian sexual health clinics. Sex Health. 2018;09:09. doi: 10.1071/SH18097. PMID: 30409244. Exclusion: Wrong outcome.30409244
55 Camporiondo MP, Farchi F, Ciccozzi M, . Detection of HPV and co-infecting pathogens in healthy Italian women by multiplex real-time PCR. Infez Med. 2016;24(1):12–7. PMID: 27031891. Exclusion: Wrong outcome.27031891
56 Cassell JA, Dodds J, Estcourt C, . The relative clinical effectiveness and cost-effectiveness of three contrasting approaches to partner notification for curable sexually transmitted infections: a cluster randomised trial in primary care. Health Technol Assess. 2015;19(5):1–115, vii–viii. doi: 10.3310/hta19050. PMID: 25619445. Exclusion: Wrong outcome.25619445
57 Castell S, Krause G, Schmitt M, . Feasibility and acceptance of cervicovaginal self-sampling within the German National Cohort (pretest 2). Bundesgesundheitsblatt, Gesundheitsforschung, Gesundheitsschutz. 2014;57(11):1270–6. doi: 10.1007/s00103-014-2054-9. PMID: 25303829. Exclusion: Wrong outcome.25303829
58 Causer LM, Guy RJ, Tabrizi SN, . Molecular test for chlamydia and gonorrhoea used at point of care in remote primary healthcare settings: a diagnostic test evaluation. Sex Transm Infects. 2018;94(5):340–5. doi: 10.1136/sextrans-2017-053443. PMID: 29748180. Exclusion: Wrong intervention.29748180
59 Chacko MR, Markham C, Thiel M, . Feasibility of providing sexually transmitted infection testing and treatment in off-campus, nonclinic settings for adolescents enrolled in a school-based research project. J Sch Health. 2014;84(6):379–86. doi: 10.1111/josh.12159. PMID: 24749920. Exclusion: Wrong outcome.24749920
60 Chai SJ, Aumakhan B, Barnes M, . Internet-based screening for sexually transmitted infections to reach nonclinic populations in the community: risk factors for infection in men. Sex Transm Dis. 2010;37(12):756–63. doi: 10.1097/OLQ.0b013e3181e3d771. PMID: 20644498. Exclusion: Wrong comparator.20644498
61 Chamberlain N, Crosby RA, Mena L, . Is patient-reported exposure a reliable indicator for anogenital gonorrhea and chlamydia screening in young black men who have sex with men? Sexually transmitted diseases. 2017;44(7):390–2. doi: 10.1097/OLQ.0000000000000619. PMID: 28608787Exclusion: Wrong comparator.28608787
62 Chambers R, Tingey L, Beach A, . Testing the efficacy of a brief sexual risk reduction intervention among high-risk American Indian adults: study protocol for a randomized controlled trial. BMC Public Health. 2016;16:366. doi: 10.1186/s12889-016-3040-y. PMID: 27129956. Exclusion: Wrong publication type.27129956
63 Chandra NL, Broad C, Folkard K, . Detection of Chlamydia trachomatis in rectal specimens in women and its association with anal intercourse: a systematic review and meta-analysis. Sex Transm Infect. 2018;94(5):320–6. doi: 10.1136/sextrans-2017-053161. PMID: 29431148. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.29431148
64 Chernesky M, Jang D, Aries M, . Self-obtained vaginal swabs detected more Chlamydia trachomatis, Neisseria gonorrhoeae and Mycoplasma genitalium infections than first catch urine collected at home compared to a clinic. Sexually Transmitted Diseases. 2018;45doi: 10.1097/OLQ.0b013e31815d968d. Exclusion: Wrong publication type.
65 Chernesky M, Jang D, Gilchrist J, . Head-to-head comparison of second-generation nucleic acid amplification tests for detection of Chlamydia trachomatis and Neisseria gonorrhoeae on urine samples from female subjects and self-collected vaginal swabs. J Clin Microbiol. 2014;52(7):2305–10. doi: 10.1128/JCM.03552-13. PMID: 24696024. Exclusion: Wrong intervention.24696024
66 Chernesky MA, Martin DH, Hook EW, . Ability of new APTIMA CT and APTIMA GC assays to detect Chlamydia trachomatis and Neisseria gonorrhoeae in male urine and urethral swabs. J Clin Microbiol. 2005;43(1):127–31. doi: 10.1128/jcm.43.1.127-131.2005. PMID: 15634960. Exclusion: Wrong intervention.15634960
67 Chow EP, Camilleri S, Ward C, . Duration of gonorrhoea and chlamydia infection at the pharynx and rectum among men who have sex with men: a systematic review. Sex Health. 2016;13(3):199–204. doi: 10.1071/SH15175. PMID: 26886136. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.26886136
68 Chow EP, Tomnay J, Fehler G, . Substantial increases in chlamydia and gonorrhea positivity unexplained by changes in individual-level sexual behaviors among men who have sex with men in an Australian sexual health service from 2007 to 2013. Sex Transm Dis. 2015;42(2):81–7. doi: 10.1097/OLQ.0000000000000232. PMID: 25585066. Exclusion: Wrong outcome.25585066
69 Chow EPF, Walker S, Read TRH, . Self-reported use of mouthwash and pharyngeal gonorrhoea detection by nucleic acid amplification test. Sex Transm Dis. 2017;44(10):593–5. doi: 10.1097/OLQ.0000000000000654. PMID: 28876323. Exclusion: Wrong outcome.28876323
70 Clark JL, Segura ER, Oldenburg CE, . Expedited Partner Therapy (EPT) increases the frequency of partner notification among MSM in Lima, Peru: a pilot randomized controlled trial. BMC Medicine. 2017;15(1):94. doi: 10.1186/s12916-017-0858-9. PMID: 28468648. Exclusion: Wrong outcome.28468648
71 Clemenzi-Allen AA, Hartogensis W, Cohen SE, . Evaluating the impact of housing status on gonorrhea and chlamydia screening in an HIV primary care setting. Sex Transm Dis. 2019;46(3):153–8. doi: 10.1097/OLQ.0000000000000939. PMID: 30383619. Exclusion: Wrong population.30383619
72 Clifton JM. Screening for chlamydia, gonorrhea, and high-risk sexual behaviors in Utah’s juvenile justice population: results and implications for practice. J Pediatr Health Care. 2018;32(4):374–80. doi: 10.1016/j.pedhc.2017.12.008. PMID: 29551274. Exclusion: Wrong outcome.29551274
73 Clifton S, Mercer C, Cassell J, . Does chlamydia testing in general practice mean missed opportunities for the diagnosis of other STIs?: a comparison of the population tested in general practice versus sexual health clinics in Britain. Sex Transm Infect. Conference: BASHH Spring Conference. 2015;91. Exclusion: Wrong publication type.
74 Cole J, Hotton A, Zawitz C, . Opt-out screening for Chlamydia trachomatis and Neisseria gonorrhoeae in female detainees at Cook County jail in Chicago, IL. Sex Transm Dis. 2014;41(3):161–5. doi: 10.1097/OLQ.0000000000000106. PMID: 24521720. Exclusion: Wrong study design for Key Question.24521720
75 Coll J, Videla S, Leon A, . Early detection of HIV infection and of asymptomatic sexually transmitted infections among men who have sex with men. Clin Microbiol Infect. 2018;24(5):540–5. doi: 10.1016/j.cmi.2017.08.012. PMID: 28843621. Exclusion: Wrong comparator.28843621
76 Cook RL, Hutchison SL, Ostergaard L, . Systematic review: noninvasive testing for Chlamydia trachomatis and Neisseria gonorrhoeae. Ann Intern Med. 2005;142(11):914–25. doi: 10.7326/0003-4819-142-11-200506070-00010. PMID: 15941699. Exclusion: Wrong comparator.15941699
77 Cornelisse VJ, Walker S, Phillips T, . Risk factors for oropharyngeal gonorrhoea in men who have sex with men: an age-matched case-control study. Sex Transm Infect. 2018;94(5):359–64. doi: 10.1136/sextrans-2017-053381. PMID: 29358525. Exclusion: Wrong outcome.29358525
78 Cosentino LA, Danby CS, Rabe LK, . Use of nucleic acid amplification testing for diagnosis of extragenital sexually transmitted infections. J Clin Microbiol. 2017;55(9):2801–7. doi: 10.1128/JCM.00616-17. PMID: 28679521. Exclusion: Wrong intervention.28679521
79 Crichton J, Hickman M, Campbell R, . Socioeconomic factors and other sources of variation in the prevalence of genital chlamydia infections: a systematic review and meta-analysis. BMC Public Health. 2015;15:729. doi: 10.1186/s12889-015-2069-7. PMID: 26224062. Exclusion: Wrong outcome.26224062
80 Cushman TA, Graves SK, Little SJ. Attitudes and preferences regarding the use of rapid self-testing for sexually transmitted infections and HIV in San Diego area men who have sex with men. Open Forum Infectious Diseases. 2019;6(3) doi: 10.1093/ofid/ofz043. PMID: 30906798. Exclusion: Wrong outcome.30906798
81 Danby CS, Cosentino LA, Rabe LK, . Patterns of extragenital chlamydia and gonorrhea in women and men who have sex with men reporting a history of receptive anal intercourse. Sex Transm Dis. 2016;43(2):105–9. doi: 10.1097/OLQ.0000000000000384. PMID: 26766527. Exclusion: Wrong comparator.26766527
82 Dangerfield DT, Farley JE, Holden J, . Acceptability of self-collecting oropharyngeal swabs for sexually transmissible infection testing among men and women. Sex Health. 2019;16(3):296–8. doi: 10.1071/sh18209. PMID: 30898197. Exclusion: Wrong intervention.30898197
83 Dasarathan S, Kalaivani S. Study of prevalence of sexually transmitted infections/human immunodeficiency virus and condom use among male-to-female transgender: a retrospective analysis from a tertiary care hospital in Chennai. Indian J Sex Trasmitted Dis AIDS. 2017;38(1):43–6. doi: 10.4103/0253-7184.196889. PMID: 28442802. Exclusion: Wrong outcome.28442802
84 Davies B, Turner KME, Frolund M, . Risk of reproductive complications following chlamydia testing: a population-based retrospective cohort study in Denmark. Lancet Infect Dis. 2016;16(9):1057–64. doi: 10.1016/S1473-3099(16)30092-5. PMID: 27289389. Exclusion: Wrong outcome.27289389
85 Davies B, Ward H, Leung S, . Heterogeneity in risk of pelvic inflammatory diseases after chlamydia infection: a population-based study in Manitoba, Canada. J Infect Dis. 2014;210 Suppl 2:S549–55. doi: 10.1093/infdis/jiu483. PMID: 25381374. Exclusion: Wrong outcome.25381374
86 Davis A, Goddard-Eckrich D, Dasgupta A, . Risk factors associated with sexually transmitted infections among women under community supervision in New York City. Int J STD AIDS. 2018;29(8):766–75. doi: 10.1177/0956462418755223. PMID: 29471763. Exclusion: Wrong study design for Key Question.29471763
87 De Baetselier I, Smet H, Abdellati S, . Evaluation of the ‘colli-pee’, a first-void urine collection device for self-sampling at home for the detection of sexually transmitted infections, versus a routine clinic-based urine collection in a one-to-one comparison study design: efficacy and acceptability among MSM in Belgium. BMJ Open. 2019;9(4):e028145. doi: 10.1136/bmjopen-2018-028145. PMID: 30948618. Exclusion: Wrong population.30948618
88 de Vries HJ. Sexually transmitted infections in men who have sex with men. Clin Dermatol. 2014;32(2):181–8. doi: 10.1016/j.clindermatol.2013.08.001. PMID: 24559552. Exclusion: Wrong study design for Key Question.24559552
89 de Vrieze NH, van Rooijen MS, van de Loeff MS, . Additional gonorrhea and chlamydia infections found with rapid follow-up screening in men who have sex with men with an indication for HIV postexposure prophylaxis. Sex Transm Dis. 2014;41(8):515–7. doi: 10.1097/OLQ.0000000000000151. PMID: 25013982. Exclusion: Wrong population.25013982
90 de Waaij DJ, Dubbink JH, Peters RP, . Comparison of GMT presto assay and roche cobas 4800 CT/NG assay for detection of Chlamydia trachomatis and Neisseria gonorrhoeae in dry swabs. J Microbiol Methods. 2015;118:70–4. doi: 10.1016/j.mimet.2015.08.020. PMID: 26327539. Exclusion: Wrong intervention.26327539
91 Desir FA, Ladd JH, Gaydos CA. Survey of partner notification practices for sexually transmissible infections in the United States. Sex Health. 2016;13(2):162–9. doi: 10.1071/SH15136. PMID: 26841251. Exclusion: Wrong intervention.26841251
92 Dionne-Odom J, Westfall AO, Van Der Pol B, . Sexually transmitted infection prevalence in women with HIV: is there a role for targeted screening? Sex Transm Dis. 2018;45(11):762–9. doi: 10.1097/OLQ.0000000000000852. PMID: 29642121. Exclusion: Wrong population.29642121
93 Dirks J, Hoebe C, van Liere G, . Standardisation is necessary in urogenital and extragenital Chlamydia trachomatis bacterial load determination by quantitative PCR: a review of literature and retrospective study. Sex Transm Infect. 2019;07:07. doi: 10.1136/sextrans-2018-053522. PMID: 30733424. Exclusion: Wrong outcome.30733424
94 DiVasta AD, Trudell EK, Francis M, . Practice-based quality improvement collaborative to increase chlamydia screening in young women. Pediatrics. 2016;137(5):05. doi: 10.1542/peds.2015-1082. PMID: 27244777. Exclusion: Wrong study design for Key Question.27244777
95 Dize L, Agreda P, Quinn N, . Comparison of self-obtained penile-meatal swabs to urine for the detection of C. trachomatis, N. gonorrhoeae and T. vaginalis. Sex Transm Infect. 2013;89(4):305–7. doi: 10.1136/sextrans-2012-050686. PMID: 23093735. Exclusion: Wrong population.23093735
96 Dize L, Barnes P, Jr., Barnes M, . Performance of self-collected penile-meatal swabs compared to clinician-collected urethral swabs for the detection of Chlamydia trachomatis, Neisseria gonorrhoeae, Trichomonas vaginalis, and Mycoplasma genitalium by nucleic acid amplification assays. Diagn Microbiol Infect Dis. 2016;86(2):131–5. doi: 10.1016/j.diagmicrobio.2016.07.018. PMID: 27497595. Exclusion: Wrong population.27497595
97 Domeika M, Bassiri M, Butrimiene I, . Evaluation of vaginal introital sampling as an alternative approach for the detection of genital Chlamydia trachomatis infection in women. Acta Obstet Gynecol Scand. 1999;78(2):131–6. PMID: 10023876. Exclusion: Wrong country.10023876
98 Drinkard LN, Huxta RA, Halbritter A, . The case for extragenital screening of Chlamydia trachomatis and Neisseria gonorrhoeae in the college health setting. Sex Transm Dis. 2017;44(5):274–7. doi: 10.1097/OLQ.0000000000000593. PMID: 28407642. Exclusion: Wrong comparator.28407642
99 Dukers-Muijrers N, van Rooijen MS, Hogewoning A, . Incidence of repeat testing and diagnoses of Chlamydia trachomatis and Neisseria gonorrhoea in swingers, homosexual and heterosexual men and women at two large Dutch STI clinics, 2006-2013. Sex Transm Infect. 2017;93(6):383–9. doi: 10.1136/sextrans-2016-052807. PMID: 28373241. Exclusion: Wrong study design for Key Question.28373241
100 Dukers-Muijrers NH, Theunissen KA, Wolffs PT, . Acceptance of home-based chlamydia genital and anorectal testing using short message service (SMS) in previously tested young people and their social and sexual networks. PLoS One. 2015;10(7):e0133575. doi: 10.1371/journal.pone.0133575. PMID: 26230085. Exclusion: Wrong intervention.26230085
101 Dukers-Muijrers NH, Wolffs PF, Eppings L, . Design of the FemCure study: prospective multicentre study on the transmission of genital and extra-genital Chlamydia trachomatis infections in women receiving routine care. BMC Infect Dis. 2016;16:381. doi: 10.1186/s12879-016-1721-x. PMID: 27502928. Exclusion: Wrong publication type.27502928
102 Earnest R, Ronn MM, Bellerose M, . Population-level benefits of extragenital gonorrhea screening among men who have sex with men: an exploratory modeling analysis. Sexually Transmitted Diseases. 2020;29:29. doi: 10.1097/OLQ.0000000000001189. PMID: 32355108. Exclusion: Wrong intervention.32355108
103 Eboigbodin KE, Hoser MJ. Multiplex strand invasion based amplification (mSIBA) assay for detection of Chlamydia trachomatis and Neisseria gonorrhoeae. Scientific Reports. 2016;6:20487. doi: 10.1038/srep20487. PMID: 26837460. Exclusion: Wrong intervention.26837460
104 Edouard S, Tamalet C, Tissot-Dupont H, . Evaluation of self-collected rectal swabs for the detection of bacteria responsible for sexually transmitted infections in a cohort of HIV-1-infected patients. J Med Microbiol. 2017;08:08. doi: 10.1099/jmm.0.000481. PMID: 28590237. Exclusion: Wrong population.28590237
105 Estcourt C, Sutcliffe L, Mercer CH, . The ballseye programme: a mixed-methods programme of research in traditional sexual health and alternative community settings to improve the sexual health of men in the UK. NIHR Journals Library. Programme Grants for Applied Research. 2016;12:12. doi: 10.3310/pgfar04200. PMID: 27997089. Exclusion: Wrong outcome.27997089
106 Estcourt CS, Gibbs J, Sutcliffe LJ, . The esexual health clinic system for management, prevention, and control of sexually transmitted infections: exploratory studies in people testing for Chlamydia trachomatis. Lancet Public Health. 2017;2(4):e182–e90. doi: 10.1016/S2468-2667(17)30034-8. PMID: 29253450. Exclusion: Wrong study design for Key Question.29253450
107 Fajardo-Bernal L, Angel-Muller E, Aponte-Gonzalez J, . Home-based specimen collection for Chlamydia trachomatis and Neisseria gonorrhoeae testing does not improve clinical management outcomes: systematic review. Sex Transm Infect. 2015;91:A56–A7. doi: 10.1136/sextrans-2015-052270.156. Exclusion: Wrong publication type.
108 Fajardo-Bernal L, Aponte-Gonzalez J, Vigil P, . Home-based versus clinic-based specimen collection in the management of Chlamydia trachomatis and Neisseria gonorrhoeae infections. Cochrane Database Syst Rev. 2015 (9):CD011317. doi: 10.1002/14651858.CD011317.pub2. PMID: 2641812826418128. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.
109 Falasinnu T, Gilbert M, Hottes TS, . Predictors identifying those at increased risk for STDs: a theory-guided review of empirical literature and clinical guidelines. Int J STD AIDS. 2015;26(12):839–51. doi: 10.1177/0956462414555930. PMID: 25324350. Exclusion: Wrong outcome.25324350
110 Fernandez G, Martro E, Gonzalez V, . Usefulness of a novel multiplex real-time PCR assay for the diagnosis of sexually-transmitted infections. Enferm Infecc Microbiol Clin. 2016;34(8):471–6. doi: 10.1016/j.eimc.2015.10.014. PMID: 26706392. Exclusion: Wrong intervention.26706392
111 Fernando KA, Fowler T, Harding J, . Detecting re-infection in patients after an initial diagnosis of gonorrhoea: is routine recall for re-screening useful? Int J STD AIDS. 2015;26(9):640–7. doi: 10.1177/0956462414548905. PMID: 25161175. Exclusion: Wrong population.25161175
112 Ferrero DV, Meyers HN, Ferrero GM, . Self-collected glans/meatal ‘dry’ swab specimen and NAAT technology detects Chlamydia trachomatis and Neisseria gonorrhoeae - implications for public policy changes. Int J STD AIDS. 2017;28(10):985–90. doi: 10.1177/0956462416684693. PMID: 28632470. Exclusion: Wrong population.28632470
113 Field N, Hughes G, Kennedy I, . Response letter to T Fowler and co-authors - estimating the positive predictive value of opportunistic population testing for gonorrhoea as part of the english chlamydia screening programme. Int J STD AIDS. 2014;25(9):692. doi: 10.1177/0956462414535205. PMID: 24810212. Exclusion: Wrong publication type.24810212
114 Field N, Kennedy I, Folkard K, . Screening for gonorrhoea using samples collected through the english national chlamydia screening programme and risk of false positives: a national survey of local authorities. BMJ Open. 2014;4(10):e006067. doi: 10.1136/bmjopen-2014-006067. PMID: 25324326. Exclusion: Wrong comparator.25324326
115 Footman A, Dionne-Odom J, Aaron KJ, . Performance of four molecular assays for detection of chlamydia and gonorrhea in a sample of HIV positive men who have sex with men. Sexually Transmitted Diseases. 2019;47(3):158–61. doi: 10.1097/OLQ.0000000000001115. PMID: 31842087. Exclusion: Wrong population.
116 Forbes G, Drayton R. Testing for pharyngeal gonorrhoea in women: an important reservoir of infection, or excessive false positive diagnoses. Sex Transm Inf. Conference: BASHH Spring Conference. 2015;91:A20. doi: 10.1136/sextrans-2015-052126.58. Exclusion: Wrong publication type.
117 Foschi C, Gaspari V, Sgubbi P, . Sexually transmitted rectal infections in a cohort of ‘men having sex with men’. J Med Microbiol. 2018;67(8):1050–7. doi: 10.1099/jmm.0.000781. PMID: 29927376. Exclusion: Wrong study design for Key Question.29927376
118 Foschi C, Nardini P, Banzola N, . Chlamydia trachomatis infection prevalence and serovar distribution in a high-density urban area in the north of Italy. J Med Microbiol. 2016;65(6):510–20. doi: 10.1099/jmm.0.000261. PMID: 27046236. Exclusion: Wrong intervention.27046236
119 Fouere S, Dimi S, Timsit J, . The DRIVER study: asymptomatic STI systematic screening versus targeted screening according to STI risk factors in a cohort of outpatients HIV-infected MSM seen in France-phase 1 results. J Int AIDS Soc. Conference: international congress of drug therapy in HIV infection. 2016;19:110. doi: 10.7448/IAS.19.8.21487. Exclusion: Wrong publication type.
120 Free C, McCarthy O, French RS, . Can text messages increase safer sex behaviours in young people? Intervention development and pilot randomised controlled trial. Health Technol Assess. 2016;20(57):1–82. doi: 10.3310/hta20570. PMID: 27483185. Exclusion: Wrong intervention.27483185
121 Freeman AH, Bernstein KT, Kohn RP, . Evaluation of self-collected versus clinician-collected swabs for the detection of Chlamydia trachomatis and Neisseria gonorrhoeae pharyngeal infection among men who have sex with men. Sex Transm Dis. 2011;38(11):1036–9. doi: 10.1097/OLQ.0b013e318227713e. PMID: 21992980. Exclusion: Wrong population.21992980
122 Frej-Madrzak M, Grybos A, Grybos M, . PCR diagnostics of Chlamydia trachomatis in asymptomatic infection by women. Ginekol Pol. 2018;89(3):115–9. doi: 10.5603/GP.a2018.0020. PMID: 29664545. Exclusion: Wrong outcome.29664545
123 Fuller SS, Mercer CH, Copas AJ, . The SPORTSMART study: a pilot randomised controlled trial of sexually transmitted infection screening interventions targeting men in football club settings. Sex Transm Infect. 2015;91(2):106–10. doi: 10.1136/sextrans-2014-051719. PMID: 25512674. Exclusion: Wrong outcome.25512674
124 Fung M, Scott KC, Kent CK, . Chlamydial and gonococcal reinfection among men: a systematic review of data to evaluate the need for retesting. Sex Transm Infect. 2007;83(4):304–9. doi: 10.1136/sti.2006.024059. PMID: 17166889. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.17166889
125 Galarraga O, Sosa-Rubi SG, Gonzalez A, . The disproportionate burden of HIV and STIs among male sex workers in Mexico City and the rationale for economic incentives to reduce risks. J Int AIDS Soc. 2014;17(19218) doi: 10.7448/IAS.17.1.19218. PMID: 25399543. Exclusion: Wrong outcome.25399543
126 Garbers S, Friedman A, Martinez O, . Adapting the get yourself tested campaign to reach black and latino sexual-minority youth. Health Promot Pract. 2016;17(5):739–50. doi: 10.1177/1524839916647329. PMID: 27225216. Exclusion: Wrong study design for Key Question.27225216
127 Garlock J, Lee L, Cucci M, . Suspected gonorrhea and chlamydia: incidence and utilization of empiric antibiotics in a health system emergency department. Am J Emerg Med. 2019;37(5):884–9. doi: 10.1016/j.ajem.2018.08.015. PMID: 30119987. Exclusion: Wrong study design for Key Question.30119987
128 Garner AL, Schembri G, Cullen T, . Should we screen heterosexuals for extra-genital chlamydial and gonococcal infections? Int J STD AIDS. 2015;26(7):462–6. doi: 10.1177/0956462414543120. PMID: 25013220. Exclusion: Wrong outcome.25013220
129 Garofalo R, Hotton AL, Kuhns LM, . Incidence of HIV infection and sexually transmitted infections and related risk factors among very young men who have sex with men. J Acquir Immune Defic Syndr. 2016;72(1):79–86. doi: 10.1097/QAI.0000000000000933. PMID: 26745827. Exclusion: Wrong outcome.26745827
130 Gaydos C, Hardick J. Point of care diagnostics for sexually transmitted infections: perspectives and advances. Expert Rev Anti Infect Ther. 2014;12(6):657–72. doi: 10.1586/14787210.2014.880651. PMID: 24484215. Exclusion: Wrong study design for Key Question.24484215
131 Gaydos C, Lewis M, Michele-Corinne AKO, . Use of rapid diagnostics for chlamydia and gonorrhoea for women in the emergency department can improve clinical management: report of a randomised clinical trial. Sex Transm Infect. 2017;93(Supplement 2):A107. doi: 10.1136/sextrans-2017-053264.275. Exclusion: Wrong population.
132 Gaydos CA. Review of use of a new rapid real-time PCR, the cepheid genexpert (Xpert) CT/NG assay, for Chlamydia trachomatis and Neisseria gonorrhoeae: results for patients while in a clinical setting. Expert Rev Mol Diagn. 2014;14(2):135–7. doi: 10.1586/14737159.2014.871495. PMID: 24450867. Exclusion: Wrong publication type.24450867
133 Gaydos CA. Let’s take a “Selfie”: self-collected samples for sexually transmitted infections. Sexually transmitted diseases. 2018b;45(4):278–9. doi: 10.1097/olq.0000000000000785. PMID: 29528988. Exclusion: Wrong outcome.29528988
134 Gaydos CA, Ako MC, Lewis M, . Use of a rapid diagnostic for Chlamydia trachomatis and Neisseria gonorrhoeae for women in the emergency department can improve clinical management: report of a randomized clinical trial. Ann Emerg Med. 2018;74(1):36–44. doi: 10.1016/j.annemergmed.2018.09.012. PMID: 30392736. Exclusion: Wrong publication type.30392736
135 Gaydos CA, Jett-Goheen M, Barnes M, . Use of a risk quiz to predict infection for sexually transmitted infections: a retrospective analysis of acceptability and positivity. Sex Transm Infect. 2016;92(1):44–8. doi: 10.1136/sextrans-2015-052058. PMID: 26285773. Exclusion: Wrong outcome.26285773
136 Gaydos CA, Van Der Pol B, Jett-Goheen M, . Performance of the cepheid CT/NG xpert rapid PCR test for detection of Chlamydia trachomatis and Neisseria gonorrhoeae. J Clin Microbiol. 2013;51(6):1666–72. doi: 10.1128/jcm.03461-12. PMID: 23467600. Exclusion: Wrong intervention.23467600
137 Geiger R, Smith DM, Little SJ, . Validation of the genexpert CT/NG assay for use with male pharyngeal and rectal swabs. Austin J HIV AIDS Res. 2016;3(1):pii. PMID: 27536736. Exclusion: Wrong intervention.27536736
138 Giguere K, Alary M. Targeting core groups for gonorrhoea control: feasibility and impact. Sex Transm Infect. 2015;91(4):241–4. doi: 10.1136/sextrans-2014-051732. PMID: 25926404. Exclusion: Wrong publication type.25926404
139 Gimenes F, Medina FS, Abreu AL, . Sensitive simultaneous detection of seven sexually transmitted agents in semen by multiplex-PCR and of HPV by single PCR. PLoS One. 2014;9(6):e98862. doi: 10.1371/journal.pone.0098862. PMID: 24921247. Exclusion: Wrong intervention.24921247
140 Goddard SL, Poynten IM, Petoumenous K, . Prevalence, incidence and predictors of anal Chlamydia trachomatis, anal Neisseria gonorrhoeae and syphilis among older gay and bisexual men in the longitudinal study for the prevention of anal cancer (SPANC). Sex Transm Infect. 2019:pii. doi: 10.1136/sextrans-2019-054011. PMID: 3101899231018992. Exclusion: Wrong intervention.
141 Gokhale P, Madrigal JM, Aparicio J, . Demographic and other characteristics, and rates of sexually transmitted infections among adolescents who underwent multiple abortions in 1 year. J Pediatr Adolesc Gynecol. 2018;31(6):610–3. doi: 10.1016/j.jpag.2018.07.011. PMID: 30081083. Exclusion: Wrong intervention.30081083
142 Golden MR, Kerani RP, Stenger M, . Uptake and population-level impact of expedited partner therapy (EPT) on Chlamydia trachomatis and Neisseria gonorrhoeae: the Washington State community-level randomized trial of EPT. PLoS Medicine / Public Library of Science. 2015;12(1):e1001777. doi: 10.1371/journal.pmed.1001777. PMID: 25590331. Exclusion: Wrong outcome.25590331
143 Golparian D, Borang S, Sundqvist M, . Evaluation of the new BD Max GC Real-Time PCR assay, analytically and clinically as a supplementary test for the BD ProbeTec GC Qx Amplified DNA assay, for molecular detection of Neisseria gonorrhoeae. J Clin Microbiol. 2015;53(12):3935–7. doi: 10.1128/JCM.01962-15. PMID: 26468501. Exclusion: Wrong comparator.26468501
144 Golparian D, Hellmark B, Unemo M. Analytical specificity and sensitivity of the novel dual-target GeneProof Neisseria gonorrhoeae PCR kit for detection of N. gonorrhoeae. APMIS. 2015;123(11):955–8. doi: 10.1111/apm.12440. PMID: 26332192. Exclusion: Wrong outcome.26332192
145 Gotz HM, Bom RJ, Wolfers ME, . Use of Chlamydia trachomatis high-resolution typing: an extended case study to distinguish recurrent or persistent infection from new infection. Sex Transm Infect. 2014;90(2):155–60. doi: 10.1136/sextrans-2013-051218. PMID: 24234071. Exclusion: Wrong population.24234071
146 Gotz HM, Veldhuijzen IK, Habbema JD, . Prediction of Chlamydia trachomatis infection: application of a scoring rule to other populations. Sex Transm Dis. 2006;33(6):374–80. doi: 10.1097/01.olq.0000194585.82456.51. PMID: 16505746. Exclusion: Wrong comparator.16505746
147 Goyal MK, Teach SJ, Badolato GM, . Universal screening for sexually transmitted infections among asymptomatic adolescents in an urban emergency department: high acceptance but low prevalence of infection. J Pediatr. 2016;171:128–32. doi: 10.1016/j.jpeds.2016.01.019. PMID: 26846572. Exclusion: Wrong outcome.26846572
148 Goyal MK, Witt R, Hayes KL, . Clinician adherence to recommendations for screening of adolescents for sexual activity and sexually transmitted infection/human immunodeficiency virus. J Pediatr. 2014;165(2):343–7. doi: 10.1016/j.jpeds.2014.04.009. PMID: 24840761. Exclusion: Wrong population.24840761
149 Grad AI, Vica ML, Matei HV, . Polymerase chain reaction as a diagnostic tool for six sexually transmitted infections - preliminary results. Clujul Med. 2015;88(1):33–7. doi: 10.15386/cjmed-373. PMID: 26528045. Exclusion: Wrong population.26528045
150 Graham S, Guy RJ, Wand HC, . A sexual health quality improvement program (SHIMMER) triples chlamydia and gonorrhoea testing rates among young people attending aboriginal primary health care services in Australia. BMC Infect Dis. 2015;15:370. doi: 10.1186/s12879-015-1107-5. PMID: 26329123. Exclusion: Wrong outcome.26329123
151 Grandcolin S, de Hauteclocque A, Lafoscade A, . Performance of a standardized interrogation to improve the screening of Chlamydia trachomatis infection. J Gynecol Obstet Biol Reprod 2015;44(8):685–91. doi: 10.1016/j.jgyn.2014.09.003. PMID: 25307616. Exclusion: Not English language but possibly relevant.25307616
152 Graseck AS, Secura GM, Allsworth JE, . Home compared with clinic-based screening for sexually transmitted infections: a randomized controlled trial. Obstet Gynecol. 2010;116(6):1311–8. doi: 10.1097/AOG.0b013e3181fae60d. PMID: 21099596. Exclusion: Wrong outcome.21099596
153 Gratrix J, Singh AE, Bergman J, . Evidence for increased chlamydia case finding after the introduction of rectal screening among women attending 2 Canadian sexually transmitted infection clinics. Clin Infect Dis. 2015;60(3):398–404. doi: 10.1093/cid/ciu831. PMID: 25336625. Exclusion: Wrong outcome.25336625
154 Gray RT, Callander D, Hocking JS, . Population-level diagnosis and care cascade for chlamydia in Australia. Sex Transm Infect. 2019;96(2):131–6. doi: 10.1136/sextrans-2018-053801. PMID: 31167824. Exclusion: Wrong publication type.31167824
155 Green A, Kerry-Barnard S, Fleming C, . Medical students’ experiences optimising follow-up in ethnically diverse, sexually active 16-24 year olds participating in the ‘test n treat’ feasibility trial of rapid chlamydia tests. Educ Prim Care. 2018;29(4):242–3. doi: 10.1080/14739879.2018.1480425. PMID: 29869588. Exclusion: Wrong publication type.29869588
156 Green A, Kerry-Barnard S, Fleming C, . Optimising follow-up at 7 months in ethnically diverse, sexually active 16-24 year olds taking part in the ‘test n treat’ feasibility trial of rapid chlamydia/gonorrhoea tests. HIV Med. 2018;19:S139. Exclusion: Wrong publication type.
157 Green N, Sherrard-Smith E, Tanton C, . Assessing local chlamydia screening performance by combining survey and administrative data to account for differences in local population characteristics. Sci Rep. 2019;9(7070) doi: 10.1038/s41598-019-43521-y. PMID: 31068656. Exclusion: Wrong intervention.31068656
158 Greiner MV, Beal SJ, Nause K, . Laboratory screening for children entering foster care. Pediatr. 2017;140(6) doi: 10.1542/peds.2016-3778. PMID: 29141915. Exclusion: Wrong outcome.29141915
159 GrilloArdila CF, Torres M, Gaitan HG, . Rapid point of care test for detecting urogenital Chlamydia trachomatis infection in nonpregnant women and men at reproductive age. Cochrane Database Syst Rev. 2015 (5) doi: 10.1002/14651858.CD011708. Exclusion: Wrong publication type.
160 Grov C, Cain D, Rendina HJ, . Characteristics associated with urethral and rectal gonorrhea and chlamydia diagnoses in a US national sample of gay and bisexual men: results from the one thousand strong panel. Sex Transm Dis. 2016;43(3):165–71. doi: 10.1097/OLQ.0000000000000410. PMID: 26859803. Exclusion: Wrong outcome.26859803
161 Gueye SB, Diop-Ndiaye H, Gningue A, . Performance of the abbott real time CT/NG assay in urines and cervico-vaginal samples from Senegal. J Infect Dev Ctries. 2014;8(7):898–903. doi: 10.3855/jidc.4026. PMID: 25022301. Exclusion: Wrong outcome.25022301
162 Guirguis-Blake JM, Henderson JT, Perdue LA. Periodic screening pelvic examination: evidence report and systematic review for the US preventive services task force. JAMA. 2017;317(9):954–66. doi: 10.1001/jama.2016.12819. PMID: 28267861. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.28267861
163 Gupta K, Brown L, Bakshi RK, . Performance of Chlamydia trachomatis OmcB enzyme-linked immunosorbent assay in serodiagnosis of Chlamydia trachomatis infection in women. J Clin Microbiol. 2018;56(9):e00275–18. doi: 10.1128/JCM.00275-18. PMID: 29899001. Exclusion: Wrong population.29899001
164 Guy RJ, Causer LM, Klausner JD, . Performance and operational characteristics of point-of-care tests for the diagnosis of urogenital gonococcal infections. Sex Transm Infect. 2017;93(S4):S16–S21. doi: 10.1136/sextrans-2017-053192. PMID: 29223959. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.29223959
165 Guy RJ, Micallef JM, Mooney-Somers J, . Evaluation of chlamydia partner notification practices and use of the “let them know” website by family planning clinicians in Australia: cross-sectional study. J Med Internet Res. 2016;18(6):e173. doi: 10.2196/jmir.5441. PMID: 27342438. Exclusion: Wrong population.27342438
166 Guy RJ, Ward J, Causer LM, . Molecular point-of-care testing for chlamydia and gonorrhoea in indigenous Australians attending remote primary health services (TTANGO): a cluster-randomised, controlled, crossover trial. Lancet Infect Dis. 2018;18(10):1117–26. doi: 10.1016/S1473-3099(18)30429-8. PMID: 30303108. Exclusion: Wrong outcome.30303108
167 Gwyn S, Cooley G, Goodhew B, . Comparison of platforms for testing antibody responses against the Chlamydia trachomatis antigen pgp3. Am J Trop Med Hyg. 2017;97(6):1662–8. doi: 10.4269/ajtmh.17-0292. PMID: 29016320. Exclusion: Wrong population.29016320
168 Hafner JW, Schaefer TJ. Sensitivity and specificity of the vaginal wet prep. J Emerg Med. 2014;46(1):83–4. doi: 10.1016/j.jemermed.2012.12.027. PMID: 24188598. Exclusion: Wrong publication type.24188598
169 Hagemann CT, Nordbo SA, Myhre AK, . Sexually transmitted infections among women attending a Norwegian sexual assault centre. Sex Transm Infect. 2014;90(4):283–9. doi: 10.1136/sextrans-2013-051328. PMID: 24567522. Exclusion: Wrong study design for Key Question.24567522
170 Hahn A, Schwarz NG, Meyer T, . PCR-based rapid diagnostic tests as a strategy for preventing infections with sexually transmitted diseases-a ‘diagnostics-as-prevention’ modelling approach. Lett Appl Microbiol. 2018;67(4):420–4. doi: 10.1111/lam.13059. PMID: 30074254. Exclusion: Wrong study design for Key Question.30074254
171 Ham JY, Jung J, Hwang BG, . Highly sensitive and novel point-of-care system, aqcare chlamydia TRF kit for detecting Chlamydia trachomatis by using europium (Eu) (III) chelated nanoparticles. Ann Lab Med. 2015;35(1):50–6. doi: 10.3343/alm.2015.35.1.50. PMID: 25553280. Exclusion: Wrong population.25553280
172 Han Y, Yin YP, Shi MQ, . Evaluation of abbott realtime CT/NG assay for detection of Chlamydia trachomatis and Neisseria gonorrhoeae in cervical swabs from female sex workers in China. PLoS One. 2014;9(3):e89658. doi: 10.1371/journal.pone.0089658. PMID: 24599315. Exclusion: Wrong comparator.24599315
173 Hananta IPY, van Dam AP, Bruisten SM, . Value of light microscopy to diagnose urogenital gonorrhoea: a diagnostic test study in Indonesian clinic-based and outreach sexually transmitted infections services. BMJ Open. 2017;7(8):e016202. doi: 10.1136/bmjopen-2017-016202. PMID: 28801418. Exclusion: Wrong comparator.28801418
174 Harding-Esch EM, Cousins EC, Chow SC, . A 30-min nucleic acid amplification point-of-care test for genital Chlamydia trachomatis infection in women: a prospective, multi-center study of diagnostic accuracy. EBioMedicine. 2018;28:120–7. doi: 10.1016/j.ebiom.2017.12.029. PMID: 29396306. Exclusion: Wrong intervention.29396306
175 Harding-Esch EM, Fuller SS, Chow SC, . Diagnostic accuracy of a prototype rapid chlamydia and gonorrhoea recombinase polymerase amplification assay: a multicentre cross-sectional preclinical evaluation. Clin Microbiol Infect. 2019;25(3):380.e1–.e7. doi: 10.1016/j.cmi.2018.06.003. PMID: 29906594. Exclusion: Wrong intervention.29906594
176 Hay PE, Kerry SR, Normansell R, . Which sexually active young female students are most at risk of pelvic inflammatory disease? A prospective study. Sex Transm Infect. 2016;92(1):63–6. doi: 10.1136/sextrans-2015-052063. PMID: 26082320. Exclusion: Wrong outcome.26082320
177 Hengel B, Wand H, Ward J, . Patient, staffing and health centre factors associated with annual testing for sexually transmissible infections in remote primary health centres. Sex Health. 2017;14(3):274–81. doi: 10.1071/SH16123. PMID: 28445684. Exclusion: Wrong outcome.28445684
178 Herbst de Cortina S, Bristow CC, Joseph Davey D, . A systematic review of point of care testing for Chlamydia trachomatis, Neisseria gonorrhoeae, and Trichomonas vaginalis. Infect Dis Obstet Gynecol. 2016;2016(4386127) doi: 10.1155/2016/4386127. PMID: 27313440. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.27313440
179 Hill MG, Menon S, Smith S, . Screening for chlamydia and gonorrhea cervicitis and implications for pregnancy outcome. Are we testing and treating at the right time? J Reprod Med. 2015;60(7-8):301–8. PMID: 26380488. Exclusion: Wrong comparator.26380488
180 Hill-Tout R, Harding-Esch EM, Pacho A, . Health-related quality of life and psychosocial impacts of a diagnosis of non-specific genital infection in symptomatic heterosexual men attending UK sexual health clinics: a feasibility study. BMJ Open. 2018;8(6):e018213. doi: 10.1136/bmjopen-2017-018213. PMID: 29960999. Exclusion: Wrong population.29960999
181 Hiransuthikul A, Janamnuaysook R, Sungsing T, . High burden of chlamydia and gonorrhoea in pharyngeal, rectal and urethral sites among Thai transgender women: implications for anatomical site selection for the screening of STI. Sex Transm Infect. 2019;0:1–6. doi: 10.1136/sextrans-2018-053835. PMID: 30982000. Exclusion: Wrong population.30982000
182 Hiransuthikul A, Pattanachaiwit S, Teeratakulpisarn N, . High subsequent and recurrent sexually transmitted infection prevalence among newly diagnosed HIV-positive Thai men who have sex with men and transgender women in the test and treat cohort. Int J STD AIDS. 2019;30(2):140–6. doi: 10.1177/0956462418799213. PMID: 30296916. Exclusion: Wrong comparator.30296916
183 Hocking J. Screening for chlamydia: does it work, results from accept. Sex Transm Infec. 2015;91:A3. Exclusion: Wrong publication type.
184 Hoenderboom BM, van Ess EF, van den Broek IVF, . Chlamydia trachomatis antibody detection in home-collected blood samples for use in epidemiological studies. J Microbiol Methods. 2018;144:164–7. doi: 10.1016/j.mimet.2017.11.022. PMID: 29196272. Exclusion: Wrong outcome.29196272
185 Holland-Hall CM, Wiesenfeld HC, Murray PJ. Self-collected vaginal swabs for the detection of multiple sexually transmitted infections in adolescent girls. J Pediatr Adolesc Gynecol. 2002;15(5):307–13. PMID: 12547662. Exclusion: Wrong outcome.12547662
186 Homsy J, King R, Bannink F, . Primary HIV prevention in pregnant and lactating Ugandan women: a randomized trial. PLoS One. 2019;14(2):e0212119. doi: 10.1371/journal.pone.0212119. PMID: 30802277. Exclusion: Wrong intervention.30802277
187 Horner PJ, Wills GS, Righarts A, . Chlamydia trachomatis pgp3 antibody persists and correlates with self-reported infection and behavioural risks in a blinded cohort study. PLoS One. 2016;11(3):e0151497. doi: 10.1371/journal.pone.0151497. PMID: 26974653. Exclusion: Wrong outcome.26974653
188 Horst AL, Rosenbohm JM, Kolluri N, . A paperfluidic platform to detect Neisseria gonorrhoeae in clinical samples. Biomed Microdevices. 2018;20(2):35. doi: 10.1007/s10544-018-0280-x. PMID: 29644437. Exclusion: Wrong outcome.29644437
189 Hosenfeld CB, Workowski KA, Berman S, . Repeat infection with Chlamydia and gonorrhea among females: a systematic review of the literature. Sex Transm Dis. 2009;36(8):478–89. doi: 10.1097/OLQ.0b013e3181a2a933. PMID: 19617871. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.19617871
190 Hou P, Tebbs JM, Bilder CR, . Hierarchical group testing for multiple infections. Biometrics. 2017;73(2):656–65. doi: 10.1111/biom.12589. PMID: 27657666. Exclusion: Wrong study design for Key Question.27657666
191 Hou P, Tebbs JM, Wang D, . Array testing for multiplex assays. Biostatistics. 2018;26:26. doi: 10.1093/biostatistics/kxy058. PMID: 30371749. Exclusion: Wrong study design for Key Question.30371749
192 Hsieh HL, Huppert J, Patel CG, . The impact of the American College of Obstetricians and Gynecologists guideline changes in pap tests on annual chlamydia test rates. J Adolesc Health. 2017;61(4):440–5. doi: 10.1016/j.jadohealth.2017.05.012. PMID: 28754585. Exclusion: Wrong study design for Key Question.28754585
193 Huang R, Ward J, Tangey A, . New molecular point-of-care test improves timeliness of treatment for Chlamydia trachomatis (CT) and Neisseria gonorrhoea (Ng) in a remote aboriginal health clinic. Sex Transm Infect. 2015;91:A121–A2. Exclusion: Wrong publication type.
194 Huang SH, Huang ML, Shedden K, . Optimal group testing designs for estimating prevalence with uncertain testing errors. J R Stat Soc Series B Stat Methodol. 2017;79(5):1547–63. doi: 10.1111/rssb.12223. PMID: 29249898. Exclusion: Wrong intervention.29249898
195 Huang SY, Hung JH, Hu LY, . Risk of sexually transmitted infections following depressive disorder: a nationwide population-based cohort study. Medicine. 2018;97(43):e12539. doi: 10.1097/MD.0000000000012539. PMID: 30412060. Exclusion: Wrong comparator.30412060
196 Hunte T, Alcaide M, Castro J. Rectal infections with chlamydia and gonorrhoea in women attending a multiethnic sexually transmitted diseases urban clinic. Int J STD AIDS. 2010;21(12):819–22. doi: 10.1258/ijsa.2010.009279. PMID: 21297090. Exclusion: Wrong outcome.21297090
197 Hurly DS, Buhrer-Skinner M, Badman SG, . Field evaluation of the CRT and ACON chlamydia point-of-care tests in a tropical, low-resource setting. Sex Transm Infect. 2014;90(3):179–84. doi: 10.1136/sextrans-2013-051246. PMID: 24337733. Exclusion: Wrong intervention.24337733
198 Ito S, Horie K, Seike K, . Usefulness of quantifying leukocytes in first-voided urine to predict positivity for Chlamydia trachomatis in asymptomatic men at high risk for chlamydial infection. J Infect Chemother. 2014;20(12):748–51. doi: 10.1016/j.jiac.2014.08.002. PMID: 25156010. Exclusion: Wrong comparator.25156010
199 Jackson JA, McNair TS, Coleman JS. Over-screening for chlamydia and gonorrhea among urban women age >=25 years. Am J Obstet Gynecol. 2015;212(1):40.e1–6. doi: 10.1016/j.ajog.2014.06.051. PMID: 24983680. Exclusion: Wrong comparator.24983680
200 Jackson LJ, Roberts TE. Measuring health and quality of life for women undergoing testing and screening for chlamydia: a systematic review. Sex Transm Dis. 2016;43(3):152–64. doi: 10.1097/OLQ.0000000000000407. PMID: 26859802. Exclusion: Wrong outcome.26859802
201 Jackson LJ, Roberts TE, Fuller SS, . Exploring the costs and outcomes of sexually transmitted infection (STI) screening interventions targeting men in football club settings: preliminary cost-consequence analysis of the SPORTSMART pilot randomised controlled trial. Sex Transm Infect. 2015;91(2):100–5. doi: 10.1136/sextrans-2014-051715. PMID: 25512670. Exclusion: Wrong intervention.25512670
202 Jacobsson S, Boiko I, Golparian D, . WHO laboratory validation of xpert CT/NG and Xpert TV on the genexpert system verifies high performances. APMIS. 2018;126(12):907–12. doi: 10.1111/apm.12902. PMID: 30456870. Exclusion: Wrong intervention.30456870
203 Jahan F, Shamsuzzaman SM, Akter S. Diagnosis of common bacterial causes of urethritis in men by gram stain, culture and multiplex PCR. Malays J Pathol. 2014;36(3):175–80. PMID: 25500516. Exclusion: Wrong study design for Key Question.25500516
204 Jain A, Cole MJ, Planche T, . An evaluation of Neisseria gonorrhoeae antimicrobial susceptibility testing in the UK. J Clin Pathol. 2014;67(11):1013–6. doi: 10.1136/jclinpath-2014-202392. PMID: 25078330. Exclusion: Wrong population.25078330
205 Jang D, Ratnam S, Gilchrist J, . Comparison of workflow, maintenance, and consumables in the genexpert infinity 80 and panther instruments while testing for Chlamydia trachomatis and Neisseria gonorrhoeae. Sex Transm Dis. 2016;43(6):377–81. doi: 10.1097/OLQ.0000000000000444. PMID: 27196259. Exclusion: Wrong population.27196259
206 Jaureguy F, Chariot P, Vessieres A, . Prevalence of Chlamydia trachomatis and Neisseria gonorrhoeae infections detected by real-time PCR among individuals reporting sexual assaults in the Paris, France area. Forensic Sci Int. 2016;266:130–3. doi: 10.1016/j.forsciint.2016.04.031. PMID: 27261924. Exclusion: Wrong population.27261924
207 Javaherian M, Sharifnia Z, Taheripanah R, . Using recombinant Chlamydia trachomatis OMP2 as antigen in diagnostic ELISA test. Iran J Microbiol. 2014;6(1):8–13. PMID: 25954485. Exclusion: Wrong population.25954485
208 Jevtusevskaja J, Krolov K, Tulp I, . The effect of main urine inhibitors on the activity of different DNA polymerases in loop-mediated isothermal amplification. Expert Rev Mol Diagn. 2017;17(4):403–10. doi: 10.1080/14737159.2017.1283218. PMID: 28092481. Exclusion: Wrong intervention.28092481
209 Jevtusevskaja J, Uusna J, Andresen L, . Combination with antimicrobial peptide lyses improves loop-mediated isothermal amplification based method for Chlamydia trachomatis detection directly in urine sample. BMC Infect Dis. 2016;16:329. doi: 10.1186/s12879-016-1674-0. PMID: 27412444. Exclusion: Wrong comparator.27412444
210 Jonsson A, Jacobsson S, Foerster S, . Performance characteristics of newer MIC gradient strip tests compared with the etest for antimicrobial susceptibility testing of Neisseria gonorrhoeae. APMIS. 2018;126(10):822–7. doi: 10.1111/apm.12887. PMID: 30191618. Exclusion: Wrong intervention.30191618
211 Jordan SJ, Schwebke JR, Aaron KJ, . Meatal swabs contain less cellular material and are associated with a decrease in gram stain smear quality compared to urethral swabs in men. J Clin Microbiol. 2017;55(7):2249–54. doi: 10.1128/JCM.00423-17. PMID: 28490486. Exclusion: Wrong population.28490486
212 Joseph Davey DL, Shull HI, Billings JD, . Prevalence of curable sexually transmitted infections in pregnant women in low- and middle-income countries from 2010 to 2015: a systematic review. Sex Transm Dis. 2016;43(7):450–8. doi: 10.1097/OLQ.0000000000000460. PMID: 27322048. Exclusion: Wrong outcome.27322048
213 Jue E, Schoepp NG, Witters D, . Evaluating 3D printing to solve the sample-to-device interface for LRS and POC diagnostics: example of an interlock meter-mix device for metering and lysing clinical urine samples. Lab Chip. 2016;16(10):1852–60. doi: 10.1039/c6lc00292g. PMID: 27122199. Exclusion: Wrong intervention.27122199
214 Kampman C, Koedijk F, Driessen-Hulshof H, . Retesting young STI clinic visitors with urogenital Chlamydia trachomatis infection in the Netherlands; response to a text message reminder and reinfection rates: a prospective study with historical controls. Sex Transm Infect. 2016;92(2):124–9. doi: 10.1136/sextrans-2015-052115. PMID: 26404946. Exclusion: Wrong population.26404946
215 Kapil R, Press CG, Hwang ML, . Investigating the epidemiology of repeat Chlamydia trachomatis detection after treatment by using C. trachomatis OmpA genotyping. J Clin Microbiol. 2015;53(2):546–9. doi: 10.1128/JCM.02483-14. PMID: 25472488. Exclusion: Wrong population.25472488
216 Kasaie P, Schumacher CM, Jennings JM, . Gonorrhoea and chlamydia diagnosis as an entry point for HIV pre-exposure prophylaxis: a modelling study. BMJ Open. 2019;9(3):e023453. doi: 10.1136/bmjopen-2018-023453. PMID: 30837248. Exclusion: Wrong study design for Key Question.30837248
217 Kaser T, Pasternak JA, Hamonic G, . Flow cytometry as an improved method for the titration of chlamydiaceae and other intracellular bacteria. Cytometry A. 2016;89(5):451–60. doi: 10.1002/cyto.a.22822. PMID: 26849001. Exclusion: Wrong population.26849001
218 Keaveney S, Sadlier C, O’Dea S, . High prevalence of asymptomatic sexually transmitted infections in HIV-infected men who have sex with men: a stimulus to improve screening. Int J STD AIDS. 2014;25(10):758–61. doi: 10.1177/0956462414521165. PMID: 24480850. Exclusion: Wrong population.24480850
219 Kellogg ND, Melville JD, Lukefahr JL, . Genital and extragenital gonorrhea and chlamydia in children and adolescents evaluated for sexual abuse. Pediatr Emerg Care. 2018;34(11):761–6. doi: 10.1097/PEC.0000000000001014. PMID: 28072668. Exclusion: Wrong population.28072668
220 Kelly H, Coltart CEM, Pant Pai N, . Systematic reviews of point-of-care tests for the diagnosis of urogenital Chlamydia trachomatis infections. Sex Transm Infect. 2017;93(S4):S22–S30. doi: 10.1136/sextrans-2016-053067. PMID: 29223960. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.29223960
221 Kent CK, Chaw JK, Wong W, . Prevalence of rectal, urethral, and pharyngeal chlamydia and gonorrhea detected in 2 clinical settings among men who have sex with men: San Francisco, California, 2003. Clin Infect Dis. 2005;41(1):67–74. doi: 10.1086/430704. PMID: 15937765. Exclusion: Wrong outcome.15937765
222 Kenyon C. Screening is not associated with reduced incidence of gonorrhoea or chlamydia in men who have sex with men (MSM); an ecological study of 23 European countries. F1000Research. 2019;8:160. doi: 10.12688/f1000research.17955.2. PMID: 31543953. Exclusion: Wrong population.31543953
223 Kenyon C, Buyze J, Klebanoff M, . The role of sexual networks in studies of how BV and STIs increase the risk of subsequent reinfection. Epidemiol Infect. 2018;146(15):2003–9. doi: 10.1017/S0950268818002157. PMID: 30182860. Exclusion: Wrong intervention.30182860
224 Kerry SR, Nightingale CM, Hay P, . Which sexually active female students get themselves tested for Chlamydia trachomatis? A cohort study. Int J STD AIDS. 2016;27(7):586–90. doi: 10.1177/0956462415587636. PMID: 25999170. Exclusion: Wrong outcome.25999170
225 Kerry-Barnard S, Fleming C, Reid F, . ‘Test n treat (TnT)’- rapid testing and same-day, on-site treatment to reduce rates of chlamydia in sexually active further education college students: study protocol for a cluster randomised feasibility trial. Trials 2018;19(1):311. doi: 10.1186/s13063-018-2674-8. PMID: 29871673. Exclusion: Wrong publication type.29871673
226 Kersaudy-Rahib D, Lydie N, Leroy C, . Chlamyweb study II: a randomised controlled trial (RCT) of an online offer of home-based Chlamydia trachomatis sampling in France. Sex Transm Infect. 2017;93(3):188–95. doi: 10.1136/sextrans-2015-052510. PMID: 28377422. Exclusion: Wrong outcome.28377422
227 Kerubo E, Laserson KF, Otecko N, . Prevalence of reproductive tract infections and the predictive value of girls’ symptom-based reporting: findings from a cross-sectional survey in rural western Kenya. Sex Transm Infect. 2016;92(4):251–6. doi: 10.1136/sextrans-2015-052371. PMID: 26819339. Exclusion: Wrong intervention.26819339
228 Keshinro B, Crowell TA, Nowak RG, . High prevalence of HIV, chlamydia and gonorrhoea among men who have sex with men and transgender women attending trusted community centres in Abuja and Lagos, Nigeria. J Int AIDS Soc. 2016;19(1):21270. doi: 10.7448/IAS.19.1.21270. PMID: 27931519. Exclusion: Wrong country.27931519
229 Khan MR, Golin CE, Friedman SR, . STI/HIV sexual risk behavior and prevalent STI among incarcerated African American men in committed partnerships: the significance of poverty, mood disorders, and substance use. AIDS Behav. 2015;19(8):1478–90. doi: 10.1007/s10461-015-1062-6. PMID: 25863467. Exclusion: Wrong intervention.25863467
230 Khoshakhlagh A, Salman Yazdi R, Navab-Akbar FT, . The prevalence of Chlamydia trachomatis infection in semen samples of both symptomatic and asymptomatic infertile men referring to royan institute, by using serological and molecular methods. Int J Fertil Steril. 2016;10(24). Exclusion: Wrong intervention.
231 Khoshakhlagh A, Salman Yazdi R, Navab-Akbar FT, . Comparison the diagnostic value of serological and molecular methods for screening and detecting Chlamydia trachomatis in semen of infertile men: a cross-sectional study. Int J Reprod Bio. 2017;15(12):763–70. PMID: 29492473. Exclusion: Wrong intervention.29492473
232 Khosropour CM, Soge OO, Suchland R, . Recurrent/intermittent vaginal and rectal chlamydial infection following treatment: a prospective cohort study among female STD clinic patients. J Infect Dis. 2019;12:12. doi: 10.1093/infdis/jiz113. PMID: 30873541. Exclusion: Wrong population.30873541
233 Kim HS, Kim TJ, Lee IH, . Associations between sexually transmitted infections, high-risk human papillomavirus infection, and abnormal cervical pap smear results in OB/GYN outpatients. J Gynecol Oncol. 2016;27(5):e49. doi: 10.3802/jgo.2016.27.e49. PMID: 27329197. Exclusion: Wrong intervention.27329197
234 Kissinger PJ. The challenges of implementing and evaluating prescription expedited partner treatment. Sex Transm Dis. 2017;44(2):109–10. doi: 10.1097/olq.0000000000000577. PMID: 28081047. Exclusion: Wrong publication type.28081047
235 Knight E, Morris M, Heaman M. A descriptive study of women presenting to an obstetric triage unit with no prenatal care. J Obstetr Gynaecol Can. 2014;36(3):216–22. doi: 10.1016/S1701-2163(15)30629-0. PMID: 24612890. Exclusion: Wrong intervention.24612890
236 Koedijk FD, van Benthem BH, Vrolings EM, . Increasing sexually transmitted infection rates in young men having sex with men in the Netherlands, 2006-2012. Emerg Themes Epidemiol. 2014;11:12. doi: 10.1186/1742-7622-11-12. PMID: 25170341. Exclusion: Wrong intervention.25170341
237 Kojima N, Park H, Konda KA, . The PICASSO cohort: baseline characteristics of a cohort of men who have sex with men and male-to-female transgender women at high risk for syphilis infection in Lima, Peru. BMC Infect Dis. 2017;17(1):255. doi: 10.1186/s12879-017-2332-x. PMID: 28399798. Exclusion: Wrong outcome.28399798
238 Korenromp EL, Wi T, Resch S, . Costing of national STI program implementation for the global STI control strategy for the health sector, 2016-2021. PLoS One. 2017;12(1):e0170773. doi: 10.1371/journal.pone.0170773. PMID: 28129372. Exclusion: Wrong intervention.28129372
239 Kumar P, Bhakuni DS, Rastogi S. Diagnosis of Chlamydia trachomatis in patients with reactive arthritis and undifferentiated spondyloarthropathy. J Infect Dev Ctries. 2014;8(5):648–54. doi: 10.3855/jidc.3644. PMID: 24820470. Exclusion: Wrong population.24820470
240 Landovitz RJ, Gildner JL, Leibowitz AA. Sexually transmitted infection testing of HIV-positive medicare and medicaid enrollees falls short of guidelines. Sex Transm Dis. 2018;45(1):8–13. doi: 10.1097/OLQ.0000000000000695. PMID: 29240633. Exclusion: Wrong population.29240633
241 Lang AS, An der Heiden M, Jansen K, . Not again! Effect of previous test results, age group and reason for testing on (re-)infection with Chlamydia trachomatis in Germany. BMC Infect Dis. 2018;18(1):424. doi: 10.1186/s12879-018-3323-2. PMID: 30144825. Exclusion: Wrong intervention.30144825
242 Lanjouw E, Ouburg S, de Vries HJ, . Background review for the ‘2015 European guideline on the management of Chlamydia trachomatis infections’. Int J STD AIDS. 2015;24:24. PMID: 26608578. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.26608578
243 Lanjouw E, Ouburg S, de Vries HJ, . 2015 European guideline on the management of Chlamydia trachomatis infections. Int J STD AIDS. 2016;27(5):333–48. doi: 10.1177/0956462415618837. PMID: 26608577. Exclusion: Wrong publication type.26608577
244 Lau A, Kong FYS, Huston W, . Factors associated with anorectal Chlamydia trachomatis or Neisseria gonorrhoeae test positivity in women: a systematic review and meta-analysis. Sex Transm Infect. 2019;16:16. doi: 10.1136/sextrans-2018-053950. PMID: 31097677. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.31097677
245 Lee S, Dowshen N, Matone M, . Variation in practice of expedited partner therapy for adolescents by state policy environment. J Adolesc Health. 2015;57(3):348–50. doi: 10.1016/j.jadohealth.2015.05.013. PMID: 26299562. Exclusion: Wrong population.26299562
246 Lewis DA. Will targeting oropharyngeal gonorrhoea delay the further emergence of drug-resistant Neisseria gonorrhoeae strains? Sex Transm Infect. 2015;91(4):234–7. doi: 10.1136/sextrans-2014-051731. PMID: 25911525. Exclusion: Wrong study design for Key Question.25911525
247 Lewis FM, Dittus P, Salmon ME, . School-based sexually transmitted disease screening: review and programmatic guidance. Sex Transm Dis. 2016;43(2 Suppl 1):S18–27. doi: 10.1097/OLQ.0000000000000283. PMID: 26779684. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.26779684
248 Li KT, Tang W, Wu D, . Pay-it-forward strategy to enhance uptake of dual gonorrhea and chlamydia testing among men who have sex with men in China: a pragmatic, quasi-experimental study. Lancet Infect Dis. 2019;19(1):76–82. doi: 10.1016/S1473-3099(18)30556-5. PMID: 30587296. Exclusion: Wrong intervention.30587296
249 Libbus MK. Chlamydia rapid test was moderately accurate for diagnosing chlamydia infection in women. Evid Based Nurs. 2008;11(3):89. doi: 10.1136/ebn.11.3.89. PMID: 18583501. Exclusion: Wrong outcome.18583501
250 Lippman SA, Jones HE, Luppi CG, . Home-based self-sampling and self-testing for sexually transmitted infections: acceptable and feasible alternatives to provider-based screening in low-income women in Sao Paulo, Brazil. Sex Transm Dis. 2007;34(7):421–8. doi: 10.1097/01.olq.0000245958.34961.27. PMID: 17091118. Exclusion: Wrong outcome.17091118
251 Llata E, Braxton J, Asbel L, . Rectal Chlamydia trachomatis and Neisseria gonorrhoeae infections among women reporting anal intercourse. Obstet Gynecol. 2018;132(3):692–7. doi: 10.1097/aog.0000000000002804. PMID: 30095784. Exclusion: Wrong outcome.30095784
252 Lolar SA, Sherwin RL, Robinson DM, . Effectiveness of an urban emergency department call-back system in the successful linkage to treatment of sexually transmitted infections. South Med J. 2015;108(5):268–73. doi: 10.14423/SMJ.0000000000000273. PMID: 25972212. Exclusion: Wrong outcome.25972212
253 Loomba P, Knight V, McNulty A. What would be missed if we didn’t screen men who have sex with men for oral Chlamydia trachomatis? A cross-sectional study. Sex Health. 2016;13(2):196–8. doi: 10.1071/SH15209. PMID: 26886379. Exclusion: Wrong study design for Key Question.26886379
254 Low N, Redmond S, Uuskula A, . Screening for genital chlamydia infection. Cochrane Database Syst Rev. 2016;9:CD010866. doi: 10.1002/14651858.CD010866.pub2. PMID: 27623210. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.27623210
255 Lunny C, Taylor D, Hoang L, . Self-collected versus clinician-collected sampling for chlamydia and gonorrhea screening: a systemic review and meta-analysis. PLoS One. 2015;10(7):e0132776. doi: 10.1371/journal.pone.0132776. PMID: 26168051. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.26168051
256 Lutz AR. Screening for asymptomatic extragenital gonorrhea and chlamydia in men who have sex with men: significance, recommendations, and options for overcoming barriers to testing. LGBT Health. 2015;2(1):27–34. doi: 10.1089/lgbt.2014.0056. PMID: 26790015. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.26790015
257 Lydie N, de Barbeyrac B, Bluzat L, . Chlamyweb study I: rationale, design and acceptability of an internet-based chlamydia testing intervention. Sex Transm Infect 2017;93(3):179–87. doi: 10.1136/sextrans-2015-052511. PMID: 28258251. Exclusion: Wrong outcome.28258251
258 Ma C, Du J, He W, . Rapid and accurate diagnosis of Chlamydia trachomatis in the urogenital tract by a dual-gene multiplex qPCR method. Journal of Medical Microbiology. 2019;68(12):1732–9. doi: 10.1099/jmm.0.001084. PMID: 31613208. Exclusion: Wrong outcome.31613208
259 Mahilum-Tapay L, Laitila V, Wawrzyniak JJ, . New point of care chlamydia rapid test--bridging the gap between diagnosis and treatment: performance evaluation study. BMJ 2007;335(7631):1190–4. doi: 10.1136/bmj.39402.463854.AE. PMID: 18055487. Exclusion: Wrong intervention.18055487
260 Marangoni A, Foschi C, Nardini P, . Evaluation of the versant CT/GC DNA 1.0 assay (kPCR) for the detection of extra-genital Chlamydia trachomatis and Neisseria gonorrhoeae infections. PLoS One. 2015;10(3):e0120979. doi: 10.1371/journal.pone.0120979. PMID: 25799263. Exclusion: Wrong intervention.25799263
261 Marinelli T, Chow EP, Tomnay J, . Rate of repeat diagnoses in men who have sex with men for Chlamydia trachomatis and Neisseria gonorrhoeae: a retrospective cohort study. Sex Health. 2015;12(5):418–24. doi: 10.1071/SH14234. PMID: 26117082. Exclusion: Wrong intervention.26117082
262 Marlowe EM, Hardy D, Krevolin M, . High-throughput testing of urogenital and extragenital specimens for detection of Chlamydia trachomatis and Neisseria gonorrhoeae with cobas CT/NG. Eur J Microbiol Immunol. 2017;7(3):176–86. doi: 10.1556/1886.2017.00018. PMID: 29034107. Exclusion: Wrong intervention.29034107
263 Martin EG, Feng W, Qian F, . Delivering partner services to reduce transmission and promote linkage to care: process outcomes varied for chlamydial infection, gonorrhea, HIV, and syphilis cases. J Public Health Manag Pract. 2017;23(3):242–6. doi: 10.1097/PHH.0000000000000351. PMID: 26480283. Exclusion: Wrong outcome.26480283
264 Mattson CL, Bradley H, Beer L, . Increased sexually transmitted disease testing among sexually active persons receiving medical care for human immunodeficiency virus infection in the United States, 2009-2013. Clin Infect Dis. 2017;64(5):629–34. doi: 10.1093/cid/ciw834. PMID: 27940947. Exclusion: Wrong population.27940947
265 May L, Ware CE, Jordan JA, . A randomized controlled trial comparing the treatment of patients tested for chlamydia and gonorrhea after a rapid polymerase chain reaction test versus standard of care testing. Sex Transm Dis. 2016;43(5):290–5. doi: 10.1097/OLQ.0000000000000438. PMID: 27100764. Exclusion: Wrong population.27100764
266 McArdle BJ, Buser GL, Hedberg K, . Chlamydia retesting among safety-net clinic patients: infertility prevention project. J Womens Health. 2018;27(9):1135–41. doi: 10.1089/jwh.2017.6747. PMID: 29694796. Exclusion: Wrong population.29694796
267 McNulty CA, Hogan AH, Ricketts EJ, . Increasing chlamydia screening tests in general practice: a modified zelen prospective cluster randomised controlled trial evaluating a complex intervention based on the theory of planned behaviour. Sex Transm Infect. 2014;90(3):188–94. doi: 10.1136/sextrans-2013-051029. PMID: 24005256. Exclusion: Wrong outcome.24005256
268 McRee AL, Esber A, Reiter PL. Acceptability of home-based chlamydia and gonorrhea testing among a national sample of sexual minority young adults. Perspect Sex Reprod Health. 2015;47(1):3–10. doi: 10.1363/47e2715. PMID: 25776809. Exclusion: Wrong outcome.25776809
269 Mensforth S, Thorley N, Radcliffe K. Auditing the use and assessing the clinical utility of microscopy as a point-of-care test for Neisseria gonorrhoeae in a sexual health clinic. Int J STD AIDS. 2018;29(2):157–63. doi: 10.1177/0956462417721062. PMID: 28705094. Exclusion: Wrong intervention.28705094
270 Meyer T, Klos C, Kofler R, . Performance evaluation of the pelvocheck CT/NG test kit for the detection of Chlamydia trachomatis and Neisseria gonorrhoeae. BMJ Open. 2016;6(1):e009894. doi: 10.1136/bmjopen-2015-009894. PMID: 26729391. Exclusion: Wrong intervention.26729391
271 Miyazaki N, Yamagishi Y, Izumi K, . Evaluation of rapid measurement of Chlamydia trachomatis and Neisseria gonorrhoeae by using automatic gene analyzer “GENECUBE”. Jpn J Antibiot. 2016;69(4):291–8. PMID: 30226955. Exclusion: Not English language but possibly relevant.30226955
272 Mizushima D, Takano M, Uemura H, . High prevalence and incidence of rectal Chlamydia infection among men who have sex with men in Japan. PLoS ONE [Electronic Resource]. 2019;14(12):e0220072. doi: 10.1371/journal.pone.0220072. PMID: 31821348. Exclusion: Wrong outcome.31821348
273 Mmeje O, Qin J, Wetmore M, . Breakdown in the expedited partner therapy treatment cascade: the role of community pharmacists. Sex Transm Dis. 2018;45. Exclusion: Wrong publication type.
274 Molina JM, Charreau I, Chidiac C, . Post-exposure prophylaxis with doxycycline to prevent sexually transmitted infections in men who have sex with men: an open-label randomised substudy of the ANRS IPERGAY trial. Lancet Infect Dis. 2018;18(3):308–17. doi: 10.1016/S1473-3099(17)30725-9. PMID: 29229440. Exclusion: Wrong intervention.29229440
275 Moncada J, Schachter J, Liska S, . Evaluation of self-collected glans and rectal swabs from men who have sex with men for detection of Chlamydia trachomatis and Neisseria gonorrhoeae by use of nucleic acid amplification tests. J Clin Microbiol. 2009;47(6):1657–62. doi: 10.1128/jcm.02269-08. PMID: 19369445. Exclusion: Wrong population.19369445
276 Mortimer NJ, Rhee J, Guy R, . A web-based personally controlled health management system increases sexually transmitted infection screening rates in young people: a randomized controlled trial. J Am Med Inform Assoc. 2015;22(4):805–14. doi: 10.1093/jamia/ocu052. PMID: 25773130. Exclusion: Wrong outcome.25773130
277 Mushanski LM, Brandt K, Coffin N, . Comparison of the BD viper system with XTR technology to the gen-probe APTIMA COMBO 2 assay using the TIGRIS DTS system for the detection of Chlamydia trachomatis and Neisseria gonorrhoeae in urine specimens. Sex Transm Dis. 2012;39(7):514–7. doi: 10.1097/OLQ.0b013e31824f2f5b. PMID: 22706212. Exclusion: Wrong intervention.22706212
278 Myers A, McCaskill SP, VanRavenstein K. Improving STD screening rates on a university campus. J Community Health. 2017;42(6):1247–54. doi: 10.1007/s10900-017-0377-9. PMID: 28589269. Exclusion: Wrong outcome.28589269
279 Nadala E-C, Goh BT, Magbanua J-P, . Performance evaluation of a new rapid urine test for chlamydia in men: prospective cohort study. BMJ 2009;339:b2655–b. doi: 10.1136/bmj.b2655. PMID: 19638650. Exclusion: Wrong intervention.19638650
280 Naldini G, Grisci C, Chiavarini M, . Association between human papillomavirus and chlamydia trachomatis infection risk in women: a systematic review and meta-analysis. International Journal of Public Health. 2019;64(6):943–55. doi: 10.1007/s00038-019-01261-w. PMID: 31175391. Exclusion: Wrong outcome.31175391
281 Nanhoe AC, Visser M, Omlo JJ, . A pill for the partner via the chlamydia patient? Results from a mixed method study among sexual health care providers in the Netherlands. BMC Infect Dis. 2018;18(1):243. doi: 10.1186/s12879-018-3139-0. PMID: 29843643. Exclusion: Wrong intervention.29843643
282 Nateghi Rostami M, Hossein Rashidi B, Aghsaghloo F, . Comparison of clinical performance of antigen based-enzyme immunoassay (EIA) and major outer membrane protein (MOMP)-PCR for detection of genital Chlamydia trachomatis infection. Int J Reprod Biomed. 2016;14(6):411–20. PMID: 27525325. Exclusion: Wrong country.27525325
283 Nateghi Rostami M, Hossein Rashidi B, Nazari R, . A multiplex assay of Trichomonas vaginalis, Chlamydia trachomatis and Neisseria gonorrhoeae infections in genital specimens. Journal of Infection in Developing Countries. 2017;11(11):833–9. doi: 10.3855/jidc.8199. PMID: 31618181. Exclusion: Wrong population.31618181
284 Nct. Adolescent sexually transmitted infection screening in the emergency department. Https://clinicaltrials.gov/show/nct03715335. 2018 PMID: 2929825229298252 Exclusion: Wrong publication type.
285 Nielsen A, Marrone G, De Costa A. Chlamydia trachomatis among youth - testing behaviour and incidence of repeat testing in Stockholm county, Sweden 2010-2012. PLoS One. 2016;11(9):e0163597. doi: 10.1371/journal.pone.0163597. PMID: 27676175. Exclusion: Wrong outcome.27676175
286 Niza C, Rudisill C, Dolan P. Vouchers versus lotteries: what works best in promoting chlamydia screening? A cluster randomised controlled trial. Appl Econ Perspect Policy. 2014;36(1):109–24. doi: 10.1093/aepp/ppt033. PMID: 25061507. Exclusion: Wrong intervention.25061507
287 Nunez-Forero L, Moyano-Ariza L, Gaitan-Duarte H, . Diagnostic accuracy of rapid tests for sexually transmitted infections in symptomatic women. Sex Transm Infect. 2016;92(1):24–8. doi: 10.1136/sextrans-2014-051891. PMID: 26136508. Exclusion: Wrong population.26136508
288 Nyatsanza F, McSorley J, Murphy S, . ‘It’s all in the message’: the utility of personalised short message service (SMS) texts to remind patients at higher risk of STIs and HIV to reattend for testing-a repeat before and after study. Sex Transm Infect. 2016;92(5):393–5. doi: 10.1136/sextrans-2015-052216. PMID: 26670912. Exclusion: Wrong outcome.26670912
289 Nyatsanza F, Trivedy A, Brook G. The effect of introducing routine self-taken extra-genital swabs in a genitourinary medicine clinic cohort: a before and after study. Int J STD AIDS. 2016;27(14):1330–3. PMID: 26672002. Exclusion: Wrong population.26672002
290 Odesanmi TY, Wasti SP, Odesanmi OS, . Comparative effectiveness and acceptability of home-based and clinic-based sampling methods for sexually transmissible infections screening in females aged 14-50 years: a systematic review and meta-analysis. Sex Health. 2013;10(6):559–69. doi: 10.1071/sh13029. PMID: 24160747. Exclusion: Wrong outcome.24160747
291 Ogale Y, Yeh PT, Kennedy CE, . Self-collection of samples as an additional approach to deliver testing services for sexually transmitted infections: a systematic review and meta-analysis. BMJ Glob Health. 2019;4(2):e001349. doi: 10.1136/bmjgh-2018-001349. PMID: 31139454. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.31139454
292 Ong JJ, Chow EPF, De Petra V, . Should asymptomatic men who have sex with men be screened for oropharyngeal chlamydia? Clinical outcomes from a cross-sectional study. Sex Transm Dis. 2018;45(2):103–6. doi: 10.1097/OLQ.0000000000000718. PMID: 29329179. Exclusion: Wrong outcome.29329179
293 Østergaard L, Andersen B, Olesen F, . Efficacy of home sampling for screening of Chlamydia trachomatis: randomised study. BMJ (Clinical research ed.). 1998;317(7150):26–7. doi: 10.1136/bmj.317.7150.26. PMID: 9651263. Exclusion: Wrong outcome.9651263
294 Parcell BJ, Ratnayake L, Kaminski G, . Value of repeat testing using cepheid genexpert CT/NG for indeterminate PCR results when diagnosing Chlamydia trachomatis and Neisseria gonorrhoeae. Int J STD AIDS. 2015;26(1):65–7. doi: 10.1177/0956462414531938. PMID: 24810211. Exclusion: Wrong intervention.24810211
295 Parker RM, Bell A, Currie MJ, . ‘Catching chlamydia’: combining cash incentives and community pharmacy access for increased chlamydia screening, the view of young people. Aust J Prim Health. 2015;21(1):79–83. doi: 10.1071/PY12135. PMID: 24139788. Exclusion: Wrong intervention.24139788
296 Parra-Sanchez M, Garcia-Rey S, Marcuello A, . Performance of the NG oligogen kit for the diagnosis of Neisseria gonorrhoeae: comparison with cobas 4800 assay. Diagn Microbiol Infect Dis. 2016;84(1):4–6. doi: 10.1016/j.diagmicrobio.2015.09.020. PMID: 26508106. Exclusion: Wrong intervention.26508106
297 Parra-Sanchez M, Garcia-Rey S, Zakariya-Yousef Breval I, . Evaluation of a dilution method for non-evaluable results in the detection of Chlamydia trachomatis and Neisseria gonorrhoeae with the cobas 4800 platform. Enferm Infecc Microbiol Clin. 2017;35(6):364–6. doi: 10.1016/j.eimc.2015.06.017. PMID: 26415750. Exclusion: Wrong outcome.26415750
298 Parra-Sanchez M, Marcuello-Lopez A, Garcia-Rey S, . Comparison of the CT oligogen kit with cobas 4800 assay for detection of Chlamydia trachomatis. Enferm Infecc Microbiol Clin. 2015;33(10):642–5. doi: 10.1016/j.eimc.2015.02.017. PMID: 25858681. Exclusion: Not English language but possibly relevant.25858681
299 Patel AV, Gaydos CA, Jett-Goheen M, . Assessing association between IWantTheKit risk quiz tool and sexually transmitted infection positivity in male users for sexually transmitted infection screening. Int J STD AIDS. 2018;29(2):122–7. doi: 10.1177/0956462417718758. PMID: 28669325. Exclusion: Wrong outcome.28669325
300 Patton ME, Kidd S, Llata E, . Extragenital gonorrhea and chlamydia testing and infection among men who have sex with men-STD Surveillance Network, United States, 2010-2012. Clin Infect Dis. 2014;58(11):1564–70. doi: 10.1093/cid/ciu184. PMID: 24647015. Exclusion: Wrong outcome.24647015
301 Pedrosa AF, Azevedo F, Lisboa C. Screening for chlamydia infection in a sexually transmitted infection clinic: a missed opportunity? Int J Dermatol. 2015;54(4):405–9. doi: 10.1111/ijd.12338. PMID: 25069382. Exclusion: Wrong intervention.25069382
302 Perry MD, Jones RN, Corden SA. Is confirmatory testing of roche cobas 4800 CT/NG test Neisseria gonorrhoeae positive samples required? Comparison of the roche cobas 4800 CT/NG test with an opa/pap duplex assay for the detection of N gonorrhoeae. Sex Transm Infect. 2014;90(4):303–8. doi: 10.1136/sextrans-2013-051410. PMID: 24653040. Exclusion: Wrong intervention.24653040
303 Peters RP, Nijsten N, Mutsaers J, . Screening of oropharynx and anorectum increases prevalence of Chlamydia trachomatis and Neisseria gonorrhoeae infection in female STD clinic visitors. Sex Transm Dis. 2011;38(9):783–7. doi: 10.1097/OLQ.0b013e31821890e9. PMID: 21844729. Exclusion: Wrong outcome.21844729
304 Phillipson L, Gordon R, Telenta J, . A review of current practices to increase chlamydia screening in the community--a consumer-centred social marketing perspective. Health Expect. 2016;19(1):5–25. doi: 10.1111/hex.12337. PMID: 25580560. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.25580560
305 Pickett ML, Melzer-Lange MD, Miller MK, . Physician adherence to centers for disease control and prevention guidelines for sexually active adolescents in the pediatric emergency setting. Pediatr Emerg Care. 2018;34(11):767–73. doi: 10.1097/PEC.0000000000000873. PMID: 27749798. Exclusion: Wrong population.27749798
306 Pimenta JM, Catchpole M, Rogers PA, . Opportunistic screening for genital chlamydial infection. II: prevalence among healthcare attenders, outcome, and evaluation of positive cases. Sex Transm Infect. 2003;79(1):22–7. doi: 10.1136/sti.79.1.22. PMID: 12576608. Exclusion: Wrong outcome.12576608
307 Pittaras TE, Papaparaskevas J, Houhoula DP, . Comparison of penile skin swab with intra-urethral swab and first void urine for polymerase chain reaction-based diagnosis of Chlamydia trachomatis urethritis in male patients. Sex Transm Dis. 2008;35(12):999–1001. doi: 10.1097/OLQ.0b013e318182a586. PMID: 18665017. Exclusion: Wrong population.18665017
308 Priest D, Read TRH, Chen MY, . Only recent sexual partners contribute to oropharyngeal gonorrhoea positivity: the number of sexual partners over different time periods as an indicator of gonorrhoea and chlamydia infection duration among men who have sex with men. Sexual Health. 2018;15(4):342–9. doi: 10.1071/SH17196. PMID: 29973330. Exclusion: Wrong outcome.29973330
309 Priyadarshi K, Prakash P, Rani A, . Multiplex nested polymerase chain reaction targeting multiple genes for the detection of Neisseria gonorrhoeae and Chlamydia trachomatis in genitourinary specimens. Indian Journal Of Sexually Transmitted Diseases And AIDS. 2019;40(2):152–8. doi: 10.4103/ijstd.IJSTD_73_18. PMID: 31922106. Exclusion: Wrong population.31922106
310 Refugio ON, Klausner JD. Syphilis incidence in men who have sex with men with human immunodeficiency virus comorbidity and the importance of integrating sexually transmitted infection prevention into HIV care. Expert Rev Anti Infect Ther. 2018;16(4):321–31. doi: 10.1080/14787210.2018.1446828. PMID: 29489420. Exclusion: Wrong population.29489420
311 Reisner SL, Jadwin-Cakmak L, Sava L, . Situated vulnerabilities, sexual risk, and sexually transmitted infections’ diagnoses in a sample of transgender youth in the United States. AIDS Patient Care STDS. 2019;33(3):120–30. doi: 10.1089/apc.2018.0249. PMID: 30844303. Exclusion: Wrong intervention.30844303
312 Ronn MM, Mc Grath-Lone L, Davies B, . Evaluation of the performance of nucleic acid amplification tests (NAATs) in detection of chlamydia and gonorrhoea infection in vaginal specimens relative to patient infection status: a systematic review. BMJ Open. 2019a;9(1):e022510. doi: 10.1136/bmjopen-2018-022510. PMID: 30659036. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.30659036
313 Rose SB, Garrett SM, Hutchings D, . Clinician education, advice and SMS/text reminders improve test of reinfection rates following diagnosis of Chlamydia trachomatis or Neisseria gonorrhoeae: before and after study in primary care. BMJ Sexual & Reproductive Health. 2019;46:32–7. doi: 10.1136/bmjsrh-2018-200185. PMID: 31628155. Exclusion: Wrong population.31628155
314 Ross CE, Tao G, Patton M, . Screening for human immunodeficiency virus and other sexually transmitted diseases among U.S. women with prenatal care. Obstet Gynecol. 2015;125(5):1211–6. doi: 10.1097/AOG.0000000000000756. PMID: 25932850. Exclusion: Wrong intervention.25932850
315 Rumyantseva T, Golparian D, Nilsson CS, . Evaluation of the new amplisens multiplex real-time PCR assay for simultaneous detection of Neisseria gonorrhoeae, Chlamydia trachomatis, Mycoplasma genitalium, and Trichomonas vaginalis. APMIS. 2015;123(10):879–86. doi: 10.1111/apm.12430. PMID: 26299582. Exclusion: Wrong intervention.26299582
316 Sachdev D, Patel AL, Sonkar SC, . Diagnosis of Neisseria gonorrhoeae using molecular beacon. Biomed Res Int. 2015;2015:597432. doi: 10.1155/2015/597432. PMID: 25802857. Exclusion: Wrong intervention.25802857
317 Sachdev D, Wasnik K, Patel AL, . Multi-centric validation of an in-house-developed beacon-based PCR diagnostic assay kit for chlamydia and neisseria and portable fluorescence detector. J Med Microbiol. 2018;67(9):1287–93. doi: 10.1099/jmm.0.000803. PMID: 30051801. Exclusion: Wrong intervention.30051801
318 Sahi SV, Rogozinska E, Sobhy S, . Accuracy of tests used to detect infection with Chlamydia trachomatis in asymptomatic pregnant women: a systematic review. Curr Opin Obstet Gynecol. 2017;29(6):375–82. doi: 10.1097/GCO.0000000000000411. PMID: 28914654. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.28914654
319 Sales JM, Smearman EL, Swartzendruber A, . Socioeconomic-related risk and sexually transmitted infection among African-American adolescent females. J Adolesc Health. 2014;55(5):698–704. doi: 10.1016/j.jadohealth.2014.05.005. PMID: 24974317. Exclusion: Wrong intervention.24974317
320 Salomon SG, Torrone E, Nakatsukasa-Ono W, . Missed opportunities for chlamydia screening in title X family planning clinics. Sex Transm Dis. 2017;44(9):519–23. doi: 10.1097/OLQ.0000000000000641. PMID: 28809768. Exclusion: Wrong intervention.28809768
321 Schillinger JA. Optimizing the Impact of Expedited Partner Therapy. Sex Transm Dis. 2018;45(5):358–60. doi: 10.1097/olq.0000000000000814. PMID: 29465636. Exclusion: Wrong publication type.29465636
322 Schlueter R, Siu A, Shelton J, . Routine screening for Chlamydia trachomatis and Neisseria gonorrhoeae in first trimester abortion. J Infect Public Health. 2018;11(4):584–5. doi: 10.1016/j.jiph.2017.10.012. PMID: 29146429. Exclusion: Wrong intervention.29146429
323 Secura GM, Allsworth JE, Madden T, . The Contraceptive CHOICE Project: reducing barriers to long-acting reversible contraception. Am J Obstet Gynecol. 2010;203(2):115.e1–7. doi: 10.1016/j.ajog.2010.04.017. PMID: 20541171. Exclusion: Wrong publication type.20541171
324 Sexton ME, Baker JJ, Nakagawa K, . How reliable is self-testing for gonorrhea and chlamydia among men who have sex with men? J Fam Pract. 2013;62(2):70–8. PMID: 23405376. Exclusion: Wrong population.23405376
325 Shannon CL, Keizur EM, Fehrenbacher A, . Sexually transmitted infection positivity among adolescents with or at high-risk for Human Immunodeficiency Virus infection in Los Angeles and New Orleans. Sexually Transmitted Diseases. 2019b;46(11):737–42. doi: 10.1097/OLQ.0000000000001056. PMID: 31453926. Exclusion: Wrong intervention.31453926
326 Sirivongrangson P, Girdthep N, Sukwicha W, . The first year of the global enhanced gonococcal antimicrobial surveillance programme (EGASP) in Bangkok, Thailand, 2015-2016. PLoS One. 2018;13(11):e0206419. doi: 10.1371/journal.pone.0206419. PMID: 30412586. Exclusion: Wrong population.30412586
327 Skulska E, Mlynarczyk-Bonikowska B, Walter de Walthoffen S, . [The comparison of real-time PCR and direct immunofluorescence in laboratory diagnostics of chlamydiosis in patients of department of dermatology and venereology medical university of Warsaw]. Med Dosw Mikrobiol. 2015;67(3-4):173–80. PMID: 27019911. Exclusion: Not English language but possibly relevant.27019911
328 Slutsker JS, Tsang LB, Schillinger JA. Do prescriptions for expedited partner therapy for chlamydia get filled? Findings from a multi-jurisdictional evaluation, United States, 2017-2019. Sex Transm Dis. 2020;47(6):376–82. doi: 10.1097/olq.0000000000001163. PMID: 32149956. Exclusion: Wrong intervention.32149956
329 Soetens LC, van Benthem BH, Op de Coul EL. Chlamydia test results were associated with sexual risk behavior change among participants of the chlamydia screening implementation in the Netherlands. Sex Transm Dis. 2015;42(3):109–14. doi: 10.1097/OLQ.0000000000000234. PMID: 25668640. Exclusion: Wrong comparator.25668640
330 Speers DJ, Chua IJ, Manuel J, . Detection of Neisseria gonorrhoeae and Chlamydia trachomatis from pooled rectal, pharyngeal and urine specimens in men who have sex with men. Sex Transm Infect. 2018;94(4):293–7. doi: 10.1136/sextrans-2017-053303. PMID: 29066627. Exclusion: Wrong outcome.29066627
331 Sugunendran H, Birley HD, Mallinson H, . Comparison of urine, first and second endourethral swabs for PCR based detection of genital Chlamydia trachomatis infection in male patients. Sex Transm Infect. 2001;77(6):423–6. doi: 10.1136/sti.77.6.423. PMID: 11714940. Exclusion: Wrong population.11714940
332 Swartzendruber A, Sales JM, Brown JL, . Correlates of incident Trichomonas vaginalis infections among African American female adolescents. Sex Transm Dis. 2014;41(4):240–5. doi: 10.1097/OLQ.0000000000000094. PMID: 24622635. Exclusion: Wrong intervention.24622635
333 Sweet RL. Pelvic inflammatory disease: current concepts of diagnosis and management. Curr Infect Dis Rep. 2012;14:194–203. doi: 10.1007/s11908-012-0243-y. PMID: 22298157. Exclusion: Wrong publication type.22298157
334 Tamarelle J, Thiebaut ACM, Sabin B, . Early screening for Chlamydia trachomatis in young women for primary prevention of pelvic inflammatory disease (i-Predict): study protocol for a randomised controlled trial. Trials 2017;18(1):534. doi: 10.1186/s13063-017-2211-1. PMID: 29132441. Exclusion: Wrong publication type.29132441
335 Taylor MM, Frasure-Williams J, Burnett P, . Interventions to improve sexually transmitted disease screening in clinic-based settings. Sex Transm Dis. 2016;43(2 Suppl 1):S28–41. doi: 10.1097/OLQ.0000000000000294. PMID: 26779685. Exclusion: Wrong outcome.26779685
336 Taylor SN, Liesenfeld O, Lillis RA, . Evaluation of the roche cobas(R) CT/NG test for detection of Chlamydia trachomatis and Neisseria gonorrhoeae in male urine. Sex Transm Dis. 2012;39(7):543–9. doi: 10.1097/OLQ.0b013e31824e26ff. PMID: 22706217. Exclusion: Wrong intervention.22706217
337 Taylor SN, Van Der Pol B, Lillis R, . Clinical evaluation of the BD probetec Chlamydia trachomatis qx amplified DNA assay on the BD viper system with XTR technology. Sex Transm Dis. 2011;38(7):603–9. doi: 10.1097/OLQ.0b013e31820a94d2. PMID: 21301389. Exclusion: Wrong intervention.21301389
338 Ten Hoor G, Hoebe CJ, van Bergen JE, . The influence of two different invitation letters on chlamydia testing participation: randomized controlled trial. J Med Internet Res. 2014;16(1):e24. doi: 10.2196/jmir.2907. PMID: 24480721. Exclusion: Wrong outcome.24480721
339 Thielemans E, Wyndham-Thomas C, Henrard S, . Screening for Chlamydia trachomatis and Neisseria gonorrhoeae infections in men who have sex with men: diagnostic accuracy of nucleic acid amplification test on pooled urine, anorectal, and pharyngeal specimens. Sex Transm Dis. 2018;45(3):195–8. doi: 10.1097/OLQ.0000000000000722. PMID: 29419710. Exclusion: Wrong population.29419710
340 Trebach JD, Chaulk CP, Page KR, . Neisseria gonorrhoeae and Chlamydia trachomatis among women reporting extragenital exposures. Sexually Transmitted Diseases. 2015;42(5):233–9. doi: 10.1097/OLQ.0000000000000248. PMID: 25868133. Exclusion: Wrong outcome.25868133
341 Tsoumanis A, Hens N, Kenyon CR. Is screening for chlamydia and gonorrhea in men who have sex with men associated with reduction of the prevalence of these infections? A systematic review of observational studies. Sex Transm Dis. 2018;45(9):615–22. doi: 10.1097/OLQ.0000000000000824. PMID: 29485537. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies.29485537
342 Valejo Coelho MM, Matos-Pires E, Serrao V, . Extragenital gonorrhoea in men who have sex with men: a retrospective study in a STI clinic in Lisbon, Portugal. Acta Medica Portuguesa. 2018;31(5):247–53. doi: 10.20344/amp.10146. PMID: 29916355. Exclusion: Wrong outcome.29916355
343 van der Helm JJ, Hoebe CJ, van Rooijen MS, . High performance and acceptability of self-collected rectal swabs for diagnosis of Chlamydia trachomatis and Neisseria gonorrhoeae in men who have sex with men and women. Sex Transm Dis. 2009;36(8):493–7. doi: 10.1097/OLQ.0b013e3181a44b8c. PMID: 19617869. Exclusion: Wrong population.19617869
344 Van Der Pol B, Daniel G, Williams J, . Performance of the BD MAXTM CT/GC/TV assay for detection of chlamydia, gonorrhoea and trichomonas. Sex Transm Infect. Conference: BASHH Spring Conference. 2015;91. Exclusion: Wrong publication type.
345 Van Der Pol B, Fife K, Taylor SN, . Evaluation of the performance of the cobas CT/NG test for use on the cobas 6800/8800 systems for detection of Chlamydia trachomatis and Neisseria gonorrhoeae in male and female urogenital samples. J Clin Microbiol. 2019;57(4) doi: 10.1128/JCM.01996-18. PMID: 30651389. Exclusion: Wrong intervention.30651389
346 Van Der Pol B, Liesenfeld O, Williams JA, . Performance of the cobas CT/NG test compared to the aptima AC2 and viper CTQ/GCQ assays for detection of Chlamydia trachomatis and Neisseria gonorrhoeae. J Clin Microbiol. 2012;50(7):2244–9. doi: 10.1128/jcm.06481-11. PMID: 22518864. Exclusion: Wrong intervention.22518864
347 Van Der Pol B, Taylor SN, Lebar W, . Clinical evaluation of the BD probetec Neisseria gonorrhoeae qx amplified DNA assay on the BD viper system with XTR technology. Sex Transm Dis. 2012;39(2):147–53. doi: 10.1097/OLQ.0b013e3182372fd8. PMID: 22249304. Exclusion: Wrong intervention.22249304
348 Van Der Pol B, Taylor SN, Mena L, . Evaluation of the performance of a point-of-care test for chlamydia and gonorrhea. JAMA Network Open. 2020;3(5):e204819. doi: 10.1001/jamanetworkopen.2020.4819. PMID: 32407506. Exclusion: Wrong comparator.32407506
349 Van Der Pol B, Williams JA, Fuller D, . Combined testing for chlamydia, gonorrhea, and trichomonas by use of the BD max CT/GC/TV assay with genitourinary specimen types. J Clin Microbiol. 2017;55(1):155–64. doi: 10.1128/JCM.01766-16. PMID: 27795343. Exclusion: Wrong intervention.27795343
350 van Dommelen L, van Tiel FH, Ouburg S, . Alarmingly poor performance in Chlamydia trachomatis point-of-care testing. Sex Transm Infect. 2010;86(5):355–9. doi: 10.1136/sti.2010.042598. PMID: 20876754. Exclusion: Wrong intervention.20876754
351 Verougstraete N, Verbeke V, De Canniere AS, . To pool or not to pool? Screening of Chlamydia trachomatis and Neisseria gonorrhoeae in female sex workers: pooled versus single-site testing. Sexually Transmitted Infections. 2020;0:1–5. doi: 10.1136/sextrans-2019-054357. PMID: 32404400. Exclusion: Wrong intervention.32404400
352 Wijers J, van Liere G, Hoebe C, . Test of cure, retesting and extragenital testing practices for Chlamydia trachomatis and Neisseria gonorrhoeae among general practitioners in different socioeconomic status areas: a retrospective cohort study, 2011-2016. PLoS One. 2018;13(3):e0194351. doi: 10.1371/journal.pone.0194351. PMID: 29538469. Exclusion: Wrong study design for Key Question.29538469
353 Willis SJ, Elder H, Cocoros N, . More screening or more disease? Gonorrhea testing and positivity patterns among men in three large clinical practices in Massachusetts, 2010-2017. Clinical Infectious Diseases. 2020 doi: 10.1093/cid/ciaa066. PMID: 3196764431967644. Exclusion: Wrong intervention.
354 Wilson E, Free C, Morris TP, . Can internet-based sexual health services increase diagnoses of sexually transmitted infections (STI)? Protocol for a randomized evaluation of an internet-based STI testing and results service. JMIR Res Protoc. 2016;5(1):e9. doi: 10.2196/resprot.4094. PMID: 26772143. Exclusion: Wrong publication type.26772143
355 Wilson E, Free C, Morris TP, . Internet-accessed sexually transmitted infection (e-STI) testing and results service: a randomised, single-blind, controlled trial. PLoS Med. 2017;14(12):e1002479. doi: 10.1371/journal.pmed.1002479. PMID: 29281628. Exclusion: Wrong outcome.29281628
356 Wilson E, Free C, Morris TP, . Effect of an internet-based sexually transmitted infection testing and results service on diagnoses and testing uptake: a single-blind, randomised controlled trial. Lancet. 2017;390(SPEC.ISS 1):S95-. Exclusion: Wrong publication type.
357 Wilson E, Free C, T PM, . E-sti testing and results service: a single blind randomised controlled trial. Sex Transm Infect. 2017;Conference:. 2017 STI and HIV world congress. Brazil 93(Supplement 2):A190. Exclusion: Wrong publication type.
358 Wilson J, Wallace H, Loftus-Keeling M, . Extra-genital samples for gonorrhoea and chlamydia in women and MSM: self-taken samples analysed separately compared with self-taken pooled samples. Sex Transm Infect. 2016;92. Exclusion: Wrong publication type.
359 Wilson J, Wallace H, Loftus-Keeling M, . Self-taken extra-genital samples compared with clinician-taken extra-genital samples for the diagnosis of gonorrhoea and chlamydia in women and MSM. Sex Transm Infect. 2016;92:A2–A3. Exclusion: Wrong publication type.
360 Wilson J, Wallace H, Loftus-Keeling M, . Clinician-taken extra-genital samples for gonorrhoea and chlamydia in women and msm compared with self-taken samples analysed separately and self-taken pooled samples. Sex Transm Infect. 2017;Conference:. 2017 STI and HIV world congress. Brazil 93(Supplement 2):A26. Exclusion: Wrong publication type.
361 Wisniewski CA, White JA, Michel C-EC, . Optimal method of collection of first-void urine for diagnosis of Chlamydia trachomatis infection in men. J Clin Microbiol. 2008;46(4):1466–9. doi: 10.1128/JCM.02241-07. PMID: 18234860. Exclusion: Wrong intervention.18234860
362 Wood M, Ellks R, Grobicki M. Outreach sexual infection screening and postal tests in men who have sex with men: are they comparable to clinic screening? Int J STD AIDS. 2015;26(6):428–31. doi: 10.1177/0956462414539668. PMID: 24912535. Exclusion: Wrong outcome.24912535
363 Wood SM, McGeary A, Wilson M, . Effectiveness of a quality improvement intervention to improve rates of routine Chlamydia trachomatis screening in female adolescents seeking primary preventive care. J Pediatr Adolesc Gynecol. 2019;32(1):32–8. doi: 10.1016/j.jpag.2018.10.004. PMID: 30394335. Exclusion: Wrong outcome.30394335
364 Yang TZT, Chen MY, Read TRH, . Sampling technique and detection rates of oropharyngeal and anorectal gonorrhoea using nucleic acid amplification tests in men who have sex with men. Sex Transm Infect. 2018;94(4):287–92. doi: 10.1136/sextrans-2017-053339. PMID: 29133523. Exclusion: Wrong outcome.29133523
365 Yussman SM, Urbach K. Introduction of universal chlamydia and gonorrhea screening in an urban school-based health center. Journal of Adolescent Health. 2018;62(2):S80–S1. Exclusion: Wrong publication type.
366 Zou H, Meng X, Grulich A, . A randomised controlled trial to evaluate the impact of sexual health clinic based automated text message reminders on testing of HIV and other sexually transmitted infections in men who have sex with men in China: protocol for the T2T study. BMJ Open. 2017;7(7):e015787. doi: 10.1136/bmjopen-2016-015787. PMID: 28698334. Exclusion: Wrong publication type.28698334

## Appendix A6 Criteria for Assessing Internal Validity of Individual Studies

### Randomized Controlled Trials (RCTs) and Cohort Studies

Criteria:

Initial assembly of comparable groups:

For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups

For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts

Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)

Important differential loss to followup or overall high loss to followup

Measurements: equal, reliable, and valid (includes masking of outcome assessment)

Clear definition of interventions

All important outcomes considered

Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs

Definition of ratings based on above criteria:

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.

Poor: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs

Source: U.S. Preventive Services Task Force. Procedure Manual.

https://www.uspreventiveservicestaskforce.org/Page/Name/appendix-vi-criteria-for-assessing-internal-validity-of-individual-studies Accessed on 4/12/19.

## Appendix A7 Expert Reviewers of the Draft Report

❖ Erin Abramsohn, MPH, DrPH, Centers for Disease Control and Prevention
❖ Andria Apostolou, PhD, MPH, Indian Health Service
❖ Jennifer Fuld, PhD, Centers for Disease Control and Prevention
❖ Charlotte A. Gaydos, DrPH, MPH, MS, Johns Hopkins University
❖ Dr. Elena Gorodetsky, MD, PhD, National Institutes of Health Office of Research on Women’s Health
❖ Katherine K. Hsu, MD, MPH, Boston University School of Medicine
❖ Sonia Lee, PhD, National Institutes of Health Eunice Kennedy Shriver National Institute of Child Health and Human Development
❖ Susan Tuddenham, MD, MPH, Johns Hopkins University
❖ Sung Sug (Sarah) Yoon, PhD, RN, National Institutes of Health National Institute of Nursing Research

Note: Reviewers provided comments on a prior version of the draft report and may or may not agree with the report findings.