# References

1 American College of Obstetricians and Gynecologists. ACOG Practice Bulletin No. 202: Gestational Hypertension and Preeclampsia. Obstetrics and gynecology. 2019;133(1):e1–e25. PMID: 30575675. 10.1097/aog.0000000000003018 30575675
2 Hutcheon JA, Lisonkova S, Joseph KS. Epidemiology of pre-eclampsia and the other hypertensive disorders of pregnancy. Best practice & research Clinical obstetrics & gynaecology. 2011;25(4):391–403.21333604
3 Trogstad L, Magnus P, Stoltenberg C. Pre-eclampsia: Risk factors and causal models. Best practice & research Clinical obstetrics & gynaecology. 2011;25(3):329–42.21349772
4 Sibai BM. The HELLP syndrome (hemolysis, elevated liver enzymes, and low platelets): much ado about nothing? Am J Obstet Gynecol. 1990;162(2):311–6.2309811
5 Ghulmiyyah L, Sibai B. Maternal mortality from preeclampsia/eclampsia. Semin Perinatol. 2012;36(1):56–9.22280867
6 Mayrink J, Costa ML, Cecatti JG. Preeclampsia in 2018: Revisiting Concepts, Physiopathology, and Prediction. ScientificWorldJournal. 2018;2018:6268276. 10.1155/2018/6268276 30622442
7 Say L, Chou D, Gemmill A, . Global causes of maternal death: a WHO systematic analysis. The Lancet Global Health. 2014;2(6):e323–e33. 10.1016/S2214-109X(14)70227-X 25103301
8 Khan KS, Wojdyla D, Say L, . WHO analysis of causes of maternal death: a systematic review. Lancet. 2006;367(9516):1066–74. 10.1016/S0140-6736(06)68397-9 16581405
9 Booker WA, Ananth CV, Wright JD, . Trends in comorbidity, acuity, and maternal risk associated with preeclampsia across obstetric volume settings. J Matern Fetal Neonatal Med. 2019;32(16):2680–7. 10.1080/14767058.2018.1446077 29478359
10 Fingar KR M-HI, Ngo-Metzger Q, . Delivery Hospitalizations Involving Preeclampsia and Eclampsia, 2005–2014: Statistical Brief #222. Rockville, MD: AHRQ; 2017.
11 Gyamfi-Bannerman C, Pandita A, Miller EC, . Preeclampsia outcomes at delivery and race. J Matern Fetal Neonatal Med. 2019:1–8. PMID: 30786794. 10.1080/14767058.2019.1581522 30786794
12 Petersen EE, Davis NL, Goodman D, . Racial/Ethnic Disparities in Pregnancy-Related Deaths - United States, 2007-2016. MMWR Morb Mortal Wkly Rep. 2019;68(35):762–5. PMID: 31487273. 10.15585/mmwr.mm6835a3 31487273
13 Creanga AA, Syverson C, Seed K, . Pregnancy-Related Mortality in the United States, 2011-2013. Obstetrics and gynecology. 2017;130(2):366–73. PMID: 28697109. 10.1097/aog.0000000000002114 28697109
14 Howell EA. Reducing Disparities in Severe Maternal Morbidity and Mortality. Clin Obstet Gynecol. 2018;61(2):387–99. PMID: 29346121. 10.1097/GRF.0000000000000349 29346121
15 Centers for Disease Control and Prevention. Causes of pregnancy-related death in the United States: 2011-2016. https://www.cdc.gov/reproductivehealth/maternal-mortality/pregnancy-mortality-surveillance-system.htm. Accessed: 2020.
16 Steegers EA, von DP, Duvekot JJ, . Pre-eclampsia. Lancet. 2010;376(9741):631–44.20598363
17 Stevens W, Shih T, Incerti D, . Short-term costs of preeclampsia to the United States health care system. Am J Obstet Gynecol. 2017;217(3):237–48 e16. 10.1016/j.ajog.2017.04.032 28708975
18 Grobman WA, Bailit JL, Rice MM, . Frequency of and factors associated with severe maternal morbidity. Obstetrics and gynecology. 2014;123(4):804–10. 10.1097/AOG.0000000000000173 24785608
19 Lisonkova S, Joseph KS. Incidence of preeclampsia: risk factors and outcomes associated with early- versus late-onset disease. Am J Obstet Gynecol. 2013;209(6):544 e1–e12. 10.1016/j.ajog.2013.08.019 23973398
20 Ananth CV, Vintzileos AM. Maternal-fetal conditions necessitating a medical intervention resulting in preterm birth. Am J Obstet Gynecol. 2006;195(6):1557–63. 10.1016/j.ajog.2006.05.021 17014813
21 Honigberg MC, Zekavat SM, Aragam K, . Long-Term Cardiovascular Risk in Women With Hypertension During Pregnancy. J Am Coll Cardiol. 2019;74(22):2743–54. 10.1016/j.jacc.2019.09.052 31727424
22 Melamed N, Ray JG, Hladunewich M, . Gestational hypertension and preeclampsia: are they the same disease? J Obstet Gynaecol Can. 2014;36(7):642–7. 10.1016/S1701-2163(15)30545-4 25184984
23 Brouwers L, van der Meiden-van Roest AJ, Savelkoul C, . Recurrence of pre-eclampsia and the risk of future hypertension and cardiovascular disease: a systematic review and meta-analysis. BJOG : an international journal of obstetrics and gynaecology. 2018;125(13):1642–54. 10.1111/1471-0528.15394 29978553
24 American College of Obstetricians and Gynecologists TFoHiP. Hypertension in pregnancy. Report of the American College of Obstetricians and Gynecologists’ Task Force on Hypertension in Pregnancy. Obstetrics and gynecology. 2013;122(5):1122–31. 10.1097/01.Aog.0000437382.03963.88 24150027
25 Behrens I, Basit S, Melbye M, . Risk of post-pregnancy hypertension in women with a history of hypertensive disorders of pregnancy: nationwide cohort study. BMJ (Clinical research ed). 2017;358:j3078. 10.1136/bmj.j3078
26 Williams D. Long-term complications of preeclampsia. Semin Nephrol. 2011;31(1):111–22. 10.1016/j.semnephrol.2010.10.010 21266269
27 Roberts JM. The perplexing pregnancy disorder preeclampsia: what next? Physiol Genomics. 2018;50(6):459–67. PMID: 29602298. 10.1152/physiolgenomics.00017.2018 29602298
28 Redman CW, Sargent IL, Staff AC. IFPA Senior Award Lecture: making sense of pre-eclampsia - two placental causes of preeclampsia? Placenta. 2014;35 Suppl:S20–5. 10.1016/j.placenta.2013.12.008
29 Redman CW, Staff AC. Preeclampsia, biomarkers, syncytiotrophoblast stress, and placental capacity. Am J Obstet Gynecol. 2015;213(4 Suppl):S9.e1, S9–11. 10.1016/j.ajog.2015.08.003 26428507
30 Rana S, Lemoine E, Granger JP, . Preeclampsia: Pathophysiology, Challenges, and Perspectives. Circ Res. 2019;124(7):1094–112. PMID: 30920918. 10.1161/CIRCRESAHA.118.313276 30920918
31 Preeclampsia and eclampsia. https://www.clinicalkey.com/#!/content/clinical_overview/67-s2.0-dcd12356-2aec-47a9-8277-9ed314ce1866.
32 Phipps E, Prasanna D, Brima W, . Preeclampsia: Updates in Pathogenesis, Definitions, and Guidelines. Clinical Journal of the American Society of Nephrology. 2016;11(6):1102–13. 10.2215/cjn.12081115 27094609
33 Ayala DE, Hermida RC. Sex differences in the administration-time-dependent effects of low-dose aspirin on ambulatory blood pressure in hypertensive subjects. Chronobiol Int. 2010;27:345–62.20370474
34 Esplin MS, Fausett MB, Fraser A, . Paternal and maternal components of the predisposition to preeclampsia. New England Journal of Medicine. 2001;344(12):867–72.
35 Gabbe SG. Obstetrics : normal and problem pregnancies. 2017.
36 Ghosh G, Grewal J, Männistö T, . Racial/ethnic differences in pregnancy-related hypertensive disease in nulliparous women. Ethn Dis. 2014;24(3):283–9.25065068
37 Johnson JD, Louis JM. Does race or ethnicity play a role in the origin, pathophysiology, and outcomes of preeclampsia? An expert review of the literature. Am J Obstet Gynecol. 2020. 10.1016/j.ajog.2020.07.038
38 Bartsch E, Medcalf KE, Park AL, . Clinical risk factors for pre-eclampsia determined in early pregnancy: systematic review and meta-analysis of large cohort studies. BMJ (Clinical research ed). 2016;353:i1753. PMID: 27094586. 10.1136/bmj.i1753 27094586
39 Wright D, Tan MY, O’Gorman N, . Predictive performance of the competing risk model in screening for preeclampsia. Am J Obstet Gynecol. 2019;220(2):199.e1–.e13. 10.1016/j.ajog.2018.11.1087 30447210
40 Henderson JT, Thompson JH, Burda BU, . Preeclampsia Screening: Evidence Report and Systematic Review for the US Preventive Services Task Force. Jama. 2017;317(16):1668–83. 10.1001/jama.2016.18315 28444285
41 Altman D, Carroli G, Duley L, . Do women with pre-eclampsia, and their babies, benefit from magnesium sulphate? The Magpie Trial: a randomised placebo-controlled trial. Lancet. 2002;359(9321):1877–90.12057549
42 Magpie Trial Follow-Up Study Collaborative Group. The Magpie Trial: a randomised trial comparing magnesium sulphate with placebo for pre-eclampsia. Outcome for children at 18 months. BJOG : an international journal of obstetrics and gynaecology. 2007;114(3):289–99. 10.1111/j.1471-0528.2006.01165.x 17166221
43 Group MTF-USC. The Magpie Trial: a randomised trial comparing magnesium sulphate with placebo for pre-eclampsia. Outcome for women at 2 years. BJOG : an international journal of obstetrics and gynaecology. 2007;114(3):300–9. 10.1111/j.1471-0528.2006.01166.x 17166220
44 Koopmans CM, Bijlenga D, Groen H, . Induction of labour versus expectant monitoring for gestational hypertension or mild pre-eclampsia after 36 weeks’ gestation (HYPITAT): a multicentre, open-label randomised controlled trial. Lancet. 2009;374(9694):979–88. 10.1016/s0140-6736(09)60736-4 19656558
45 Haapsamo M, Martikainen H, R„s„nen J. Low-dose aspirin reduces uteroplacental vascular impedance in early and mid gestation in IVF and ICSI patients: a randomized, placebo-controlled double-blind study. Ultrasound in obstetrics & gynecology : the official journal of the International Society of Ultrasound in Obstetrics and Gynecology. 2008;32:687–93.
46 Hofmeyr GJ, Lawrie TA, Atallah Á N, . Calcium supplementation during pregnancy for preventing hypertensive disorders and related problems. The Cochrane database of systematic reviews. 2018;10(10):Cd001059. 10.1002/14651858.CD001059.pub5 30277579
47 World Health Organization. WHO recommendation: calcium supplementation during pregnancy for prevention of pre-eclampsia and its complications: World Health Organization; 2018.
48 Rumbold A, Duley L, Crowther CA, . Antioxidants for preventing pre-eclampsia. The Cochrane database of systematic reviews. 2008(1):Cd004227. 10.1002/14651858.CD004227.pub3 18254042
49 Zhou SJ, Yelland L, McPhee AJ, . Fish-oil supplementation in pregnancy does not reduce the risk of gestational diabetes or preeclampsia. Am J Clin Nutr. 2012;95(6):1378–84. 10.3945/ajcn.111.033217 22552037
50 Meher S, Duley L. Garlic for preventing pre-eclampsia and its complications. The Cochrane database of systematic reviews. 2006(3):Cd006065. 10.1002/14651858.Cd006065 16856110
51 Bodnar LM, Catov JM, Simhan HN, . Maternal vitamin D deficiency increases the risk of preeclampsia. The Journal of clinical endocrinology and metabolism. 2007;92(9):3517–22. 10.1210/jc.2007-0718 17535985
52 Wen SW, White RR, Rybak N, . Effect of high dose folic acid supplementation in pregnancy on pre-eclampsia (FACT): double blind, phase III, randomised controlled, international, multicentre trial. BMJ (Clinical research ed). 2018;362:k3478. 10.1136/bmj.k3478
53 Duley L, Henderson-Smart D. Reduced salt intake compared to normal dietary salt, or high intake, in pregnancy. The Cochrane database of systematic reviews. 2000(2):Cd001687. 10.1002/14651858.Cd001687 10796269
54 Baschat AA, Magder LS, Doyle LE, . Prediction of preeclampsia utilizing the first trimester screening examination. Am J Obstet Gynecol. 2014;211(5):514 e1–7. 10.1016/j.ajog.2014.04.018 24746997
55 Vane JR, Botting RM. The mechanism of action of aspirin. Thromb Res. 2003;110(5-6):255–8. 10.1016/s0049-3848(03)00379-7 14592543
56 Wertaschnigg D, Reddy M, Mol BWJ, . Evidence-Based Prevention of Preeclampsia: Commonly Asked Questions in Clinical Practice. J Pregnancy. 2019;2019:2675101. 10.1155/2019/2675101 31467716
57 Ayala DE, Ucieda R, Hermida RC. Chronotherapy with low-dose aspirin for prevention of complications in pregnancy. Chronobiol Int. 2013;30(1-2):260–79. 10.3109/07420528.2012.717455 23004922
58 Baschat AA, Dewberry D, Seravalli V, . Maternal blood-pressure trends throughout pregnancy and development of pre-eclampsia in women receiving first-trimester aspirin prophylaxis. Ultrasound in Obstetrics & Gynecology. 2018;52(6):728–33. PMID: 29266502. 10.1002/uog.18992 29266502
59 Rolnik DL, Wright D, Poon LC, . Aspirin versus Placebo in Pregnancies at High Risk for Preterm Preeclampsia. N Engl J Med. 2017;377(7):613–22. 10.1056/NEJMoa1704559 28657417
60 Duley L, Henderson-Smart DJ, Meher S, . Antiplatelet agents for preventing pre-eclampsia and its complications. The Cochrane database of systematic reviews. 2007(2):CD004659.17443552
61 Askie LM, Duley L, Henderson-Smart DJ, . Antiplatelet agents for prevention of pre-eclampsia: a meta-analysis of individual patient data. Lancet. 2007;369(9575):1791–8. 10.1016/S0140-6736(07)60712-0 17512048
62 Voelker R. USPSTF: Low-dose aspirin may help reduce risk of preeclampsia. JAMA - Journal of the American Medical Association. 2014;311(20):2055. 10.1001/jama.2014.5390 24866995
63 Hoffman MK, Goudar SS, Kodkany BS, . Low-dose aspirin for the prevention of preterm delivery in nulliparous women with a singleton pregnancy (ASPIRIN): a randomised, double-blind, placebo-controlled trial. The Lancet. 2020;395(10220):285–93. 10.1016/S0140-6736(19)32973-3
64 Tolcher MC, Chu DM, Hollier LM, . Impact of USPSTF recommendations for aspirin for prevention of recurrent preeclampsia. Am J Obstet Gynecol. 2017;217(3):365.e1–.e8. 10.1016/j.ajog.2017.04.035 28455079
65 World Health O. WHO Recommendations for prevention and treatment of pre-eclampsia and eclampsia. World Health Organization; 2011.
66 American College of Obstetricians and Gynecologists. ACOG Committee Opinion No. 743: Low-Dose Aspirin Use During Pregnancy. Obstetrics and gynecology. 2018;132(1):e44–e52. 10.1097/aog.0000000000002708 29939940
67 National Institute for Health and Clinical Excellence. Hypertension in Pregnancy. Manchester, UK: National Institute for Health and Clinical Excellence; 2010.
68 Bushnell C, McCullough LD, Awad IA, . Guidelines for the prevention of stroke in women: a statement for healthcare professionals from the American Heart Association/American Stroke Association. Stroke. 2014;45(5):1545–88. 10.1161/01.str.0000442009.06663.48 24503673
69 LeFevre ML, Force USPST. Low-dose aspirin use for the prevention of morbidity and mortality from preeclampsia: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014;161(11):819–26. PMID: 25200125. 10.7326/M14-1884 25200125
70 Henderson JT, Whitlock EP, O’Connor E, . Low-dose aspirin for prevention of morbidity and mortality from preeclampsia: a systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2014;160(10):695–703. 10.7326/M13-2844 24711050
71 Henderson JT, Whitlock EP, O’Connor E, . Low-dose aspirin for prevention of morbidity and mortality from preeclampsia: a systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2014;160(10):695–703. PMID: 24711050. 10.7326/M13-2844 24711050
72 U.S. Preventive Services Task Force. Final Recommendation Statement: Low-Dose Aspirin Use for the Prevention of Morbidity and Mortality From Preeclampsia: Preventive Medication. https://www.uspreventiveservicestaskforce.org/Page/Document/RecommendationStatementFinal/low-dose-aspirin-use-for-the-prevention-of-morbidity-and-mortality-from-preeclampsia-preventive-medication.
73 United Nations Development Programme. Human Development Report. New York, NY: United Nations; 2016.
74 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015.
75 Raudenbush SW. Analyzing effect sizes: Random-effects models. In: Cooper H, Hedges LV, Valentine JC, editors. The Handbook of Research Synthesis and Meta-Analysis. 2nd ed. New York, New York: Russell Sage Foundation; 2009. p. 296–314.
76 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. 2003;22(17):2693–710. PMID: 12939780. 10.1002/sim.1482 12939780
77 Veroniki AA, Jackson D, Bender R, . Methods to calculate uncertainty in the estimated overall effect size from a random-effects meta-analysis. Res Synth Methods. 2019;10(1):23–43. 10.1002/jrsm.1319 30129707
78 Yusuf S, Peto R, Lewis J, . Beta blockade during and after myocardial infarction: An overview of the randomized trials. Progress in Cardiovascular Diseases. 1985;27(5):335–71.2858114
79 Cheng J, Pullenayegum E, Marshall JK, . Impact of including or excluding both-armed zero-event studies on using standard meta-analysis methods for rare event outcome: a simulation study. BMJ open. 2016;6(8):1–10. 10.1136/bmjopen-2015-010983
80 Peters JL, Sutton AJ, Jones DR, . Comparison of two methods to detect publication bias in meta-analysis. Jama. 2006;295(6):676–80. PMID: 16467236. 10.1001/jama.295.6.676 16467236
81 Sterne JAC, Harbord RM. Funnel plots in meta-analysis. The Stata Journal. 2004;4(2):127–41. 10.1177/1536867X0400400204
82 Jin Z-C, Zhou X-H, He J. Statistical methods for dealing with publication bias in meta-analysis. Stat Med. 2015;34(2):343–60. 10.1002/sim.6342 25363575
83 Whitlock EP, Eder M, Thompson JH, . An approach to addressing subpopulation considerations in systematic reviews: the experience of reviewers supporting the U.S. Preventive Services Task Force. Systematic Reviews. 2017;6(1):41. 10.1186/s13643-017-0437-3 28253915
84 Higgins JPTT, J.; Cumpston, M.; Li, T.; Page, M. J.; Welch, V. A. (editors). Cochrane Handbook for Systematic Reviews of Interventions version 6.0. www.training.cochrane.org/handbook.
85 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD): Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID: None.
86 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
87 Wallenburg HC, Dekker GA, Makovitz JW, . Low-dose aspirin prevents pregnancy-induced hypertension and pre-eclampsia in angiotensin-sensitive primigravidae. Lancet. 1986;1(8471):1–3.2867260
88 Benigni A, Gregorini G, Frusca T, . Effect of low-dose aspirin on fetal and maternal generation of thromboxane by platelets in women at risk for pregnancy-induced hypertension. New England Journal of Medicine. 1989;321(6):357–62.
89 Schiff E, Peleg E, Goldenberg M, . The use of aspirin to prevent pregnancy-induced hypertension and lower the ratio of thromboxane A2 to prostacyclin in relatively high risk pregnancies. New England Journal of Medicine. 1989;321(6):351–6.
90 McParland P, Pearce JM, Chamberlain GV. Doppler ultrasound and aspirin in recognition and prevention of pregnancy-induced hypertension. Lancet. 1990;335(8705):1552–5.1972487
91 Hauth JC, Goldenberg RL, Parker CR, Jr., . Low-dose aspirin therapy to prevent preeclampsia. Am J Obstet Gynecol. 1993;168(4):1083–91.8475955
92 Sibai BM, Caritis SN, Thom E, . Prevention of preeclampsia with low-dose aspirin in healthy, nulliparous pregnant women. The National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. New England Journal of Medicine. 1993;329(17):1213–8.
93 Viinikka L, Hartikainen-Sorri AL, Lumme R, . Low dose aspirin in hypertensive pregnant women: effect on pregnancy outcome and prostacyclin-thromboxane balance in mother and newborn. Br J Obstet Gynaecol. 1993;100(9):809–15.8217999
94 Caspi E, Raziel A, Sherman D, . Prevention of pregnancy-induced hypertension in twins by early administration of low-dose aspirin: a preliminary report. American journal of reproductive immunology (New York, NY : 1989). 1994;31(1):19–24.
95 CLASP: A randomised trial of low-dose aspirin for the prevention and treatment of pre-eclampsia. Lancet. 1994;343(8898):619.7906809
96 Davies NJ, Gazvani MR, Farquharson RG, . Low-Dose Aspirin in the Prevention of Hypertensive Disorders of Pregnancy in Relatively Low-Risk Nulliparous Women. Hypertens. 1995;14(1):49–55.
97 Gallery EDM, Ross MR, Hawkins M, . Low-Dose Aspirin in High-Risk Pregnancy? Hypertens. 1997;16(2):229–38. 10.3109/10641959709031640
98 Hermida RC, Ayala DE, Iglesias M, . Time-dependent effects of low-dose aspirin administration on blood pressure in pregnant women. Hypertension (Dallas, Tex : 1979). 1997;30(3 Pt 2):589–95.
99 Caritis S, Sibai B, Hauth J, . Low-Dose Aspirin to Prevent Preeclampsia in Women at High Risk. New England Journal of Medicine. 1998;338(11):701–5. 10.1056/NEJM199803123381101
100 Rotchell YE, Cruickshank JK, Gay MP, . Barbados Low Dose Aspirin Study in Pregnancy (BLASP): a randomised trial for the prevention of pre-eclampsia and its complications. Br J Obstet Gynaecol. 1998;105(3):286–92.9532988
101 Grab D, Paulus WE, Erdmann M, . Effects of low-dose aspirin on uterine and fetal blood flow during pregnancy: results of a randomized, placebo-controlled, double-blind trial. Ultrasound in obstetrics & gynecology : the official journal of the International Society of Ultrasound in Obstetrics and Gynecology. 2000;15(1):19–27.
102 Subtil D, Goeusse P, Puech F, . Aspirin (100 mg) used for prevention of pre-eclampsia in nulliparous women: the Essai Regional Aspirine Mere-Enfant study (Part 1). BJOG : an international journal of obstetrics and gynaecology. 2003;110(5):475–84.12742332
103 Yu CK, Papageorghiou AT, Parra M, . Randomized controlled trial using low-dose aspirin in the prevention of pre-eclampsia in women with abnormal uterine artery Doppler at 23 weeks’ gestation. Ultrasound in obstetrics & gynecology : the official journal of the International Society of Ultrasound in Obstetrics and Gynecology. 2003;22(3):233–9.
104 Villa P, Kajantie E, Raikkonen K, . Aspirin in the prevention of pre-eclampsia in high-risk women: a randomised placebo-controlled PREDO Trial and a meta-analysis of randomised trials. BJOG : an international journal of obstetrics and gynaecology. 2013;120(1):64–74.
105 Mone F, Mulcahy C, McParland P, . Trial of feasibility and acceptability of routine low-dose aspirin versus Early Screening Test indicated aspirin for pre-eclampsia prevention (TEST study): a multicentre randomised controlled trial. BMJ open. 2018;8(7):e022056. PMID: 30056389. 10.1136/bmjopen-2018-022056 30056389
106 Scazzocchio E, Oros D, Diaz D, . Impact of aspirin on trophoblastic invasion in women with abnormal uterine artery Doppler at 11-14 weeks: a randomized controlled study. Ultrasound in obstetrics & gynecology : the official journal of the International Society of Ultrasound in Obstetrics and Gynecology. 2017;49(4):435–41. 10.1002/uog.17351
107 Morris JM, Fay RA, Ellwood DA, . A randomized controlled trial of aspirin in patients with abnormal uterine artery blood flow. Obstetrics and gynecology. 1996;87(1):74–8. 10.1016/0029-7844(95)00340-1 8532271
108 Jensen MS, Rebordosa C, Thulstrup AM, . Maternal use of acetaminophen, ibuprofen, and acetylsalicylic acid during pregnancy and risk of cryptorchidism. Epidemiology. 2010;21(6):779–85.20805751
109 Keim SA, Klebanoff MA. Aspirin use and miscarriage risk. Epidemiology. 2006;17(4):435–9.16755260
110 Newnham JP, Godfrey M, Walters BJ, . Low dose aspirin for the treatment of fetal growth restriction: a randomized controlled trial. The Australian & New Zealand journal of obstetrics & gynaecology. 1995;35(4):370–4.8717556
111 Vainio M, Kujansuu E, Iso-Mustajarvi M, . Low dose acetylsalicylic acid in prevention of pregnancy-induced hypertension and intrauterine growth retardation in women with bilateral uterine artery notches. BJOG : an international journal of obstetrics and gynaecology. 2002;109(2):161–7.11888098
112 Poon LC, Wright D, Rolnik DL, . Aspirin for Evidence-Based Preeclampsia Prevention trial: effect of aspirin in prevention of preterm preeclampsia in subgroups of women according to their characteristics and medical and obstetrical history. Am J Obstet Gynecol. 2017;217(5):585.e1–.e5. 10.1016/j.ajog.2017.07.038 28784417
113 Clasp Collaborative Group. Low dose aspirin in pregnancy and early childhood development: follow up of the collaborative low dose aspirin study in pregnancy. CLASP collaborative group 50. Br J Obstet Gynaecol. 1995;102(11):861–8.8534620
114 Adkins K, Allshouse AA, Metz TD, . Impact of aspirin on fetal growth in diabetic pregnancies according to White classification. American Journal of Obstetrics & Gynecology. 2017;217(4):465.e1–.e5. PMID: 28599894. 10.1016/j.ajog.2017.05.062 28599894
115 Abramovici A, Jauk V, Wetta L, . Low-dose aspirin, smoking status, and the risk of spontaneous preterm birth. American journal of perinatology. 2015;32(5):445–50. PMID: 25261702. 10.1055/s-0034-1390352 25261702
116 Cantu JA, Jauk VR, Owen J, . Is low-dose aspirin therapy to prevent preeclampsia more efficacious in non-obese women or when initiated early in pregnancy? Journal of Maternal-Fetal & Neonatal Medicine. 2015;28(10):1128–32. PMID: 25048750. 10.3109/14767058.2014.947258 25048750
117 Tolcher MC, Sangi-Haghpeykar H, Aagaard KM. Low-dose aspirin (ASA) for preeclampsia prevention among high-risk women by ethnicity and race. American Journal of Obstetrics and Gynecology. 2018;218(1):S564.
118 American College of Obstetricians and Gynecologists. Practice Bulletin No. 183: Postpartum Hemorrhage. Obstetrics & Gynecology. 2017;130(4):e168–e86. PMID: 00006250-201710000-00056. 10.1097/aog.0000000000002351 28937571
119 Centers for Disease Control and Prevention. Data on Selected Pregnancy Complications in the United States. https://www.cdc.gov/reproductivehealth/maternalinfanthealth/pregnancy-complications-data.htm#post.
120 Creanga AA, Berg CJ, Ko JY, . Maternal mortality and morbidity in the United States: where are we now? J Womens Health (Larchmt). 2014;23(1):3–9. PMID: 24383493. 10.1089/jwh.2013.4617 24383493
121 Callaghan WM, Mackay AP, Berg CJ. Identification of severe maternal morbidity during delivery hospitalizations, United States, 1991-2003. Am J Obstet Gynecol. 2008;199(2):133 e1–8. PMID: 18279820. 10.1016/j.ajog.2007.12.020 18279820
122 Koopmans CM, van der Tuuk K, Groen H, . Prediction of postpartum hemorrhage in women with gestational hypertension or mild preeclampsia at term. Acta obstetricia et gynecologica Scandinavica. 2014;93(4):399–407. PMID: 24575790. 10.1111/aogs.12352 24575790
123 Duley L, Meher S, Hunter KE, . Antiplatelet agents for preventing pre-eclampsia and its complications. Cochrane Database of Systematic Reviews. 2019(10). 10.1002/14651858.CD004659.pub3
124 Landon M, Galan H, Jauniaux E, . Antepartum and Postpartum Hemorrhage. Gabbe’s Obstetrics: Normal and Problem Pregnancies. 8 ed. Philadelphia, PA: Elsevier; 2021.
125 Landon M, Galan H, Jauniaux E, . The Neonate. Gabbe’s Obstetrics: Normal and Problem Pregnancies. 8 ed. Philadelphia, PA: Elsevier; 2021.
126 Stewart GB, Altman DG, Askie LM, . Statistical analysis of individual participant data meta-analyses: a comparison of methods and recommendations for practice. PLoS ONE [Electronic Resource]. 2012;7(10):e46042.
127 Meher S, Duley L, Hunter K, . Antiplatelet therapy before or after 16 weeks’ gestation for preventing preeclampsia: an individual participant data meta-analysis. Am J Obstet Gynecol. 2017;216(2):121–8.e2. 10.1016/j.ajog.2016.10.016 27810551
128 van Vliet EO, Askie LA, Mol BW, . Antiplatelet Agents and the Prevention of Spontaneous Preterm Birth: A Systematic Review and Meta-analysis. Obstetrics and gynecology. 2017;129(2):327–36. 10.1097/aog.0000000000001848 28079785
129 Seidler AL, Askie L, Ray JG. Optimal aspirin dosing for preeclampsia prevention. American Journal of Obstetrics & Gynecology. 2018;219(1):117–8. PMID: 29588190. 10.1016/j.ajog.2018.03.018 29588190
130 Nakhai-Pour HR, Berard A. Major malformations after first-trimester exposure to aspirin and NSAIDs. Expert Review of Clinical Pharmacology. 2008;1(5):605–16.24422733
131 Coomarasamy A, Braunholtz D, Song F, . Individualising use of aspirin to prevent pre-eclampsia: a framework for clinical decision making. BJOG : an international journal of obstetrics and gynaecology. 2003;110(10):882–8.14550356
132 Hernandez RK, Werler MM, Romitti P, . Nonsteroidal antiinflammatory drug use among women and the risk of birth defects. American Journal of Obstetrics and Gynecology. 2012;206(3):228.e1–.e8. 10.1016/j.ajog.2011.11.019 22196851
133 Given JE, Loane M, Garne E, . Gastroschisis in Europe – A Case-malformed-Control Study of Medication and Maternal Illness during Pregnancy as Risk Factors. Paediatr Perinat Epidemiol. 2017;31(6):549–59. 10.1111/ppe.12401 28841756
134 Schulz K, Grimes D. Essential Concepts in Clinical Research: Randomised Controlled Trials and Observational Epidemiology. 2 ed: Elsevier; 2019.
135 Wright D, Poon LC, Rolnik DL, . Aspirin for Evidence-Based Preeclampsia Prevention trial: influence of compliance on beneficial effect of aspirin in prevention of preterm preeclampsia. American Journal of Obstetrics & Gynecology. 2017;217(6):685.e1–.e5. PMID: 28888591. 10.1016/j.ajog.2017.08.110 28888591
136 Shanmugalingam R, Wang X, Motum P, . Clinical Influence of Nonadherence With Prophylactic Aspirin in Preventing Preeclampsia in High-Risk Pregnancies: A Multicenter, Prospective, Observational Cohort Study. Hypertension (Dallas, Tex : 1979). 2020;75(4):1125–32. PMID: 32114852. 10.1161/HYPERTENSIONAHA.119.14107 32114852
137 Young BC, Thadhani R, Karumanchi SA. Aspirin to Prevent Preterm Preeclampsia: More Progress. Hypertension (Dallas, Tex : 1979). 2020;75(4):941–2. PMID: 32114845. 10.1161/HYPERTENSIONAHA.119.14277 32114845
138 van Montfort P, Scheepers HCJ, van Dooren IMA, . Low-dose-aspirin usage among women with an increased preeclampsia risk: A prospective cohort study. Acta obstetricia et gynecologica Scandinavica. 2020. PMID: 31953956. 10.1111/aogs.13808 31953956
139 Al-Rubaie Z, Askie LM, Ray JG, . The performance of risk prediction models for pre-eclampsia using routinely collected maternal characteristics and comparison with models that include specialised tests and with clinical guideline decision rules: a systematic review. BJOG : an international journal of obstetrics and gynaecology. 2016;123(9):1441–52. PMID: 10.1111/1471-0528.14029 [doi].27225348
140 Tan MY, Wright D, Syngelaki A, . Comparison of diagnostic accuracy of early screening for pre-eclampsia by NICE guidelines and a method combining maternal factors and biomarkers: results of SPREE. Ultrasound in Obstetrics & Gynecology. 2018;51(6):743–50. 10.1002/uog.19039 29536574
141 Akolekar R, Syngelaki A, Poon L, . Competing risks model in early screening for preeclampsia by biophysical and biochemical markers. Fetal Diagn Ther. 2013;33(1):8–15. PMID: 22906914.22906914
142 O’Gorman N, Wright D, Poon LC, . Multicenter screening for pre-eclampsia by maternal factors and biomarkers at 11-13 weeks’ gestation: comparison with NICE guidelines and ACOG recommendations. Ultrasound in obstetrics & gynecology : the official journal of the International Society of Ultrasound in Obstetrics and Gynecology. 2017;49(6):756–60. PMID: 28295782. 10.1002/uog.17455 28295782
143 Roberts JM, Himes KP. Pre-eclampsia: Screening and aspirin therapy for prevention of pre-eclampsia. Nature Reviews Nephrology. 2017;13(10):602–4. 10.1038/nrneph.2017.121
144 Allen RE, Zamora J, Arroyo-Manzano D, . External validation of preexisting first trimester preeclampsia prediction models. European Journal of Obstetrics and Gynecology and Reproductive Biology. 2017;217:119–25. 10.1016/j.ejogrb.2017.08.031 28888181
145 Bailey B, Euser AG, Bol KA, . High-altitude residence alters blood-pressure course and increases hypertensive disorders of pregnancy. J Matern Fetal Neonatal Med. 2020:1–8. PMID: 32228111. 10.1080/14767058.2020.1745181 32228111
146 Bai W, Li Y, Niu Y, . Association between ambient air pollution and pregnancy complications: A systematic review and meta-analysis of cohort studies. Environ Res. 2020;185:109471. PMID: 32276169. 10.1016/j.envres.2020.109471 32276169
147 Wilson DL, Howard ME, Fung AM, . The presence of coexisting sleep-disordered breathing among women with hypertensive disorders of pregnancy does not worsen perinatal outcome. PloS one. 2020;15(2):e0229568. PMID: 32101584. 10.1371/journal.pone.0229568 32101584
148 Li L, Zhao K, Hua J, . Association between Sleep-Disordered Breathing during Pregnancy and Maternal and Fetal Outcomes: An Updated Systematic Review and Meta-Analysis. Front Neurol. 2018;9:91. PMID: 29892255. 10.3389/fneur.2018.00091 29892255
149 Aukes AM, Yurtsever FN, Boutin A, . Associations Between Migraine and Adverse Pregnancy Outcomes: Systematic Review and Meta-analysis. Obstet Gynecol Surv. 2019;74(12):738–48. PMID: 31881091. 10.1097/OGX.0000000000000738 31881091
150 Palatnik A, Grobman WA, Miller ES. Is a history of preeclampsia associated with an increased risk of a small for gestational age infant in a future pregnancy? American Journal of Obstetrics & Gynecology. 2016;215(3):355.e1–6. PMID: 26994655. 10.1016/j.ajog.2016.03.011 26994655
151 North RA, McCowan LM, Dekker GA, . Clinical risk prediction for pre-eclampsia in nulliparous women: development of model in international prospective cohort. BMJ (Clinical research ed). 2011;342:d1875.
152 Myatt L, Clifton RG, Roberts JM, . First-trimester prediction of preeclampsia in nulliparous women at low risk. Obstetrics and gynecology. 2012;119(6):1234–42. PMID: 22617589.22617589
153 Chappell LC, Seed PT, Myers J, . Exploration and confirmation of factors associated with uncomplicated pregnancy in nulliparous women: prospective cohort study. BMJ (Clinical research ed). 2013;347:f6398. PMID: 24270055.24270055
154 Skrastad R, Hov G, Blaas HG, . Risk assessment for preeclampsia in nulliparous women at 11-13 weeks gestational age: prospective evaluation of two algorithms. BJOG : an international journal of obstetrics and gynaecology. 2014. PMID: 25471057.25471057
155 Mone F, Mulcahy C, McParland P, . Should we recommend universal aspirin for all pregnant women? American Journal of Obstetrics & Gynecology. 2017;216(2):141.e1–.e5. PMID: 27659212. 10.1016/j.ajog.2016.09.086 27659212
156 Ayala NK, Rouse DJ. A Nudge Toward Universal Aspirin for Preeclampsia Prevention. Obstetrics and gynecology. 2019;133(4):725–8. PMID: 30870274. 10.1097/AOG.0000000000003167 30870274
157 Mone F, O’Mahony JF, Tyrrell E, . Preeclampsia Prevention Using Routine Versus Screening Test-Indicated Aspirin in Low-Risk Women. Hypertension (Dallas, Tex : 1979). 2018;72(6):1391–6. PMID: 30571234. 10.1161/HYPERTENSIONAHA.118.11718 30571234
158 Rolnik DL, O’Gorman N, Roberge S, . Early screening and prevention of preterm pre-eclampsia with aspirin: time for clinical implementation. Ultrasound in obstetrics & gynecology : the official journal of the International Society of Ultrasound in Obstetrics and Gynecology. 2017;50(5):551–6. PMID: 28887883. 10.1002/uog.18899 28887883
159 Ross KM, Dunkel Schetter C, McLemore MR, . Socioeconomic Status, Preeclampsia Risk and Gestational Length in Black and White Women. J Racial Ethn Health Disparities. 2019;6(6):1182–91. PMID: 31368002. 10.1007/s40615-019-00619-3 31368002
160 Shahul S, Tung A, Minhaj M, . Racial Disparities in Comorbidities, Complications, and Maternal and Fetal Outcomes in Women With Preeclampsia/eclampsia. Hypertens Pregnancy. 2015;34(4):506–15. PMID: 26636247. 10.3109/10641955.2015.1090581 26636247
161 Wu P, Chew-Graham CA, Maas AH, . Temporal Changes in Hypertensive Disorders of Pregnancy and Impact on Cardiovascular and Obstetric Outcomes. Am J Cardiol. 2020. PMID: 32273052. 10.1016/j.amjcard.2020.02.029 32273052
162 Whelton PK, Carey RM, Aronow WS, . 2017 ACC/AHA/AAPA/ABC/ACPM/AGS/APhA/ASH/ASPC/NMA/PCNA Guideline for the Prevention, Detection, Evaluation, and Management of High Blood Pressure in Adults: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Hypertension (Dallas, Tex : 1979). 2018;71(6):e13–e115. PMID: 29133356. 10.1161/hyp.0000000000000065 29133356
163 Duckitt K, Harrington D. Risk factors for pre-eclampsia at antenatal booking: systematic review of controlled studies. BMJ (Clinical research ed). 2005;330(7491):565.
164 Hauspurg A, Sutton EF, Catov JM, . Aspirin Effect on Adverse Pregnancy Outcomes Associated With Stage 1 Hypertension in a High-Risk Cohort. Hypertension (Dallas, Tex : 1979). 2018;72(1):202–7. PMID: 29802215. 10.1161/hypertensionaha.118.11196 29802215
165 Finneran MM, Gonzalez-Brown VM, Smith DD, . Obesity and laboratory aspirin resistance in high-risk pregnant women treated with low-dose aspirin. American Journal of Obstetrics & Gynecology. 2019;220(4):385.e1–.e6. PMID: 30786253. 10.1016/j.ajog.2019.01.222 30786253
166 Menard MK, Main EK, Currigan SM. Executive summary of the reVITALize initiative: standardizing obstetric data definitions. Obstetrics and gynecology. 2014;124(1):150–3. PMID: 24901267. 10.1097/AOG.0000000000000322 24901267
167 American College of Obstetricians and Gynecologists. Obstetric Data Definitions: reVITALize. https://www.acog.org/-/media/project/acog/acogorg/files/pdfs/publications/revitalize-ob.pdf?la=en&hash=D9ECE1577C2A0B535F42C1B8DC492070.
168 Jayet PY, Rimoldi SF, Stuber T, . Pulmonary and systemic vascular dysfunction in young offspring of mothers with preeclampsia. Circulation. 2010;122(5):488–94. PMID: 20644018. 10.1161/CIRCULATIONAHA.110.941203 20644018
169 Nahum Sacks K, Friger M, Shoham-Vardi I, . Prenatal exposure to preeclampsia as an independent risk factor for long-term cardiovascular morbidity of the offspring. Pregnancy Hypertens. 2018;13:181–6. PMID: 30177050. 10.1016/j.preghy.2018.06.013 30177050
170 Maher GM, Dalman C, O’Keeffe GW, . Association between preeclampsia and attention-deficit hyperactivity disorder: a population-based and sibling-matched cohort study. Acta Psychiatr Scand. 2020. PMID: 32056200. 10.1111/acps.13162 32056200
171 Nahum Sacks K, Friger M, Shoham-Vardi I, . Long-term neuropsychiatric morbidity in children exposed prenatally to preeclampsia. Early Hum Dev. 2019;130:96–100. PMID: 30711915. 10.1016/j.earlhumdev.2019.01.016 30711915
172 Sun BZ, Moster D, Harmon QE, . Association of Preeclampsia in Term Births With Neurodevelopmental Disorders in Offspring. JAMA Psychiatry. 2020. 10.1001/jamapsychiatry.2020.0306
173 Davis EF, Lazdam M, Lewandowski AJ, . Cardiovascular risk factors in children and young adults born to preeclamptic pregnancies: a systematic review. Pediatrics. 2012;129(6):e1552–e61.22614768
174 Valdiviezo C, Garovic VD, Ouyang P. Preeclampsia and hypertensive disease in pregnancy: their contributions to cardiovascular risk. Clin Cardiol. 2012;35(3):160–5.22389120
175 Bellamy L, Casas JP, Hingorani AD, . Pre-eclampsia and risk of cardiovascular disease and cancer in later life: systematic review and meta-analysis. BMJ (Clinical research ed). 2007;335(7627):974.
176 Lykke JA, Langhoff-Roos J, Sibai BM, . Hypertensive pregnancy disorders and subsequent cardiovascular morbidity and type 2 diabetes mellitus in the mother. Hypertension (Dallas, Tex : 1979). 2009;53(6):944–51.
177 Miller EC, Boehme AK, Moon YP, . Preeclampsia and early stroke incidence in The California teachers study. Stroke. 2018;49.
178 Mongraw-Chaffin ML, Cirillo PM, Cohn BA. Preeclampsia and cardiovascular disease death: prospective evidence from the child health and development studies cohort. Hypertension (Dallas, Tex : 1979). 2010;56(1):166–71.
179 Bergman L, Torres-Vergara P, Penny J, . Investigating Maternal Brain Alterations in Preeclampsia: the Need for a Multidisciplinary Effort. Curr Hypertens Rep. 2019;21(9):72. PMID: 31375930. 10.1007/s11906-019-0977-0 31375930
180 Aukes AM, De Groot JC, Wiegman MJ, . Long-term cerebral imaging after pre-eclampsia. BJOG : an international journal of obstetrics and gynaecology. 2012;119(9):1117–22.22703533
181 Wiegman MJ, De Groot JC, Jansonius NM, . Long-term visual functioning after eclampsia. Obstetrics and gynecology. 2012;119(5):959–66.22525906
182 Lederer M, Wong A, Diego D, . Tracking the Development of Cerebrovascular Risk Factors Following Pregnancy With Preeclampsia. J Stroke Cerebrovasc Dis. 2020:104720. PMID: 32220554. 10.1016/j.jstrokecerebrovasdis.2020.104720 32220554
183 National Institute for Health and Clinical Excellence. Hypertension in pregnancy: diagnosis and management Manchester, UK: National Institute for Health and Clinical Excellence; 2020.
184 FIGO Working Group on Good Clinical Practice in Maternal-Fetal Medicine. Good clinical practice advice: First trimester screening and prevention of pre-eclampsia in singleton pregnancy. Int J Gynaecol Obstet. 2019;144(3):325–9. 10.1002/ijgo.12741 30710362