# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Iris Mabry-Hernandez, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; the National Heart, Lung, and Blood Institute, the Office of Research on Women’s Health, and the Centers for Disease Control and Prevention, for providing federal partner review of the draft report; Lisa Askie, PhD, MPH, BN, CM, NICC, Robert Silver, MD, Shireen Meher, MD, and James Roberts, MD, who provided expert review of the draft report; Jennifer Lin, MD, for mentoring and project oversight; and Melinda Davies, MA, and Neon Brooks, PhD, for technical and editorial assistance at the Center for Health Research.