# Chapter 4 Discussion

## Summary of Evidence

We identified three new trials eligible for this updated systematic review. The summaries of evidence and evaluations of the overall strength of evidence for each Key Question are provided in Table 6. There was reasonably consistent and precise evidence of effectiveness of daily low dose aspirin for prevention of fetal growth restriction and preterm birth among individuals at increased risk of preeclampsia. Preventing these outcomes has long-term implications for child and adult health. Newer evidence from a large trial contributed to greater precision for estimating a statistically significant association between aspirin and the prevention of perinatal mortality than in the 2014 review. Data from meta-analyses suggest that use of prophylactic low dose aspirin in women at increased risk for preeclampsia results in a 15 to 20 percent reduced risk of the disease and also for complications that lead to perinatal morbidity and mortality. The incidence of preeclampsia for participants assigned to placebo groups ranged widely, and this contributes to the range of absolute risk reductions related to disease incidence. The two largest trials, CLASP and MFMU-HR, reported similarly modest, statistically insignificant risk reductions of approximately 10 percent with absolute risk reductions near 2 percent. The more recent ASPRE trial obtained larger and statistically significant risk reductions, with absolute reductions for the incidence of preeclampsia closer to 2 percent and for preterm birth over 3 percent.

Table 6 Summary of Evidence

Key Question | No. of Studies; (No. of observations); Study Designs | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
KQ1. Does aspirin reduce adverse maternal, perinatal, child, or combined health outcomes in pregnant persons at increased risk of preeclampsia?; KQ1a. Does the effectiveness of aspirin for reducing adverse health outcomes vary by subpopulations defined by personal characteristics or preeclampsia risk factors? | 18 RCTs; 10 good quality, 8 fair quality; (n= 15,908) | Aspirin was associated with a reduced risk of perinatal mortality (pooled RR 0.79, 95% CI 0.66, 0.96; I^2^ 0%), preterm birth (pooled RR 0.80, 95%CI 0.67, 0.95; I^2^ 49%), and SGA/IUGR (pooled RR 0.82, 95%CI 0.68, 0.99; I^2^ 41%); Limited subpopulation data, but within trial comparison suggested greater effectiveness in nonsmokers | Reasonably consistent^*^; Reasonably precise^**^ | Small study effects could not be ruled out for SGA/IUGR and preterm delivery Rare maternal health outcomes, such as eclampsia and maternal mortality, occurred too infrequently to estimate preventive effectiveness Subgroup effects limited by modest number included studies and few within trial subgroup analyses reported | Moderate for perinatal health benefits | Studies in prenatal care settings in US or comparable settings, however mostly White participants; Different criteria for identifying at risk populations; Aspirin dose 50-150mg a day
KQ2. Does aspirin prevent preeclampsia in pregnant persons at increased risk for preeclampsia?; KQ2a. Does the effectiveness of aspirin for reducing preeclampsia vary by subpopulations defined by personal characteristics or preeclampsia risk factors? | 16 RCTs; 10 good quality 6 fair quality; (n= 15,767) | Aspirin was associated with a statistically significant reduction in the risk of preeclampsia compared to placebo (pooled RR, 0.85 [95% CI, 0.75 to 0.95], I^2^ 0%); No evidence of statistical difference in the magnitude of preeclampsia risk reduction related to the timing of treatment initiation, the dosage of aspirin used, or personal characteristics such as smoking history, parity, and BMI | Reasonably consistent evidence for aspirin benefit; Reasonably precise 15% reduced risk of preeclampsia associated with daily aspirin use | Small study effects could not be ruled out and might lead to some overestimation of pooled effect sizes Confounding of study size with other study and participant characteristics could influence subgroup comparisons Subgroup effects limited by modest number included studies and few within trial subgroup analyses reported | Moderate | Studies in prenatal care settings in US or comparable settings, however mostly White participants; Different criteria for identifying at risk populations; Aspirin dose 50-150mg a day
KQ3. What are the harms of aspirin use to prevent preeclampsia during pregnancy?; KQ3a. Do the harms of aspirin use to prevent preeclampsia vary by subpopulations defined by personal characteristics or preeclampsia risk factors? | 21 RCTs; (16 increased risk and 5 average risk populations); 14 good quality 7 fair quality; (n = 26,757) | Studies conducted among average and increased risk populations did not find any clear evidence of harms associated with daily aspirin use (<150mg) taken during the second or third trimester of pregnancy. No difference in harms by the dosage or timing of aspirin or for specific populations were identified in limited subgroup comparisons.; Bleeding harms were uncommon and showed null effects for differences in risk of postpartum hemorrhage (pooled RR 1.03, [95% CI, 0.94, 1.12] I^2^ 0%, k=11), or fetal intracranial bleeding (pooled RR, 0.90 [95% CI, 0.51, 1.57]; I^2^ 19%, k=9) were found. The result for placental abruption (pooled RR, 1.15 [95% CI, 0.76, 1.72] I^2^ 25%, k=13) was also null. Longer term followup from one large trial found no difference in child developmental outcomes for aspirin compared with placebo exposed groups. No differences were found within a limited set of studies reporting other rare perinatal harms. | Reasonably consistent evidence of null effects for bleeding harms of daily aspirin, especially among pregnant individuals at increased preeclampsia risk.; Reasonably precise evidence for null effects, but less precise for especially rare harms. | Reported harms were rare and not consistently reported across studies. | Moderate for no difference in bleeding harms between groups, low for very rare or inconsistently reported harms.^***^ | Studies in prenatal care settings in US or comparable settings, however mostly White participants; Different criteria for identifying at risk populations; Aspirin dose 50-150mg a day; Harms from trials in average risk and increased risk populations

* Direction and magnitude of effects within and across for important perinatal health outcomes that could be quantitatively synthesized, with low to moderate statistical heterogeneity

** Confidence intervals did not cross null, including for rare outcomes such as perinatal mortality where even small effects are clinically important.

*** Postpartum hemorrhage >1000 mL, longer term developmental harms, congenital malformations.

We estimated the number needed to treat (NNT) for preeclampsia, SGA/IUGR, and preterm birth using a range of values of incidence reported for the outcomes in the included evidence. The NNTs calculated from the midrange of study reported incidence rates for preterm birth and SGA/IUGR (17%) were similar, both around 30, but with wide confidence intervals (SGA/IUGR NNT = 33, 95% CI 18, 588 and preterm NNT= 29, 95% CI 18, 118) (Table 7). The NNT was estimated to be 20 or fewer at higher assumed levels of disease incidence for these outcomes, while at the lowest levels of risk, the NNT was 79 for SGA/IUGR and 50 for preterm birth. We estimated the NNT for preeclampsia prevention to be 74 (95% CI 44, 222) when the incidence of preeclampsia is nine percent, over twice the population average, and 51 (95% CI 31, 154) when the incidence is thirteen percent, approximately three times the population average.

Table 7 Theoretical Number Needed to Treat (NNT) Across Different Levels of Outcome Incidence

Outcome | % Outcome incidence in population | Pooled RR estimate | % Absolute risk reduction | NNT (95% CI)
SGA/IUGR | 7 | 0.82 | -1 | 79 (45, 1429)
SGA/IUGR | 17 | 0.82 | -3 | 33 (18, 588)
SGA/IUGR | 24 | 0.82 | -4 | 23 (13, 417)
Preterm Birth | 10 | 0.80 | -2 | 50 (30, 200)
Preterm Birth | 17 | 0.80 | -3 | 29 (18, 118)
Preterm Birth | 31 | 0.80 | -6 | 16 (10, 65)
Perinatal mortality | 1 | 0.79 | -0.2 | 476 (294, 2500)
Perinatal mortality | 6 | 0.79 | -1 | 79 (49, 417)
Preeclampsia | 9 | 0.85 | -1 | 74 (44, 222)
Preeclampsia | 13 | 0.85 | -2 | 51 (31, 154)
Preeclampsia | 19 | 0.85 | -3 | 35 (21, 105)

Abbreviations: NNH = Number needed to harm; NNT= Number needed to treat; RR = Relative risk; SGA/IUGR = Small for gestational age/Intrauterine growth restriction

Because aspirin use is known to affect pathways involving the inhibition of platelet aggregation, maternal and perinatal bleeding outcomes are important potential harms to consider. The addition of three new trials in the analysis of potential aspirin harms did not alter the previous null findings for the most consistently reported bleeding outcomes. Notably, however, the largest new trial, ASPRE, did not report postpartum hemorrhage outcomes, which limits the information available for assessing potential bleeding harms with a higher dosage than most trials (150mg). Bleeding outcomes, maternal hemorrhage and fetal intracranial bleeding (intraventricular and cerebral hemorrhage) were reported most consistently across all of the included trials. Given the lack of any statistically significant evidence of harms associated with daily low-dose aspirin use in pregnancy, we did not compute numbers needed to harm.

Maternal hemorrhage is the leading cause of severe maternal morbidity in the United States.^118^ Data from the U.S.-based National inpatient sample indicate the incidence of postpartum hemorrhage has been increasing.^119^ From 1993 to 2014, the number of delivery hospitalizations affected by postpartum hemorrhage requiring blood transfusion increased from 7.9/10,000 to 39.7/10,000. In 2009, postpartum hemorrhage accounted for slightly more than 10 percent of maternal deaths (1.7 per 100,000 live births).^7,^ ^118,^ ^120,^ ^121^ Having preeclampsia may increase a patient’s risk for postpartum hemorrhage by various mechanisms, including prolonged induction of labor or coagulation abnormalities in patients with HELLP syndrome.^118,^ ^122^ The effect of aspirin prophylaxis during pregnancy on postpartum hemorrhage risk, defined in most studies as blood loss of 500 mL or more, was reported in eleven of the trials in this review, comprising results from over 23,000 participants. There was no increased risk of postpartum hemorrhage associated with aspirin use in trial populations at average or increased risk for preeclampsia. This null finding was accompanied by a reasonably precise confidence interval ranging from three percent reduced risk to nine percent increased risk, and no evidence of statistical heterogeneity. Postpartum blood loss may not be accurately measured in clinical practice, and the clinical significance of the 500mL threshold has been questioned, particularly for patients who receive cesarean section procedures.^123^ A direct consequence of increased blood loss, such as incidence of maternal transfusion, would be a more informative outcome. The absence of differences in the available bleeding related outcomes, however, is reassuring for the daily regimen of 150mg or less of aspirin in pregnancy. The possibility of clinically significant differences for more rare, serious bleeding complications cannot be entirely ruled out, but because preeclampsia increases hemorrhage risk, effective aspirin prophylaxis could also reduce the occurrence of this harm.

Placental abruption, defined as premature separation of the placenta before delivery^124^ is a condition which may be accompanied by maternal hemorrhage, disruption of blood flow to the fetus, need for emergent delivery, and/or stillbirth. The diagnosis of abruption is primarily made clinically and is less common than either preeclampsia or preterm birth, with national and international population-based studies suggesting abruption occurs in about 0.5 to 1.4 percent of pregnancies.^107–111^ Placental abruption was a reported outcome in 13 trials, including 5 among average-risk individuals, comprising data on over 25,000 trial participants. The null finding for this intermediate outcome was less precisely estimated, and less consistent, than for postpartum hemorrhage, however, the lack of significant effect is consistent with the null findings for health outcomes that may result from placental abruption, including maternal and fetal hemorrhage and death. For less consistently reported harms such as congenital malformations, there was no evidence of an association with aspirin use, but the power to evaluate group differences for these outcomes was limited by their rarity.

Intraventricular hemorrhage (fetal intracranial bleeding) is the most common neurologic complication of prematurity, with risk for this outcome increasing with the degree of fetal prematurity at birth.^125^ In a meta-analysis of 9 trials, the incidence of fetal intracranial bleeding did not differ between aspirin and placebo groups. The pooled effect confidence interval, which ranged from a 40 percent risk reduction to a 35 percent increase, was imprecise because the outcome was rare, however, the effect was in the direction of a reduced risk of fetal intracranial bleeding associated with prophylactic low dose aspirin, which parallels the observed reduction in risk of preterm birth.

Overall, meta-regression analyses did not support notable differences in effects for different study designs or population characteristics. Some benefit was observed across a range of aspirin dosages and timing, risk assessment approaches, and enrolled populations. Although there is some evidence for a greater benefit for perinatal health outcomes when aspirin is started earlier in pregnancy, results were inconsistent across outcomes, and comparisons may be confounded by other shared study features. There were too few studies included in the review to include multiple covariates in meta-regression, as would be needed to identify independent associations adjusted for other factors. In addition, some aspirin protocol features were too uncommon to compare across studies.

## Comparison of Our Results With Findings From Other Systematic Reviews

The results of this review are consistent with findings from other systematic reviews including a recent Cochrane Collaboration review^123^ and an older individual participant meta-analysis conducted by the Paris Collaborative Group (Paris IPD-MA) with trials published before the year 2006.^61,^ ^126–129^ Ten of the RCTs included in this review ^89,^ ^91,^ ^92,^ ^95,^ ^97–100,^ ^103,^ ^107^ were included in the Paris IPD-MA.^61^ The Cochrane review included 77 trials conducted with 40,249 participants and their babies and incorporated available Paris IPD-MA data when available, pooling it with study level trial results that were more recently published. The Paris IPD-MA and Cochrane review both included trials of other anti-platelet medication, as well as aspirin combined with other medications. Despite differences in scope and approach, the Cochrane review results were mostly consistent with the findings of our review, with statistically significant benefits for prevention of preeclampsia, perinatal mortality, preterm birth, and small for gestational age, and null, less precisely estimated effects for risks of harm. There also were not statistically significant differences in aspirin effectiveness at different levels of preeclampsia risk in interaction tests conducted in the IPD-MA or the Cochrane review. The pooled effect magnitudes differed for some outcomes compared with our review findings. The most disparate result was for preterm birth, with the Cochrane analyses estimating a more modest statistically significant 9 percent risk reduction compared to the 19 percent risk reduction we estimated. The Cochrane review differed from ours in terms of included study design characteristics (e.g., included settings and medication regimens), preeclampsia risk levels (e.g., the Cochrane review included lower risk populations), risk of bias exclusions, and statistical methods (i.e., Cochrane review used fixed effects meta-analysis and incorporated individual level trial data). Likely a combination of these differences contributed to the differences in effect magnitudes, but the consistency of the finding of a beneficial effect of aspirin across important outcomes among all three reviews speaks to the strength of the evidence of aspirin for preeclampsia prevention in the large body of studies that has accrued to date.

The Cochrane review and Paris IPD-MA reported findings that were consistent with our review with respect to risks of harms associated with daily low dose aspirin use in pregnancy. None of the three reviews found statistically significant differences between groups in rates of postpartum hemorrhage (≥ 500mL), placental abruption, fetal intraventricular hemorrhage, or other neonatal bleeding harms. In the Paris IDP-MA, there was a trend on the margin of statistical significance suggesting the possibility of higher risk of postpartum hemorrhage, based on evidence from 16 trials (RR 1.06, 95%CI 1.00, 1.13); the Cochrane review, which added results from 3 additional trials, showed a similar trend that was also not statistically significant. These results are difficult to interpret given the problems with the outcome definition and clinical significance of postpartum hemorrhage already discussed. Additionally, differences in the review scope, such as the inclusion of other antiplatelet medications and combined antithrombotic therapies in the other two systematic reviews could be associated with different risks for hemorrhage than aspirin alone. Overall, the large number of participants in trials evaluated in these reviews and ours do not provide a clear signal suggesting bleeding harms.

Consistent with our results, neither the Cochrane review nor the Paris IPD-MA found any definitive subgroup differences. As noted, the Paris IPD-MA results do not include evidence from more recent trials and was scoped more broadly than our current review.^61^ Nevertheless, due to the strengths of an individual participant level of analysis for defining outcomes and assessing subgroup differences, the detailed findings warrant additional consideration. There was no evidence of subgroup differences tested with the Paris IPD-MA in effects by aspirin dosage, the timing of initiation of aspirin therapy, or according to characteristics and preeclampsia risks for study participants. The study found no difference in effectiveness for participants starting before 20 weeks of gestation compared to those starting treatment 20 weeks or later in pregnancy (p=0.24). Similarly, a secondary analysis of the data found no difference in effectiveness for preeclampsia prevention or for prevention of perinatal mortality when comparing treatment starting at less than 16 weeks of gestation to later initiation (p=0.98 and p=0.08, respectively).^127^ The study also tested differences in intervention effects on preeclampsia prevention by aspirin dosage (<75 mg versus > 75mg) among trials that used aspirin only (excluding studies with other anti-platelet medications). The interaction test was not statistically significant (p=0.23). A secondary analysis comparing effects for dosages of ≤81mg compared with >81 mg doses suggest a possible trend toward greater risk reduction at higher aspirin doses (<81mg: RR = 0.92, 95%CI 0.85, 0.99; >81mg: RR = 0.74, 95%CI 0.60, 0.92), but the estimated effect confidence intervals overlap and a test for interaction was not reported.^129^

Overall, there is consistency across all major reviews of the accumulated evidence in finding that aspirin is effective for preventing preeclampsia and related outcomes, with no notable harms, and little indication of differences in effectiveness between particular regimens or risk populations. In general, there are no clear differences in effectiveness for different protocols or study populations supported by our review or other well-conducted comprehensive reviews on the topic.

## Limitations

### Exclusions for Publication Language and Study Setting

Our search was limited to English language literature, and only trials conducted in settings with very high Human Development Index scores were included. Large trials conducted in other settings could provide additional relevant information, but other reviews without this exclusion have not found substantively different results.^61,^ ^123^ A large, recently published multicountry trial enrolled average-risk nulliparous participants from seven community sites in the Democratic Republic of Congo, Guatemala, Kenya, Pakistan, and Zambia from March 2016 to June 2018 and randomized 11,976 pregnant individuals to 81mg of aspirin or placebo between 6/0 weeks and 13/6 weeks of gestation.^63^ Had we not limited our review by setting, this trial would have contributed to our analysis of Key Question 3 (evaluating harms) and would not have changed our main conclusions: the trial did not find any study group differences in a large set of reported adverse events and potential harms, including postpartum hemorrhage and congenital malformations.

### Small-Study Effects

We found evidence of small-study effects for several outcomes. This suggests that smaller null or negative studies may not be present in the published literature or that smaller trials have systematic differences in conduct and methods than larger trials, skewing pooled results toward an overestimation of effectiveness. We conducted sensitivity analyses using fixed effects models, given the propensity for random effects models to amplify small-study effects. These analyses demonstrated small differences in the magnitude of effects for various outcomes, though all effects remained statistically significant. Different statistical approaches for estimating pooled effects and testing subgroup comparisons, however, cannot fully address some limitations in the data. For example, the two largest studies used the same low aspirin dosage (60mg) and enrolled the majority of their study participants after 16 weeks of gestation. The MFMU-HR trial additionally instructed participants to cease aspirin use if preeclampsia developed. Thus, the small-study effects seen in the evidence cannot be entirely disentangled from other features of the included studies. It is not possible to determine which factors – those external to the evidence such as publication bias, or those specific to the design of the included studies – are responsible for small-study effects, and both types of factors could contribute.

### Confounding of Aspirin Initiation Timing Effects

The most recent Cochrane review^123^ and the Paris IPD-MA^61^ did not find evidence of differences in aspirin effectiveness associated with the timing of aspirin use during pregnancy when analyzing effects with initiation before 20 weeks of gestation compared to later start times using study level data and individual participant data. Our subgroup findings agree with and were similarly interpreted. Other systematic reviews focused on selected subsets of the available trial evidence have reported significant differences in effectiveness related to the timing of aspirin initiation using a cutpoint of 16 weeks of gestation. This could be due to problems with subgroup comparisons at the study level, which are subject to more serious bias and confounding than individual level comparisons. A secondary analysis of the IPD-MA data examining effects for aspirin initiated before 16 weeks of gestation or started later also did not show a statistically significant differences in the effects.^127^ Given the inconsistency in evidence for timing effects across outcomes and the potential for confounding to influence subgroup comparisons, there is not clear evidence that aspirin is more effective when aspirin is started before 16 weeks of gestation. This was true in our current review of aspirin effectiveness focused on increased-risk populations, and in the Cochrane review that includes a broader literature along with results from the Paris IPD-MA.^123^ Further research is needed to examine the possibility that earlier initiation may lead to greater benefit for some individuals, but it appears that even those presenting for prenatal care beyond 16 weeks can derive a benefit from daily low-dose aspirin.

### Observational Evidence Exclusions

The 2014 USPSTF review included two observational cohort studies that were not included in this update. These studies examined any aspirin use during pregnancy and reported null findings for the potentially harmful outcomes considered, miscarriage and cryptorchidism.^108,^ ^109^ The current review adopted a narrower approach to assessing observational studies for inclusion, given the size and maturity of the trial evidence on the topic, and the unique aspirin protocol used in trials that is not found in large observational studies examining outcomes associated with aspirin use at any time or dosage during pregnancy for a range of possible indications. We would have included any observational cohort studies that reported harms outcomes among women taking daily aspirin for preeclampsia prevention, but none were identified in our literature search.

A large body of observational evidence has examined whether aspirin and nonsteroidal anti-inflammatory drugs increase the risk of birth defects. Findings are somewhat mixed; most studies report no association or unclear results,^130–133^ but there are important limitations to the literature. In studies of aspirin for preeclampsia prevention, a low dosage is initiated after the first trimester, when embryogenesis is complete. Therefore, some types of birth defects would not be expected to occur. Most observational studies cannot adjust for the timing, dosage, or indication for aspirin exposure. Ascertainment bias and unmeasured confounding also limit conclusions that can be drawn even from large, well conducted case-control studies.^132^ From the observational evidence, there are not clear or consistent associations found between aspirin and birth defects. If present, such effects would be very small in order to have escaped detection in the observational and trial data available on this topic.

### Adherence

Our review reported and meta-analyzed results only from intention to treat analyses, in accordance with methodological guidance for conducting systematic reviews and best practices for interpreting trial evidence.^84,^ ^134^ There is evidence in the literature from secondary analyses of trials that differences in adherence to daily aspirin use may contribute to the differences in effectiveness observed in the trial literature, and that efficacy of aspirin use is considerably higher than effectiveness.^59,^ ^135^ We did not analyze data from trials based on adherence to treatment, and from a pragmatic standpoint, the estimates we provide in this review are more representative of the effects that might be expected in clinical populations with varying levels of adherence to a recommended preventive intervention. The MFMU-HR trial, which reported modest null effects of prophylaxis, reported that 80 percent of participants reported taking at least 80 percent of their aspirin tablets, and found no differences in effectiveness based on self-reported adherence.^99^ However, there is evidence from a multicenter observational cohort study that adherence to aspirin (100mg or 150mg) greater than 90 percent (assessed with blood test) compared with any lower level of adherence resulted in statistically significant differences in its effectiveness for preeclampsia and perinatal health outcomes.^136^ An accompanying editorial noted that adherence could be affected by the methods a trial takes to determine risk and to assess medication adherence, and these adherence differences could account for differences in effect magnitudes seen across aspirin trials.^137^ Similarly, there is evidence that adherence to aspirin prophylaxis may be relatively low in pregnancy, with somewhat higher levels for those concerned about their risk for preeclampsia.^138^ These studies highlight the potential importance of further research to understand the importance of adherence for obtaining preventive benefits.

## Identifying Patients at Increased Risk for Preeclampsia

Currently, there is limited evidence about the best approach for identifying women at risk of preeclampsia.^139,^ ^140^ Trials varied in their approaches for identifying participants and in the exclusion criteria they used. A little over half of the included trials used multiple risk factors to identify women at risk for preeclampsia, and of the trials that relied on a single risk factor, only two relied on the same one (abnormal doppler ultrasound readings).^90,^ ^103^Consequently, baseline characteristics of the study populations varied significantly, resulting in a broad range of preeclampsia incidence rates in the control groups (4 - 30%) (Table 4). Some of the tests used to identify women at risk of developing preeclampsia in the older trials were conducted in the second trimester of pregnancy (some as late as 26-28 weeks of gestation) and are not currently used in clinical practice (i.e., hemoglobin >13.2 g/dL, maternal roll over test resulting in rise of diastolic blood pressure >15 mg Hg above baseline, and increased blood pressure response to angiotensin II infusion).^87,^ ^89,^ ^96^

Study level subgroup comparisons tested in this review did not find differences in aspirin effectiveness based on the approach taken for identifying women at increased risk of preeclampsia. While studies that used clinical risk factors in conjunction with clinical tests or imaging consistently recruited populations with high incidence of preeclampsia (18 and 23%),^89,^ ^104^ several studies using clinical risk factors alone achieved similarly high levels of preeclampsia incidence ranging from 8 percent to 20 percent (Table 4).^57,^ ^93–95,^ ^98,^ ^99,^ ^101^ Subgroup analyses did not show any differences in the effectiveness of aspirin between studies that used clinical history risk factors alone to identify women at increased risk compared to those that incorporated clinical tests or imaging, nor did the effectiveness of aspirin vary by the incidence of preeclampsia in the study control group (≤12% vs >12%) (Table 4). However, subgroup comparisons were limited by the diversity of approaches taken and the inability to account for potential confounding from other study characteristics (e.g., aspirin protocol) with the available trials.

The most recently published RCT of aspirin for prevention of preeclampsia, the ASPRE trial, was the only trial to use a previously developed, externally validated risk prediction model for predicting preeclampsia.^141^ The model was used to assess risk of preeclampsia leading to preterm birth in participants with singleton pregnancies at 11 to 12 weeks of gestation. The prediction algorithm draws on Bayesian statistics to first estimate risk based on several clinical history characteristics; weight, height, maternal age, race/ethnicity, previous preeclampsia, family history of preeclampsia, chronic hypertension, diabetes type 1 or 2, systemic lupus erythematosus or antiphospholipid syndrome, and conception by in vitro fertilization. This was then supplemented with serum biomarker tests (pregnancy associated plasma protein-A and placental growth factor), mean arterial pressure, and Doppler ultrasound readings of the uterine artery pulsatility index. Using this algorithm, the trial identified a study population where 11 percent of control group participants developed preeclampsia, about 3 times the incidence in the general population. It is not clear whether the greater effectiveness of aspirin seen in the ASPRE trial relative to other large trials can be attributed to the risk assessment approach, and how much is due to other differences, such as the higher aspirin dosage, or the early initiation of aspirin at 12 to 13 weeks of gestation and continuation until 36 weeks or onset of labor. Whether the algorithm identifies a population particularly responsive to aspirin cannot be determined without further comparative research.^141^

The MFMU-HR trial conducted stratified enrollment and analyses to test whether aspirin was more effective for certain risk groups relative to others. The trial defined four risk categories: those at risk of diabetes, chronic hypertension, and multifetal gestation, and those with a previous pregnancy affected by preeclampsia. There were no statistically significant effects of aspirin for preventing preeclampsia or other health outcomes in the trial overall or within risk category subgroups. All risk groups except the chronic hypertension category had similarly modest reductions in preeclampsia risk (approximately 10%). In the chronic hypertension risk category, more participants in the aspirin treatment group developed preeclampsia than in the placebo group, but the estimate was imprecise and comparisons between groups were statistically underpowered.

Despite ongoing efforts to develop a screening test or prediction algorithm that can be used in early pregnancy to identify individuals who are likely to develop preeclampsia, clinical history taking remains a practical and commonly-used approach that can select populations with higher incidence of preeclampsia than the population average. Aspirin was effective across a range of populations at different levels of risk who were selected based on a variety of approaches. Risk prediction models that include uterine artery Doppler ultrasound readings and biochemical markers from serum testing alongside patient characteristics are more resource-intensive and difficult to clinically implement but may hold potential. The most widely tested prediction models have yet to be externally validated, and require further evaluation to determine their clinical effectiveness and value to support widespread use across a range of populations.^1,^ ^40,^ ^66^

Some researchers have advocated for broader clinical uptake of the algorithm used in the ASPRE trial for selecting patients to aspirin prophylaxis,^142^ including a recommendation from the International Federation of Gynecology and Obstetrics (FIGO) (Table 1) (co-authored by the model developers). Others have questioned this based on practical shortcomings and knowledge gaps, highlighting its limited suitability to general clinical practice for now.^1,^ ^40,^ ^66,^ ^139,^ ^143^ Many pregnant individuals would not be eligible for screening, including those entering prenatal care beyond 12 weeks of gestation or who are pregnant with twins or more. It is also unclear what level and attributes of test performance are most important assigning aspirin prophylaxis, given the low risk of the intervention. For low dose aspirin prophylaxis, optimizing specificity rather than sensitivity (higher false positive rate) might be reasonable. Validated prediction tools with strong test performance attributes would be very valuable for improving prenatal care and early intervention if they were able to identify those who are very likely to develop preeclampsia, but may be less important for identifying a clinical population in routine care that might benefit from aspirin prophylaxis. A review comparing the test performance attributes of development and validation models for the predictive model found significant differences in accuracy depending on the cohort used, leading the authors to conclude that more effort should be dedicated to refinement and validation of models as well as studies evaluating whether model use improves clinical care and outcomes.^144^

Comparisons of clinical risk assessment approaches recommended by ACOG, NICE, and USPSTF to formal prediction algorithms for identifying populations at increased risk that could benefit from aspirin to prevent preeclampsia have highlighted differences in test performance characteristics. Not surprisingly, these comparisons show that prediction models designed to optimize accuracy have greater predictive value. As others have noted,^143^ however, while accurate prediction of preterm preeclampsia in singleton pregnancy is important for many purposes, lengthy clinical risk assessment procedures may not represent the most efficient, practical, or effective way to ensure that recommendations to use aspirin during pregnancy reach the broad population of individuals that could potentially benefit from use. Further research is needed to determine whether there is a discernable difference between aspirin effectiveness for individuals identified using a prediction model and those identified using clinical history risk factors in routine prenatal care. Implementation trials comparing these strategies in real-world settings would be particularly valuable, especially if designed to address questions related to aspirin timing as well. It would be especially important to further strengthen approaches for identifying individuals that are most likely to manifest severe features of preeclampsia that lead to more serious morbidity and mortality.

In addition to the trial evidence included in this review, several reviews and large cohort studies provide evidence on important risk factors for preeclampsia. These were cited in the previous USPSTF recommendation statement^69^ and were referenced in the recent ACOG recommendation for aspirin to prevent preeclampsia.^66,^ ^145^ A similar set of risk factors were cited in the updated National Institute for Health and Clinical Excellence recommendation for the United Kingdom (Table 1). These include several risk factors known to be independently associated with the highest likelihoods of developing preeclampsia: history of preeclampsia, multifetal gestation, chronic hypertension, and type 1 or type 2 diabetes. Other, more moderate risk factors are associated with an increased risk, such as maternal age over 35 and nulliparity, but are inconsistently or only modestly independently associated with preeclampsia risk. More than one moderate risk factor, occurring in the same individual, however, would be expected to identify increased risk for preeclampsia similar to levels observed in the control groups of the trials that established intervention effectiveness.

There has been no change in the main clinical risk factors associated with preeclampsia that would be reasonable to consider for identifying similar-risk populations to those included in the 2014 USPSTF review. Clinical risk factors included in the risk predication model used in the ASPRE trial were similar to those recommended by NICE, ACOG, and the USPSTF, with the exception of in vitro conception. This clinical history could be incorporated into current clinical assessment practices, although only a small fraction of participants in aspirin trials had this risk factor. There are also other risk factors not included in the current guidelines that may also be associated with a moderate risk for preeclampsia and warrant further research both in terms of establishing the potential association and evaluating whether aspirin prophylaxis would be beneficial. These include high altitude residence, exposure to air pollution,^146^ sleep disordered breathing during pregnancy,^147,^ ^148^ and migraine headaches.^149^ Table 8 provides a list of established clinical history risk factors that can be used alongside clinical judgment of risk to identify increased-risk populations that are likely to approximate the population included in the trials on aspirin prophylaxis reviewed here.

Table 8 Factors Associated With Increased Preeclampsia Risk Based on Patient Medical History^*^

Risk Level | Medical history and personal characteristics
High^†^ | - History of preeclampsia; - Chronic hypertension; - Pregestational Type I or II diabetes mellitus; - Multifetal gestation; - Renal disease; - Autoimmune disease (i.e., systemic lupus erythematous, antiphospholipid syndrome)
Moderate^‡^ | - Nulliparous, having never given birth; - Obesity (body mass index >30 kg/m^2^); - Family history of preeclampsia (mother or sister); - Black race^§^; - Low socioeconomic status^§^; - Age ≥35 years; - Personal pregnancy history (e.g., low birthweight or small for gestational age, previous adverse pregnancy outcome, >10-year pregnancy interval); - In vitro conception
Low | Previous uncomplicated full-term delivery

* Includes only risk factors that can be obtained from the patient medical history. Clinical measures such as serum biomarkers and uterine artery Doppler ultrasound have also been used in some trials to identify an increased risk population. A risk prediction algorithm combining clinical risk factors and biochemical and imaging markers was used in one trial for risk assessment in the first trimester among individuals with singleton pregnancies.

† Risk factors consistently and independently associated with the greatest risk of preeclampsia, with preeclampsia risk is at least twice as high as rates observed in an unselected population.

‡ Risk factors independently associated with moderate preeclampsia risk, some more consistently than others. Clinical judgment of risk for the specific patient and population or the presence of more than one risk factor could be used to identify a population at risk for preeclampsia at levels observed in the trial evidence on aspirin prophylaxis

§ Associated with increased risk due to environmental, social, and historical inequities shaping health exposures, access to health care, and the unequal distribution of resources, not biological propensities.

Having had a previous pregnancy complicated by a hypertensive disorder is a consistent, well-established risk factor for preeclampsia, and there is some evidence that this risk factor identifies a population that may be particularly responsive to aspirin prophylaxis.^61^ Additionally, a history of preeclampsia may be associated with an increased risk of having an SGA infant, even if preeclampsia does not occur, highlighting the importance of this risk factor for identifying individuals that could benefit from aspirin prophylaxis.^150^ Of course, for nulliparous individuals, this important pregnancy history risk factor is unavailable. First pregnancies are at somewhat greater risk for preeclampsia than later pregnancies; as a result, the population-attributable risk is high for nulliparous patients.^38^ Studies we reviewed that enrolled general nulliparous populations without additional risk factors had incidence of preeclampsia below or just above the population average in their control groups.^91,^ ^92,^ ^100,^ ^102,^ ^105^ Efforts to develop prediction algorithms focused on nulliparous populations have had limited success,^139,^ ^151–153^ and generally have not performed better than recommended approaches to clinical risk assessment. The addition of serum markers and imaging findings may improve performance,^39,^ ^154^ but further validation in nulliparous populations and comparison to other risk assessment approaches is needed. Research to inform risk assessment for those having a first pregnancy is needed to ensure that those who would benefit from aspirin prophylaxis are identified.

Finally, there is a developing discussion in the literature^155–157^ as to whether low dose aspirin prophylaxis should be considered for all pregnant women given challenges predicting who will develop preeclampsia, particularly among nulliparous individuals, and the absence of any clear evidence of harms.^156,^ ^158^ The inclusion of low-risk populations in systematic reviews tends to result in more modest effect estimates compared to reviews focused on higher risk populations, but in the most recent Cochrane review, there was not a statistically significant difference in aspirin effectiveness between different levels of risk.^123^ We also did not find differences in the main harms outcomes we evaluated when comparing the effects between studies conducted among average-risk (mainly nulliparous) populations and studies with increased-risk study populations. With additional research, it may become reasonable to consider a shift away from identifying increased-risk populations toward identifying low-risk populations that are unlikely to derive any benefit from aspirin prophylaxis for preeclampsia prevention. This will require more evidence on the long-term safety and benefits of aspirin prophylaxis to support intervention involving larger numbers needed to treat.

## Evidence Gaps and Future Research

In addition to the gaps around identifying patients at increased risk for preeclampsia and most likely to have more severe complications (detailed above), there are a number of other evidence gaps that call for future research. The literature we reviewed is limited for the purposes of identifying the specific aspirin protocol (dosage, timing, continuation, time of day) that is likely to have the greatest benefit, and the risk population that is most likely to benefit. In addition, the long-term risks and benefits of low dose aspirin for the mother or her child are uncertain, as the included trials have not reported long-term outcomes. The studies we reviewed varied considerably on these characteristics, in addition to having differences in excluded populations and sample size. No studies reported head-to-head comparisons of different protocols or risk assessment strategies, and only one trial was designed to compare effectiveness for different risk populations, and it was underpowered for drawing conclusions. Interaction tests for subgroup differences within trials were uncommon, and, when available, did not generally identify differences in effectiveness by the factors examined. Meta-analysis results for some outcomes, and especially for making subgroup comparisons, were limited by low numbers of included studies and low event rates for some outcomes. Comparisons between studies in meta-regression were generally not statistically significant. When differences were seen, as for the timing of aspirin initiation on preterm birth prevention, the limited number of studies compared and potential for confounding prevented us from drawing strong conclusions. For example, only one study evaluated differences in the action of aspirin depending on the time of day it was taken,^57^ providing limited evidence that effectiveness may be greater when aspirin is taken at least 8 hours after waking or at bedtime. Further research is needed to explore this possibility. Overall, the low to moderate statistical heterogeneity and consistency of effects across a range of outcomes supports the conclusion of this review, that low dose aspirin is effective for preventing preeclampsia and related perinatal morbidity and mortality for individuals at increased risk for preeclampsia. More research will be needed to determine the optimal aspirin protocol and identify key populations most likely to obtain benefits.

## Applicability of Evidence and Health Equity

The included studies in this review ranged from explanatory to pragmatic in their design features but were all randomized trials and therefore represent a subset of the larger population of pregnant individuals who were willing to undergo randomization to daily medication use during pregnancy. The effectiveness of the intervention, due to differences in adherence or the health status between participants and the general population, may not match what has been found in clinical trials.

The majority of participants in the included trials were White, limiting the generalizability of results to racially and ethnically diverse populations at risk for preeclampsia. Only the two United States trials, the MFMU-HR trial,^99^ which recruited women at increased risk for developing preeclampsia, and the MFMU-LR trial,^92^ in average-risk nulliparous individuals, enrolled substantial numbers of Black and Latinx study participants; none of the included studies enrolled significant numbers of other minority racial or ethnic groups. Thus, the evidence is limited for assessing whether there could be racial or ethnic differences in the effectiveness or potential harms of aspirin in pregnancy. This is a troubling in light of the greater morbidity from preeclampsia experienced by Black women in the United States compared to other racial and ethnic groups.^11^ More than half the participants enrolled in MFMU-HR were Black, and the trial did not find a difference in aspirin effectiveness by race/ethnicity (coded as ‘nonWhite’ versus ‘White’), but the low magnitude of effects in this trial limited the comparison. Racial/ethnic differences in aspirin effectiveness or harms could exist, owing to the prevalence of different risk factors in different racial groups, environment/gene interactions, or other factors. Such differences could contribute to heterogeneity in the effect magnitudes observed in the evidence we reviewed. Given the troubling disparities in maternal health and birth outcomes documented among Black women in the United States,^11,^ ^159,^ ^160^ research is urgently needed to address this evidence gap.

A retrospective cohort study of births among “Hispanic” and “African-American” individuals with a history of preeclampsia provides evidence that benefits seen in the trials included in this review can be obtained in routine care settings. The study compared preeclampsia recurrence before and after the release of the 2014 USPSTF recommendation for aspirin prophylaxis.^64^ Adjusted analyses indicated 30 percent reduced recurrence of preeclampsia, despite an increase in rates of pregestational diabetes over the study period (a significant risk factor for preeclampsia). Although the observational study design is subject to risk of bias from historical trends and other unmeasured confounding, it supports the applicability of trial evidence synthesized in this review on to routine care provided in clinical settings serving diverse populations. Nevertheless, further research on implementation will be needed to ensure that effective interventions are equitably distributed, as health disparities in preeclampsia may be further exacerbated by unequal access high quality antenatal health care where effective interventions are implemented in practice.

## Chronic and Gestational Hypertension

A recent study of over 44 million deliveries in the Nationwide Inpatient Sample dataset found that the incidence of hypertensive disorders in pregnancy increased from 8.4 percent in 2004 to 10.9 percent in 2014, with the largest increases seen in the categories of gestational hypertension and chronic hypertension. Of note, women with chronic hypertension without preeclampsia had higher risks of cardiovascular events (myocardial infarction and arrhythmia) than women with preeclampsia without hypertension. Women with chronic hypertension as well as preeclampsia had the highest risk of adverse outcomes (including much higher risks of preterm birth, stillbirth, and stroke).^161^

The trials included in our review also showed higher preeclampsia incidence for participants entering the study with elevated blood pressure than those without elevated blood pressure, when this was reported. Participants with chronic hypertension enrolled in the MFMU-HR trial had the highest rates of preeclampsia, and nearly the same proportion of participants developed preeclampsia in the aspirin group as in the placebo group, 25 and 26 percent, respectively. A subgroup analysis in the ASPRE trial suggested a higher risk of preterm birth with preeclampsia among women with chronic hypertension in the aspirin group than in similar women assigned to placebo:^59^ a test for an interaction between hypertension status and treatment group was on the margin of statistical significance. These two trials suggest that aspirin may not be effective for individuals with hypertension diagnosed before pregnancy, but the results are inconclusive. In addition, the trial literature we reviewed was limited for determining whether a diagnosis of chronic hypertension using the AHA’s revised lower systolic and diastolic blood pressure cut points of 130 and 80, respectively, should be incorporated when identifying women at risk of preeclampsia.^162^ In a systematic review of cohort studies evaluating risk factors for preeclampsia, a systolic blood pressure at the initial visit of ≥130 mm Hg vs <130 was associated with an unadjusted relative risk of preeclampsia of 2.37 (1.78 to 3.15) and a diastolic blood pressure of ≥ 80 versus <80 was associated with a unadjusted relative risk of preeclampsia of 1.38 (1.01 to 1.87).^163^

There is limited, but suggestive evidence from secondary analysis of data from the MFMU-HR trial that for individuals with stage 1 hypertension at baseline (less than 26 weeks of gestation) that were not previously hypertensive, aspirin may be more beneficial for certain risk groups.^164^ Though the analysis had limitations, it suggested that the presence of stage 1 hypertension before 26 weeks of gestation was associated with later preeclampsia incidence, and that aspirin was more effective for preeclampsia prevention among individuals with this level of hypertension than among those without. A similar analysis of the entire study population reported in the primary MFMU-HR trial publication, however, found similar aspirin effectiveness for participants who were not hypertensive at baseline but had systolic blood pressure of 120 to 134 mmHg and those who were normotensive at study entry (before 26 weeks of gestation).^99^ A trial included for harms in this review, also conducted in racially and ethnically diverse patients recruited from MFMU network^92^ sites, found that aspirin may be effective in healthy nullipara with SBP 120-134 mm Hg at baseline, whereas no difference between aspirin and placebo was found for lower baseline blood pressure levels.^99^ Among the risk group in MFMU-HR with chronic hypertension at study entry, who were excluded from the secondary analysis described above, there were more cases of preeclampsia in the aspirin group than the control group.

Taken together, these findings suggest that those with chronic hypertension (now considered stage 2 chronic hypertension) may be less responsive to aspirin prophylaxis, while individuals without a history of chronic hypertension who are newly identified as having stage 1 hypertension early in pregnancy may be more likely to benefit than individuals with no hypertension. Future research is needed to determine whether there is a subgroup of women with pre-existing hypertension, perhaps those with a recent diagnosis at a lower diagnostic cut point, who may benefit from aspirin therapy. The limited data leave it unclear whether the risk of superimposed preeclampsia may be mitigated by aspirin prophylaxis, especially among women with stage 2 hypertension, but no studies have been adequately powered to examine this hypothesis.

Another area of uncertainty is the benefit of aspirin for the prevention of gestational hypertension in the absence of preeclampsia. We attempted to address this question by pooling all cases of gestational hypertension from studies that provided the outcome. Our meta-analysis found that the direction of risk reduction was the same for gestational hypertension as for preeclampsia, but even though effect magnitude was greater, the estimate did not achieve statistical significance. One challenge in assessing gestational hypertension from the available RCT data is that the presence of this condition is not commonly reported in a way that would allow us to identify participants who were diagnosed with preeclampsia after an initial diagnosis of gestational hypertension. Thus, if aspirin reduces the likelihood that gestational hypertension will transition to preeclampsia, there could be more cases of gestational hypertension (rather than preeclampsia) reported in the intervention group. Aspirin might also reduce the risk for gestational hypertension. Given that gestational hypertension and preeclampsia are now treated the same at term (i.e. delivery is recommended at 37 weeks of gestation for both conditions),^1^ we conducted an additional exploratory analysis assessing whether aspirin was effective for reducing the risk of hypertensive disorders of pregnancy as a whole in trials reporting adequate data. We found a significant risk reduction in the aspirin condition, supporting the possibility that aspirin may be useful for prevention of both gestational hypertension and preeclampsia. Further confirmatory research is needed.

## Obesity

One question for which current trial data are limited is whether the dosing of aspirin for the prevention of preeclampsia should differ for women with a higher body mass index. Only two of the included trials performed analyses stratified by BMI to examine the differential impact of LDA for prevention of preeclampsia (MFMU-HR, 60 mg) and prevention of preeclampsia with preterm birth (ASPRE, 150 mg) and found no significant differences by BMI category. One hypothesis for why the dose of aspirin may need to be different for women with obesity is that the degree of thromboxane inhibition achieved at a given dose may vary by BMI. To examine whether aspirin is associated with less thromboxane inhibition among women with obesity, a subsequent secondary analysis was conducted in a subgroup of 1002 of the original 2539 ppts the MFMU-HR trial.^165^ Women in the cohort were stratified by BMI (obese ≥30 kg/m^2^ vs nonobese <30 kg/m^2^). The primary outcome was rate of complete thromboxane B2 (TXB2) inhibition, defined as undetectable TXB2 levels <0.01 ng/mL and the secondary outcomes were rates of preeclampsia at any gestational age and preeclampsia with preterm delivery <37 weeks in women with and without undetectable TXB2 levels. Women with obesity assigned to LDA had statistically significant lower rates of undetectable TXB2 levels in the second trimester (39.4% vs 30.2%; P =.04), but not during the third trimester (41.4% vs 32.9%; P=.12), and were substantially less likely to have undetectable levels of TXB2 at both time points (30.6% vs 17.7%; P = .010). However, there were no differences in rates of preeclampsia in women receiving LDA with undetectable TXB2 levels in the second trimester (17.2% vs 20.8%; P=.34), third trimester (16.4%vs 19.7%; P=.46), or at both time points (16.5% vs 17.5%; P = .83), and there were no differences in rates of preeclampsia with delivery less than 37 weeks in women with undetectable TXB2 levels in the second trimester (9.9% vs 9.2%; P=.71), third trimester (4.5% vs 7.4%; P = .27), or at both time points (5.1% vs 6.3%; P =.83).

In summary, while there appears to be a differential effect of aspirin on thromboxane inhibition among women with obesity, this does not appear to result in a differential impact on outcomes, although trial data examining the effect of BMI are limited.

## Identifying Serious Harms

The challenge in identifying potentially serious harms is apparent when considering the outcome of clinically significant postpartum hemorrhage. As noted above, the trial evidence most commonly used a measure of 500mL or more of blood loss to define postpartum hemorrhage, but this number is of questionable clinical significance.^123^ In 2014, after all but two of the studies included in this review were published, the national reVITALize initiative^166^ worked to standardize obstetric data definitions and redefined postpartum hemorrhage as a cumulative blood loss greater than or equal to 1,000 mL, or blood loss accompanied by signs or symptoms of hypovolemia within 24 hours after the birth process (including intrapartum loss) regardless of route of delivery.^167^ This new definition is believed to be more clinically meaningful and has been adopted by the American College of Obstetrics & Gynecology.^118^ Future trials may benefit from adoption of an outcome measure consistent with this definition to better assess whether there are meaningful differences in postpartum hemorrhage rates associated with aspirin to prevent preeclampsia. In the meantime, the possibility of clinically significant differences for more rare, serious implications cannot be entirely ruled out.

## Longer-Term Health Outcomes

It is possible that there are longer-term child and adult health implications associated with preeclampsia and/or its prevention with aspirin prophylaxis. Only one included trial reported followup beyond the perinatal period:^95^ a subset of the children of trial participants were assessed at 18 months of age.^113^ While this study was reassuring with regard to the lack of developmental harms in toddlerhood, there remains a need for longer-term followup, to assess potential harms and potential benefits of intervention. A growing body of research suggests that exposure to preeclampsia in utero may be harmful to future health. Longer-term trial followup could evaluate the possibility that prevention of preeclampsia with aspirin may reduce offspring risk of cardiovascular disease^168,^ ^169^ as well as for neurocognitive conditions such as attention deficit hyperactivity disorder,^170,^ ^171^ autism spectrum disorder, epilepsy, intellectual disability, and vision or hearing loss.^172^

Followup on trial participants would similarly have the potential to shed light on whether prevention of preeclampsia during pregnancy has long-term health implications for mothers. A number of studies have found associations between preeclampsia and long-term cardiovascular health outcomes.^173,^ ^174^ Estimates suggest a possible doubling or tripling of cardiovascular disease risk in women who have had preeclampsia during any pregnancy,^175,^ ^176^ as well as an increased risk for early stroke (before age 60).^177^ Risks may be considerably higher in women who had early-onset preeclampsia.^178^ Subclinical brain and endothelial damage may occur from the cardiovascular strain and metabolic effects of preeclampsia.^174,^ ^179–181^ It is unclear whether these changes cause the observed increased long-term cardiovascular disease and mortality risk associated with a history of preeclampsia, or if differences arise from underlying risk profiles among women that potentiate the development of both of these short- and long-term outcomes.^182^ Further research, including extended followup on aspirin trials, could shed light on the mechanisms and causal pathways between preeclampsia prevention and longer-term health.^179^

## Conclusions

Few new studies have been published since the previous review conducted for the USPSTF. The addition of a large trial strengthened the evidence for the effectiveness of low dose aspirin for preventing preeclampsia and reducing the risk of SGA/IUGR, preterm birth, and perinatal mortality, across a range of aspirin protocols and increased-risk populations. Data from over 25,000 individuals randomized to daily aspirin use for preeclampsia prevention do not suggest that there are serious harms associated with low dose aspirin use for this purpose during pregnancy. The evidence included in this review cannot rule out rare harms from low dose aspirin use during pregnancy, although findings are reassuringly consistent with the findings of large registry and cohort studies (not included in this review) examining potential harms of aspirin exposure at any gestation, at any dose, and for any indication. The effectiveness of aspirin is supported across a range of risk assessment strategies, aspirin dosages, and protocols regarding when during pregnancy to begin taking aspirin. Further research is needed to address gaps in the research related to potential variability in the effectiveness of aspirin that could not be resolved from subgroup comparisons in the existing trial evidence on this topic. Even if aspirin has only modest effectiveness for improving the pregnancy outcomes evaluated, their seriousness means that the intervention could result in important benefits to population health. Finally, the benefits of aspirin prophylaxis may not always reach those at risk, especially populations with limited access to high quality prenatal care. Implementing strategies that promote equitable access to this intervention could help address preeclampsia health inequities, especially those observed for Black women in the United States.