# Chapter 3 Results

## Description of Included Studies

Our literature search yielded 3749 unique citations. From these, we reviewed the full text of 183 articles (Appendix B Figure 1). Of these, 23 studies (33 articles) met our inclusion criteria. We excluded the remaining 150 full-text articles (Appendix C).

Of the 23 included studies (n=26,952) 19 are carried forward from the previous USPSTF review conducted in 2014.^57,^ ^87–104^ These studies met the inclusion and exclusion criteria of the current review and were combined with four newly identified RCTs.^59,^ ^105–107^ Four studies included in the previous review were excluded based on risk of bias and eligibility determinations according to the scope of the current review.^108–111^ Among the included studies, 18 (10 good-quality) met the inclusion criteria for KQ 1 (maternal and perinatal health outcomes); 16 (10 good-quality) met the inclusion criteria for KQ 2 (preeclampsia); and 21 (14 good-quality) met the inclusion criteria for KQ 3 (harms). One IPD-MA was identified but was not included because our prespecified inclusion and exclusion criteria for intervention and setting were not met. The results of this study are discussed in the next chapter. For KQs 1 and 2, we included trials that enrolled pregnant individuals at increased risk of preeclampsia. For KQ 3 we included studies reporting harms from trials enrolling pregnant individuals at increased risk (16 included trials) and at average risk of preeclampsia (5 included trials) (Appendix B Figure 1).

### Population and Setting Details

Tables 2 and 3 provide summary information on study population, setting, design, and intervention characteristics of the included studies. For KQ 1 and KQ 2, assessing the effectiveness of aspirin in preventing preeclampsia and related health outcomes for pregnant individuals at increased risk for preeclampsia, we included a large Maternal Fetal Medicine Unit Network in High Risk Women (MFMU-HR) trial (n=2,539) funded by National Institute of Child Health and Human Development that recruited participants from 13 clinical sites in the United States from May 1991 to June 1995.^99^ Two large international trials coordinated from the United Kingdom were also included:^59,^ ^95^ The Collaborative Low dose Aspirin Study in Pregnancy (CLASP) (n=9,364) trial enrolled participants from 213 centers across 16 countries from January 1988 to December 1992,^95^ and the Combined Multimarker Screening and Randomized Treatment with Aspirin for Evidence-based Preeclampsia Prevention (ASPRE) trial (n=1,776) enrolled participants 13 maternity hospitals based in 6 countries (United Kingdom, Spain, Italy, Belgium, Greece, Israel) from April 2014 to April 2016.^59^ There were 15 smaller trials included from various countries.^57,^ ^87–90,^ ^93,^ ^94,^ ^96–98,^ ^101,^ ^103,^ ^104,^ ^106,^ ^107^ For KQ 3, assessing harms associated with aspirin use during pregnancy, we included five additional RCTs of women considered to be at average risk for preeclampsia.^91,^ ^92,^ ^100,^ ^102,^ ^105^ These five RCTs included a good-quality multisite study conducted in the United States MFMU sites that enrolled average- or low-risk participants (MFMU-LR) (n=3,135),^92^ a smaller U.S.-based study (n=606),^91^ a large good-quality multisite study in France and Belgium (n=3,294),^102^ a large good-quality hospital-based study in Barbados (n=3,647),^100^ and a smaller fair-quality study from Ireland (n=362).^105^

Table 2 Population, Study Design, and Intervention Characteristics, Increased Risk Population

Author, year; Country; Study quality | N rand | Included Populations | Main medical history exclusions | Aspirin dosage, mg | Treatment time of day, pregnancy duration | Control condition | Mean age (range) | Nulliparous, % | Race/ethnicity, % | Smoking, % | Chronic HTN, %
ASPRE, 2017^59^; Spain, Italy, UK, Israel, Belgium, Greece; Good | 1776 | Increased risk, risk prediction algorithm at 11-13 weeks’ gestation | Unconscious or severely ill status, learning difficulties or serious mental illness, major fetal abnormality, regular aspirin use within 28 days before screening, bleeding disorder, peptic ulceration, hypersensitivity to aspirin, long-term use of nonsteroidal antiinflammatory medication | 150 | Not specified 11 to 14 weeks; 36 weeks | Placebo | 31.5^*^ | IG: 68.5; CG: 66.1 | White: 67.1; Black: 25.2; Asian: 6.4; Other: 1.3 | IG: 7.1; CG: 7.2 | IG: 6.1; CG: 7.4
Ayala, 2012^57^; Spain; Good | 350 | Increased risk, receiving pregnancy care at high-risk obstetric unit due to range of factors | Multiple pregnancy, chronic HTN or any other condition requiring the use of BP-lowering medication, cardiovascular disorders, chronic liver disease, any disease requiring the use of anti-inflammatory medication, DM or any other endocrine disease such as hyperthyroidism | 100 | Randomly assigned (various) 12 to 16 weeks; delivery | Placebo | 30.7 | IG: 49.4; CG: 55.1 | NR | NR | NR
Benigni, 1989^88^; Italy; Fair | 33 | Increased risk, HTN or previous history of fetal death due to placental insufficiency, severe IUGR, early onset PreE [<32 weeks] | Women with antiphospholipid antibodies (lupus-like, anticoagulant, anticardiolipin antibodies) | 60 | Not specified 12 weeks; delivery | Placebo | 31.5 (NR) | NR | NR | IG: 6.3; CG: 0 | IG: 35.2; CG: 31.3
Caspi, 1994^94^; Ireland; Good | 48 | Increased risk, uncomplicated twin pregnancies | Chronic renal, cardiovascular, pulmonary or hepatic disorders, coagulopathy or peptic ulcer, gestational DM, known hypersensitivity to aspirin | 100 | Morning Start of the second trimester; delivery | Placebo | 28.3 | IG: 41.6; CG: 30.4 | NR | NR | IG: 1.0; CG: 3.0
CLASP, 1994^95^; US, Australia, Canada, Germany, Spain, Hong Kong, Ireland, Netherlands, New Zealand, Sweden, UK, Argentina, Belgium, Malaysia, Russia, UAE; Good | 9364 | Increased risk, determined by clinician based on range of factors including obstetric history, family history, patient and pregnancy characteristics | Increased risk of bleeding, asthma, allergy to aspirin, or a high likelihood of immediate delivery | 60 | Not specified 12 to 32 weeks; delivery | Placebo | 28.5 | IG: 27.9; CG: 27.9 | NR | IG: 20.7; CG: 20.1 | IG: 19.9; CG: 20.2
Davies, 1995^96^; UK; Fair | 122 | Increased risk, hemoglobin concentration greater than 13.2 g/dL | Multiple pregnancy, DM, recurrent spontaneous abortions, or any contraindication to aspirin therapy | 75 | Not specified 18 weeks; delivery | Placebo | 25.0 | IG: 100; CG: 100 | White: 95.8 | IG: 10.3; CG: 13.3 | IG: 0; CG: 0
Gallery, 1997^97^; Australia; Fair | 108 | Increased risk, chronic HTN or previous early, severe PreE | Women with history of aspirin allergy, aspirin-sensitive asthma, or preexisting bleeding diathesis | 100 | Not specified 17 to 19 weeks; two weeks before planned delivery | Placebo | 28.5 (22-38) | IG: 42.0; CG: 43.0 | White: 95.5 | NR | IG: 57.0; CG: 52.0
Grab, 2000^101^; Germany; Fair | 43 | Increased risk, early IUGR, impaired uteroplacental blood, chronic HTN or previous still birth, growth restriction, or PreE | DM, proteinuric HTN; fetal malformations or chromosome abnormalities | 100 | Not specified 18 weeks; 38 weeks | Placebo | NR | NR | NR | NR | IG: 50.0; CG: 38.1
Hermida, 1997^98^; Spain; Good | 100 | Increased risk, receiving pregnancy care at high-risk hospital unit due to broad range of PreE factors | Multiple gestation pregnancy, chronic HTN, chronic liver disease, disease requiring the use of anti-inflammatory medication, DM, hyperthyroidism | 100 | Randomly assigned (various) 12 to 16 weeks; delivery | Placebo | 30.2 | NR | White: 100; Black: 0; Asian: 0; NatAm: 0; Hisp: 0; Other: 0 | NR | NR
McParland, 1990^90^; UK; Fair | 106 | Increased risk, nulliparous with persistent abnormal Doppler flow-velocity waveforms at 24 weeks’ gestation | Known aspirin allergy, maternal DM, bleeding disorders, peptic ulceration, systemic lupus erythematosus | 75 | Not specified 24 weeks; delivery | Placebo | 26.1 | IG: 100; CG: 100 | White: 69.0; Black: 20.0; Asian: 7.0; Other: 4.0 | IG: 16; CG: 23 | NR
MFMU-HR, 1998^99^; US; Good | 2539 | Increased risk, four risk groups: DM, chronic HTN, multifetal gestation, previous PreE | Multifetal gestation in combination with DM, HTN, or proteinuria, history of PreE, current proteinuria | 60 | Not specified 13 to 26 weeks; delivery or if PreE developed | Placebo | 26.5 | NR | White: 32.7; Black: 56.3; Hisp: 10.8; Other: 0.5 | IG: 16.8; CG: 16.4 | NR
Morris, 1996^107^ | 102 | Nulliparous with abnormal uterine artery waveforms at 18 weeks’ gestation | Pregnancies dated at less than 17 weeks’ or more than 19 weeks’ of gestation | 100 | Not specified 17-19 weeks; NR | Placebo | 23.8 | 100 | NR | NR | NR
Scazzocchio, 2017^106^; Spain; Good | 186 | Increased risk, abnormal Doppler ultrasound at 11-14 weeks’ gestation, maternal age > 18 years | Preexisting HTN, immune, renal, or cardiovascular disease, history of PreE in a previous pregnancy, history of gastric ulcer, known allergy or hypersensitivity to aspirin, hemorrhagic disease, fetal malformation, active treatment with heparin or aspirin before recruitment, multifetal gestation | 150 | Evening 11 to 14 weeks; delivery | Placebo | 32.9 | IG: 62.5; CG: 64.0 | NR | IG: 11.3; CG: 12.0 | IG: 0; CG: 0
Schiff, 1989^89^; Israel; Good | 65 | Increased risk, nulliparity, twin gestation, history of PreE, or positive rollover test | Chronic HTN, pregnancy induced hypertension or proteinuria in current pregnancy, long-term treatment with nonsteroidal anti-inflammatory drugs or use in previous 6 weeks, thrombocytopenia, coagulation disorders, heart failure, chronic renal or pulmonary disease, hepatic or peptic ulcer disease, hypersensitivity to aspirin | 100 | Not specified 28 or 29 weeks to 38 weeks | Placebo | 27.4 | NR | White: 100 | NR | IG: 0; CG: 0
Viinikka, 1993^93^; Finland; Fair | 208 | Increased risk, HTN or previous severe PreE | None | 50 | Not specified 16 weeks; delivery | Placebo | 33.0 | IG: 25.2; CG: 23.8 | NR | NR | IG: 86.4; CG: 91.4
Villa, 2012^104^; Finland; Fair | 152 | Increased risk, broad range of PreE risk factors and abnormal Doppler ultrasound at 12-14 weeks’ gestation | Aspirin allergy, tobacco smoking in current pregnancy, multiple gestation pregnancy, asthma, peptic ulcer, placental ablation, inflammatory bowel diseases, rheumatoid arthritis, hemophilia or thrombophilia | 100 | Not specified 12 to 14 weeks; 35 weeks or delivery (whatever came first) | Placebo | 30.9 (20-40) | IG: 26.2; CG: 15.0 | NR | IG: 0; CG: 0 | IG: 13.1; CG: 20.0
Wallenburg, 1986^87^; Netherlands; Good | 46 | Increased risk, Angiotensin-II sensitivity determined by blood pressure test | HTN or cardiovascular renal disease | 60 | Morning 28 weeks; delivery | Placebo | 24 (17-38) | IG: 100; CG: 100 | NR | IG: 21.7; CG: 17.4 | IG: 0; CG: 0
Yu, 2003^103^; UK, Chile, South Africa, Brazil; Good | 560 | Increased risk, abnormal Doppler ultrasound at 22-24 weeks’ gestation | Chronic HTN, renal disease, cardiovascular disease, DM, bleeding disorders, systemic lupus erythematosus, peptic ulceration, hypersensitivity to aspirin, fetal abnormality or fetal growth restriction at 23 weeks’ gestation | 150 | Not specified 22 to 24 weeks; 36 weeks | Placebo | 29^*^ (23-33) | IG: 26.8; CG: 23.4 | White: 62.3; Black: 27.6; Other: 10.1 | IG: 9.4; CG: 9.7 | IG: 0; CG: 0

Abbreviations: ABPM = Ambulatory blood pressure monitoring; AIDS = Acquired immunodeficiency syndrome; CG = Control group; DM = Diabetes mellitus; Hisp = Hispanic; HTN = Hypertension; IG = Intervention group; NR = Not reported; PreE = Preeclampsia; UK = United Kingdom; US = United States

* Median

Table 3 Population, Study Design, and Intervention Characteristics, Average Risk Population

Author, year; Country; Study quality | N rand | Included Population | Main medical history exclusions | Aspirin dosage, mg | Treatment time of day, pregnancy duration | Control condition | Mean age (range) | Nulliparous, % | Race/ethnicity, % | Smoking, % | Chronic HTN, %
Hauth, 1993^91^; US; Good | 606 | Average risk, nulliparous | Any illness or condition known to increase the incidence of PreE or PIH (i.e. renal disease, collagen vascular disease, DM, multifetal gestation, chronic HTN) | 60 | Not specified No later than 22 weeks; delivery | Placebo | 20.4 | IG: 100; CG: 100 | White: 28.5; Black: 71.5 | NR | IG: 0; CG: 0
Mone, 2018^105^; Ireland; Fair | 362 | Average risk, nulliparous | Fetal congenital anomaly at recruitment, aspirin hypersensitivity | 75 | Evening 11 to 13 weeks; 36 weeks | No treatment | 33.5 (19-44) | IG: 100; CG: 100 | White: 96.8; Black: 0.8; Asian: 2.4; Other: 0 | IG: 9.2; CG: 5.9 | IG: 0; CG: 0
Rotchell, 1998^100^; Barbados; Good | 3647 | Average risk, nulliparous and multiparous | Increased risk of bleeding, known allergy or contraindication to aspirin, high likelihood of immediate delivery, previous placental abruption | 75 | Not specified 12 to 32 weeks; delivery | Placebo | NR | IG: 44.0; CG: 44.0 | NR | NR | IG: 0.44; CG: 0.44
MFMU-LR, 1993^92^; US; Good | 3135 | Average risk, nulliparous | Chronic HTN, renal disease, DM, or other [unspecified] medical illnesses | 60 | Not specified 13 to 25 weeks; delivery | Placebo | 20.5 | IG: 100; CG: 100 | White: 17.9; Black: 49.8; Hisp: 31.6 | IG: 11.5; CG: 10.7 | IG: 0; CG: 0
Subtil, 2003^102^; France, Belgium; Good | 3294 | Average risk, nulliparous | Chronic HTN, antiphospholipid antibodies, lupus, contraindication to aspirin or other anticoagulant use (e.g., allergy, frequent hematomas or bleeding, hemorrhage during medical procedures, recent ulcer, severe asthma) | 100 | Not specified 14 to 20 weeks; 34 weeks | Placebo | 24.7 | IG: 100; CG: 100 | NR | IG: 25.0; CG: 24.9 | IG: 0; CG: 0

Abbreviations: CG = Control group; DM = Diabetes mellitus; Hisp = Hispanic; HTN = Hypertension; IG = Intervention group; NR = Not reported; PreE = Preeclampsia; PIH = Pregnancy-induced hypertension

Among trials included to assess the effectiveness of aspirin, a variety of study procedures and criteria were used to identify populations of pregnant persons at increased risk for preeclampsia (Table 4). The most common method was examination of participant characteristics and personal or family medical history (e.g., age, BMI, parity, multifetal gestation, history of hypertensive disorders, history of pregnancy complications). Among these studies, history of hypertensive disorders (preeclampsia, gestational hypertension, or chronic hypertension), alone or in combination with other risk factors, was used as the primary method to identify trial participants in ten studies,^57,^ ^88,^ ^89,^ ^93,^ ^95,^ ^97–99,^ ^101,^ ^104^ and multifetal gestation was used in six trials.^57,^ ^89,^ ^94,^ ^95,^ ^98,^ ^99^ Other clinical risk factors used included metabolic disease;^57,^ ^98^ diabetes (prepregnancy or gestational),^99,^ ^104^ history of IUGR/SGA,^88,^ ^101,^ ^104^ spontaneous abortion,^57,^ ^98,^ ^104^ or stillbirth;^88,^ ^101^ renal disease;^95,^ ^97^ and maternal age.^57,^ ^95,^ ^98^

Table 4 Patient Risk Factors and Clinical Tests Used to Identify Study Populations at Increased Risk for Preeclampsia

Author, Year | %Preeclampsia incidence in control group | Hx of preeclampsia or hypertension^*^ | Maternal Age | Nulliparity | Multifetal gestation | Renal Disease | Metabolic disease | Hx of Stillbirth | Hx spontaneous abortion | Hx of SGA/IUGR | Diabetes | Prediction model^†^ | Hemoglobin concentration | Positive rollover test | Angiotensin-II sensitivity | Abnormal Doppler readings
Benigni, 1989^88^ | NR | x | | | | | | x | | x
Gallery, 1997^97^ | NR | x | | | | x
Scazzocchio, 2017^‡^,^106^ | 4 | | | | | | | | | | | | | | | x
CLASP, 1994^95^ | 8 | x | x | | x | x
Caspi, 1994^94^ | 9 | | | | x
Grab, 2000^101^ | 10 | x | | | | | | x | | x
ASPRE, 2017^59^ | 11 | X | | | | | | | | | | x | | | | X
Viinikka, 1993^93^ | 11 | x
Davies, 1995^96^ | 12 | | | x^§^ | | | | | | | | | x
Ayala, 2012^57^ | 13 | x | x | x | x | | x | | x
Hermida, 1997^98^ | 14 | x | x | x | x | | x | | x
Villa, 2012^104^ | 18 | x | | | | | | | x | x | x | | | | | x
McParland, 1990^90^ | 19 | | | x^§^ | | | | | | | | | | | | x
Yu, 2003^ǁ103^ | 19 | | | | | | | | | | | | | | | x
MFMU-HR, 1998^99^ | 20 | x | | | x | | | | | | x
Morris, 1996^107^ | 14 | | | x | | | | | | | | | | | | x
Schiff, 1989^89^ | 23 | x | | x | x | | | | | | | | | x
Wallenburg, 1986^87^ | 30 | | | x^§^ | | | | | | | | | | | x

Abbreviations: Hx = History; SGA/IUGR = Small for gestational age/intrauterine growth restriction; NR = Not reported

* Includes personal history of gestational hypertension, chronic hypertension, or preeclampsia

† Prediction model includes maternal risk factors, serum biomarkers, Doppler ultrasound

‡ Excluded individuals with a multifetal gestation or history of preeclampsia, hypertension, renal disease, or cardiovascular disease.

§ Population limited to nulliparous individuals

ǁ Excluded criteria included individuals with history of hypertensive disease, renal and cardiovascular disease, and diabetes.

Most risk factors and clinical tests used for identifying increased-risk populations, whether used alone or in combination with other factors, were associated with at least a two-fold higher risk for preeclampsia. An exception to this was nulliparity, which is understood to be a more modest independent risk factor for preeclampsia. Nulliparity was combined with other risk factors to identify an increased-risk population in three of the effectiveness trials.^57,^ ^89,^ ^98,^ ^107^ Nulliparity alone was used to select participants in four of the five studies enrolling average-risk populations that were included for evaluating harms of aspirin use in pregnancy.^91,^ ^92,^ ^102,^ ^105^ These studies, which reported preeclampsia incidence in the control condition ranging from 2 to 6 percent (similar to the population average), were not included for evaluating KQ1 and KQ2 as nulliparity alone was not considered sufficient evidence of increased risk in accordance with the scope defined for the previous and current review.

Risk assessment also frequently involved diagnostic measurements or assays, either as the primary means to identify individuals at risk, or in combination with medical history and personal characteristics. Abnormal Doppler readings were used in six studies.^59,^ ^90,^ ^103,^ ^104,^ ^106,^ ^107^ One study relied on angiotensin-II sensitivity identified via blood pressure response to IV infusion of angiotensin II.^87^ Another required a positive rollover test in which rolling the participant from her left side to her back resulted in rise of diastolic blood pressure >15 mg Hg above baseline.^89^ One study used a second trimester hemoglobin concentration greater than 13.2 g/dL to determine the risk of an individual participant in the trial.^96^ Finally, one trial utilized a prediction model that combined maternal demographic factors and medical history, mean arterial pressure, uterine-artery pulsality index, and maternal serum pregnancy-associated plasma protein A and placental growth factor to identify persons at increased risk for preterm birth secondary to preeclampsia.^59^

The inclusion and exclusion criteria in the trials were usually well described, but details on the baseline demographic characteristics and risk factors of enrolled participants were sparsely and inconsistently reported (Appendix E Table 1). Overall, the population of women included in the trials was young (mean age ranging from 20.4 to 33.5 years) and predominantly White, with only three trials reporting majority populations of Black women (ranging from approximately 50% to 72%).^91,^ ^92,^ ^99^ Parity was reported in most trials, with the proportion nulliparous ranging from approximately 15 to 100 percent of study participants. Similarly, the proportion of participants with a history of chronic hypertension at baseline ranged from no participants (in low or average-risk population studies included for KQ3) to nearly all having this history (91%). History of smoking and current smoking were reported in 13 trials and ranged from approximately 10 to 40 percent of participants.^59,^ ^87,^ ^88,^ ^90,^ ^92,^ ^95,^ ^96,^ ^99,^ ^102–106^ Mean BMI ranged from 22.3 to 29.7 kg/m^2^ in the studies reporting this baseline characteristic.

### Intervention Characteristics

Included trials varied widely in timing of and dosages of aspirin treatment (Table 2, Table 3). The gestational age at which aspirin therapy was initiated across the trials varied substantially with nine trials starting therapy in participants as early 11 to 12 weeks of gestation and five allowing initiation to continue as late as 36 to 38 weeks of gestation. The most common date of aspirin discontinuation was delivery, but eight trials stopped aspirin prophylaxis before delivery,^59,^ ^89,^ ^97,^ ^101–105^ as early as 34 weeks^102^ or at the point when preeclampsia developed.^99^ Aspirin dosages ranged from 50 to 150 mg daily. The majority of trials used either dosages of 60 mg (6 trials)^87,^ ^88,^ ^91,^ ^92,^ ^95,^ ^99^ or 100 mg (9 trials);^57,^ ^89,^ ^94,^ ^97,^ ^98,^ ^101,^ ^102,^ ^104,^ ^107^ two of the newly identified trials used a higher dose of 150 mg per day.^59,^ ^106^ A matching placebo was the comparator in all trials except in one study included for harms, in which participants in the control arm received usual care with no placebo.^105^

Meta-analysis was possible for seven outcomes that were reported with enough consistency across multiple studies to support valid estimation of effects. The relevant results related to each Key Question are presented in detail below (Table 5). The three largest included trials, MFMU-HR, CLASP, and ASPRE,^59,^ ^95,^ ^99,^ ^112–117^ conducted prespecified or exploratory comparisons and reported statistical tests for interaction suitable for evaluating subgroup differences (Appendix F, Table 1).

Table 5 Summary of Meta-Analysis Results

| No. studies reporting outcome (N Randomized) | Pooled Analysis No. studies (n analyzed)^*^ | Pooled RR random effects model^†^ (95% CI) | I^2^ % | Tau^2^ | Effect Range | Effect Median (IQR)
Perinatal mortality | 15 (15,527) | 11 (13,860) | 0.79 (0.66, 0.96) | 0.0 | 0.0 | 0.31 to 5.15; ARD: −6.3 to 2.9 | 0.96 (0.59 to 1.10); ARD: 0.0 (-1.1 to 0.5)
Preterm birth | 13 (15,213) | 13 (13,619) | 0.80 (0.67, 0.95) | 48.7 | 0.02 | 0.12 to 1.03; ARD: −19.5 to 0 | 0.65 (0.35 to 0.90); ARD: −5.7 (-12.9 to −3.0)
SGA/IUGR | 16 (15,757) | 16 (14,385) | 0.82 (0.68, 0.99) | 41.2 | 0.04 | 0.30 to 1.22; ARD: −25.7 to 4.9 | 0.63 (0.48 to 0.97); ARD: −4.6 (-8.9 to −0.2)
Preeclampsia | 16 (15,767) | 16 (14,093) | 0.85 (0.75, 0.95) | 0.0 | 0.0 | 0.07 to 1.43; ARD: −30.4 to 4.1 | 0.72 (0.31 to 0.89); ARD: −4.1 (-8.4 to −1.3)
Postpartum hemorrhage | 11 (23,583) | 9 (23,133) | 1.03 (0.94, 1.12) | 0.0 | 0.0 | 0.38 to 2.84; ARD: −4.2 to 9.1 | 1.02 (0.94 to 1.23); ARD: 0.2 (-0.4 to 0.9)
Placental abruption | 13 (25,761) | 10 (24,970) | 1.15 (0.76, 1.72) | 25.3 | 0.07 | 0.64 to 5.56; ARD: −0.6 to 1.8 | 1.21 (0.96 to 2.07); ARD: 0.3 (0 to 0.6)
Fetal intracranial bleeding | 9 (23,959) | 6 (23,719) | 0.90 (0.51, 1.57) | 19.2 | 0.06 | 0.17 to 2.06; ARD: −0.3 to 0.6 | 0.94 (0.74 to 1.08); ARD: 0.0 (-0.1 to 0.0)

Abbreviations: ARD = Absolute risk difference; CI = Confidence interval; IQR = Interquartile range; k = Number of studies; N = Number of observations; RR = Risk ratio; SGA/IUGR = Small for gestational age / Intrauterine growth restriction

* Studies that reported no events in both study arms were excluded from the pooled analysis.

† Restricted maximum likelihood model with Knapp-Hartung confidence intervals

## KQ1 Does Aspirin Reduce Adverse Maternal, Perinatal, Child, or Combined Health Outcomes in Pregnant Persons at Increased Risk of Preeclampsia?

### Summary of Results

Eighteen trials (n=15,908) reported maternal, perinatal, or child health outcomes for daily aspirin use (50mg to 150mg daily) compared with a matching placebo starting as early as 11 weeks or as late as 32 weeks of gestation and continuing until late pregnancy or delivery. In pooled analyses, aspirin was consistently associated with a reduced risk of perinatal mortality, preterm birth, and SGA/IUGR (Table 5). Preventive effects of aspirin on the three main outcomes ranged from 20 to 30 percent reduced risk. Evidence from one within-trial comparison indicated that aspirin may be more effective among nonsmokers than among smokers. Aggregate comparisons between different design and participant characteristics of the included studies suggested that the benefit of aspirin for preventing preterm birth may be larger when aspirin was started before 16 weeks of gestation than when started later. There also was evidence of a larger effect of aspirin for preventing preterm birth in studies enrolling a larger proportion of nulliparous participants (who also had other risk factors). We did not observe statistically significant differences between specific populations for the preeclampsia or SGA/IUGR outcomes, and differences for preterm birth could be attributed to multiple comparisons. Nevertheless, small-study effects could not be ruled out and might lead to some overestimation of pooled effect sizes. Confounding of study size with other study and participant characteristics could have influenced subgroup comparisons. For example, the two largest studies reported the smallest risk reductions for all outcomes, but these studies also both started treatment later than 16 weeks of gestation and used very low aspirin dosages. Other rare health outcomes, such as eclampsia and maternal mortality, occurred too infrequently to estimate preventive effectiveness.

### Detailed Results

#### Maternal Health

Direct maternal health consequences of preeclampsia are extremely rare and include eclampsia, HELLP syndrome, stroke, organ failure, and death. Few trials reported these events, and pooled estimates were not possible to compute. In the few large studies with these and other maternal health outcomes, risk estimates were too imprecise to assess differences by study group (Appendix E Table 2). Many of the perinatal outcomes described below also have implications for maternal health and well-being, as do outcomes described as potential harms for KQ3.

#### Perinatal Mortality

Fifteen trials reported on perinatal mortality (N =15,527). Four of these reported no perinatal deaths in either study arm and were not included in the pooled analysis.^89,^ ^96,^ ^98,^ ^107^ Seven reported two or fewer events in one or both study arms.^57,^ ^87,^ ^88,^ ^90,^ ^93,^ ^94,^ ^97^ No individual study reported a statistically significant difference in perinatal mortality and all were underpowered for this outcome, but the pooled effect estimate showed a statistically significant 21 percent reduction in the risk of perinatal mortality associated with aspirin use (pooled RR 0.79, 95% CI 0.66, 0.96; I^2^ 0%; k=11, n=13,860) (Figure 2, Appendix E Table 3). The pooled effect was consistent with the findings from the three largest trials, which reported more cases of perinatal mortality in the control group than in the aspirin group, with relative risks ranging from 0.59 to 0.80. Smaller trials reported effects that were less consistently in the direction of a benefit, but confidence intervals were overlapping.

Figure 2 Perinatal Mortality, Sorted by Study Size

Abbreviations: CI = Confidence interval; mg = Milligrams; PE = Preeclampsia; REML = Restricted maximum likelihood; RR = Risk ratio

*Excluded 4 studies with both arms having zero events.

Figure 2 is a forest plot depicting the relative risk for perinatal mortality after aspirin prophylaxis and sorted by sample size. This figure is discussed in the Results section.

#### Preterm Birth

Thirteen trials reported on preterm birth (<37 weeks of gestation) (N = 15,213). Results across these trials were consistently in the direction of a preventive benefit of daily aspirin use, with no trial finding more cases of preterm birth in the aspirin group than in the placebo group. The estimated pooled effect showed a 20 percent reduced risk of preterm birth associated with intervention (pooled RR 0.80, 95%CI 0.67, 0.95; I^2^ 49%; k=13, n=13,619) (Figure 3, Appendix E Table 4). The primary outcome of the ASPRE trial^59^ was “preterm preeclampsia” a composite of preeclampsia and preterm birth. For pooled analyses, we used reported data from this trial to compute a preterm birth outcome consistent with what was reported in all other trials: preterm birth with or without a preeclampsia diagnosis. The combination of preeclampsia and preterm birth is a less common outcome, with ASPRE reporting 1.6 percent (13/798) in the aspirin group and 4.3 percent (35/822) in the placebo group, and the reported effectiveness of aspirin for the outcome (OR 0.38, 95%CI, 0.20, 0.74) was greater than for the prevention of any preterm birth. Nevertheless, the computed relative risk of any preterm birth for the ASPRE trial also favored aspirin (RR 0.65, 95% CI, 0.47, 0.90). Trials rarely reported cases of spontaneous preterm birth separately from induced preterm birth, and few studies reported the number of cases of very early and early preterm birth included in the preterm birth outcome.

Figure 3 Preterm Birth Before 37 Weeks’ Gestation, Sorted by Study Size

Abbreviations: CI = Confidence interval; mg = Milligrams; PE = Preeclampsia; REML = Restricted maximum likelihood; RR = Risk ratio

Figure 3 is a forest plot depicting the relative risk for preterm birth after aspirin prophylaxis and sorted by sample size. This figure is discussed in the Results section.

#### Small for Gestational Age or Intrauterine Growth Restriction

Sixteen trials reported on SGA/IUGR (N = 15,757) and all but two^90,^ ^99^ reported fewer cases in the aspirin group than in the placebo group. The estimated pooled effect indicated a 18 percent reduced risk of having an SGA/IUGR infant for women who took aspirin (pooled RR 0.82, 95% CI 0.68, 0.99; I^2^ 41%; k=16; n=14,385) (Figure 4, Appendix E Table 5).

Figure 4 Small for Gestational Age or Intrauterine Growth Restriction, Sorted by Study Size

Abbreviations: CI = Confidence interval; mg = Milligrams; PE = Preeclampsia; REML = Restricted maximum likelihood; RR = Risk ratio

Figure 4 is a forest plot depicting the relative risk of small for gestational age or intrauterine growth restriction (IUGR) after aspirin prophylaxis and sorted by sample size. This figure is discussed in the Results section.

Studies did not consistently report birthweight or gestational age at birth, but the results that were reported are consistent with the aspirin effects on SGA/IUGR and preterm birth (Appendix E Tables 6 and 7, Appendix F Figure 1). Combined mean birthweight (grams) was higher with aspirin use than with placebo across eleven studies (n=10,987) that reported the outcome (weighted mean difference 126.9; [95%CI 39.8, 214.0]; I^2^ 50.0%).

### Small-Study Effects

Tests for small-study effects were statistically significant for preterm birth (Peters p = 0.026) and approached statistical significance for SGA/IUGR (Peters p = 0.072) (data not shown). This suggests that the pooled effects for these outcomes may overestimate the effectiveness of aspirin due to differences in the way smaller studies were conducted or the absence of small null or negative studies in the published literature. Visual inspection of funnel plots also revealed an imbalance of the distribution of study findings and standard errors consistent with the statistically significant test for small-study effects. Because random effects meta-analysis modeling weights smaller studies more heavily, they can exacerbate bias due to small-study effects.^84^ The fixed effect sensitivity analysis (data not shown) suggests that the random effect estimates for SGA/IUGR and preterm birth could be slightly overestimated due to small-study effects, but that the random effects confidence intervals provide good coverage for the range of likely effects.

## KQ1a Does the Effectiveness of Aspirin for Reducing Adverse Health Outcomes Vary by Subpopulations Defined by Personal Characteristics or Preeclampsia Risk Factors?

Valid tests for subgroup differences were available from the three largest trials (Appendix F Table 1).^95,^ ^99,^ ^112^ We conducted subgroup comparisons at the aggregate level using stratified forest plots and meta-regression. Subgroup differences were assessed for the outcomes of preterm birth (<37 weeks of gestation) and SGA/IUGR since these outcomes had enough studies and precision to reasonably support statistical comparisons between groups (Appendix F Figure 3 and Figure 4). These study level comparisons should be interpreted with reservations given the evidence of small-study effects for these outcomes and others, and as the two largest trials started aspirin use later in pregnancy (≥16 weeks of gestation) and used very low aspirin dosages (60mg).

### Aspirin Timing and Dosage

The CLASP trial compared the effect of aspirin (60 mg) initiated at ≤20 weeks versus >20 weeks of gestation for preventing preterm birth, SGA/IUGR, and perinatal mortality and found no statistically significant differences (Appendix F Table 1).^95^ Similarly, no differences were found in the MFMU-HR trial for comparisons of participants initiating aspirin before or after 16 weeks of gestation.^99^

In across study comparisons of subgroup study effects, a comparison of the pooled relative risk of IUGR/SGA between studies with aspirin started before 16 weeks of gestation (pooled RR, 0.59 [95% CI, 0.41, 0.86], I^2^ 35%, k=6, n=2,351) and those where the majority of participants began daily aspirin use later (pooled RR, 0.95 [95% CI, 0.80, 1.13], I^2^ 16%, k=10, n=12,034) was statistically significant (p=0.03) (Figure 5, Appendix F Figure 3). For prevention of preterm birth, there was further evidence that aspirin is more effective if started before 16 weeks of gestation, but only four studies reporting the outcome were in the earlier initiation subgroup; there was a statistically significant difference between the pooled relative risk of preterm birth associated with initiation of aspirin before 16 weeks of gestation (pooled RR, 0.49 [95% CI, 0.26, 0.95], I^2^ 28%, k=4, n=2,103) and the estimate from studies where the majority of participants began aspirin later (pooled RR, 0.91 [95% CI, 0.85, 0.96], I^2^ 0%, k=9, n=11,516) (p=0.02) (Figure 6, Appendix F Figure 4).

Figure 5 Small for Gestational Age and Intrauterine Growth Restriction Stratified by Timing of Aspirin Initiation

Abbreviations: CI = Confidence interval; mg = Milligrams; PE = Preeclampsia; REML = Restricted maximum likelihood; RR = Risk ratio

Figure 5 is a forest plot depicting the relative risk of small for gestational age or intrauterine growth restriction (IUGR) after aspirin prophylaxis, comparing aspirin initiation before and after 16 weeks of gestation. This figure is discussed in the Results section.

Figure 6 Preterm Birth Stratified by Timing of Aspirin Initiation

Abbreviations: CI = Confidence interval; mg = Milligrams; PE = Preeclampsia; REML = Restricted maximum likelihood; RR = Risk ratio

Figure 6 is a forest plot depicting the relative risk for preterm birth after aspirin prophylaxis, comparing aspirin initiation before and after 16 weeks of gestation. This figure is discussed in the Results section.

There was not a statistically significant difference in effectiveness related to the dosage of aspirin used in trials for the SGA/IUGR outcome (Appendix F Figure 3), but for preterm birth, greater risk reductions were seen in trials with dosages greater than 75mg/d (pooled RR, 0.68 [95% CI, 0.52, 0.88], I^2^ 22%, k = 9, n = 3,065) compared to those using lower doses (pooled RR, 0.91 [95% CI .81, 1.02], I^2^ 0%, k = 4, n = 10,554) (Appendix F Figure 4).

Very few studies with large n’s contributed to the estimation of the effect for doses <75 mg/d, however, and it is not possible to determine whether shared study design and population characteristics, account for the association.

### Personal Characteristics and Clinical History

The CLASP trial found no significant difference in the effectiveness of aspirin or preventing perinatal mortality, IUGR, and preterm birth (<37 weeks of gestation) between multiparous and nulliparous study participants. The MFMU-HR trial compared preterm birth and SGA outcomes by BMI and smoking status. Only one of these contrasts was statistically significant—the effectiveness of aspirin (60 mg/day) to prevent preterm birth among nonsmokers (RR 0.91, 95%CI 0.84, 0.99) was greater than for smokers (RR 1.17, 95% CI 0.99, 1.39) (p=0.01) (Appendix F Table 1). The ASPRE trial tested differences in aspirin effectiveness for preventing preeclampsia with preterm birth for several personal characteristic and clinical history factors including maternal age, BMI, racial origin (Afro Caribbean, Caucasian, Other), assisted versus natural conception, smoking status, family history of preeclampsia, parity, and diagnosed chronic hypertension, but did not identify any statistically significant differences. Several of these post-hoc comparisons were limited by relatively small numbers of participants in specific subgroups, and low event rates for this primary outcome resulted in wide confidence intervals.

In study level comparisons, there was a significantly stronger effect of aspirin on prevention of preterm birth in studies in which a majority (more than 50%) of participants were nulliparous than in those in which nulliparous participants were a minority (Appendix F Figure 4). Again, however, few studies were available for comparisons, limiting interpretation of the association.

### Preeclampsia Risk Assessment Approach

Differences among trials in their criteria for identifying populations at increased preeclampsia risk were not associated with differences in the effectiveness of aspirin for prevention of preterm birth or SGA/IUGR. Trials that used risk assessments based on clinical history rather than clinical tests or prediction models were not found to be less effective at identifying a population that benefited from aspirin (Appendix F Figure 3 and Figure 4). There was also no significant difference between effects of aspirin use on prevention of SGA/IUGR or preterm birth in studies that used abnormal Doppler ultrasound as part of the risk assessment with those that did not. There were also no significant differences in the estimated effectiveness of aspirin in studies where more or less than 12 percent of participants in the placebo group developed preeclampsia, although absolute risk reductions were greater when the incidence of preeclampsia in the control group was higher.

## KQ2 Does Aspirin Prevent Preeclampsia in Pregnant Persons at Increased Risk for Preeclampsia?

### Summary of Results

Aspirin use was started as early as 11 weeks of gestation and as late as 32 weeks of gestation at dosages of 50 to 150mg per day in the 16 RCTs (N=15,767) reporting preeclampsia outcomes for pregnant individuals at increased risk. The meta-analysis estimated a statistically significant 15 percent reduced risk of preeclampsia for aspirin treatment relative to placebo. The possibility that this risk reduction is overestimated could not be ruled out. We found evidence of small-study effects that could be due to the absence of smaller studies with null or negative findings in the published literature or differences in the ways smaller studies were conducted (e.g., aspirin protocols, populations enrolled, implementation, study quality). The two largest trials found modest, nonsignificant within study effects of 10 to 12 percent reduced risk of preeclampsia, however, these trials also used lower doses of aspirin than many of the other trials. Across the trials, approaches for identifying individuals at increased risk varied, as did the inclusion and exclusion criteria, generating a broad range of absolute risk reductions. We found no evidence of statistically significant differences in the magnitude of preeclampsia risk reductions related to the timing of treatment initiation; the dosage of aspirin used; or personal characteristics such as smoking history, parity, and BMI, nor were the approaches to assessing preeclampsia risk or the incidence of preeclampsia observed in the study population related to differences in effectiveness.

### Detailed Results

Sixteen included RCTs (N = 15,767) reported on the effectiveness of aspirin to prevent preeclampsia (Table 5, Appendix E Table 8). Across these studies, the incidence of preeclampsia in the placebo condition ranged from 4 to 30 percent, reflecting the broad range of criteria used for identifying increased-risk populations (Table 4). Aspirin was associated with a statistically significant reduction in the risk of preeclampsia compared to placebo (pooled RR, 0.85 [95% CI, 0.75 to 0.95], I^2^ 0%, n = 14,093) (Figure 7). Effects were consistent across the included studies; all but two small studies reported effects in the direction of a treatment benefit.^101,^ ^106^ Of the largest trials, two using 60mg aspirin reported approximately 10 percent risk reductions with confidence intervals that were not statistically significant ^95,^ ^99^ and a more recent large trial using 150mg aspirin showed a statistically significant 28 percent reduction in the risk of preeclampsia.^59^

Figure 7 Preeclampsia, Sorted by Study Size

Abbreviations: CI = Confidence interval; mg = Milligrams; PE = Preeclampsia; REML = Restricted maximum likelihood; RR = Risk ratio

Figure 7 is a forest plot depicting the relative risk for preeclampsia after aspirin prophylaxis and sorted by sample size. This figure is discussed in the Results section.

A test for small-study effects was statistically significant (Peters p = 0.035), suggesting that the pooled effect may overestimate the effectiveness of aspirin for this outcome due to publication bias or differences in the ways smaller studies were conducted. Visual inspection of a funnel plot also showed a tendency for larger studies to report smaller effect sizes. Because random effects meta-analysis models weight smaller studies more heavily, they can exacerbate bias due to small-study effects. Therefore, we conducted sensitivity analyses for the preeclampsia outcome using fixed effects meta-analysis. Unlike the findings for health outcomes, the fixed effects result for preeclampsia was less conservative, estimating 17 percent risk reduction with greater precision than the random effects model. Thus, we did not find evidence that the random effects modeling approach resulted in overestimation of the effect for this outcome, possibly due to the lack of statistical heterogeneity seen for the outcome.

#### Other Hypertensive Disorders of Pregnancy

Half of the studies reporting preeclampsia also reported the effectiveness of aspirin for prevention of gestational hypertension (k=9, N=2,789). Meta-analysis of this outcome showed inconsistency of effects, imprecision, and higher statistical heterogeneity than for more commonly reported outcomes, and could not include the two largest trials; it did not find a significant effect of aspirin use on gestational hypertension (pooled RR 0.74, [95%CI, 0.46, 1.18], I^2^ 51%, k=9, n=2,591) (Appendix E Table 9, Appendix F Figure 2). An analysis of 8 studies where it was possible to combine cases of gestational hypertension with cases of preeclampsia to create a composite outcome measure of hypertensive disorders of pregnancy showed a statistically significant effect of aspirin use (RR 0.65; [95%CI 0.44, 0.96]; I^2^ 59.4%) (data not shown), but the result cannot support strong inferences given the exclusion of the two largest trials from the analysis and substantial clinical and statistical heterogeneity.

## KQ2a Does the Effectiveness of Aspirin for Reducing Preeclampsia Vary by Subpopulations Defined by Personal Characteristics or Preeclampsia Risk Factors?

Valid tests for subgroup differences were available from the two largest trials.^95,^ ^99^ We also conducted subgroup comparisons at the aggregate level using stratified plots and meta-regression.

### Aspirin Timing and Dosage

Both of the largest trials (CLASP and MFMU-HR) reported tests for differences in aspirin effectiveness according to the timing of initiation; however, none of the comparisons were statistically significant (the CLASP trial required a 99% confidence range for tests of subgroup effects to account for multiple comparisons) (Appendix F Table 1).

In aggregate, in subgroup comparisons with the included studies in this review, we did not find an effect of aspirin administration timing on preeclampsia risk. The pooled risk reduction in studies initiating aspirin before 16 weeks of gestation was lower (RR, 0.68 [95%CI, 0.53 to 0.89], I^2^ 0%, k=5, n=2,346) than for studies with later initiation (RR, 0.88 [95% CI, 0.77 to 1.00], I^2^ 0%, k=11, n=11,747) but the difference was not statistically significant (p=0.08) (Figure 8).

Figure 8 Preeclampsia Stratified by Timing of Aspirin Initiation

Abbreviations: CI = Confidence interval; mg = Milligrams; PE = Preeclampsia; REML = Restricted maximum likelihood; RR = Risk ratio

Figure 8 is a forest plot depicting the relative risk for preeclampsia after aspirin prophylaxis, comparing aspirin initiation before and after 16 weeks of gestation. This figure is discussed in the Results section.

There was also not a statistically significant difference in aspirin effectiveness by dosage in aggregate stratified analyses. Preeclampsia risk reduction with ≥75 mg of aspirin (RR, 0.72 [95% CI, 0.56, 0.93]) was slightly greater compared with <75 mg (RR, 0.89 [95% CI, 0.74, 1.07]), but the test for an interaction was not statistically significant (p=0.10) (Appendix F Figure 5). Analyses comparing dosages at or above 100mg to lower dosages also did not yield statistically significant interactions. We also did not find any indication of a dose-response relationship in forest plots sorted by aspirin dosage.

### Personal Characteristics and Clinical History

The CLASP trial found no evidence of differences in effectiveness of aspirin use (60mg) for reducing preeclampsia between nulliparous versus multiparous study participants. Comparisons from the MFMU-HR trial found no evidence of differences in the effectiveness of aspirin for preeclampsia according to BMI (<30 versus ≥30 kg/m^2^) or reported smoking during pregnancy (Appendix F Table 1). Stratified estimates of the effectiveness of aspirin by broad racial categories were conducted in the MFMU-HR trial, but statistical tests for interaction were not conducted; a smaller magnitude risk reduction was reported for “nonWhite” participants but the confidence intervals overlapped for the two strata (data not shown).

Meta-regression comparisons of subgroups of the included studies for this outcome did show a significant difference in aspirin effectiveness associated with the proportion of participants who were nulliparous. The effect size was estimated to be somewhat greater in the studies where more than half of participants were nullipara at increased preeclampsia risk (RR, 0.64 [95% CI, 0.46, 0.89]) compared to those with fewer nullipara (RR, 0.89 [95% CI, 0.80, 0.99]) (p=0.02). (Appendix F Figure 5). Differences in other characteristics of these studies could account for this trend, but there were too few studies included in the review to adjust for potential confounders by including additional covariates in meta-regression.

### Preeclampsia Risk Assessment Approach

We did not observe significant differences in the estimated effectiveness of aspirin for prevention of preeclampsia based on how studies identified an increased-risk population, nor between studies that identified populations where more or less than 12 percent of participants developed preeclampsia (Appendix F Figure 5).

## KQ3 What Are the Harms of Aspirin Use to Prevent Preeclampsia During Pregnancy?

### Summary of Results

Data from 21 trials (N= 26,757) provided evidence on potential harms of daily low dosages of aspirin. The most consistently reported harms outcomes were placental abruption, postpartum hemorrhage, and fetal intracranial bleeding. Other reported perinatal outcomes included cephalohematoma, congenital malformations and anomalies, and respiratory distress syndrome. We did not identify greater risks of placental abruption, postpartum hemorrhage, or fetal intracranial bleeding in participants treated with aspirin than those who were not in pooled analyses, nor were there differences within studies for less commonly reported and more rare perinatal harms. There was no evidence to indicate differences in these risks by the dosage or timing of aspirin used in the studies. Longer-term followup from one large multicenter trial was also reassuring, finding no difference in child developmental harms associated with aspirin for preeclampsia prevention taken during pregnancy. Finally, there were no significant differences found between treatment and control groups for other reported side effects or complications such as NICU admissions, rates of Cesarean deliveries, petechiae, purpura, and other instances of singular adverse events; and aspirin was generally well tolerated.

### Detailed Results

We analyzed data from 21 trials on potential harms of aspirin use throughout pregnancy for the prevention of preeclampsia. Sixteen of the included trials reporting harms outcomes were conducted among pregnant individuals at increased preeclampsia risk and five were among average-risk populations. Daily aspirin doses ranged from 50mg to 150mg per day and start times ranged from 11 to 32 weeks of gestation. Pooled analyses were possible for three reported outcomes related to potential bleeding harms of aspirin use (Table 5).

#### Postpartum Hemorrhage

There was not a statistically significant difference in the risk of postpartum hemorrhage (most commonly defined as ≥ 500 mL blood loss) in 11 trials (N=23,583) randomized to aspirin or placebo (pooled RR 1.03, [95% CI, 0.94, 1.12] I^2^ 0%, k=9, n=23,133). Most large trials consistently reported postpartum hemorrhage as a trial outcome, with the exception of the recent ASPRE trial. There was not a statistically significant difference in the risk of postpartum hemorrhage for average-risk versus increased-risk study populations (p = 0.12) (Figure 10, Table 5, Appendix E Table 10).

Figure 10 Postpartum Hemorrhage Stratified by Risk, Sorted by Study Size

Abbreviations: CI = Confidence interval; mg = Milligrams; PE = Preeclampsia; REML = Restricted maximum likelihood; RR = Risk ratio

*Excluded 2 studies with both arms having zero events.

Figure 10 is a forest plot depicting the relative risk for post-partum hemorrhage after aspirin prophylaxis sorted by sample size, comparing increased and average risk population. This figure is discussed in the Results section.

#### Placental Abruption

Thirteen trials (N=25,761), seven conducted among increased-risk populations and five in average-risk populations, reported placental abruption. Three of the trials reported no cases in either study arm,^93,^ ^94,^ ^98^ and three additional trials reported 2 or fewer cases in one or both study arms.^91,^ ^96,^ ^105^ There was not a statistically significant difference between groups in the risk of abruption in meta-analysis (pooled RR, 1.15 [95% CI, 0.76, 1.72] I^2^ 25%, k=10, n=24,970) and this effect did not differ between studies of average-risk and increased-risk populations (p = 0.41) (Figure 9, Table 5, Appendix E Table 11).

Figure 9 Placental Abruption Stratified by Risk, Sorted by Study Size

Abbreviations: CI = Confidence interval; mg = Milligrams; PE = Preeclampsia; REML = Restricted maximum likelihood; RR = Risk ratio

*Excluded 3 studies with both arms having zero events.

Figure 9 is a forest plot depicting the relative risk for placental abruption after aspirin prophylaxis sorted by sample size, comparing increased and average risk populations. This figure is discussed in the Results section.

#### Infant Bleeding Outcomes

Aspirin was not associated with a difference in the risk of fetal intracranial bleeding (cerebral or intraventricular hemorrhage) in a meta-analysis of nine trials (N=23,959) using daily doses ranging from 60mg to 150mg (pooled RR, 0.90 [95% CI, 0.51, 1.57]; I^2^ 19%, k=6, n=23,719) (Figure 11, Table 5). The outcome is rare—three trials reported one or fewer cases (Appendix E Table 12). Two trials reported cases of cephalohematoma; one small trial reported a single case in the control group^89^ and a larger trial reported more cases in the intervention condition (68/1480, 4.6%) compared to placebo (55/1505, 3.7%); however, the relative risk in the larger trial was imprecise because of the low event rate (RR, 1.26, [95% CI, 0.89, 1.78]).^92^ The same trial reported a composite outcome defined as any infant bleeding disorder, again finding slightly more cases in the aspirin group than the placebo group (7.0% vs. 6.5%) but not a statistically significant difference (RR, 1.08, [95% CI, 0.83, 1.41]).

Figure 11 Fetal Intracranial Bleeding Stratified by Risk, Sorted by Study Size

Abbreviations: CI = Confidence interval; mg = Milligrams; PE = Preeclampsia; REML = Restricted maximum likelihood; RR = Risk ratio

*Excluded 3 studies with both arms having zero events.

Figure 11 is a forest plot depicting the relative risk for fetal intracranial bleeding after aspirin prophylaxis sorted by sample size, comparing increased and average risk population. This figure is discussed in the Results section.

#### Congenital Malformations and Other Infant Outcomes

Four trials reported on congenital anomalies or malformations (N= 2,283), which were very rare (Appendix E Table 12). Three of the trials reported more cases in the placebo group^59,^ ^97,^ ^105^ and one small trial reported a single case of anencephaly that occurred in the aspirin group.^93^ One trial reported cases of respiratory distress syndrome, with more occurring in the placebo group, but there was statistical imprecision in the estimated odds based on the study reported confidence interval estimated for this secondary outcome (aOR 0.53, [99% CI, 0.20, 1.40]).

#### Longer-Term Infant Harms

The CLASP trial conducted followup surveys and reported on longer-term child health outcomes for participants from trial sites in the United Kingdom and Canada. This included developmental outcomes at age 12 months (n=4,168 – United Kingdom followup data) and 18 months (n=4,365 – United Kingdom and Ottawa followup data). The trial found no differences in hospital visits, gross motor development, or height and weight measurements between treatment groups (Appendix E Table 13).

#### Other Maternal and Infant Complications

In addition to the primary, more commonly reported potential harms of aspirin evaluated above, some trials also reported on other adverse events (Appendix E Table 12). For the most part, comparisons between study groups for these outcomes provide assurance of the safety of aspirin during pregnancy. A large trial conducted with an average-risk population using a 75mg/day aspirin dose (n=3647) reported no differences in duration of hospital stay, prenatal hospital admission, blood transfusions, or rates of induced labor between participants taking aspirin than those taking placebo.^100^ Another large trial in an average-risk population using a 60mg/day dose (n=2985) reported similar results, with no significant differences in newborn rates of petechiae, purpura, excessive bleeding with circumcision, or any bleeding disorders between the two study groups.^92^ Further, there were no significant differences in the need for transfusions between those taking aspirin and those taking placebo, and no cases of bleeding complications among women who received aspirin and epidural anesthesia. The MFMU-HR trial (n=2503) reported no differences in a composite measure of any adverse events for mothers or neonates, but provided few details.^99^ In the CLASP trial there were fewer cases of infants admitted to special care units in the treatment group, and the duration of stay was similar between treated and untreated infants. In the aspirin-treated group, however, significantly more women needed a blood transfusion after delivery (4.0% vs. 3.2%, significance test not reported). The higher rate of transfusion was not associated with different rates or severity of postpartum hemorrhage. A few studies reported other potential maternal harms, including premature rupture of membranes and pulmonary embolism, and did not find differences by study group (Appendix E Table 14). However, these studies were underpowered for comparing rare outcomes. Nine other trials^87,^ ^88,^ ^91,^ ^93,^ ^94,^ ^96,^ ^102,^ ^103,^ ^105^ reported comparisons between study groups in the rates of induction of labor, Cesarean deliveries, transfusions, or neonatal admissions, finding no significant differences, with the exception of one study^87^ finding a greater number of Cesarean Sections in the placebo group compared with those taking aspirin, and two studies finding significantly more neonatal admissions in the placebo groups.^93,^ ^103^

#### Treatment Adherence and Reasons for Trial Withdrawals

Participants withdrew from treatment for a variety of reasons. It was common for participants to withdraw due to nonmedical reasons, including relocating, changing their minds about trial participation, or nonadherence to treatment. Adherence, when reported, was generally high, although was reported in a variety of ways. A common reporting measure of adherence in the trials was the number of women who were found to be taking at least 80 percent of their treatment medication; this number ranged from 72 to 88 percent. The mean ‘compliance’ index (number of pills taken/number of days between visits X 100), as well as the median number of pills taken based on pill counts was also reported in select trials and ranged from 94 to 97 percent. Medical reasons for withdrawal included concerns regarding asthma attacks, increased bleeding time, increased activity of aspartate amino transferase in serum, urticaria, and epigastric pain. Women also withdrew from trials after miscarriage or the termination of pregnancy.

## KQ3a Do the Harms of Aspirin Use to Prevent Preeclampsia Vary by Subpopulations Defined by Personal Characteristics or Preeclampsia Risk Factors?

We tested for differences in placental abruption or postpartum hemorrhage by aspirin dosage and timing among the included trials using meta-regression. No differences in harms related to the dosage of aspirin were seen in comparisons that included all trials included for these harms (Appendix F Figure 6 and Figure 7).

When comparing the effect estimates between studies of average-risk and increased-risk study populations, there were no statistically significant differences in estimates of placental abruption (p=0.41), postpartum hemorrhage (p=0.12), or intracranial fetal bleeding (p=0.34), although the effect estimates in the increased-risk population studies were closer to 1 in all cases (Figure 9, Figure 10, Figure 11).