# Chapter 2 Methods

## Scope and Purpose

This systematic review will provide updated evidence regarding the effectiveness of aspirin in reducing adverse maternal, perinatal, and child outcomes, as well as the effectiveness of aspirin in preventing preeclampsia in those at risk. In addition, the harms of aspirin use to prevent preeclampsia will be evaluated. The USPSTF will use this review to update its 2014 recommendation for primary care practices.^69^ This review includes all trials from the previous review^70^ that met current inclusion/exclusion criteria as well as newly identified studies.

## Key Questions and Analytic Framework

We followed USPSTF procedures and methods to define study inclusion and exclusion criteria (Appendix A Table 1) and developed an analytic framework (Figure 1) with three Key Questions (KQs).

Figure 1 Analytic Framework

Figure 1 is an analytic framework that depicts the three Key Questions described in the Methods section of the report. In general, the figure illustrates how the use of aspirin prophylaxis can prevent preeclampsia and related adverse maternal and fetal health outcomes as well as possible harms.

The KQs are:

1. Does aspirin reduce adverse maternal, perinatal, child, or combined health outcomes in pregnant persons at increased risk of preeclampsia?
  a. Does the effectiveness of aspirin for reducing adverse health outcomes vary by subpopulations defined by personal characteristics or preeclampsia risk factors?
2. Does aspirin prevent preeclampsia in pregnant persons at increased risk for preeclampsia?
  a. Does the effectiveness of aspirin for reducing preeclampsia vary by subpopulations defined by personal characteristics or preeclampsia risk factors?
3. What are the harms of aspirin use to prevent preeclampsia during pregnancy?
  a. Do the harms of aspirin use to prevent preeclampsia vary by subpopulations defined by personal characteristics or preeclampsia risk factors?

## Data Sources and Searches

We considered all studies from the previous review^71^ conducted to support the 2014 USPSTF recommendation^72^ on this topic for inclusion in the current review and performed a comprehensive search of MEDLINE, PubMed (publisher-supplied only), Embase, and the Cochrane Collaboration Registry of Controlled Trials for relevant studies published between January 2013 and May 15, 2020. This search was designed to partially overlap with the end search dates of the previous USPSTF-commissioned review of this topic, and to identify new studies. Studies included in the previous USPSTF review were evaluated for inclusion against the inclusion and exclusion criteria for the current review. A research librarian developed and executed the search, which was peer-reviewed by a second research librarian (Appendix A).

We also examined the reference lists of other previously published reviews, meta-analyses, and primary studies to identify additional potential studies for inclusion. We supplemented our searches with suggestions from experts and articles identified through news and table-of-contents alerts. We also searched ClinicalTrials.gov (https://ClinicalTrials.gov/) for ongoing trials (Appendix G). We imported the literature from these sources directly into EndNote® X9 (Thomson Reuters, New York, NY).

## Study Selection

Two reviewers independently reviewed the titles and abstracts of all identified articles to determine whether studies met inclusion and exclusion criteria for design, population, intervention, and outcomes (Appendix A Table 1). Two reviewers then independently evaluated the full-text article(s) of all potentially included studies against the complete inclusion and exclusion criteria. Disagreements regarding the abstract and/or full-text review were resolved by discussion and consultation with a third reviewer if necessary. Excluded studies and reasons for exclusion are listed in Appendix D.

We developed an a priori set of criteria for inclusion and exclusion of studies with input from USPSTF members and based on our understanding of the literature (Appendix A Table 1). For the KQ1 and KQ2 questions of effectiveness, RCTs and individual participant data meta-analyses (IPD-MAs) of pregnant persons at increased risk for preeclampsia were considered for inclusion. Risk of preeclampsia was determined based on personal sociodemographic characteristics, medical history, diagnostic measurements or assays, or risk prediction models. For the KQ3 question evaluating harms, these criteria were expanded to include (1) RCTs conducted in lower or average-risk populations; and (2) comparative observational studies of pregnant persons exposed to aspirin for preeclampsia prevention over the course of pregnancy, as well as their similarly exposed fetuses, infants, and children. Appendix A Table 1 lists all outcomes that were considered for inclusion in the review. Studies limited to persons seeking fertility treatments were not included. Only studies of daily aspirin (≥ 50 mg) for the primary prevention of preeclampsia were considered for inclusion, but studies evaluating nonaspirin antiplatelet medications or aspirin combined with other potentially active interventions (e.g., dietary supplements, weight loss), or studies of aspirin aimed at preventing other complications of pregnancy such as miscarriage, were not. The review was limited to studies conducted in countries with “very high” Human Development Index (2016) scores as published by the United Nations Development Programme.^73^ We also limited our included studies to those published in English and deemed good- or fair-quality based on USPSTF quality rating standards.^74^

## Quality Assessment and Data Abstraction

Two reviewers applied USPSTF design-specific criteria to assess the methodological quality of all eligible studies (Appendix A Table 2). We assigned each study a quality rating of “good,” “fair,” or “poor.” Discordant quality ratings were resolved by discussion or adjudicated by a third reviewer as needed. Studies rated as poor quality were excluded from the review.

Good-quality RCTs were those that met all or nearly all of the specified quality criteria (e.g., comparable groups were assembled initially and maintained throughout the study, followup was 90% or higher, assessment procedures were described and blinded if they involved direct interviews, randomization methods were described, allocation was concealed). Fair-quality studies did not meet all criteria but did not have serious threats to their internal validity related to design, execution, or reporting. Intervention studies rated as poor quality generally had several important limitations, including at least one of the following risks of bias: very high attrition (generally > 40%); differential attrition between intervention arms (generally > 20%); lack of baseline comparability between groups without adjustment; or problematic issues in trial conduct, analysis, or reporting of results (e.g., possible selective reporting; inappropriate exclusion of participants from analyses; questionable validity of allocation or assessment procedures).

For all of the included studies, one reviewer extracted key elements into standardized abstraction forms in DistillerSR (Evidence Partners, Ottawa, Canada). Key elements included general characteristics of the study (e.g., author, year, study design), clinical and demographic characteristics of the sample and setting (e.g., age, race/ethnicity, baseline clinical characteristics, setting, country), analytic methods, and results. A second reviewer checked the data for accuracy.

When abstracting reported data on health outcomes, we included the number of participants experiencing an event, as well as incidence rates, as appropriate. For KQ1, we abstracted the following maternal health outcomes: eclampsia, puerperal cerebrovascular disorder, cerebrovascular hemorrhage, edema, or embolus; renal or hepatic injury/failure; pulmonary edema; mortality; mental health diagnoses or symptoms; and any reported measures of well-being. Fetal, neonatal, and child health outcomes included preterm delivery; mean gestational age; low birth weight; intrauterine growth restriction/small for gestational age; and stillbirth or neonatal mortality. The study defined definitions of outcomes were described and the most commonly reported were combined for meta-analysis. Where available, we aimed to abstract information on the number of early and very early preterm births, and separate cases of spontaneous from induced preterm birth. For KQ2 (preeclampsia prevention effectiveness), we abstracted the incidence of preeclampsia reported in each RCT. For KQ 3 (harms of aspirin use for preeclampsia prevention), we abstracted reports of abruptio placentae, intracranial fetal bleeding, postpartum hemorrhage or estimated blood loss, and any other major harm to the mother or fetus reported.

## Data Synthesis and Analysis

This review was conducted in accordance with current USPSTF procedures and systematic review methods.^74^ Tables describing key study design and participant characteristics were created. Pooled effect estimates of the relative risks of health outcomes associated with aspirin use were generated using random effects model with restricted maximum likelihood (REML) and Knapp-Hartung adjustment methods.^75,^ ^76^ This analytic approach overcomes limitations of other estimators for tau-square that have been found to generate overly precise confidence limits, especially when pooling fewer than 20 studies.^77^ For rare outcomes (i.e., perinatal mortality) we conducted sensitivity analyses using the Peto odds ratio method,^78^ as well as pooled analyses including and excluding studies that had no events in either study arm, to assess the robustness of the final RR pooled estimates.^79^ We identified study design and participant characteristics that could possibly explain heterogeneity in aspirin effectiveness among the included studies. To examine subgroup differences, we generated stratified forest plots using the Cochran Q statistical test for interaction and conducted REML meta-regression analyses using the Knapp Hartung correction. Variables anticipated a priori to be potential sources of heterogeneity included aspirin dosage, timing, and duration; population risk characteristics (e.g., incidence of preeclampsia in the control condition, strategy for selecting participants); study size; and control condition (i.e., placebo versus no treatment). We defined comparison groups based on clinically meaningful distinctions. For comparisons of effects by population risk of preeclampsia, we compared studies where more than 12 percent of participants developed preeclampsia in the control group to studies with lower incidence rates. This threshold was selected to distinguish trials with approximately 3 times incidence seen in the general population. We also compared studies that used a Doppler ultrasound test as part of the risk assessment procedure with those that did not, and studies that used any lab or imaging tests compared to those relying only on clinical history and exams. For each KQ, the statistical heterogeneity of included studies was estimated with I^2^ statistics and Tau^2^. The distribution of trial results was examined with funnel plots and Peters tests to assess whether there was evidence of small-study effects.^80–82^

In accordance with published methodological guidance on evaluating subgroup effects within trials,^83^ we abstracted the results of within study differences to support inferences related to subgroup effects only if statistically valid tests for interaction were reported.

For each outcome measure, we calculated the number needed to treat (NNT) by first estimating the absolute risk reduction based on the pooled risk ratio and two to three estimated levels of baseline risk of the outcome of interest (i.e., absolute risk reduction=(risk ratio-1)*population risk). Because there was a wide range of risks for some of the outcomes (preeclampsia, SGA/IUGR, preterm birth), we selected population risk levels empirically using the included studies corresponding to the 20th, 50th, and 80th percentiles of outcome incidence in the control arm of the trials. For perinatal mortality we used the lowest and highest incidence levels reported in trials included in the pooled analysis for this outcome. From the absolute risk reduction for every level of baseline risk tested, we calculated the NNT as the inverse of the absolute risk ratio.^84^

We used Stata version 16.1 (StataCorp LP, College Station, TX) for all analyses. All significance testing was two-sided, and results were considered statistically significant if the p-value was 0.05 or less.

## Grading the Strength of the Body of Evidence

The strength of the overall body of evidence for each KQ was graded using an adaptation of the Evidence-based Practice Center approach,^85^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^86^ This adaptation explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations, risk of bias). We do not evaluate the fifth domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there was insufficient evidence for a particular outcome). Study quality summarizes the quality ratings of the individual trials included for an outcome and indicates the degree to which the results are likely to have adequately low risk of bias. The limitations domain highlighted important restrictions in answering the overall KQ (e.g., lack of replication of interventions, nonreporting of outcomes important to patients).

The overall strength of evidence was graded as “high,” “moderate,” “low,” or “insufficient.” “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. At least two independent reviewers rated the overall strength of evidence for each intervention type. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

A draft Research Plan for this review was posted for public comment on the USPSTF website from June 20 to July 23, 2019. Several minor additions and wording changes were made to improve the clarity and specificity of the inclusion criteria. Additional clinically important categories used for defining preeclampsia and preterm birth were included to more fully represent health outcomes that may be reported in the literature. A final research plan was posted on the USPSTF website on September 26, 2019.

A draft version of this report was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report when appropriate. Additionally, a draft of the report was posted for public comment on the USPSTF Web site from February 23, 2021 through March 23, 2021. The draft received very few comments, leading to small editorial changes but no updates to the included evidence or our conclusions.

## USPSTF Involvement

We worked with four USPSTF members at key points throughout this review, particularly when determining the scope and methods for the review and when developing the Analytic Framework and Key Questions. After revisions reflecting the public comment period, the USPSTF members approved the final analytic framework, KQs, and inclusion and exclusion criteria. AHRQ funded this review under a contract to support the work of the USPSTF. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.