# Appendix G Ongoing Studies

Trial identifier | Study name | Location | Estimated N and Age range | Interventions | Outcome Measures | Status
NCT03735433 | The Effect of Two Aspirin Dosing Strategies for Obese Women at High Risk for Preeclampsia | USA | 400; 18-45 years | ASA, 81 mg vs. ASA, 162 mg | Incidence of Diagnosis of preeclampsia \| Incidence of aspirin resistance based on incomplete inhibition of TBx2 | Recruiting; Start date: Jan 2019; Est completion date: Jan 2020
NCT03961360 | Effectiveness of Higher Aspirin Dosing for Prevention of Preeclampsia in High Risk Obese Gravida (ASPREO) | USA | 220; 18-45 years | ASA, 181 mg vs. ASA, 162 mg | Preeclampsia diagnosis \| Maternal Outcomes-Incidence of preterm preeclampsia \| Maternal Outcomes-Gestational Hypertension \| Maternal Outcomes-Placenta Abruption \| Maternal Outcomes-Eclampsia \| Maternal Outcomes-HELLP syndrome \| Maternal Outcomes-Postpartum Hemorrhage \| Maternal Outcomes-Other maternal bleeding \| Maternal Outcomes-Need for blood transfusion \| Neonatal Outcomes- Gestational age at delivery \| Neonatal Outcomes-Delivery at < 37 weeks \| Neonatal Outcomes-Apgar score at 5 min ≤ 5 \| Neonatal Outcomes-Small for gestational age \| Neonatal Outcomes-Neonatal Intensive Care Unit (NICU) length of stay \| Neonatal Outcomes-Intraventricular Hemorrhage Grade III-IV \| Neonatal Outcomes-Bronchopulmonary Dysplasia \| Neonatal Outcomes-Necrotizing Enterocolitis | Recruiting; Start date: May 2019; Est completion date: May 2020
NCT03893630 | Role of ASpirin in Placental and Maternal Endothelial Cell Regulation IN Pre-eclampsia (ASPERIN) | USA | 150; 18-45 years | ASA, 81 mg vs. ASA, 162 mg vs. Standard of care | Change in Pulsatility Index (PI) \| Onset of Pre-eclampsia \| Severity of Pre-eclampsia \| Composite Neonatal outcomes including frequency of Intraventricular hemorrhage (IVH), Bronchopulmonary dysplasia (BPD), Respiratory distress syndrome (RDS), Necrotizing enterocolitis(NEC) \| Change in s-ICAM levels over time \| Change in PIGF levels over time \| Change in CRP levels over time \| Change in IL-6 over time \| Change in TNF over time | Recruiting; Start date: April 2019; Est completion date: June 2020
NCT03574909 | IRELAnD: Investigating the Role of Early Low-dose Aspirin in Diabetes (IRELAnD) | Ireland | 300; 18 years or older | ASA, 150 mg vs placebo | Preeclampsia \| Birth weight \| Preterm birth \| Perinatal mortality \| Parameters of neonatal morbidity: Gestational age at delivery \| Parameters of neonatal morbidity: Birth weight \| Parameters of neonatal morbidity: NICU admission \| Respiratory morbidity: Duration of invasive ventilation \| Duration of O2 \| Duration of hospital stay \| Use of nitric oxide \| Number and type of inotropes \| Duration of inotrope use \| Apgar score \| Umbilical artery acidosis at birth \| Intracranial hemorrhage \| Culture-proven sepsis \| Necrotizing enterocolitis \| Hypoxic ischemic encephalopathy \| Shoulder dystocia \| Composite measure of Maternal outcomes not directly related to primary outcome \| Hemorrhage \| Sepsis | Not yet recruiting; Start date: Sept 2018; Est completion date: Sept 2021
NCT04158830 | Aspirin (ASA) Therapy and Preeclampsia Prevention | USA | 900; 14-50 years | ASA, 81 mg vs. 2 × ASA, 81 mg | Preeclampsia | Not yet recruiting; Start date: Dec 2019; Est completion date: Nov 2021
NCT04070573 | Low Doses of Aspirin in the Prevention of Preeclampsia (ASAPP) | USA | 400; 18-60 years | ASA, 81 mg vs. ASA, 162 mg | Incidence of preterm (<37 weeks) preeclampsia \| Incidence of preeclampsia with severe features \| Aspirin adherence \| Maternal and Fetal Outcomes \| Time-to-event for preeclampsia \| Aspirin compliance \| Impact of co-morbidities on incidence of preeclampsia | Recruiting; Start date: Oct 2019; Est completion date: Aug 2024