# Appendix F Evidence Tables

Appendix F Table 1 Within Trial Subgroup Differences in Aspirin Effectiveness Based on Reported Tests for Interaction

Appendix F Figure 1 Pooled Estimate of Mean Birthweight, Grams

Abbreviations: CI = Confidence interval; mg = Milligrams; PreE = Preeclampsia; n = Sample size; NR = Not reported; SD = Standard deviation; WMD = Weighted mean difference

Appendix F Figure 1 is a forest plot depicting the pooled analysis of mean birth weight after aspirin prophylaxis and sorted by sample size. This figure is discussed in the Results section.

Appendix F Figure 2 Gestational Hypertension, Sorted by Study Size

Abbreviations: CI = Confidence interval; mg = Milligrams; PreE = Preeclampsia; NR = Not reported; RR = Risk ratio

Appendix F Figure 2 is a forest plot depicting the relative risk for gestational hypertension after aspirin prophylaxis and sorted by sample size. This figure is discussed in the Results section.

Appendix F Figure 3 Subgroup Analyses of Aspirin Effectiveness Comparisons for Dosage, Timing, Study Design, and Population Characteristics on Small for Gestational Age or Intrauterine Growth Restriction

Abbreviations: CI = Confidence interval; K = Number of studies; mg = milligrams; N = Number of observations; RR= Relative Risk

Appendix F Figure 3 is a forest plot of multiple subgroup analyses on small for gestational age or intrauterine growth restriction (IUGR) summarizing the estimated effects within various characteristics: daily aspirin dose, gestation of aspirin initiation, sample size, nulliparity, preeclampsia incidence in control arm, and risk assessment types. The plot displays the number of studies and sample size within each subgroup, the plot of effect sizes and their 95% confidence intervals and the p-values of the corresponding significance tests. The test of between-group differences for each characteristic is based on the Qb-value (an extension of Cochran’s Q statistics).

Appendix F Figure 4 Subgroup Analyses of Aspirin Effectiveness Comparisons for Dosage, Timing, Study Design, and Population Characteristics on Preterm Delivery

Abbreviations: CI = Confidence interval; K = Number of studies; mg = milligrams; N = Number of observations; RR= Relative Risk

Appendix F Figure 4 is a forest plot of multiple subgroup analyses on preterm delivery summarizing the estimated effects within various characteristics: daily aspirin dose, gestation of aspirin initiation, sample size, nulliparity, preeclampsia incidence in control arm, and risk assessment types. The plot displays the number of studies and sample size within each subgroup, the plot of effect sizes and their 95% confidence intervals and the p-values of the corresponding significance tests. The test of between-group differences for each characteristic is based on the Qb-value (an extension of Cochran’s Q statistics).

Appendix F Figure 5 Subgroup Analyses of Aspirin Effectiveness Comparisons for Dosage, Timing, Study Design, and Population Characteristics on Preeclampsia

Abbreviations: CI = Confidence interval; K = Number of studies; mg = milligrams; N = Number of observations; RR= Relative Risk

Appendix F Figure 5 is a forest plot of multiple subgroup analyses on preeclampsia summarizing the estimated effects within various characteristics: daily aspirin dose, gestation of aspirin initiation, sample size, nulliparity, preeclampsia incidence in control arm, and risk assessment types. The plot displays the number of studies and sample size within each subgroup, the plot of effect sizes and their 95% confidence intervals and the p-values of the corresponding significance tests. The test of between-group differences for each characteristic is based on the Qb-value (an extension of Cochran’s Q statistics).

Appendix F Figure 6 Subgroup Analyses of Aspirin Effectiveness Comparisons for Dosage and Timing on Placental Abruption^*^ * Excluded 3 studies with both groups having zero events

Abbreviations: CI = Confidence interval; k = Number of studies; mg = milligrams; N = Number of observations; RR= Relative Risk

Appendix F Figure 6 is a forest plot of multiple subgroup analyses on placental abruption summarizing the estimated effects of daily aspirin dose and gestation of aspirin initiation. The plot displays the number of studies and sample size within each subgroup, the plot of effect sizes and their 95% confidence intervals and the p-values of the corresponding significance tests. The test of between-group differences for each characteristic is based on the Qb-value (an extension of Cochran’s Q statistics).

Appendix F Figure 7 Subgroup Analyses of Aspirin Effectiveness Comparisons for Dosage and Timing on Postpartum Hemorrhage^*^ * Excluded 2 studies with both groups having zero events

Abbreviations: CI = Confidence interval; k = Number of studies; mg = milligrams; N = Number of observations; RR= Relative Risk

Appendix F Figure 7 is a forest plot of multiple subgroup analyses on postpartum hemorrhage summarizing the estimated effects of daily aspirin dose and gestation of aspirin initiation. The plot displays the number of studies and sample size within each subgroup, the plot of effect sizes and their 95% confidence intervals and the p-values of the corresponding significance tests. The test of between-group differences for each characteristic is based on the Qb-value (an extension of Cochran’s Q statistics).