# Appendix E Detailed Tables

Appendix E Table 1 Study Population Baseline Characteristics of Included Studies

Author, year; Quality | Included populations | Excluded populations | Mean age (range) | Race/ethnicity, % | Mean BMI, kg/m2 | Nulliparous % | Smoking, % | Other health behaviors and conditions, %
ASPRE, 2017^59^; Good | Aged 18 years or more, singleton pregnancy, live fetus at the time that scanning was performed at 11 to 13 weeks’ gestation, high risk (>1 in 100) for preterm preeclampsia according to the screening algorithm | Unconscious or severely ill status, learning difficulties or serious mental illness, major fetal abnormality identified at the time that scanning was performed at 11 to 13 weeks of gestation, regular treatment with aspirin within 28 days before screening, bleeding disorder such as von Willebrand’s disease, peptic ulceration, hypersensitivity to aspirin, long-term use of nonsteroidal anti-inflammatory medication, and participation in another drug trial within 28 days before screening | 31.5^*^ | White: 67.1; Black: 25.2; Asian: 6.4; Other: 1.3 | IG: 26.7; CG: 26.5 | IG: 68.5; CG: 66.1 | IG: 7.1; CG: 7.2 | Previous PreE; IG: 10.9; CG: 10.2; Chronic HTN; IG: 6.1; CG: 7.4; Chronic DM; IG: 1.9; CG: 1.2
Ayala, 2012^57^; Good | Higher risk for gestational HTN or preeclampsia, receiving medical care and follow-up at the Obstetric Physiopathology service (high-risk unit) of the hospital, ≤16 weeks’ gestation, maternal age ≥18 years | Multiple pregnancy, chronic HTN or any other condition requiring the use of BP-lowering medication, cardiovascular disorders (unstable angina pectoris, heart failure, life-threatening arrhythmia, atrial fibrillation, kidney failure, and grade III–IV retinopathy), chronic liver disease, any disease requiring the use of anti-inflammatory medication, DM or any other endocrine disease such as hyperthyroidism, history of drug/alcohol abuse, night/ shiftwork employment, AIDS, intolerance to ABPM, and inability to communicate and comply with all of the study requirements | 30.7 | NR | IG: 25.4; CG: 25.5 | IG: 49.4; CG: 55.1 | NR | NR
Benigni, 1989^88^; Fair | At high risk of pregnancy-induced HTN, with HTN, or previous obstetrical history (fetal death due to placental insufficiency, severe IUGR, early onset PreE [<32 weeks]) | Women with antiphospholipid antibodies (lupus-like, anticoagulant, anticardiolipin antibodies) | 31.5 | NR | NR | NR | IG: 6.3; CG: 0 | Previous PreE; IG: 50; CG: 35; Chronic HTN; IG: 35.2; CG: 31.3
Caspi, 1994^94^; Good | Uncomplicated twin pregnancies | Chronic renal, cardiovascular, pulmonary or hepatic disorders, pastor present coagulopathy or peptic ulcer, gestational DM and known hypersensitivity to aspirin | 28.3 | NR | NR | IG: 41.6; CG: 30.4 | NR | Chronic HTN; IG: 1.0; CG: 3.0; Multifetal Gestation; IG: 100; CG: 100
CLASP, 1994^95^; Good | 12 to 32 weeks’ gestation, at sufficient risk of developing preeclampsia or IUGR for the use of low-dose aspirin to be considered; risk factors for prophylactic aspirin use defined as history of preeclampsia or IUGR in previous pregnancy, chronic HTN, renal disease, maternal age, family history, or multiple pregnancy; or, for therapeutic use, women with signs or symptoms of preeclampsia or IUGR in current pregnancy | Increased risk of bleeding, asthma, allergy to aspirin, or a high likelihood of immediate delivery | 28.5 | NR | NR | IG: 27.9; CG: 27.9 | IG: 20.7; CG: 20.1 | Chronic HTN; IG: 19.9; CG: 20.2; Chronic DM; IG: 2.7; CG: 3.1
Davies, 1995^96^; Fair | No previous pregnancy beyond 12 weeks’ gestation, 12 to 19 weeks’ gestation, hemoglobin concentrate > 13.2 g/dL, DBP <90 mmHg, no proteinuria at time of randomization | Multiple pregnancy, DM, recurrent spontaneous abortions, or any contraindication to aspirin therapy | 25.0 | White: 95.8 | NR | IG: 100; CG: 100 | IG: 10.3; CG: 13.3 | Previous PreE; IG: 0; CG: 0; Chronic HTN; IG: 0; CG: 0; Chronic DM; IG: 0; CG: 0; Multifetal Gestation; IG: 0; CG: 0
Gallery, 1997^97^; Fair | <16 weeks’ gestation, at high risk of developing preeclampsia | Women with a history of aspirin allergy, aspirin-sensitive asthma, or preexisting bleeding diathesis | 28.5 (22-38) | White: 95.5 | NR | IG: 42.0; CG: 43.0 | NR | Previous PreE; IG: 17.0; CG: 22.0; Chronic HTN; IG: 57.0; CG: 52.0
Grab, 2000^101^; Fair | Singleton pregnancies, <20 weeks’ gestation with early IUGR, impaired uteroplacental blood, chronic HTN, history of still birth, growth restriction, or preeclampsia | DM, preexisting proteinuric HTN, fetal malformations, or chromosome abnormalities | NR | NR | NR | NR | NR | Previous PreE; IG: 40.9; CG: 42.9; Chronic HTN; IG: 50.0; CG: 38.1; Multifetal Gestation; IG: 0; CG: 0
Hauth, 1993^91^; Good | Nulliparous, age 28 years or younger, no later than 22 weeks of gestation | History of illness or conditions known to increase the incidence of PreE or PIH (i.e. renal disease, collagen vascular disease, DM, multifetal gestation, chronic HTN), failed “run-in” test for compliance | 20.4 | White: 28.5; Black: 71.5 | NR | IG: 100; CG: 100 | NR | Chronic HTN; IG: 0; CG: 0; Chronic DM; IG: 0; CG: 0
Hermida, 1997^98^; Good | Absence of any condition requiring the use of antihypertensive medication, maternal age 18 to 40 years, <16 weeks’ gestation. | Multiple pregnancy, chronic HTN, chronic liver disease, any disease requiring the use of anti-inflammatory medication, DM, or any other endocrine disease such as hyperthyroidism, intolerance to the use of ambulatory BP monitor, among others | 30.2 | White: 100 | IG: 25.3; CG: 24.9 | NR | NR | Multifetal Gestation; IG: 0; CG: 0
McParland, 1990^90^; Fair | Nulliparous, persistent abnormal Doppler flow-velocity waveforms | Known ASA allergy, maternal DM, bleeding disorders, peptic ulceration, systemic lupus erythematosus | 26.1 | White: 69.0; Black: 20.0; Asian: 7.0; Other: 4.0 | IG: 24.1; CG: 24.6 | IG: 100; CG: 100 | IG: 16; CG: 23 | NR
MFMU-HR, 1998^99^; Good | One of four high risk groups: DM, chronic HTN, multifetal gestation, or previous preeclampsia | Multifetal gestation in combination with DM, HTN, or proteinuria, history of PreE, current proteinuria | 26.5 | White: 32.7; Black: 56.3; Hisp: 10.8; Other: 0.5 | NR | NR | IG: 16.8; CG: 16.4 | NR
Mone, 2018^105^; Fair | Nulliparous, aged 18 years or older, 11 to 13 weeks’ gestation, viable singleton pregnancy, did not meet criteria for taking aspirin based upon major preeclampsia risk factors (chronic kidney disease, autoimmune disease, DM, and chronic HTN) | Participants already taking part in a clinical trial, coexistence of a fetal congenital anomaly at recruitment, aspirin hypersensitivity | 33.5 (19-44) | White: 96.8; Black: 0.8; Asian: 2.4 | IG: 25.2; CG: 22.9 | IG: 100; CG: 100 | IG: 9.2; CG: 5.9 | Chronic HTN; IG: 0; CG: 0; Chronic DM; IG: 0; CG: 0
Morris, 1996^107^ | Nulliparous with abnormal uterine artery waveforms at 18 weeks’ gestation | Pregnancies dated at less than 17 weeks’ or more than 19 weeks’ of gestation | 23.8 | NR | NR | IG: 100; CG: 100 | NR | NR
Rotchell, 1998^100^; Good | 12 to 32 weeks’ gestation without contraindications | Increased risk of bleeding, known allergy to aspirin, high likelihood of immediate delivery or previous placental abruption | NR | NR | NR | IG: 44.0; CG: 44.0 | NR | Chronic HTN; IG: 0.44; CG: 0.44; Chronic DM; IG: 0.71; CG: 0.44; Gestational DM; IG: NR; CG: NR; Multifetal Gestation; IG: 0.82; CG: 1.0
Scazzocchio, 2017^106^; Good | Aged 18 years or older, singleton pregnancy, 11 to 14 weeks’ gestation, crown-rump length of 45 to 84 mm, mean UtA pulsatility index > 95th percentile | Preexisting HTN, immune, renal, or cardiovascular disease, history of preeclampsia in a previous pregnancy, history of gastric ulcer, known allergy or hypersensitivity to aspirin, hemorrhagic disease, fetal malformation (including chromosomopathy), active treatment with heparin or aspirin before recruitment, multifetal gestation, maternal age <18 years | 32.9 | NR | IG: 23.5; CG: 23.5 | IG: 62.5; CG: 64.0 | IG: 11.3; CG: 12.0 | Previous PreE; IG: 0; CG: 0; Chronic HTN; IG: 0; CG: 0
Schiff, 1989^89^; Good | At least one of the following risk factors: nulliparity, twin gestation, history of PreE; had to screen positive during a roll-over test (which tested BP before & after rolling from the left side to back) | History of chronic HTN, long-term treatment with nonsteroidal anti-inflammatory drugs or the use of these drugs in the previous 6 weeks, PIH detected prior to screening, proteinuria detected before screening, history of thrombocytopenia, coagulation disorders, heart failure, chronic renal or pulmonary disease, hepatic or peptic ulcer disease, history of hypersensitivity to ASA | 27.4 | White: 100 | NR | NR | NR | Previous PreE; IG: 17.6; CG: 16.1; Chronic HTN; IG: 0; CG: 0; Multifetal Gestation; IG: 8.8; CG: 6.5
MFMU-LR, 1993^92^; Good | Nulliparous, 13 to 25 weeks’ gestation, BP <135/85 mmHg, no proteinuria | History of chronic HTN, renal disease, DM, or other medical illnesses | 20.5 | White: 17.9; Black: 49.8; Hisp: 31.6 | NR | IG: 100; CG: 100 | IG: 11.5; CG: 10.7 | Chronic HTN; IG: 0; CG: 0; Chronic DM; IG: 0; CG: 0; Multifetal Gestation; IG: 1.3; CG: 1.2
Subtil, 2003^102^; Good | Nulliparous (no previous delivery at or after 22 weeks’ gestation), 14 to 20 weeks’ gestation, planned to continue prenatal care and give birth in the participating facility, provided written informed consent | History of HTN, potential indication (antiphospholipid antibodies, lupus) for or a contraindication (allergy, frequent hematomas or bleeding, history of hemorrhage during surgery, tooth extraction or other, recent gastric or duodenal ulcer, severe asthma) to aspirin or other anticoagulant treatment during this pregnancy | 24.7 | NR | IG: 22.5; CG: 22.3 | IG: 100; CG: 100 | IG: 25.0; CG: 24.9 | Chronic HTN; IG: 0; CG: 0; Multifetal Gestation; IG: 1.2; CG: 1.6
Viinikka, 1993^93^; Fair | At risk of developing preeclampsia, defined as having arterial HTN (BP without treatment >140/90 mmHG already before pregnancy), or having severe preeclampsia in a previous pregnancy | None | 33.0 | NR | NR | IG: 25.2; CG: 23.8 | NR | Previous PreE; IG: 13.6; CG: 8.6; Chronic HTN; IG: 86.4; CG: 91.4
Villa, 2012^104^; Fair | Presenting with at least one of the following risk factors: <20 years of age, >40 years of age, BMI >30, chronic HTN (> or equal to 140/90 mmHg or medication for HTN before 20 weeks’ gestation), Sjorgren’s syndrome, lupus, or history of one of the following: gestational DM, PreE, SGA, fetus mortus (fetal death after 22 weeks’ gestation or >500 g weight in a previous pregnancy), and transvaginal color doppler ultrasound at all patients from 12 +0 weeks to 13 +6 weeks’ gestation, second degree diastolic notch present eligible for randomization | Allergy to aspirin, tobacco smoking during this pregnancy, multiple pregnancy, history of one or more of the following: asthma, peptic ulcer, placental ablation, inflammatory bowel diseases, rheumatoid arthritis, hemophilia or thrombophilia | 30.9 (20-40) | NR | IG: 27.9; CG: 29.7 | IG: 26.2; CG: 15.0 | IG: 0; CG: 0 | Previous PreE; IG: 32.8; CG: 28.3; Chronic HTN; IG: 13.1; CG: 20.0; Gestational DM; IG: 6.6; CG: 16.7
Wallenburg, 1986^87^; Good | Healthy, nulliparous, uncomplicated pregnancy of 26 weeks’ duration, maximum diastolic blood pressure of 80mmHg, positive angiotensin II sensitivity test | History of HTN or cardiovascular renal disease | 24 (17-38) | NR | NR | IG: 100; CG: 100 | IG: 21.7; CG: 17.4 | Previous PreE; IG: 0; CG: 0; Chronic HTN; IG: 0; CG: 0; Gestational HTN; IG: 0; CG: 0
Yu, 2003^103^; Good | Mean PI above 1.6, early diastolic notching of uterine arteries identified by transvaginal color Doppler ultrasound | Pre-existing HTN, renal, or cardiovascular disease, DM, bleeding disorders, systemic lupus erythematosus, peptic ulceration, hypersensitivity to aspirin, and the finding at the 23-week scan of a fetal abnormality or fetal growth restriction | 29^*^ (23-33) | White: 62.3; Black: 27.6; Other: 10.1 | IG: 25.0; CG: 25.6 | IG: 26.8; CG: 23.4 | IG: 9.4; CG: 9.7 | Previous PreE; IG: 11.2; CG: 8.6; Chronic HTN; IG: 0; CG: 0; Chronic DM; IG: 0; CG: 0

Abbreviations: ABPM = Ambulatory blood pressure monitoring; AIDS = Acquired immunodeficiency syndrome; ASA = Acetylsalicylic acid; CG = Control group; DBP = Diastolic blood pressure; DM = Diabetes mellitus; Hisp = Hispanic; HTN = Hypertension; IG = Intervention group; IUGR = Intrauterine growth restriction; NR = Not reported; PreE = Preeclampsia; PI = pulsatility index; PIH = Pregnancy-induced hypertension; SGA = Small for gestational age

* Median

Appendix E Table 2 Maternal Health Outcomes, Increased Risk Population

Author, year | Outcome | Outcome definition | IG n/N (%) | CG n/N (%) | Effect (95%CI)^*^
CLASP, 1994^95^ | Eclampsia | NR | 7/4,659^†^ (0.2) | 7/4,650 (0.2) | -
Morris, 1996^107^ | Eclampsia | Severe HTN developed postnatally associated with abnormal renal function and hyperuricemia, culminating in a generalized convulsion 6 days after delivery | 1/52 (1.9) | 0/50 (0.0) | -
Wallenburg, 1986^87^ | Eclampsia | NR | 0/21 (0) | 1/23 (4.3) | -
Villa, 2012^104^ | HELLP Syndrome | Hemolysis, elevated liver enzymes, and low platelets | 0/61 (0) | 1/60 (0.02) | -
Scazzacchio, 2017^106^ | Incomplete HELLP syndrome^‡^ | NR | NR | NR | -

Abbreviations: CG = Control group; CI = Confidence interval; CLASP = Collaborative Low-dose Aspirin Study in Pregnancy; HELLP = Hemolysis, elevated liver enzymes, low platelet count; IG = Intervention group, NR = Not reported

* Dash symbol (“-“) indicates insufficient data to calculate effect

† All pregnancies with data

‡ One participant in each study group developed severe preeclampsia; one with severe hypertension and the other with incomplete HELLP syndrome; authors do not specify to which study group these participants belong

Appendix E Table 3 Effect of Aspirin on Perinatal Mortality, Increased Risk Population

Author, year | Outcome definition | IG n/N (%) | CG n/N (%) | Effect
ASPRE, 2017^59^ | Perinatal mortality without preeclampsia | 8/798 (1.0) | 14/822 (1.7) | OR^*^: 0.59 (99% CI: 0.19 to 1.85)
Ayala, 2012^57^ | Perinatal mortality | 2/176 (1.1) | 5/174 (2.9) | RR^†^: 0.40 (95% CI: 0.08 to 2.01)
Benigni, 1989^88^ | Perinatal mortality | 0/17 (0.0) | 1/16 (6.3) | RR^†^: 0.31 (95% CI: 0.01 to 7.21)
Caspi, 1994^94^ | Perinatal mortality | 2/48 (4.2) | 2/46 (4.3) | RR^†^: 0.96 (95% CI: 0.14 to 6.52)
CLASP, 1994^95^ | Stillbirths included all intrauterine deaths at or after 24 weeks, and neonatal deaths included all deaths after birth up to the age of 28 days. | 77/4123 (1.9) | 97/4134 (2.3) | RR^†^: 0.80 (95% CI: 0.59 to 1.07)
Davies, 1995^96^ | Perinatal mortality | 0/58 (0.0) | 0/60 (0.0) | RR^†^,^‡^: 1.03 (95% CI: 0.02 to 51.26)
Gallery, 1997^97^ | Perinatal mortality | 4/58 (6.9) | 2/50 (4.0) | RR^†^: 1.72 (95% CI: 0.33 to 9.02)
Hermida, 1997^98^ | Perinatal mortality | 0/50 (0.0) | 0/50 (0.0) | RR^†^,^‡^: 1.00 (95% CI: 0.02 to 49.44)
McParland, 1990^90^ | Perinatal mortality | 1/48 (2.1) | 3/52 (5.8) | RR^†^: 0.36 (95% CI: 0.04 to 3.35)
MFMU-HR, 1998^99^ | Perinatal mortality | 43/1254 (3.4) | 56/1249 (4.5) | RR: 0.80 (95% CI: 0.50 to 1.10)
Morris, 1996^107^ | Perinatal mortality | 0/52 (0.0) | 0/50 (0.0) | NR
Schiff, 1989^89^ | Perinatal mortality | 0/34 (0.0) | 0/32 (0.0) | RR^†^,^‡^: 0.94 (95% CI: 0.02 to 46.16)
Viinikka, 1993^93^ | Perinatal mortality | 2/97 (2.1) | 0/100 (0.0) | RR^†^: 5.15 (95% CI: 0.25 to 105.98)
Wallenburg, 1986^87^ | Perinatal mortality | 1/21 (4.8) | 1/23 (4.3) | RR^†^: 1.10 (95% CI: 0.07 to 16.43)
Yu, 2003^103^ | Perinatal mortality | 7/276 (2.5) | 4/278 (1.4) | OR^§^: 1.89 (95% CI: 0.52 to 6.83)

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; OR = Odds ratio; RR = Risk ratio

* Adjustment for the effect of the estimated risk for preeclampsia at screening and the participating center

† Crude calculation

‡ Excluded from pooled analysis.

§ Adjusted for Maternal age, parity, ethnicity, education, smoking status, partner, previous pre-eclampsia, family history of pre-eclampsia, body mass index, blood pressure at randomization, mean pulsatility index, and the presence of unilateral or bilateral notch

Appendix E Table 4 Effect of Aspirin on Preterm Birth, Increased Risk Population

Author, year | Outcome definition | IG n/N (%) | CG n/N (%) | Effect (95% CI)
ASPRE, 2017^59^ | Delivery at <37 wks of gestation | 53/798 (6.6) | 84/822 (10.2) | RR^*^: 0.65 (95% CI: 0.47 to 0.90)
Ayala, 2012^57^ | Delivery at <37 wks of gestation | 7/176 (4.0) | 20/174 (11.5) | RR^*^: 0.35 (95% CI: 0.15 to 0.80)
Benigni, 1989^88^ | Delivery at <37 wks of gestation | 2/17 (11.8) | 5/16 (31.3) | RR^*^: 0.38 (95% CI: 0.08 to 1.67)
Caspi, 1994^94^ | Delivery at <37 wks of gestation | 11/24 (45.8) | 14/23 (60.9) | RR^*^: 0.75 (95% CI: 0.44 to 1.30)
CLASP, 1994^95^ | Delivery at <37 wks of gestation | 686/3992 (17.2) | 761/3982 (19.1) | RR^*^: 0.90 (95% CI: 0.82 to 0.99)
Davies, 1995^96^ | Delivery at <34 wks of gestation | 1/58 (1.7) | 1/60 (1.7) | RR^*^: 1.03 (95% CI: 0.07 to 16.15)
Gallery, 1997^97^ | Delivery at <37 wks of gestation | 6/58 (10.3) | 8/50 (16.0) | RR^*^: 0.65 (95% CI: 0.24 to 1.74)
Hermida, 1997^98^ | Delivery at <37 wks of gestation | 1/50 (2.0) | 5/50 (10.0) | RR^*^: 0.20 (95% CI: 0.02 to 1.65)
MFMU-HR, 1998^99^ | Delivery at <37 wks of gestation | 502/1254 (40.0) | 537/1249 (43.0) | RR: 0.90 (95% CI: 0.90 to 1.00)
Morris, 1996^107^ | Delivery at <37 wks of gestation | 3/52 (5.8) | 5/50 (10.0) | NR
Schiff, 1989^89^ | Delivery at <37 wks of gestation | 2/34 (5.9) | 6/32 (18.8) | RR^*^: 0.31 (95% CI: 0.07 to 1.44)
Wallenburg, 1986^87^ | Delivery at <37 wks of gestation | 0/21 (0.0) | 4/23 (17.4) | RR^*^: 0.12 (95% CI: 0.01 to 2.12)
Yu, 2003^103^ | Delivery at <37 wks of gestation | 67/276 (24.3) | 75/278 (27.0) | OR^†^: 0.86 (95% CI: 0.57 to 1.29)
ASPRE, 2017^59^ | Delivery at <37 wks of gestation with preeclampsia | 13/798 (1.6) | 35/822 (4.3) | OR^‡^: 0.38 (95% CI: 0.20 to 0.74)
ASPRE, 2017^59^ | Delivery at <34 wks of gestation with preeclampsia | 3/798 (0.4) | 15/822 (1.8) | OR^‡^: 0.18 (99% CI: 0.03 to 1.03)

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; OR = Odds ratio; RR = Risk ratio; wks = Weeks

* Crude calculation

† Maternal age, parity, ethnicity, education, smoking status, partner, previous pre-eclampsia, family history of pre-eclampsia, body mass index, blood pressure at randomization, mean pulsatility index, and the presence of unilateral or bilateral notch.

‡ Adjustment for the effect of the estimated risk for preeclampsia at screening and the participating center

Appendix E Table 5 Effect of Aspirin on Intrauterine Growth Restriction, Increased Risk Population

Author, year | Outcome definition | IG n/N (%) | CG n/N (%) | Effect (95% CI)
ASPRE, 2017^59^ | <10^th^ percentile | 148/785 (18.9) | 187/807 (23.2) | OR^*^: 0.77 (99% CI: 0.56 to 1.06)
Ayala, 2012^57^ | Monthly echography assessments in all participants | 16/176 (9.1) | 32/174 (18.4) | RR^†^: 0.49 (95% CI: 0.28 to 0.87)
Benigni, 1989^88^ | <10^th^ percentile | 2/17 (11.8) | 6/16 (37.5) | RR^†^: 0.31 (95% CI: 0.07 to 1.33)
Caspi, 1994^94^ | <10^th^ percentile | 6/48 (12.5) | 11/46 (23.9) | RR^†^: 0.52 (95% CI: 0.21 to 1.30)
CLASP, 1994^95^ | <3^rd^ percentile | 244/4123 (5.9) | 272/4134 (6.6) | RR^†^: 0.90 (95% CI: 0.76 to 1.06)
Davies, 1995^96^ | 5 – 10^th^ percentile | 3/58 (5.2) | 3/60 (5.0) | RR^†^: 1.03 (95% CI: 0.22 to 4.92)
Hermida, 1997^91^ | NR | 1/50 (2.0) | 2/50 (4.0) | RR^†^: 0.50 (95% CI: 0.05 to 5.34)
McParland, 1990^90^ | <5^th^ percentile | 7/48 (14.6) | 7/52 (13.5) | RR^†^: 1.08 (95% CI: 0.41 to 2.86)
MFMU-HR, 1998^99^ | <10^th^ percentile | 129/1254 (10.3) | 108/1249 (8.6) | RR: 1.20 (95% CI: 0.90 to 1.50)
Morris, 1996^107^ | <10^th^ percentile | 14/52 (26.9) | 11/50 (22.0) | NR
Scazzocchio, 2017^106^ | <10th percentile | 7/80 (8.8) | 13/75 (17.3) | RR^†^: 0.50 (95% CI: 0.21 to 1.20)
Schiff, 1989^89^ | <10th percentile | 2/34 (5.9) | 6/31 (19.4) | RR^†^: 0.30 (95% CI: 0.07 to 1.40)
Viinikka, 1993^93^ | Birth weight ≤2 SD | 4/97 (4.1) | 9/100 (9.0) | RR^†^: 0.46 (95% CI: 0.15 to 1.44)
Villa, 2012^104^ | Birth weight <-2 SD | 2/61 (3.3) | 6/60 (10.0) | RR: 0.50 (95% CI: 0.10 to 1.90)
Wallenburg, 1986^87^ | <10th percentile | 4/21 (19.0) | 6/23 (26.1) | RR^†^: 0.73 (95% CI: 0.24 to 2.23)
Yu, 2003^103^ | <5th percentile | 61/276 (22.1) | 68/278 (24.5) | OR^‡^: 0.83 (95% CI: 0.54 to 1.28)

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; NR = Not reported; OR = Odds ratio; RR = Risk ratio; SD = Standard deviation

* Adjusted for the effect of the estimated risk for preeclampsia at screening and the participating center

† Crude calculation

‡ Adjusted for maternal age, parity, ethnicity, education, smoking status, partner, previous pre-eclampsia, family history of pre-eclampsia, body mass index, blood pressure at randomization, mean pulsatility index, and the presence of unilateral or bilateral notch

Appendix E Table 6 Effect of Aspirin on Birth Weight, Increased Risk Population

Author, year | Outcome definition | IG mean (SD) | CG mean (SD) | Effect (95% CI)^*^
Ayala, 2012^57^ | Birth weight, g | Mean: 3286 (519) | Mean: 3162 (580) | Calc MeanDiff: 124.00 (95% CI: 8.72 to 239.28)
Benigni, 1989^88^ | Birth weight, g | Mean: 2922 (599) | Mean: 2264 (1072) | Calc MeanDiff: 658.00 (95% CI: 70.24 to 1245.76)
Caspi, 1994^94^ | Birth weight, g | Mean: 2502 (561) | Mean: 2108 (542) | Calc MeanDiff: 394.00 (95% CI: 170.86 to 617.14)
CLASP, 1994^95^ | Birth weight, g | Mean: 3024 (788) | Mean: 2991 (810) | MeanDiff: 32.00 (95% CI: 0.00 to 64.00)
Gallery, 1997^97^ | Birth weight, g^+^ | Mean: 3291 (514.3928) | Mean: 3029 (714.1779) | Calc MeanDiff: 262.00 (95% CI: 24.09 to 499.91)
Grab, 2000^101^ | Birth weight, g | Median: 3150 (Range: 560 to 3770) | Median: 2900 (Range: 800 to 4070) | -
Hermida, 1997^98^ | Birth weight, g | Mean: 3265 (452.5483) | Mean: 3155 (678.8225) | Calc MeanDiff: 110.00 (95% CI: −116.14 to 336.14)
McParland, 1990^90^ | Birth weight, g | Mean: 3068 (555) | Mean: 2954 (852) | Calc MeanDiff: 114.00 (95% CI: −170.39 to 398.39)
Morris, 1996^107^ | Birth weight, g | Mean: 3145 (633) | Mean: 3049 (576) | NR
Scazzocchio, 2017^106^ | Birth weight, g | Mean: 3112 (526) | Mean: 3117 (529) | Calc MeanDiff: −5.00 (95% CI: −171.16 to 161.16)
Schiff, 1989^89^ | Adjusted birth weight percentile^†^ | Mean: 43.9 (13.7) | Mean: 38.6 (12.2) | Calc MeanDiff: 5.30 (95% CI: −1.03 to 11.63)
Schiff, 1989^89^ | Birth weight, g | Mean: 3037 (NR) | Mean: 2706 (NR) | -
Viinikka, 1993^93^ | Birth weight, g | Mean: 3348 (707) | Mean: 3170 (665) | Calc MeanDiff: 178.00 (95% CI: −13.61 to 369.61)
Villa, 2012^104^ | Birth weight, g | Mean: 3413 (630) | Mean: 3321 (871) | Calc MeanDiff: 92.00 (95% CI: −178.52 to 362.52)
Wallenburg, 1986^87^ | Birth weight, g | Median: 3190 (Range: 2380 to 4320) | Median: 3040 (Range: 530 to 4035) | -

Abbreviations: Calc MeanDiff = Calculated Mean Difference; CG = Control group; CI = Confidence interval; IG = Intervention group; SD = Standard deviation

* Dash symbol (“-“) indicates insufficient data to calculate effect

† Adjusted for gestational age at delivery

Appendix E Table 7 Effect of Aspirin on Gestational Age, Increased Risk Population

Author, year | Outcome description | IG mean (SD) | CG mean (SD) | Effect (95% CI)^*^
Ayala, 2012^57^ | Monthly echography assessments in all participants | Mean: 39.5 (1.6) | Mean: 39.2 (1.9) | Calc MeanDiff: 0.30 (95% CI: −0.07 to 0.67)
Benigni, 1989^88^ | Duration of pregnancy (weeks) | Mean: 39 (2) | Mean: 35 (4) | Calc MeanDiff: 4.00 (95% CI: 1.86 to 6.14)
Caspi, 1994^94^ | Gestational age at birth (wk), mean; gestational age was determined by last menstrual period, ovulation or ovum pickup in in vitro fertilization (NF) cases, and confirmed by first or early second trimester ultrasound scan | Mean: 36 (31) | Mean: 35 (2.3) | Calc MeanDiff: 1.00 (95% CI: −11.71 to 13.71)
CLASP, 1994^95^ | Average duration of pregnancy (weeks) | Mean: 38.15 (3.82) | Mean: 37.99 (3.93) | Calc MeanDiff: 0.16 (95% CI: 0.00 to 0.32)
Davies, 1995^96^ | Mean age of birth (weeks) | Mean: 39.9 (NR) | Mean: 39.6 (NR) | -
Gallery, 1997^97^ | Mean gestational age at delivery (calculated without 4 intrauterine deaths, as the extent of postmortem weight alteration could not be assessed) | Mean: 38.6 (1.469694) | Mean: 37.5 (2.828427) | Calc MeanDiff: 1.10 (95% CI: 0.24 to 1.96)
Grab, 2000^101^ | Gestational age at delivery (wks) | Median: 39.7 (Range: 26.6 to 42.1) | Median: 38.6 (Range: 28.3 to 41.4) | -
Hermida, 1997^98^ | Gestational age at delivery (wks) | Mean: 39.6 (1.414214) | Mean: 39.4 (2.12132) | Calc MeanDiff: 0.20 (95% CI: −0.51 to 0.91)
McParland, 1990^90^ | Gestation at delivery (wks) | Mean: 39.5 (2.1) | Mean: 38.7 (3.9) | Calc MeanDiff: 0.80 (95% CI: −0.44 to 2.04)
Schiff, 1989^89^ | Gestational age at birth (wks) | Mean: 38.9 (1.14) | Mean: 37.3 (.86) | Calc MeanDiff: 1.60 (95% CI: 1.11 to 2.09)
Viinikka, 1993^93^ | Age of gestation at delivery (weeks) | Mean: 38.6 (2.1) | Mean: 38.2 (2) | Calc MeanDiff: 0.40 (95% CI: −0.17 to 0.97)
Wallenburg, 1986^87^ | Week of delivery | Median: 40 (Range: 37 to 42) | Median: 39 (Range: 30 to 43) | -

Abbreviations: Calc MeanDiff = Calculated Mean Difference; CG = Control group; CI = Confidence interval; IG = Intervention group; SD = Standard deviation

* Dash symbol (“-“) indicates insufficient data to calculate effect

Appendix E Table 8 Effect of Aspirin on Preeclampsia, Increased Risk Population

Author, year | Outcome definition | IG n/N (%) | CG n/N (%) | Effect (95% CI)
ASPRE, 2017^59^ | SBP ≥140 mmHg and/or DBP ≥90 mmHg on at least two occasions four hours apart developing after 20 weeks of gestation in previously normotensive women. HTN should be accompanied by proteinuria ≥300 mg in 24 hours or two readings of at least ++ on dipstick analysis of midstream or catheter urine specimens if no 24-hour collection is available. In preeclampsia superimposed on chronic HTN significant proteinuria (as defined above) should develop after 20 weeks’ gestation in women with known chronic HTN (history of HTN before conception or the presence of HTN at the booking visit before 20 weeks’ gestation in the absence of trophoblastic disease) | 66/798 (8.3) | 94/822 (11.4) | RR^*^: 0.72 (95% CI: 0.54 to 0.98)
Ayala, 2012^57^ (657) | Hyperbaric index consistently above the threshold for diagnosis of HTN in pregnancy after the 20th wk of gestation and proteinuria, ≥300 mg/24-h urine, diagnosed after the 20th wk of gestation in a previously normotensive woman | 11/176 (6.3) | 22/174 (12.6) | RR^*^: 0.49 (95% CI: 0.25 to 0.99)
Caspi, 1994^94^ (114) | Sustained elevation of more than 15 mmHg of DBP or 30 mmHg of SBP (on at least two occasions six or more hours apart) compared to levels in the second trimester before treatment, presence of proteinuria of more than 300 mg per day (in the absence of urinary tract infection associated with HTN) | 0/24 (0.0) | 2/23 (8.7) | RR^*^: 0.19 (95% CI: 0.01 to 3.80)
CLASP, 1994 ^95^ | Development of HTN and proteinuria after randomization. For those with baseline DBP below 90 mmHg, HTN defined as a rise of at least 25 mmHg, to 90 mmHg or higher. For those with an initial DBP of 90 mmHg or above, an increment of at least 15 mmHg was required. Proteinuria defined as the appearance after randomization of at least 1+ on protein stick-testing during pregnancy, without evidence of urinary tract infection. | 267/3992 (6.7) | 302/3982 (7.6) | RR^*^: 0.88 (95% CI: 0.75 to 1.03)
Davies, 1995^96^ | Two DBP readings of >90 mmHg at least 6 hours apart or a single reading of >110 mmHg, proteinuria defined as + + on reagent strip testing or greater than 300 mg/L in a 24-h urine collection. | 5/58 (8.6) | 7/60 (11.7) | OR: 0.70 (95% CI: 0.20 to 2.40)
Grab, 2000^101^ | Proteinuric HTN | 3/22 (13.6) | 2/21 (9.5) | RR^*^: 1.43 (95% CI: 0.27 to 7.73)
Hermida, 1997^98^ | Gestational HTN and proteinuria, above 300 mg/24 h, with or without edema | 3/50 (6.0) | 7/50 (14.0) | RR^*^: 0.43 (95% CI: 0.12 to 1.56)
McParland, 1990^90^ | Proteinuric HTN, specific SBP/DBP, proteinuria not defined | 1/48 (2.1) | 10/52 (19.2) | RR^*^: 0.11 (95% CI: 0.01 to 0.81)
MFMU-HR, 1998^99^ | Women who did not have HTN or proteinuria at BL who developed HTN plus one of the following: proteinuria, thrombocytopenia, or pulmonary edema. HTN defined as either SBP ≥ 140 mmHg or DBP ≥ 90 mmHg on two occasions at least 4 hours apart. Proteinuria defined as excretion of 300 mg of protein in a 24-hour urine collection, or two dipstick-test results of ≥2 + (≥100 mg per deciliter), the values recorded at least four hours apart, with no evidence of urinary tract infection. Thrombocytopenia defined as a platelet count of less than 100,000 per cubic millimeter. | 226/1254 (18.0) | 250/1249 (20.0) | RR: 0.90 (95% CI: 0.80 to 1.10)
Morris, 1996^107^ | PIH plus proteinuria (1+ or more on dipstick testing on at least two occasions 6 hours apart) or hyperuricemia | 4/52 (7.7) | 7/50 (14.0) | NR
Scazzocchio, 2017^106^ | SBP ≥ 140 mmHg or DBP ≥ 90 mmHg on two readings at least four hours apart in previously normotensive women after 20 weeks gestation, and proteinuria >300 mg/24 hr | 4/80 (5.0) | 3/75 (4.0) | RR^*^: 1.25 (95% CI: 0.29 to 5.40)
Scazzocchio, 2017^106^ | Severe preeclampsia, defined as: BP ≥ 160/110 mmHg on two or more occasions, proteinuria ≥ 5g/24 hr, or the presence of maternal complications including: eclampsia, HELLP syndrome (lactate dehydrogenase > 600 IU/L, aspartate transaminase > 62 IU/L, platelet count <100 × 10^9/L), acute renal failure (creatinine > 1.2 mg/dL), subcapsular hepatic hematoma, pulmonary edema, placental abruption, or the presence of disseminated intravascular disease | 1/80 (1.3) | 1/75 (1.3) | RR^*^: 0.94 (95% CI: 0.06 to 14.72)
Schiff, 1989^89^ | SBP > 140 mmHg, DBP > 90 mmHg, or both when measured on at least two occasions within 24 hours of each other; accompanied by proteinuria (>1 g in 24 hours) | 1/34 (2.9) | 7/31 (22.6) | RR^*^: 0.13 (95% CI: 0.02 to 1.00)
Viinikka, 1993^93^ | Exacerbation of preexisting HTN (>160/120 mmHg) or the emergence of HTN (>160/110 mmHg) in women normotensive before pregnancy, and proteinuria > 300 mg/24 hours. | 9/97 (9.3) | 11/100 (11.0) | RR^*^: 0.84 (95% CI: 0.37 to 1.95)
Villa, 2012^104^ | Blood pressure > or equal to 140 and/or 90 mmHg in two consecutive measurements and proteinuria > or equal to 0.3 g/24 hours | 8/61 (13.1) | 11/60 (18.3) | RR: 0.80 (95% CI: 0.40 to 1.80)
Villa, 2012^104^ | Early preeclampsia; preeclampsia diagnosed before 34 + 0 weeks of gestation | 1/61 (1.6) | 4/60 (6.7) | RR: 0.50 (95% CI: 0.10 to 2.60)
Villa, 2012^104^ | Preterm preeclampsia; preeclampsia diagnosed before 37 + 0 weeks of gestation | 3/61 (4.9) | 5/60 (8.3) | RR: 0.80 (95% CI: 0.20 to 2.80)
Villa, 2012^104^ | SBP ≥160 and/or DBP ≥110 and/or proteinuria ≥5 g/24 hours) | 3/61 (4.9) | 8/60 (13.3) | RR: 0.50 (95% CI: 0.20 to 1.60)
Wallenburg, 1986^87^ | DBP >95 mmHg on at least two occasions six or more hours apart and concomitant proteinuria (0.5 g/L) in the absence of a urinary tract infection | 0/21 (0.0) | 7/23 (30.4) | RR^*^: 0.07 (95% CI: 0.00 to 1.20)
Yu, 2003^103^ | Two recordings of DBP of 90 mmHg or higher at least four hours apart or one recording of DBP of at least 120 mmHg, in a previously normotensive woman, and a urine protein excretion of at least 300 mg in 24h or two readings of 2+ or higher on dipstick analysis of midstream or catheter urine specimens if no 24h collection is available. | 49/276 (17.8) | 52/278 (18.7) | OR^†^: 0.88 (95% CI: 0.56 to 1.40)

Abbreviations: BL = Baseline; CG = Control group; CI = Confidence interval; DBP = Diastolic blood pressure; HELLP = Hemolysis, Elevated Liver enzyme levels, and Low Platelet levels; hr = Hour; IG = Intervention group; SBP = Systolic blood pressure; OR = Odds ratio; RR = Risk ratio

* Crude calculation

† Adjusted for maternal age, parity, ethnicity, education, smoking status, partner, previous pre-eclampsia, family history of pre-eclampsia, body mass index, blood pressure at randomization, mean pulsatility index, and the presence of unilateral or bilateral notch.

Appendix E Table 9 Effect of Aspirin on Gestational Hypertension, Increased Risk Population

Author, year | Outcome definition | IG n/N (%) | CG n/N (%) | Effect (95% CI)
ASPRE, 2017^59^ | SBP should be 140 mmHg or more and/or the DBP should be 90 mmHg or more on at least two occasions four hours apart developing after 20 weeks of gestation in previously normotensive women. | 80/798 (10.0) | 69/822 (8.4) | RR^*^: 1.19 (95% CI: 0.88 to 1.62)
Ayala, 2012^57^ | Hyperbaric index (HBI): total area of BP excess summed over the 24-h period above the upper limit of the time-varying tolerance interval calculated as a function of gestational age; consistently above the threshold for diagnosis of HTN in pregnancy after the 20^th^ wk of gestation | 26/176 (14.8) | 49/174 (28.2) | RR^*^: 0.52 (95% CI: 0.34 to 0.80)
Benigni, 1989^88^ | Pregnancy-induced HTN, blood pressure levels higher than 140/90 mmHg in women whose blood pressure had previously been normal. | 0/17 (0.0) | 3/16 (18.8) | RR^*^: 0.13 (95% CI: 0.01 to 2.42)
Caspi, 1994^94^ | Sustained elevation of more than 15 mmHg of DBP or 30 mmHg of SBP (on at least two occasions 6 or more hours apart) compared to levels in the second trimester before treatment. | 1/24 (4.2) | 6/23 (26.1) | RR^*^: 0.16 (95% CI: 0.02 to 1.23)
Davies, 1995^96^ | Two DBP readings of > 90 mmHg at least 6 hours apart or a single reading of > 110 mmHg | 2/58 (3.4) | 4/60 (6.7) | RR^*^: 0.52 (95% CI: 0.10 to 2.72)
Hermida, 1997^98^ | Conventional BP values above 140/90 mmHg for systolic/diastolic BP without clinical record of HTN previous to pregnancy | 5/50 (10.0) | 9/50 (18.0) | RR^*^: 0.56 (95% CI: 0.20 to 1.54)
McParland, 1990^90^ | Pregnancy-induced HTN; specific SBP/DPB not defined | 6/48 (12.5) | 13/52 (25.0) | RR^*^: 0.50 (95% CI: 0.21 to 1.21)
Morris, 1996^107^ | Antenatal blood pressure > 140/90, with a rise in DBP of at least 15 mmHg on at least two occasions 6 hours apart | 8/52 (15.4) | 7/50 (14.0) | NR
Villa, 2012^104^ | New onset HTN after 20 weeks gestation | 10/61 (16.4) | 6/60 (10.0) | RR: 1.40 (95% CI: 0.60 to 3.50)

Abbreviations: CI = Confidence interval; CG = Control group; DBP = Diastolic blood pressure; HBI = Hyperbaric index; HTN = Hypertension; IG = Intervention group; RR = Risk ratio; SBP = Systolic blood pressure; wk = Week

* Crude calculation

Appendix E Table 10 Harms of Maternal Bleeding, Average and Increased Risk Populations

Author, year | Outcome | Outcome definition | IG n/N (%) | CG n/N (%) | Effect (95% CI)
Ayala, 2012^57^ | Antepartum hemorrhage | NR | 6/176 (3.4) | 9/174 (5.2) | RR^*^: 0.66 (95% CI: 0.24 to 1.81)
MFMU-LR, 1993^92^ | Bleeding During Delivery | Excessive blood loss (>500 mL for vaginal delivery and >1000 mL for a cesarean delivery) | 102/1485 (6.9) | 109/1500 (7.3) | RR^*^: 0.95 (95% CI: 0.73 to 1.23)
CLASP, 1994^95^ | Blood Transfusion Required | NR | 188/4659 (4.0) | 147/4650 (3.2)
Mone, 2018^105^ | Blood Transfusion Required | NR | 3/192 (1.6) | 4/354 (1.1) | OR: 0.50 (95% CI: 0.10 to 2.70)
Morris, 1996^107^ | Antepartum hemorrhage | NR | 2/52 (3.8) | 1/50 (2.0) | NR
Rotchell, 1998^100^ | Blood Transfusion Required | NR | 19/1819 (1.0) | 18/1822 (1.0)
MFMU-LR, 1993^92^ | Blood Transfusion Required | NR | 7/1485 (0.5) | 10/1500 (0.7) | RR^*^: 0.71 (95% CI: 0.27 to 1.85)
Subtil, 2003^102^ | Blood Transfusion Required | NR | 3/1634 (0.2) | 9/1640 (0.5)
Yu, 2003^103^ | Blood Transfusion Required | NR | 6/276 (2.2) | 7/278 (2.5)
Ayala, 2012^57^ | Postpartum hemorrhage | NR | 3/176 (1.7) | 6/174 (3.4) | RR^*^: 0.49 (95% CI: 0.13 to 1.95)
CLASP, 1994^95^ | Postpartum hemorrhage | Placental bleed ≥500 mL | 1200/4659 (25.8) | 1182/4650 (25.4) | RR^*^: 1.01 (95% CI: 0.95 to 1.09)
Hermida, 1997^98^ | Postpartum hemorrhage | Antepartum hemorrhage, no complication with maternal bleeding | 0/50 (0.0) | 0/50 (0.0) | RR^*^,^†^: 1.00 (95% CI: 0.02 to 49.44)
MFMU-HR, 1998^99^ | Postpartum hemorrhage | NR | 73/1254 (5.8) | 77/1249 (6.2) | RR: 0.90 (95% CI: 0.70 to 1.30)
Mone, 2018^105^ | Postpartum hemorrhage | >500 mL blood loss | 25/179 (14.0) | 9/183 (4.9) | RR^*^: 2.84 (95% CI: 1.36 to 5.91)
Mone, 2018^105^ | Postpartum hemorrhage | >1000 mL blood loss | 7/179 (3.9) | 5/183 (2.7) | RR^*^: 1.43 (95% CI: 0.46 to 4.43)
Rotchell, 1998^100^ | Postpartum hemorrhage | ≥500 mL blood loss | 178/1819 (9.8) | 175/1822 (9.6) | RR^*^: 1.02 (95% CI: 0.84 to 1.24)
Scazzocchio, 2017^106^ | Postpartum hemorrhage | NR | 2/80 (2.5) | 5/75 (6.7) | RR^*^: 0.38 (95% CI: 0.08 to 1.87)
MFMU-LR, 1993^92^ | Postpartum hemorrhage | NR | 45/1485 (3.0) | 37/1500 (2.5) | RR^*^: 1.23 (95% CI: 0.80 to 1.89)
Subtil, 2003^102^ | Postpartum hemorrhage | ≥500 mL blood loss | 63/1634 (3.9) | 49/1640 (3.0) | RR^*^: 1.29 (95% CI: 0.89 to 1.86)
Wallenburg, 1986^87^ | Postpartum hemorrhage | Postpartum hemorrhage | 0/21 (0.0) | 0/23 (0.0) | RR^*^,^†^: 1.09 (95% CI: 0.02 to 52.67)
Yu, 2003^103^ | Postpartum hemorrhage | >500 mL blood loss | 73/276 (26.4) | 71/278 (25.5) | OR^‡^: 1.09 (95% CI: 0.73 to 1.62)

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; NR = Not reported; OR = Odds ratio; RR = Risk ratio

* Crude calculation

† Excluded in the pooled metanalysis.

‡ Adjusted for maternal age, parity, ethnicity, education, smoking status, partner, previous pre-eclampsia, family history of pre-eclampsia, body mass index, blood pressure at randomization, mean pulsatility index, and the presence of unilateral or bilateral notch.

Appendix E Table 11 Harms of Placental Abruption, Average and Increased Risk Populations

Author, year | Outcome definition | IG n/N (%) | CG n/N (%) | Effect (95% CI)
ASPRE, 2017^59^ | Placental abruption without preeclampsia | 4/798 (0.5) | 6/822 (0.7) | RR^*^: 0.69 (95% CI: 0.19 to 2.42)
Caspi, 1994^94^ | Placental abruption | 0/24 (0.0) | 0/23 (0.0) | RR^*^,^†^: 0.96 (95% CI: 0.02 to 46.47)
CLASP, 1994^95^ | Placental abruption | 86/4659 (1.8) | 71/4650 (1.5) | RR^*^: 1.21 (95% CI: 0.89 to 1.65)
Davies, 1995^96^ | Placental abruption | 2/58 (3.4) | 1/60 (1.7) | OR: 1.24 (95% CI: 0.20 to 23.90)
Hauth, 1993^91^ | Placental abruption | 1/302 (0.3) | 0/302 (0.0) | RR^*^: 3.00 (95% CI: 0.12 to 73.35)
Hermida, 1997^98^ | Placental abruption | 0/50 (0.0) | 0/50 (0.0) | RR^*^,^†^: 1.00 (95% CI: 0.02 to 49.44)
MFMU-HR, 1998^99^ | Diagnosed according to clinical criteria: vaginal bleeding, uterine tenderness, as well as examination of the placenta. | 17/1254 (1.4) | 25/1249 (2.0) | RR: 0.70 (95% CI: 0.40 to 1.30)
Mone, 2018^105^ | Placental abruption | 1/179 (0.6) | 0/183 (0.0) | RR^*^: 3.07 (95% CI: 0.13 to 74.78)
Rotchell, 1998^100^ | Placental abruption | 9/1819 (0.5) | 14/1822 (0.8) | RR^*^: 0.64 (95% CI: 0.28 to 1.48)
MFMU-LR, 1993^92^ | Diagnosed according to clinical findings (vaginal bleeding, uterine tenderness) or placental examination | 11/1485 (0.7) | 2/1500 (0.1) | RR: 5.56 (95% CI: 1.24 to 25.06)
Subtil, 2003^102^ | Placental abruption either clinical or detected in a pathology examination of the placenta | 13/1634 (0.8) | 9/1640 (0.5) | RR: 1.45 (95% CI: 0.62 to 3.38)
Viinikka, 1993^93^ | Placental abruption | 0/97 (0.0) | 0/100 (0.0) | RR^*^,^†^: 1.03 (95% CI: 0.02 to 51.43)
Yu, 2003^103^ | Placental abruption | 10/276 (3.6) | 5/278 (1.8) | OR^‡^: 2.54 (95% CI: 0.78 to 8.21)

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; OR = Odds ratio; RR = Risk ratio

* Crude calculation

† Exclude in the pooled metanalysis.

‡ Adjusted for maternal age, parity, ethnicity, education, smoking status, partner, previous pre-eclampsia, family history of pre-eclampsia, body mass index, blood pressure at randomization, mean pulsatility index, and the presence of unilateral or bilateral notch.

Appendix E Table 12 Perinatal Harms, Average and Increased Risk Populations

Author, year | Outcome | Outcome definition | IG n/N (%) | CG n/N (%) | Effect (95% CI)
MFMU-LR, 1993^92^ | Any bleeding disorder | Any bleeding disorder (infant) | 104/1480 (7.0) | 98/1505 (6.5) | RR^*^: 1.08 (95% CI: 0.83 to 1.41)
Schiff, 1989^89^ | Cephalohematoma | Cephalohematoma | 0/34 (0.0) | 1/32 (3.1) | RR^*^: 0.31 (95% CI: 0.01 to 7.45)
MFMU-LR, 1993^92^ | Cephalohematoma | Cephalohematoma | 68/1480 (4.6) | 55/1505 (3.7) | RR^*^: 1.26 (95% CI: 0.89 to 1.78)
ASPRE, 2017^59^ | Congenital malformations | Fetal structural defects | 8/798 (1.0) | 16/822 (1.9) | RR^*^: 0.52 (95%CI −0.34 to 1.36)
Gallery, 1997^97^ | Congenital malformations | Congenital malformations | 2/54 (3.7) | 4/50 (8.0) | RR^*^: 0.46 (95% CI: 0.09 to 2.42)
Mone, 2018^105^ | Congenital malformations | Total congenital anomaly (includes cardiac, GI, neurological, renal) | 3/179 (1.7) | 4/183 (2.2) | RR^*^: 0.77 (95% CI: 0.17 to 3.38)
Viinikka, 1993^93^ | Congenital malformations | Fetal anencephaly | 1/97 (1.0) | 0/100 (0.0) | RR^*^: 3.09 (95% CI: 0.13 to 74.98)
ASPRE, 2017^59^ | Fetal intracranial bleeding | Intraventricular hemorrhage of grade ≥II | 2/798 (0.3) | 1/822 (0.1) | OR^†^: 2.23 (99% CI: 0.09 to 52.70)
Benigni, 1989^88^ | Fetal intracranial bleeding | Intracranial hemorrhage | 0/17 (0.0) | 0/16 (0.0) | RR^*^: 0.94 (95% CI: 0.02 to 44.98)
MFMU-HR, 1998^99^ | Fetal intracranial bleeding | Defined according to ultrasound criteria | 21/1254 (1.7) | 14/1249 (1.1) | RR: 1.50 (95% CI: 0.80 to 2.80)
MFMU-LR, 1993^92^ | Fetal intracranial bleeding | Cerebral hemorrhage | 10/1480 (0.7) | 11/1505 (0.7) | RR^*^: 0.92 (95% CI: 0.39 to 2.17)
CLASP, 1994^95^ | Fetal intracranial bleeding | Intraventricular hemorrhage | 33/4810 (0.7) | 45/4821 (0.9) | RR^*^: 0.74 (95% CI: 0.47 to 1.15)
Rotchell, 1998^100^ | Fetal intracranial bleeding | Intraventricular hemorrhage | 0/1834 (0.0) | 1/1841 (0.1) | RR^*^: 0.33 (95% CI: 0.01 to 8.21)
Schiff, 1989^89^ | Fetal intracranial bleeding | Intraventricular hemorrhage | 0/34 (0.0) | 0/32 (0.0) | RR^*^: 0.94 (95% CI: 0.02 to 46.16)
Subtil, 2003^102^ | Fetal intracranial bleeding | Intraventricular hemorrhage grade II, III, or IV | 1/1645 (0.1) | 6/1660 (0.4) | RR^*^: 0.17 (95% CI: 0.02 to 1.40)
ASPRE, 2017^59^ | Respiratory distress syndrome | Respiratory distress syndrome treated with surfactant and ventilation | 11/798 (1.4) | 22/822 (2.7) | OR^†^: 0.53 (99% CI: 0.20 to 1.40)
Gallery, 1997^97^ | Severe hyaline membrane disease | Neonatal death caused by severe hyaline membrane disease | 0/58 (0.0) | 1/50 (2.0) | RR^*^: 0.29 (95% CI: 0.01 to 6.92)
Gallery, 1997^97^ | Staphylococcus epidermis septicemia | One neonatal death from Staphylococcus epidermis septicemia | 0/58 (0.0) | 1/50 (2.0) | RR^*^: 0.29 (95% CI: 0.01 to 6.92)

Abbreviations: CG = Control group; CI = Confidence interval; GI = Gastrointestinal; IG = Intervention group; OR = Odds ratio; RR = Risk ratio

* Crude calculation

† Adjustment for the effect of the estimated risk for preeclampsia at screening and the participating center

Abbreviations: CG = Control group; IG = Intervention group

Appendix E Table 13 Longer Term Followup Outcomes Among Infants Born to CLASP Trial Participants

Study, Year; Quality | Treatment group | N Analyzed | Child outcomes, n (%)
CLASP, 1994^95^; Good; 18-month followup | IG | 2,146 | Gross motor failure:; 9 (0.4); Fine motor failure:; 28 (1.3); Height <3^rd^ percentile:; 236 (11.0); Weight <3^rd^ percentile:; 112 (5.2)
CLASP, 1994^95^; Good; 18-month followup | CG | 2,219 | Gross motor failure:; 10 (0.5); Fine motor failure:; 39 (1.8); Height <3^rd^ percentile:; 248 (11.2); Weight <3^rd^ percentile:; 129 (5.8)

Appendix E Table 14 Other Maternal Outcomes, Average and Increased Risk Populations

Author, year | Outcome | Outcome definition | IG n/N (%) | CG n/N (%) | Effect (95% CI)
Mone, 2018^105^ | Any Adverse Event | NR | 123/192 (64.1) | 143/354 (40.4) | OR: 2.60 (95% CI: 1.80 to 3.80)
Mone, 2018^105^ | Serious Adverse Event | NR | 32/179 (17.9) | 28/183 (15.3) | RR^*^: 1.17 (95% CI: 0.74 to 1.86)
Morris, 1996^107^ | Any Adverse Event | NR | 29/52 (55.7) | 28/50 (56.0) | NR
ASPRE, 2017^59^ | Maternal death | Maternal death due to pulmonary embolism | 0/798 (0.0) | 1/822 (0.1) | RR^*^: 0.34 (95% CI: 0.01 to 8.42)
Hauth, 1993^91^ | Preterm Rupture of Membranes | Preterm premature rupture of membranes | 9/302 (3.0) | 8/302 (2.6) | RR^*^: 1.13 (95% CI: 0.44 to 2.88)
MFMU-LR, 1993^92^ | Preterm Rupture of Membranes | Premature rupture of membranes with preterm delivery | 49/1485 (3.3) | 54/1500 (3.6) | RR^*^: 0.92 (95% CI: 0.63 to 1.34)

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; NR = Not reported; OR = Odds ratio; RR = Risk ratio

* Crude calculation