# Appendix D Excluded Studies

Reason for Exclusion^*^
E1 Relevance; E1a Not primary data (e.g., editorial, narrative review)
E2 Study design; E2a Single arm cohort, case-control study
E3 Setting; E3a Study country not a “very high” HDI
E4 Population; E4a Population not at increased risk (e.g. nulliparous otherwise healthy women)
E5 Intervention; E5a Aspirin plus other medication; E5b Intervention other than aspirin
E6 Comparator; E6a Comparative effectiveness – active comparator
E7 No relevant outcomes; E7a Secondary analysis of included study with no relevant outcomes; E7b Preliminary reporting, incomplete information
E8 Poor study quality
E9 Non-English language

* Assigned at full-text phase

1 Abramovici, A, Jauk, V, . Analysis of low-dose aspirin by smoking status for select perinatal outcomes. Am J Obstet Gynecol. 208(1): S261. 2013. 10.1016/j.ajog.2012.10.779 KQ1E7b, KQ2E7b, KQ3E7b
2 Abramovici, A, Jauk, V, . Low-dose aspirin is associated with a reduction in spontaneous preterm birth among non-smokers. Am J Obstet Gynecol. 208(1): S260–S261. 2013. 10.1016/j.ajog.2012.10.778 KQ1E7b, KQ2E7b, KQ3E7b
3 Adkins, K, Allshouse, A, . Impact of low-dose aspirin on fetal growth in diabetic pregnancies: the importance of white classification. Am J Obstet Gynecol. 216(1): S292–S293. 2017. KQ1E7b, KQ2E7b, KQ3E7b
4 Allshouse, AA, Jessel, RH, . The impact of low-dose aspirin on preterm birth: secondary analysis of a randomized controlled trial. J Perinatol. 36(6): 427–31. 2016. PMID: 26890552. 10.1038/jp.2016.3 KQ1E2, KQ2E2, KQ3E226890552
5 Ananth, C, Coletta-Lucas, J, . Timing of adverse neonatal outcomes in pregnancies complicated by preeclampsia and small for gestational age births in a cohort of high-risk pregnancies. Am J Obstet Gynecol. 208(1): S264. 2013. 10.1016/j.ajog.2012.10.786 KQ1E7b, KQ2E7b, KQ3E7b
6 Anca-Daniela, S, Banica, R, . Low dose aspirin for preventing fetal growth restriction: A randomised trial. J Perinat Med. 43. 2015. 10.1515/jpm-2015-2002 KQ1E7b, KQ2E7b, KQ3E7b
7 Anderson, S, Jauk, V, . Mid-trimester blood pressures below 140/90 and risk of small-for-gestational age (SGA) in pregnancies complicated by chronic hypertension. Am J Obstet Gynecol. 212(1): S345–S346. 2015. 10.1016/j.ajog.2014.10.914 KQ1E7b, KQ2E7b, KQ3E7b
8 Andrikopoulou, M, Purisch, SE, . Beyond preeclampsia: Low dose aspirin reduces spontaneous preterm birth. Am J Obstet Gynecol. 218(1): S10. 2018. KQ1E4a, KQ2E4a, KQ3E7a
9 Andrikopoulou, M, Purisch, SE, . Low-dose aspirin is associated with reduced spontaneous preterm birth in nulliparous women. Am J Obstet Gynecol. 219(4): 399.e1–399.e6. 2018. PMID: 29913174. 10.1016/j.ajog.2018.06.011 KQ1E4a, KQ2E4a, KQ3E7a29913174
10 Ankumah, NA, Cantu, J, . Risk of adverse pregnancy outcomes in women with mild chronic hypertension before 20 weeks of gestation. Obstet Gynecol. 123(5): 966–72. 2014. PMID: 24785847. 10.1097/AOG.0000000000000205 KQ1E2, KQ2E2, KQ3E224785847
11 Ankumah, NA, Tita, A, . Pregnancy outcome vary by blood pressure level in women with mild-range chronic hypertension. Am J Obstet Gynecol. 208(1): S261–S262. 2013. 10.1016/j.ajog.2012.10.780 KQ1E7b, KQ2E7b, KQ3E7b
12 Askie, L, Duley, L. Associations between the timing and dosing of aspirin prophylaxis and term and preterm pre-eclampsia. BMJ Evid Based Med. 2018. PMID: 29880699. 10.1136/bmjebm-2018-110931 KQ1E1a, KQ2E1a, KQ3E1a29880699
13 Askie, LM, Duley, L, . Antiplatelet agents for prevention of pre-eclampsia: a meta-analysis of individual patient data. Lancet. 369(9575): 1791–1798. 2007. 10.1016/S0140-6736(07)60712-0 KQ1E5, KQ2E5, KQ3E517512048
14 August, P, Helseth, G, . Sustained release, low-dose aspirin ameliorates but does not prevent preeclampsia (PE) in a high risk population. Proceedings of the 9th International Congress, International Society for the Study of Hypertension. 72. 1994. KQ1E7b, KQ2E7b, KQ3E7b
15 Ayala, DE, Hermida, RC. Chronotherapy with low-dose aspirin for prevention of complications in pregnancy. Cardiology (Switzerland). 125. 410. 2013. 10.1159/000354059 KQ1E7b, KQ2E7b, KQ3E7b
16 Baschat, AA, Dewberry, D, . Maternal blood-pressure trends throughout pregnancy and development of pre-eclampsia in women receiving first-trimester aspirin prophylaxis. Ultrasound Obstet Gynecol. 52(6): 728–733. 2018. PMID: 29266502. 10.1002/uog.18992 KQ1E2a, KQ2E2a, KQ3E2a29266502
17 Becker, R, Keller, T, . Individual risk assessment of adverse pregnancy outcome by multivariate regression analysis may serve as basis for drug intervention studies: retrospective analysis of 426 high-risk patients including ethical aspects. Arch Gynecol Obstet. 288(1): 41–8. 2013. PMID: 23389246. 10.1007/s00404-013-2723-1 KQ1E2, KQ2E2, KQ3E223389246
18 Block-Abraham, DM, Turan, OM, . First-trimester risk factors for preeclampsia development in women initiating aspirin by 16 weeks of gestation. Obstet Gynecol. 123(3): 611–617. 2014. PMID: 24513777. KQ1E2a, KQ2E2a, KQ3E2a24513777
19 Cantu, J, Biggio, J, . Timing of initiation of low-dose aspirin therapy and preeclampsia prevention in high-risk women. Am J Obstet Gynecol. 208(1): S266. 2013. 10.1016/j.ajog.2012.10.793 KQ1E7b, KQ2E7b, KQ3E7b
20 Carbillon, L. Prevention of early-onset pre-eclampsia. The Lancet. 389(10078): 1514–1515. 2017. 10.1016/S0140-6736(17)30950-9 KQ1E1a, KQ2E1a, KQ3E1a
21 Carpentier, C, Bujold, E, . P08.03: Low-dose aspirin for prevention of fetal growth restriction and pre-eclampsia in twins: the GAP pilot randomised. Ultrasound in Obstetrics & Gynecology. 50. 178–178. 2017. 10.1002/UOG.18072 KQ1E7b, KQ2E7b, KQ3E7b
22 Carson, MP, Chen, KK. Hypertension in a woman planning pregnancy. CMAJ. 186(2): 129–130. 2014. 10.1503/cmaj.130433 KQ1E1a, KQ2E1a, KQ3E1a24246591
23 Chen, Y, Zhao, D, . Association of intrauterine exposure to aspirin and blood pressure at 7 years of age: a secondary analysis. BJOG: An International Journal of Obstetrics & Gynaecology. 126(5): 599–607. 2019. PMID: 30471180. 10.1111/1471-0528.15561 KQ1E2, KQ2E2, KQ3E230471180
24 Chu, S, Huang, L, . In utero exposure to aspirin and risk of asthma in childhood. Epidemiology. 27(5): 726–731. 2016. 10.1097/EDE.0000000000000519 KQ1E2a, KQ2E2a, KQ3E2a27258324
25 Connealy, B, Carreno, C, . A history of prior preeclampsia is a major risk factor for preterm birth. Am J Obstet Gynecol. 208(1): S264. 2013. 10.1016/j.ajog.2012.10.785 KQ1E2, KQ2E2, KQ3E2
26 Connell, MT, Sjaarda, LA, . The Effects of Aspirin in Gestation and Reproduction (EAGeR) Trial: A Story of Discovery. Semin Reprod Med. 35(4): 344–352. 2017. PMID: 29036741. 10.1055/s-0037-1606384 KQ1E1a, KQ2E1a, KQ3E1a29036741
27 Day, RO, Graham, GG. Therapeutics: Non-steroidal anti-inflammatory drugs (NSAIDs). BMJ (Online). 347(7917). 2013. 10.1136/bmj.f3195 KQ1E1a, KQ2E1a, KQ3E1a
28 de Vries, JI, van Pampus, MG, . Low-molecular-weight heparin added to aspirin in the prevention of recurrent early-onset pre-eclampsia in women with inheritable thrombophilia: the FRUIT-RCT. Journal of Thrombosis & Haemostasis. 10(1): 64–72. 2012. KQ1E6a, KQ2E6a, KQ3E6a22118560
29 Demers, S, Bujold, E, . Enoxaparin and Aspirin Compared With Aspirin Alone to Prevent Placenta-Mediated Pregnancy Complications: A Randomized Controlled Trial [Comment on Haddad “Enoxaparin and Aspirin Compared With Aspirin Alone to Prevent Placenta-Mediated Pregnancy Complications: A Randomized Controlled Trial”]. Obstet Gynecol. 129(2): 387–388. 2017. PMID: 28121820. 10.1097/aog.0000000000001882 KQ1E1a, KQ2E1a, KQ3E1a28121820
30 Demers, S, Roberge, S, . Low-dose aspirin for the prevention of adverse pregnancy outcomes in women with elevated alpha-fetoprotein. Journal of Maternal-Fetal & Neonatal Medicine. 28(6): 726. 2015. PMID: 24893560. 10.3109/14767058.2014.930428 KQ1E1a, KQ2E1a, KQ3E1a24893560
31 Demers, S, Roberge, S, . The use of aspirin during pregnancy. American Journal of Obstetrics & Gynecology.208(2):161–2, 2013 Feb. (2): 161–2, 2013. 2013. KQ1E1a, KQ2E1a, KQ3E1a23174288
32 Di Renzo, GC, Gratacos, E, . Good clinical practice advice: First trimester screening and prevention of pre-eclampsia in singleton pregnancy. International Journal of Gynecology and Obstetrics. 144(3): 325–329. 2019. 10.1002/ijgo.12741 KQ1E1a, KQ2E1a, KQ3E1a30710362
33 Dixon, CL, Marrs, C, . Effect of Low-Dose Aspirin on the Time of Onset of Preeclampsia and Time of Delivery. Am J Perinatol. 34(12): 1219–1226. 2017. PMID: 28445915. 10.1055/s-0037-1602421 KQ1E7a, KQ2E7a, KQ3E7a28445915
34 El-Achi, V, Park, F, . Does low dose aspirin prescribed for risk of early onset preeclampsia reduce the prevalence of preterm prelabor rupture of membranes?. J Matern Fetal Neonatal Med. 1–6. 2019. PMID: 31018725. 10.1080/14767058.2019.1611768 KQ1E2, KQ2E2, KQ3E831018725
35 Erratum: Aspirin for Evidence-Based Preeclampsia Prevention trial: effect of aspirin in prevention of preterm preeclampsia in subgroups of women according to their characteristics and medical and obstetrical history (American Journal of Obstetrics and Gynecology (2017) 217(5) (585.e1–585.e5) (S0002937817309298) (10.1016/j.ajog.2017.07.038)). Am J Obstet Gynecol. 218(4): 454. 2018. 10.1016/j.ajog.2018.01.002 KQ1E1a, KQ2E1a, KQ3E1a29397907
36 Euser, AG, Metz, TD, . Low-dose aspirin for pre-eclampsia prevention in twins with elevated human chorionic gonadotropin. J Perinatol. 36(8): 601–5. 2016. 10.1038/jp.2016.55 KQ1E7a, KQ2E7a, KQ3E7a27054838
37 Euser, AG, Metz, TD, . Low-dose aspirin reduces the incidence of preeclampsia in women with multiple gestations and elevated human chorionic gonadotropin. Reproductive Sciences. 22. 70A–71A. 2015. KQ1E2, KQ2E2, KQ3E2
38 Ferrier, C, North, R, . Low dose aspirin delays the onset of pre-eclampsia in pregnancies with abnormal uteroplacental circulation. Proceedings of the 10th World Congress of the ISSHP. 151. 1996. KQ1E7b, KQ2E7b, KQ3E7b
39 Finneran, MM, Gonzalez-Brown, VM, . Obesity and laboratory aspirin resistance in high-risk pregnant women treated with low-dose aspirin. Am J Obstet Gynecol. 220(4): 385.e1–385.e6. 2019. PMID: 30786253. 10.1016/j.ajog.2019.01.222 KQ1E7a, KQ2E7a, KQ3E7a30786253
40 Fratto, VM, Ananth, CV, . Late preterm neonatal morbidity in hypertensive versus normotensive women. Hypertension in Pregnancy. 35(2): 242–9. 2016. PMID: 26930156. 10.3109/10641955.2016.1139720 KQ1E2, KQ2E2, KQ3E226930156
41 Gee, Se, Ma’ayeh, M, . 1156: glycemic control and aspirin resistance in patients taking low-dose aspirin for preeclampsia prevention. Am J Obstet Gynecol. 222(1): S712–. 2020. KQ1E7, KQ2E7, KQ3E7
42 Gray, PH. In infants born extremely preterm, aspirin or NSAID use during pregnancy are associated with increased risk of quadriparetic cerebral palsy. Evid Based Nurs. 17(1): 16–7. 2014. PMID: 23635955. 10.1136/eb-2012-101101 KQ1E1a, KQ2E1a, KQ3E1a23635955
43 Greene, MF, Solomon, CG. Aspirin to prevent preeclampsia. N Engl J Med. 377(7): 690–691. 2017. 10.1056/NEJMe1708920 KQ1E1a, KQ2E1a, KQ3E1a28813213
44 Greer, IA. Antithrombotic therapy for pregnancy complications: let’s not throw the baby out with the bath water. Evidence Based Medicine. 20(1): 10. 2015. PMID: 25225334. 10.1136/ebmed-2014-110078 KQ1E1a, KQ2E1a, KQ3E1a25225334
45 Gyamfi-Bannerman, C, Fratto, V, . Late preterm neonatal morbidity in high-risk hypertensive versus normotensive women. Am J Obstet Gynecol. 208(1): S207. 2013. 10.1016/j.ajog.2012.10.645 KQ1E7b, KQ2E7b, KQ3E7b
46 Gyamfi-Bannerman, C, Fratto, V, . Risk of neonatal morbidity at late preterm gestations in relation to low-risk hypertensive versus normotensive women. Am J Obstet Gynecol. 208(1): S206–S207. 2013. 10.1016/j.ajog.2012.10.644 KQ1E4a, KQ2E4a, KQ3E7a
47 Haddad, B, Winer, N, . Enoxaparin and Aspirin Compared With Aspirin Alone to Prevent Placenta-Mediated Pregnancy Complications: A Randomized Controlled Trial. Obstet Gynecol. 128(5): 1053–1063. 2016. PMID: 27741174. KQ1E6a, KQ2E6a, KQ3E6a27741174
48 Handal-Orefice, R, Andrikopoulou, M, . Aspirin: A potential for reducing intrauterine growth restriction in low-risk women. Reproductive Sciences. 25(1): 100A. 2018. KQ1E4a, KQ2E4a, KQ3E7a
49 Handal-Orefice, R, Turitz, A, . 818: risk-reducing potential of aspirin among low-risk nulliparous, obese women. Am J Obstet Gynecol. 222(1): S515–. 2020. KQ1E7a, KQ2E7a, KQ3E7a
50 Harrington, K, Kurdi, W, . A prospective management study of slow-release aspirin in the palliation of uteroplacental insufficiency predicted by uterine artery Doppler at 20 weeks. Ultrasound Obstet Gynecol. 15(1): 13–8. 2000. KQ1E5, KQ2E5, KQ3E510776007
51 Hastie, R, Hesselman, S, . Prophylactic aspirin use during pregnancy is associated antenatal complications; a Swedish population register-based cohort study. Pregnancy Hypertens. 17. S16. 2019. KQ1E2, KQ2E2, KQ3E2a
52 Hauspurg, A, Sutton, EF, . Aspirin Effect on Adverse Pregnancy Outcomes Associated With Stage 1 Hypertension in a High-Risk Cohort. Hypertension. 72(1): 202–207. 2018. PMID: 29802215. 10.1161/hypertensionaha.118.11196 KQ1E7a, KQ2E7a, KQ3E7a29802215
53 Helou, A, Walker, S, . Management of pregnancies complicated by hypertensive disorders of pregnancy: Could we do better?. Aust N Z J Obstet Gynaecol. 57(3): 253–259. 2017. PMID: 27396975. 10.1111/ajo.12499 KQ1E2, KQ2E2, KQ3E227396975
54 Hernandez, RK, Werler, MM, . Nonsteroidal antiinflammatory drug use among women and the risk of birth defects. Am J Obstet Gynecol. 206(3): 228.e1–228.e8. 2012. 10.1016/j.ajog.2011.11.019 KQ1E2a, KQ2E2a, KQ3E2a22196851
55 Hofmeyr, GJ, Magee, LA. Aspirin and pre-eclampsia: the heart of the matter?. Bjog. 2020. KQ1E1a, KQ2E1a, KQ3E1a
56 Jensen, MS, Rebordosa, C, . Maternal use of acetaminophen, ibuprofen, and acetylsalicylic acid during pregnancy and risk of cryptorchidism. Epidemiology. 21(6): 779–785. 2010. KQ1E2, KQ2E2, KQ3E220805751
57 Jessel, R, Allshouse, A, . Does low-dose aspirin prevent preterm birth?. Am J Obstet Gynecol. 212(1): S342. 2015. 10.1016/j.ajog.2014.10.907 KQ1E7b, KQ2E7b, KQ3E7b
58 Jiang, N, Liu, Q, . Effect of calcium channel blockers plus low-dosage aspirin on hypertensive pregnancy outcomes. Obstet Gynecol. 123. 57S. 2014. 10.1097/01.AOG.0000447355.99952.06 KQ1E7b, KQ2E7b, KQ3E7b
59 Kalafat, E, Shirazi, A, . The role of aspirin in prevention of preeclampsia in twin pregnancies: does the dose matter?. Am J Obstet Gynecol. 2020. KQ1E2, KQ2E2, KQ3E7
60 Kane, SC, da Silva Costa, F, . Recent developments in early pregnancy screening: Are we getting closer to the Holy Grail?. Med J Aust. 200(3): 140–141. 2014. 10.5694/mja13.10955 KQ1E1a, KQ2E1a, KQ3E1a24528414
61 Katsi, V, Kanellopoulou, T, . Aspirin vs Heparin for the Prevention of Preeclampsia. Curr Hypertens Rep. 18(7): 57. 2016. PMID: 27251704. 10.1007/s11906-016-0664-3 KQ1E2, KQ2E2, KQ3E227251704
62 Keim, SA, Klebanoff, MA. Aspirin use and miscarriage risk. Epidemiology. 17(4): 435–439. 2006. KQ1E2, KQ2E2, KQ3E216755260
63 Khazardoost, S, Mousavi, S, . Effect of aspirin in prevention of adverse pregnancy outcome in women with elevated alpha-fetoprotein. Journal of Maternal-Fetal & Neonatal Medicine. 27(6): 561–5. 2014. PMID: 23901798. 10.3109/14767058.2013.822483 KQ1E3a, KQ2E3a, KQ3E3a23901798
64 Kumar, N, Das, V, . Pilot Interventional Study Comparing Fetomaternal Outcomes of 150 mg Versus 75 mg Aspirin Starting Between 11 and 14 Weeks of Pregnancy in Patients with High Risk of Preeclampsia: A Randomized Control Trial. J Obstet Gynaecol India. 70(1): 23–29. 2020. KQ1E3a, KQ2E3a, KQ3E3a32030002
65 Lan, PG, Gillin, AG, . Effect of early use of low-dose aspirin therapy on late-onset preeclampsia. Journal of Maternal-Fetal & Neonatal Medicine. 32(13): 2137–2142. 2019. PMID: 29366353. 10.1080/14767058.2018.1427718 KQ1E2, KQ2E2, KQ3E629366353
66 Leeson, P. Updated review identifies no adverse impact on mother or offspring during the perinatal period of aspirin use for prevention of preeclampsia. Evidence Based Medicine. 20(1): 11. 2015. PMID: 25238770. 10.1136/ebmed-2014-110056 KQ1E1a, KQ2E1a, KQ3E1a25238770
67 Leon, M, Moussa, H, . Rate of GDM and pregnancy outcomes in chronic hypertensive pregnancies with and without gestational diabetes mellitus. Am J Obstet Gynecol. 212(1): S403–S404. 2015. 10.1016/j.ajog.2014.10.1048 KQ1E7b, KQ2E7b, KQ3E7b
68 Leon, MG, Moussa, HN, . Rate of Gestational Diabetes Mellitus and Pregnancy Outcomes in Patients with Chronic Hypertension. Am J Perinatol. 33(8): 745–50. 2016. PMID: 26890438. 10.1055/s-0036-1571318 KQ1E2, KQ2E2, KQ3E226890438
69 Li, YY, Gu, QR, . Preventing preterm preeclampsia. Am J Obstet Gynecol. 219(6): 633–634. 2018. 10.1016/j.ajog.2018.08.027 KQ1E1a, KQ2E1a, KQ3E1a30144402
70 Lind, DV, Main, KM, . Maternal use of mild analgesics during pregnancy associated with reduced anogenital distance in sons: a cohort study of 1027 mother-child pairs. Hum Reprod. 32(1): 223–231. 2017. PMID: 27852690. KQ1E2a, KQ2E2a, KQ3E2a27852690
71 Liu, F, Yang, H, . Effect of a small dose of aspirin on quantitative test of 24-h urinary protein in patients with hypertension in pregnancy. Exp Ther Med. 13(1): 37–40. 2017. PMID: 28123464. 10.3892/etm.2016.3924 KQ1E3a, KQ2E3a, KQ3E3a28123464
72 Liu, FM, Zhao, M, . Effect of regular oral intake of aspirin during pregnancy on pregnancy outcome of high-risk pregnancy-induced hypertension syndrome patients. Eur Rev Med Pharmacol Sci. 20(23): 5013–5016. 2016. PMID: 27981529. KQ1E3a, KQ2E3a, KQ3E3a27981529
73 Low-dose aspirin for prevention of preeclampsia. Med Lett Drugs Ther. 56(1445): 49. 2014. KQ1E1a, KQ2E1a, KQ3E1a24956307
74 Mason, R, Jones, HA. An audit of antenatal management and outcomes of pregnancies with low first-trimester serum pregnancy-associated plasma protein-A (PAPP-A). BJOG: An International Journal of Obstetrics and Gynaecology. 125. 68. 2018. 10.1111/1471-0528.15493 KQ1E1, KQ2E1, KQ3E1
75 Meher, S, Alfirevic, Z. Aspirin for pre-eclampsia: beware of subgroup meta-analysis. Ultrasound Obstet Gynecol. 41(5): 479–85. 2013. PMID: 23610032. 10.1002/uog.12470 KQ1E1a, KQ2E1a, KQ3E1a23610032
76 Meher, S, Duley, L, . Antiplatelet therapy before or after 16 weeks’ gestation for preventing preeclampsia: an individual participant data meta-analysis. Am J Obstet Gynecol. 216(2): 121–128.e2. 2017. 10.1016/j.ajog.2016.10.016 KQ1E5, KQ2E5, KQ3E527810551
77 Meiri, H, Sammar, M, . Prediction of preeclampsia by placental protein 13 and background risk factors and its prevention by aspirin. J Perinat Med. 42(5): 591–601. 2014. PMID: 24607918. 10.1515/jpm-2013-0298 KQ1E2, KQ2E2, KQ3E224607918
78 Mendel, A, Bernatsky, SB, . Low aspirin use and high prevalence of pre-eclampsia risk factors among pregnant women in a multinational SLE inception cohort. Ann Rheum Dis. 78(7): 1010–1012. 2019. KQ1E2, KQ2E2, KQ3E730573656
79 Mogra, R. Screening and prevention of pre-term pre-eclampsia – A prime time to act. Australasian Journal of Ultrasound in Medicine. 21(4): 187–190. 2018. 10.1002/ajum.12101 KQ1E1a, KQ2E1a, KQ3E1a
80 Mol, BWJ, Van Vliet, EOG, . Antiplatelet agents and the prevention of spontaneous preterm birth: A meta-analysis of individual participant data. J Paediatr Child Health. 51. 53. 2015. KQ1E7b, KQ2E7b, KQ3E7b
81 Mone, F, Mulcahy, C, . A randomised controlled trial and cost effectiveness analysis of low dose aspirin with an early screening test for pre-eclampsia in low risk women. BJOG: An International Journal of Obstetrics and Gynaecology. 124. 10–11. 2017. 10.1111/1471-0528.14585 KQ1E7a, KQ2E7a, KQ3E7a28940873
82 Mone, F, Mulcahy, C, . A randomised controlled trial and cost-effectiveness analysis of low dose aspirin with an early screening test for preeclampsia in low risk women. Reproductive Sciences. 24(1): 68A. 2017. 10.1177/1933719117699773 KQ1E7a, KQ2E7a, KQ3E7a
83 Mone, F, Mulcahy, C, . Performance of the fetal medicine foundation preeclampsia screening test in nulliparous women: results of the TEST multicenter RCT. BJOG: an international journal of obstetrics and gynaecology. Conference: 19th annual conference of the british maternal and fetal medicine society, BMFMS 2017. Netherlands. 124. 10. 2017. 10.1111/1471-0528.14585 KQ1E7b, KQ2E7b, KQ3E7b28940873
84 Mone, F, Mulcahy, C, . The impact of low dose aspirin on markers of placental disease-results of the test multicenter RCT. BJOG: An International Journal of Obstetrics and Gynaecology. 124. 11. 2017. 10.1111/1471-0528.14585 KQ1E7b, KQ2E7b, KQ3E7b
85 Mone, F, Mulcahy, C, . The impact of low dose aspirin on preeclampsia biomarkers and fetal growth in lowrisk women. Am J Obstet Gynecol. 218(1): S303. 2018. KQ1E7a, KQ2E7a, KQ3E7a
86 Moore, G, Allshouse, A, . Early aspirin decreases late-onset preeclampsia (≥34 weeks), particularly in women with chronic hypertension. Am J Obstet Gynecol. 210(1): S144–S145. 2014. 10.1016/j.ajog.2013.10.305 KQ1E2, KQ2E2, KQ3E2
87 Moore, GS, Allshouse, AA, . Baseline placental growth factor levels for the prediction of benefit from early aspirin prophylaxis for preeclampsia prevention. Pregnancy Hypertens. 5(4): 280–6. 2015. PMID: 26597741. 10.1016/j.preghy.2015.06.001 KQ1E2, KQ2E2, KQ3E226597741
88 Moore, GS, Allshouse, AA, . Early initiation of low-dose aspirin for reduction in preeclampsia risk in high-risk women: a secondary analysis of the MFMU High-Risk Aspirin Study. J Perinatol. 35(5): 328–31. 2015. 10.1038/jp.2014.214 KQ1E7a, KQ2E7a, KQ3E7a25474553
89 Mosha, D, Mazuguni, F, . Medication exposure during pregnancy: A pilot pharmacovigilance system using health and demographic surveillance platform. BMC Pregnancy Childbirth. 14(1). 2014. 10.1186/1471-2393-14-322 KQ1E3a, KQ2E3a, KQ3E3a
90 Mousavi, S. Effect of aspirin in prevention of adverse pregnancy outcome in women with elevated alpha-fetoprotein. J Perinat Med. 43. 2015. 10.1515/jpm-2015-2003 KQ1E3a, KQ2E3a, KQ3E3a
91 Moussa, HN, Hosseini Nasab, S, . Adverse pregnancy outcomes in deliveries prior to, at and beyond 39 weeks; low- and high-risk women. Journal of Maternal-Fetal & Neonatal Medicine. 31(19): 2545–2549. 2018. PMID: 28651448. 10.1080/14767058.2017.1347624 KQ1E7a, KQ2E7a, KQ3E7a28651448
92 Moussa, HN, Leon, MG, . Pregnancy outcomes between superimposed preeclampsia with and without severe features-evaluation of the new ACOG task force guidelines. Reproductive Sciences. 22. 179A. 2015. KQ1E7b, KQ2E7b, KQ3E7b
93 Moussa, HN, Leon, MG, . Pregnancy Outcomes in Women with Preeclampsia Superimposed on Chronic Hypertension with and without Severe Features. Am J Perinatol. 34(4): 403–408. 2017. PMID: 27606778. 10.1055/s-0036-1592134 KQ1E7, KQ2E7, KQ3E727606778
94 Moussa, HN, Wu, ZH, . Customized versus Population Fetal Growth Norms and Adverse Outcomes Associated with Small for Gestational Age Infants in a High-Risk Cohort. Am J Perinatol. 32(7): 621–6. 2015. PMID: 25262454. 10.1055/s-0034-1390343 KQ1E7a, KQ2E7a, KQ3E7a25262454
95 Mulcahy, C, Mone, F, . Performance of routine first trimester sonographic evaluation of fetal anatomy: Results of the multicentre test RCT. Am J Obstet Gynecol. 216(1): S83–S84. 2017. KQ1E7a, KQ2E7a, KQ3E7a
96 Mulcahy, C, Mone, F, . The Impact of Aspirin on Ultrasound Markers of Uteroplacental Flow in Low-Risk Pregnancy: Secondary Analysis of a Multicenter RCT. Am J Perinatol. 36(8): 855–863. 2019. PMID: 30396226. 10.1055/s-0038-1675208 KQ1E7, KQ2E7, KQ3E730396226
97 Murtoniemi, K, Vahlberg, T, . The effect of low-dose aspirin on serum placental growth factor levels in a high-risk PREDO cohort. Pregnancy Hypertens. 13. 51–57. 2018. PMID: 30177071. 10.1016/j.preghy.2018.04.003 KQ1E7, KQ2E7, KQ3E730177071
98 Navaratnam, K, Agarwal, U, . Aspirin nonresponsiveness in pregnant women at high risk of pre-eclampsia. BJOG: An International Journal of Obstetrics and Gynaecology. 126. 4. 2019. 10.1111/1471-0528.15629 KQ1E1, KQ2E1, KQ3E1
99 Newnham, JP, Godfrey, M, . Low dose aspirin for the treatment of fetal growth restriction: a randomized controlled trial. Aust N Z J Obstet Gynaecol. 35(4): 370–374. 1995. KQ1E4, KQ2E4, KQ3E48717556
100 Nicolaides, KH. Aspirin versus Placebo in Pregnancies at High Risk for Preterm Preeclampsia. N Engl J Med. 377(24): 2400. 2017. PMID: 29236633. 10.1056/NEJMc1713798 KQ1E1a, KQ2E1a, KQ3E1a29236633
101 Nobles, CJ, Mendola, P, . Preconception and very early pregnancy blood pressure and development of preterm preeclampsia, term preeclampsia and gestational hypertension. Fertil Steril. 112(3): e301–e302. 2019. KQ1E2, KQ2E2, KQ3E2
102 Odibo, AO, Goetzinger, KR, . Early prediction and aspirin for prevention of pre-eclampsia (EPAPP) study: a randomized controlled trial. Ultrasound Obstet Gynecol. 46(4): 414–8. 2015. 10.1002/uog.14889 KQ1E8, KQ2E8, KQ3E825914193
103 Ohno, M, Girsen, A, . Does low-dose aspirin for preeclampsia prevention increase the risk of antepartum bleeding or placental abruption?. Am J Obstet Gynecol. 210(1): S189. 2014. 10.1016/j.ajog.2013.10.406 KQ1E7a, KQ2E7a, KQ3E7a
104 Otero Gonzalez, A, Uribe Moya, S, . Hyperbaric index in the primary prevention of hypertensive complications in high-risk pregnancy. Nefrologia. 35(6): 572–7. 2015. PMID: 26547790. 10.1016/j.nefro.2015.10.001 KQ1E2a, KQ2E2a, KQ3E2a26547790
105 Papatheodorou, SI. Re: Early prediction and aspirin for prevention of pre-eclampsia (EPAPP) study: a randomized controlled trial. A. O. Odibo, K. R. Goetzinger, L. Odibo and M. G. Tuuli. Ultrasound Obstet Gynecol 2015; 46: 414–418. Ultrasound Obstet Gynecol. 46(4): 389. 2015. PMID: 26428714. 10.1002/uog.15736 KQ1E1a, KQ2E1a, KQ3E1a25914193
106 Parchem, JG, Sibai, BM. An aspirin a day in pregnancy keeps childhood hypertension away? BJOG: An International Journal of Obstetrics and Gynaecology. 126(5): 608. 2019. 10.1111/1471-0528.15598 KQ1E1a, KQ2E1a, KQ3E1a”30734451
107 Parikh, NI, Gonzalez, J. Preeclampsia and hypertension: Courting a long while: Time to make it official. JAMA Intern Med. 177(7): 917–918. 2017. 10.1001/jamainternmed.2017.1422 KQ1E1a, KQ2E1a, KQ3E1a28444352
108 Park, F, Russo, K, . Prediction and Prevention of Early-Onset Preeclampsia: Impact of Aspirin after First-Trimester Screening. Obstet Gynecol Surv. 71(1): 11–13. 2016. 10.1097/01.ogx.0000476311.74309.ae KQ1E1a, KQ2E1a, KQ3E1a
109 Park, F, Russo, K, . The impact of aspirin on the prevalence of early onset pre-eclampsia after first trimester screening. Prenat Diagn. 34. e4. 2014. KQ1E2, KQ2E2, KQ3E2
110 Pasquier, E, De Saint Martin, L. To the editor. Ann Intern Med. 163(6): 484–485. 2015. KQ1E1a, KQ2E1a, KQ3E1a26370019
111 Petersen, TG, Liew, Z, . Use of paracetamol, ibuprofen or aspirin in pregnancy and risk of cerebral palsy in the child. Int J Epidemiol. 47(1): 121–130. 2018. PMID: 29149272. 10.1093/ije/dyx235 KQ1E2a, KQ2E2a, KQ3E2a29149272
112 Poon, LC, Rolnik, DL, . ASPRE Trial: Incidence of Preterm Preeclampsia in Patients Fulfilling ACOG and NICE Criteria According to Risk by FMF Algorithm. Obstet Gynecol Surv. 73(11): 623–625. 2018. 10.1097/01.ogx.0000547739.61320.71 KQ1E7a, KQ2E7a, KQ3E7a
113 Preconception blood pressure linked to pregnancy loss risk. Clinical Pharmacist. 10(7). 2018. 10.1211/CP.2018.20204909 KQ1E1a, KQ2E1a, KQ3E1a
114 Prefumo, F, Frusca, T, . Acetylsalicylic acid in pregnant women with chronic hypertension. Am J Obstet Gynecol. 218(4): 463–464. 2018. 10.1016/j.ajog.2018.01.020 KQ1E1a, KQ2E1a, KQ3E1a
115 Premru-Srsen, T, Kocic, Z, . Effect of current guidelines on prevention of pre-eclampsia with low-dose aspirin in primary settings: A population-based case-control study. Int J Gynaecol Obstet. 2020. KQ1E2a, KQ2E2a, KQ3E2a
116 Quinlivan, JA. Simple and safe: preventing preterm birth with aspirin. Lancet. 395(10220): 250–252. 2020. KQ1E1a, KQ2E1a, KQ3E1a31982051
117 Rezk, M, Ellakwa, H, . Maternal and fetal morbidity following discontinuation of antihypertensive drugs in mild to moderate chronic hypertension: A 4-year observational study. Pregnancy Hypertens. 6(4): 291–294. 2016. PMID: 27939471. 10.1016/j.preghy.2016.05.002 KQ1E3a, KQ2E3a, KQ3E3a27939471
118 Roberge, S, Demers, S, . Initiation of aspirin in early gestation for the prevention of pre-eclampsia. BJOG: An International Journal of Obstetrics and Gynaecology. 120(6): 773–774. 2013. 10.1111/1471-0528.12170 KQ1E1a, KQ2E1a, KQ3E1a
119 Roberge, S, Demers, S, . Low-dose aspirin for prevention of morbidity and mortality from preeclampsia. Ann Intern Med. 161(8): 613. 2014. 10.7326/L14-5020-4 KQ1E1a, KQ2E1a, KQ3E1a
120 Roberge, S, Giguère, Y, . Erratum: Early administration of low-dose aspirin for the prevention of severe and mild preeclampsia: A systematic review and meta-analysis (American Journal of Perinatology (2014) 31 (e3)). Am J Perinatol. 31(6): e3. 2014. 10.1055/s-0033-1343351 KQ1E1a, KQ2E1a, KQ3E1a
121 Roberge, S, Odibo, AO, . Aspirin for the Prevention of Preeclampsia and Intrauterine Growth Restriction. Clin Lab Med. 36(2): 319–29. 2016. 10.1016/j.cll.2016.01.013 KQ1E2, KQ2E2, KQ3E227235915
122 Roberts, JM, Himes, KP. Pre-eclampsia: Screening and aspirin therapy for prevention of pre-eclampsia. Nature Reviews Nephrology. 13(10): 602–604. 2017. 10.1038/nrneph.2017.121 KQ1E1a, KQ2E1a, KQ3E1a
123 Rodger, MA. Prevention of early-onset pre-eclampsia – Authors’ reply. The Lancet. 389(10078): 1515. 2017. 10.1016/S0140-6736(17)30951-0 KQ1E1a, KQ2E1a, KQ3E1a
124 Schiff, E, Barkai, G, . Low-dose aspirin does not influence the clinical course of women with mild pregnancy-induced hypertension. Obstet Gynecol. 76(5 Pt 1): 742–4. 1990. KQ1E4, KQ2E4, KQ3E42216216
125 Seidler, AL, Askie, L, . Optimal aspirin dosing for preeclampsia prevention. Am J Obstet Gynecol. 219(1): 117–118. 2018. PMID: 29588190. 10.1016/j.ajog.2018.03.018 KQ1E5, KQ2E5, KQ3E529588190
126 Sentilhes, L, Azria, E, . Aspirin versus placebo in pregnancies at high risk for preterm preeclampsia. N Engl J Med. 377(24): 2399–2400. 2017. 10.1056/NEJMc1713798 KQ1E1a, KQ2E1a, KQ3E1a29239588
127 Sharma, AK, Bhatla, N. Aspirin for pregnancies at high risk for preterm pre-eclampsia. Natl Med J India. 31(1): 26–27. 2018. KQ1E1a, KQ2E1a, KQ3E1a30348920
128 Sharma, N, Srinivasan, S, . Role of Aspirin in High Pulsatility Index of Uterine Artery: A Consort Study. J Obstet Gynaecol India. 68(5): 382–388. 2018. PMID: 30224843. 10.1007/s13224-017-1058-4 KQ1E3a, KQ2E3a, KQ3E3a30224843
129 Sibai, BM. Therapy: Low-dose aspirin to reduce the risk of pre-eclampsia?. Nature Reviews Endocrinology. 11(1): 6–8. 2015. 10.1038/nrendo.2014.199 KQ1E1a, KQ2E1a, KQ3E1a
130 Sisti, G. Maternal Outcomes Associated with Lower Range Stage 1 Hypertension. Obstet Gynecol. 133(1): 190. 2019. 10.1097/AOG.0000000000003045 KQ1E1a, KQ2E1a, KQ3E1a
131 Sjaarda, LA, Radin, RG, . Preconception Low-Dose Aspirin Restores Diminished Pregnancy and Live Birth Rates in Women With Low-Grade Inflammation: A Secondary Analysis of a Randomized Trial. J Clin Endocrinol Metab. 102(5): 1495–1504. 2017. PMID: 28323989. 10.1210/jc.2016-2917 KQ1E1, KQ2E1, KQ3E128323989
132 Stanescu, AD, Banica, R, . Low dose aspirin for preventing fetal growth restriction: A randomised trial. J Perinat Med. 46(7): 776–779. 2018. 10.1515/jpm-2017-0184 KQ1E8, KQ2E8, KQ3E829381473
133 Stern, C, Karoline, MP, . The effect of low dose aspirin on pregnancy outcomes in women with recurrent preeclampsia. Reproductive Sciences. 21(3): 353A. 2014. 10.1177/1933719114528275 KQ1E7b, KQ2E7b, KQ3E7b
134 Stewart, GB, Altman, DG, . Statistical analysis of individual participant data meta-analyses: a comparison of methods and recommendations for practice. PLoS ONE [Electronic Resource]. 7(10): e46042. 2012. KQ1E5, KQ2E5, KQ3E5
135 Sutton, EF, Hauspurg, A, . Maternal Outcomes Associated With Lower Range Stage 1 HypertensionMaternal Outcomes Associated With Lower Range Stage 1 Hypertension. Obstet Gynecol. 132(4): 843–849. 2018. 10.1097/aog.0000000000002870 KQ1E7a, KQ2E7a, KQ3E7a30204698
136 Talari, H, Mesdaghinia, E, . Aspirin and preeclampsia prevention in patients with abnormal uterine artery blood flow. Iran Red Crescent Med J. 16(8): e17175. 2014. PMID: 25389483. 10.5812/ircmj.17175 KQ1E3a, KQ2E3a, KQ3E3a25389483
137 Theilen, L, Campbell, H, . 613: platelet activation and placenta-mediated adverse pregnancy outcomes. Am J Obstet Gynecol. 222(1): S392–. 2020. KQ1E7, KQ2E7, KQ3E7
138 Thilaganathan, B. The ASPRE pre-eclampsia trial: Implications for basic research and clinical practice. Cardiovasc Res. 114(8): e60–e61. 2018. 10.1093/cvr/cvy107 KQ1E1a, KQ2E1a, KQ3E1a30052896
139 Thompson, JM, Waldie, KE, . Associations between acetaminophen use during pregnancy and ADHD symptoms measured at ages 7 and 11 years. PLoS ONE [Electronic Resource]. 9(9): e108210. 2014. PMID: 25251831. 10.1371/journal.pone.0108210 KQ1E2a, KQ2E2a, KQ3E2a25251831
140 Thornton, J. Initiation of aspirin in early gestation for the prevention of pre-eclampsia. BJOG: An International Journal of Obstetrics and Gynaecology. 120(6): 774–775. 2013. 10.1111/1471-0528.12169 KQ1E1a, KQ2E1a, KQ3E1a23565954
141 Tong, S, Mol, BW, . Preventing preeclampsia with aspirin: does dose or timing matter?. Am J Obstet Gynecol. 216(2): 95–97. 2017. 10.1016/j.ajog.2016.12.003 KQ1E1a, KQ2E1a, KQ3E1a28148451
142 Vainio, M, Kujansuu, E, . Low dose acetylsalicylic acid in prevention of pregnancy-induced hypertension and intrauterine growth retardation in women with bilateral uterine artery notches. BJOG. 109(2): 161–167. 2002. KQ1E5, KQ2E5, KQ3E511888098
143 van Vliet, EO, Askie, LA, . Antiplatelet Agents and the Prevention of Spontaneous Preterm Birth: A Systematic Review and Meta-analysis. Obstet Gynecol. 129(2): 327–336. 2017. 10.1097/aog.0000000000001848 KQ1E5, KQ2E5, KQ3E528079785
144 Villa, PM, Kajantie, E, . Aspirin in the prevention of pre-eclampsia in high-risk women. BJOG: An International Journal of Obstetrics and Gynaecology. 120(6): 773. 2013. 10.1111/1471-0528.12135 KQ1E1a, KQ2E1a, KQ3E1a
145 Voutetakis, A, Pervanidou, P, . Aspirin for the Prevention of Preeclampsia and Potential Consequences for Fetal Brain Development. JAMA Pediatr. 2019. PMID: 31135877. 10.1001/jamapediatrics.2019.1260 KQ1E1a, KQ2E1a, KQ3E1a31135877
146 Wheeler, S, Grotegut, C, . Aspirin for preeclampsia prevention, latency and chorioamnionitis in preterm premature rupture of membranes. Am J Obstet Gynecol. 213(6): 897. 2015. KQ1E7b, KQ2E7b, KQ3E7b
147 Wright, D, Nicolaides, KH. Aspirin delays the development of preeclampsia. Am J Obstet Gynecol. 2019. PMID: 30797761. 10.1016/j.ajog.2019.02.034 KQ1E7a, KQ2E7a, KQ3E7a30797761
148 Wright, D, Poon, LC, . Aspirin for Evidence-Based Preeclampsia Prevention trial: influence of compliance on beneficial effect of aspirin in prevention of preterm preeclampsia. Am J Obstet Gynecol. 217(6): 685.e1–685.e5. 2017. PMID: 28888591. 10.1016/j.ajog.2017.08.110 KQ1E7a, KQ2E7a, KQ3E7a28888591
149 Wright, D, Rolnik, DL, . Aspirin for Evidence-Based Preeclampsia Prevention trial: effect of aspirin on length of stay in the neonatal intensive care unit. Am J Obstet Gynecol. 218(6): 612.e1–612.e6. 2018. PMID: 29505771. 10.1016/j.ajog.2018.02.014 KQ1E7a, KQ2E7a, KQ3E7a29505771
150 Zhao, m Y. Low-dose aspirin prescribed at bed time for the prevention of pre-eclampsia in high-risk pregnant women. Shengzhi Yu Biyun. 32(5): 355–359. 2012. KQ1E9, KQ2E9, KQ3E9