# Appendix C Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

- Ayala, DE, Ucieda, R, . Chronotherapy With Low-Dose Aspirin for Prevention of Complications in Pregnancy. Chronobiol.Int. 30(1-2): 260–279. 2012. 10.3109/07420528.2012.717455.23004922
- Benigni, A, Gregorini, G, . Effect of low-dose aspirin on fetal and maternal generation of thromboxane by platelets in women at risk for pregnancy-induced hypertension. N Engl J Med. 321(6): 357–362. 1989.2664523
- MFMU-HR, Caritis, Steve, Sibai, Baha, . Low-Dose Aspirin to Prevent Preeclampsia in Women at High Risk. N Engl J Med. 338(11): 701–705. 1998. 10.1056/NEJM199803123381101 9494145
  - Abramovici, A, Jauk, V, . Low-dose aspirin, smoking status, and the risk of spontaneous preterm birth. Am J Perinatol. 32(5): 445–50. 2015. PMID: 25261702. 10.1055/s-0034-1390352 25261702
  - Adkins, K, Allshouse, AA, . Impact of aspirin on fetal growth in diabetic pregnancies according to White classification. Am J Obstet Gynecol. 217(4): 465.e1–465.e5. 2017. PMID: 28599894. 10.1016/j.ajog.2017.05.062 28599894
  - Cantu, JA, Jauk, VR, . Is low-dose aspirin therapy to prevent preeclampsia more efficacious in non-obese women or when initiated early in pregnancy?. Journal of Maternal-Fetal & Neonatal Medicine. 28(10): 1128–32. 2015. PMID: 25048750. 10.3109/14767058.2014.947258 25048750
  - Tolcher, MC, Sangi-Haghpeykar, H, . Low-dose aspirin (ASA) for preeclampsia prevention among high-risk women by ethnicity and race. Am J Obstet Gynecol. 218(1): S564. 2018.
- Caspi, E, Raziel, A, . Prevention of pregnancy-induced hypertension in twins by early administration of low-dose aspirin: a preliminary report. Am J Reprod Immunol. 31(1): 19–24. 1994.8166943
- CLASP: A randomised trial of low-dose aspirin for the prevention and treatment of pre-eclampsia. Lancet. 343(8898): 619. 1994.7906809
  - Clasp Collaborative Group. Low dose aspirin in pregnancy and early childhood development: follow up of the collaborative low dose aspirin study in pregnancy. CLASP collaborative group 50. Br J Obstet Gynaecol. 102(11): 861–868. 1995.8534620
- Davies, NJ, Gazvani, MR, . Low-Dose Aspirin in the Prevention of Hypertensive Disorders of Pregnancy in Relatively Low-Risk Nulliparous Women. Hypertension in Pregnancy. 14(1): 49–55. 1995.
- Gallery, EileenDM, Ross, MargaretR, . Low-Dose Aspirin in High-Risk Pregnancy?. Hypertension in Pregnancy. 16(2): 229–238. 1997. 10.3109/10641959709031640
  - Leslie, GI, Gallery, ED, . Neonatal outcome in a randomized, controlled trial of low-dose aspirin in high-risk pregnancies. J Paediatr Child Health. 31(6): 549–552. 1995.8924310
- Grab, D, Paulus, WE, . Effects of low-dose aspirin on uterine and fetal blood flow during pregnancy: results of a randomized, placebo-controlled, double-blind trial. Ultrasound Obstet Gynecol. 15(1): 19–27. 2000.10776008
- Hauth, JC, Goldenberg, RL, . Low-dose aspirin therapy to prevent preeclampsia. Am J Obstet Gynecol. 168(4): 1083–1091. 1993.8475955
- Hermida, RC, Ayala, DE, . Time-dependent effects of low-dose aspirin administration on blood pressure in pregnant women. Hypertension. 30(3 Pt 2): 589–595. 1997.9322987
- McParland, P, Pearce, JM, . Doppler ultrasound and aspirin in recognition and prevention of pregnancy-induced hypertension. Lancet. 335(8705): 1552–1555. 1990.1972487
- Mone, F, Mulcahy, C, . Trial of feasibility and acceptability of routine low-dose aspirin versus Early Screening Test indicated aspirin for pre-eclampsia prevention (TEST study): a multicentre randomised controlled trial. BMJ Open. 8(7): e022056. 2018. PMID: 30056389. 10.1136/bmjopen-2018-022056 30056389
  - Mone, F, Mulcahy, C, . Evaluation of the Effect of Low-Dose Aspirin on Biochemical and Biophysical Biomarkers for Placental Disease in Low-Risk Pregnancy: Secondary Analysis of a Multicenter RCT. Am J Perinatol. 2019. PMID: 30646422. 10.1055/s-0038-1677476 30646422
- Morris, JM, Fay, RA, . A randomized controlled trial of aspirin in patients with abnormal uterine artery blood flow. Obstet Gynecol. 87(1): 74–8. 1996.8532271
- Rolnik, Wright DL, Poon D, O’Gorman LC, . Aspirin Versus Placebo in Pregnancies at High Risk for Preterm Preeclampsia. N Engl J Med. 377(7): 613–622. 2017. 10.1056/NEJMoa1704559 28657417
  - Ling, HZ, Jara, PG, . Maternal cardiac function in women at high-risk for pre-eclampsia treated with 150 mg aspirin or placebo: an observational study. Bjog. 2020.
  - Poon, LC, Wright, D, . Aspirin for Evidence-Based Preeclampsia Prevention trial: effect of aspirin in prevention of preterm preeclampsia in subgroups of women according to their characteristics and medical and obstetrical history. Am J Obstet Gynecol. 217(5): 585.e1–585.e5. 2017. 10.1016/j.ajog.2017.07.038 28784417
- Rotchell, YE, Cruickshank, JK, . Barbados Low Dose Aspirin Study in Pregnancy (BLASP): a randomised trial for the prevention of pre-eclampsia and its complications. Br J Obstet Gynaecol. 105(3): 286–292. 1998.9532988
- Scazzocchio, E, Oros, D, . Impact of aspirin on trophoblastic invasion in women with abnormal uterine artery Doppler at 11-14 weeks: a randomized controlled study. Ultrasound Obstet Gynecol. 49(4): 435–441. 2017. 10.1002/uog.17351 27807890
- Schiff, E, Peleg, E, . The use of aspirin to prevent pregnancy-induced hypertension and lower the ratio of thromboxane A2 to prostacyclin in relatively high risk pregnancies. N Engl J Med. 321(6): 351–356. 1989.2664522
- MFMU-LR, Sibai, BM, Caritis, SN, . Prevention of preeclampsia with low-dose aspirin in healthy, nulliparous pregnant women. The National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. N Engl J Med. 329(17): 1213–1218. 1993.8413387
  - Tolcher, MC, Sangi-Haghpeykar, H, . Race and ethnicity varies both efficacy and attributable risk of low-dose aspirin (ASA) for preeclampsia prevention among low-risk women. Am J Obstet Gynecol. 218(1): S203. 2018.
- Subtil, D, Goeusse, P, . Aspirin (100 mg) used for prevention of pre-eclampsia in nulliparous women: the Essai Regional Aspirine Mere-Enfant study (Part 1). BJOG. 110(5): 475–484. 2003.12742332
- Viinikka, L, Hartikainen-Sorri, AL, . Low dose aspirin in hypertensive pregnant women: effect on pregnancy outcome and prostacyclin-thromboxane balance in mother and newborn. Br J Obstet Gynaecol. 100(9): 809–815. 1993.8217999
- Villa, P, Kajantie, E, . Aspirin in the prevention of pre-eclampsia in high-risk women: a randomised placebo-controlled PREDO Trial and a meta-analysis of randomised trials. BJOG. 120(1): 64–74. 2013.
- Wallenburg, HC, Dekker, GA, . Low-dose aspirin prevents pregnancy-induced hypertension and pre-eclampsia in angiotensin-sensitive primigravidae. Lancet. 1(8471): 1–3. 1986.2867260
- Yu, CK, Papageorghiou, AT, . Randomized controlled trial using low-dose aspirin in the prevention of pre-eclampsia in women with abnormal uterine artery Doppler at 23 weeks’ gestation. Ultrasound Obstet Gynecol. 22(3): 233–239. 2003.12942493