# Appendix B Literature Flow Diagram

Appendix B Figure 1 Literature Flow Diagram

*Studies may appear in more than one Key Question

Figure 1 is a flow chart that summarizes the search and selection of articles. There were 5277 citations identified by searching MEDLINE, Embase, PubMed (publisher supplied only), and the Cochrane Collaboration Registry of Controlled Trials. An additional 20 citations were identified from outside sources such as reference lists and suggestions from peer reviewers, and 27 citations from previous USPSTF Aspirin for Preeclampsia review in 2015 were also included. After duplicates were removed, 3749 unique citations were screened at the title/abstract stage. The full-text of 183 citations were examined for inclusion for one or more of the three Key Questions. The following number of articles were included for Key Question 1 (n=27), Key Question 2 (n=24), Key Question 3 (n=31). Reasons for excluding the other articles are available in Appendix D.