# Appendix A Detailed Methods Aspirin

Key:

- / = MeSH subject heading
- $ = truncation
- ti = word in title
- ab = word in abstract
- pt = publication type
- * = truncation
- kw = keyword
- lnk = subheading
- de = index term
- exp = explode
- py = publication year

MEDLINE

Database: Ovid MEDLINE(R) and Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Daily and Versions(R) <1946 to July 22, 2019>

Search Strategy:

------------------------------------------------------------

1. Pregnancy/
2. Pregnant Women/
3. pregnan$.ti,ab.
4. Pre-Eclampsia/
5. Hypertension, Pregnancy-Induced/
6. Eclampsia/
7. HELLP Syndrome/
8. preeclamp$.ti,ab.
9. eclamp$.ti,ab.
10. ((edema or oedema or proteinuria or hypertension or hypertensive) adj5 (gestosis or gestoses or antenatal or prenatal or gestation$ or perinatal)).ti,ab.
11. eph gestosis.ti,ab.
12. (tox?emi$ adj3 (eph or pregnan$)).ti,ab.
13. HELLP.ti,ab.
14. or/1-13
15. exp Aspirin/
16. Platelet Aggregation Inhibitors/
17. aspirin.ti,ab.
18. acetylsalicylic acid.ti,ab.
19. acetyl salicylic acid.ti,ab.
20. antiplatelet$.ti,ab.
21. anti platelet$.ti,ab.
22. (platelet$ adj3 (inhibit$ or antiaggregant$ or antagonist$)).ti,ab.
23. or/15-22
24. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial or pragmatic clinical trial).pt.
25. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/
26. Meta-Analysis as Topic/
27. control groups/ or double-blind method/ or single-blind method/
28. clinical trial$.ti,ab.
29. controlled trial$.ti,ab.
30. random$.ti,ab.
31. (metaanaly$ or meta analy$).ti,ab.
32. trial.ti.
33. placebo.ti,ab.
34. or/24-33
35. 14 and 23 and 34
36. Pregnancy/
37. (pregnan$ or postpartum or post partum or antenatal or prenatal or gestation$ or perinatal or maternal or f?etal or f?etus or neonat$).ti,ab.
38. 36 or 37
39. adverse effects.fs.
40. harm$.ti,ab.
41. adverse.ti,ab.
42. Hemorrhage/
43. h?emorrhag$.ti,ab.
44. bleed$.ti,ab.
45. blood loss.ti,ab.
46. exp Gastrointestinal Diseases/
47. (gastro$ or gastric or epigastric or instestinal).ti,ab.
48. (behavio* or development$).ti,ab.
49. or/39-48
50. 38 and 49
51. Pregnancy complications/
52. Maternal death/
53. Maternal mortality/
54. Maternal Exposure/
55. Fetal death/
56. Fetal mortality/
57. Congenital abnormalities/
58. Postpartum hemorrhage/
59. Abruptio Placentae/
60. Abortion, Spontaneous/
61. Ductus Arteriosus, Patent/
62. Chorioamnionitis/
63. ((pregnan$ or maternal or f?etal or f?etus or neonat$) adj3 complication$).ti,ab.
64. ((congenital or birth or f?etal or f?etus) adj3 (defect$ or abnormal$ or anomal$ or malform$)).ti,ab.
65. ((maternal or f?etal or f?etus or perinatal) adj3 (death$ or mortality)).ti,ab.
66. miscarr$.ti,ab.
67. (spontaneous abortion$ or spontaneous labo?r).ti,ab.
68. abruptio$.ti,ab.
69. ductus arteriosus.ti,ab.
70. (chorioamnionitis or intraamniotic infection or intra-amniotic infection).ti,ab.
71. or/51-70
72. 50 or 71
73. 23 and 72
74. 35 or 73
75. limit 74 to (english language and yr=“2012 -Current”)
76. 75 not (animals/ not humans/)
77. remove duplicates from 76

PUBMED- [publisher supplied references only]

#1 Search pregnan*[tiab] OR preeclamp*[tiab] OR eclamp*[tiab]
#2 Search aspirin[tiab] OR acetylsalicylic acid[tiab] OR acetyl salicylic acid[tiab] OR antiplatelet$[tiab] OR anti platelet$[tiab] OR (platelet*[tiab] AND (inhibit*[tiab] OR antiaggregant*[tiab] OR antagonist*))
#3 Search (#1 AND #2)
#4 Search (#3 AND publisher[sb])
#5 Search (#3 AND publisher[sb]) Filters: Publication date from 2012/01/01
#6 Search (#3 AND publisher[sb]) Filters: Publication date from 2012/01/01; English

Cochrane Central Register of Controlled Clinical Trials (http://www.thecochranelibrary.com/) (CENTRAL)

#1 pregnan*:ti,ab,kw or preeclamp*:ti,ab,kw or eclamp*:ti,ab,kw
#2 ((edema:ti,ab or oedema:ti,ab or proteinuria:ti,ab or hypertension:ti,ab or hypertensive:ti,ab) NEAR/5 (gestosis:ti,ab or gestoses:ti,ab or antenatal:ti,ab or prenatal:ti,ab or gestation*:ti,ab or perinatal:ti,ab))
#3 eph gestosis:ti,ab
#4 (tox*emi*:ti,ab NEAR/3 (eph:ti,ab or pregnan*:ti,ab))
#5 #1 OR #2 OR #3 OR #4
#6 aspirin:ti,ab,kw or “acetylsalicylic acid”:ti,ab,kw or antiplatelet*:ti,ab,kw or anti next platelet*:ti,ab,kw
#7 platelet*:ti,ab AND (inhibit*:ti,ab or antiaggregant*:ti,ab or antagonist*:ti,ab)
#8 #6 OR #7
#9 #5 AND #8 with Publication Year from 2012 to 2019, in Trials

Embase

- No. Query Results
#1 ‘pregnancy’/de
#2 ‘pregnant woman’/de
#3 pregnan*:ab,ti
#4 ‘eclampsia and preeclampsia’/exp
#5 ‘pregnancy toxemia’/de
#6 ‘hellp syndrome’/de
#7 preeclamp*:ti,ab
#8 eclamp*:ti,ab
#9 ((edema OR oedema OR proteinuria OR hypertension OR hypertensive) NEAR/5 (gestosis OR gestoses OR antenatal OR prenatal OR gestation* OR perinatal)):ti,ab
#10 ‘eph gestosis’:ti,ab
#11 (tox$emi* NEAR/3 (eph OR pregnan*)):ti,ab
#12 hellp:ti,ab
#13 #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12
#14 ‘acetylsalicylic acid’/de
#15 ‘antithrombocytic agent’/de
#16 aspirin:ti,ab
#17 ‘acetylsalicylic acid’:ti,ab
#18 ‘acetyl salicylic acid’:ti,ab
#19 antiplatelet*:ti,ab
#20 ‘anti platelet*’:ti,ab
#21 (platelet* NEAR/3 (inhibit* OR antiaggregant* OR antagonist*)):ti,ab
#22 #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21
#23 ‘clinical trial’/de
#24 ‘controlled clinical trial’/de
#25 ‘randomized controlled trial’/exp
#26 ‘single blind procedure’/de
#27 ‘double blind procedure’/de
#28 ‘crossover procedure’/de
#29 ‘placebo’/de
#30 ‘randomized controlled trial (topic)’/de
#31 ‘clinical trial (topic)’/de
#32 ‘controlled clinical trial (topic)’/de
#33 ‘meta analysis’/exp
#34 ‘meta analysis (topic)’/de
#35 ‘clinical trial*’:ti,ab
#36 ‘controlled trial*’:ti,ab
#37 random*:ti,ab
#38 metaanaly*:ti,ab OR ‘meta analy*’:ti,ab
#39 trial:ti
#40 placebo:ti,ab
#41 #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40
#42 #13 AND #22 AND #41
#43 pregnan*:ti,ab OR postpartum:ti,ab OR ‘post partum’:ti,ab OR antenatal:ti,ab OR prenatal:ti,ab OR gestation*:ti,ab OR perinatal:ti,ab OR maternal:ti,ab OR f$etal:ti,ab OR f$etus:ti,ab OR neonat*:ti,ab
#44 #1 OR #43
#45 ‘adverse drug reaction’/lnk OR ‘complication’/lnk OR ‘drug toxicity’/lnk OR ‘side effect’/lnk
#46 harm*:ti,ab
#47 adverse:ti,ab
#48 ‘bleeding’/de
#49 h$emorrhag*:ti,ab
#50 bleed*:ti,ab
#51 blood AND loss:ti,ab
#52 ‘gastrointestinal disease’/de
#53 gastro*:ti,ab OR gastric:ti,ab OR epigastric:ti,ab OR instestinal:ti,ab
#54 behavio*:ti,ab OR development*:ti,ab
#55 #45 OR #46 OR #47 OR #48 OR #49 OR #50 OR #51 OR #52 OR #53 OR #54
#56 #44 AND #55
#57 ‘pregnancy disorder’/de
#58 ‘pregnancy complication’/de
#59 ‘maternal death’/de
#60 ‘maternal mortality’/de
#61 ‘maternal exposure’/de
#62 ‘fetus death’/de
#63 ‘fetus mortality’/de
#64 ‘congenital disorder’/de
#65 ‘postpartum hemorrhage’/de
#66 ‘solutio placentae’/de
#67 ‘spontaneous abortion’/de
#68 ‘patent ductus arteriosus’/de
#69 ‘chorioamnionitis’/exp
#70 ((pregnan* OR maternal OR f$etal OR f$etus OR neonat*) NEAR/3 complication*):ti,ab
#71 ((congenital OR birth OR f$etal OR f$etus) NEAR/3 (defect* OR abnormal* OR anomal* OR malform*)):ti,ab
#72 ((maternal OR f$etal OR f$etus OR perinatal) NEAR/3 (death* OR mortality)):ti,ab
#73 miscarr*:ti,ab
#74 ‘spontaneous abortion*’:ti,ab OR ‘spontaneous labo$r’:ti,ab
#75 abruptio*:ti,ab OR ‘solutio placentae’:ti,ab
#76 ‘ductus arteriosus’:ti,ab
#77 chorioamnionitis:ti,ab OR ‘intraamniotic infection’:ti,ab OR ‘intra-amniotic infection’:ti,ab
#78 #57 OR #58 OR #59 OR #60 OR #61 OR #62 OR #63 OR #64 OR #65 OR #66 OR #67 OR #68 OR #69 OR #70 OR #71 OR #72 OR #73 OR #74 OR #75 OR #76 OR #77
#79 #56 OR #78
#80 #22 AND #79
#81 #42 OR #80
#82 (#42 OR #80) AND [english]/lim
#83 #82 AND (2012:py OR 2013:py OR 2014:py OR 2015:py OR 2016:py OR 2017:py OR 2018:py OR 2019:py) AND [embase]/lim
#84 #83 NOT ((‘animal’/exp OR ‘nonhuman’/de) NOT ‘human’/exp)

Appendix A Table 1 Inclusion and Exclusion Criteria

| Inclusion | Exclusion
Populations | KQs 1, 2 (Efficacy): Pregnant persons at increased risk for preeclampsia based on:; - Personal sociodemographic characteristics; - Medical history; - Diagnostic measurements or assays (e.g., uterine artery Doppler, biomarkers); - Risk prediction model; KQ 3 (Harms): Pregnant persons, fetuses, infants, and children. | Nonhuman populations; nonpregnant persons; studies that only/exclusively include persons seeking fertility treatment; and other selected nongeneralizable populations
Disease/condition | Primary prevention of preeclampsia | Trials of aspirin aimed at preventing other complications of pregnancy (e.g., stillbirth)
Setting | Countries categorized as “very high” on the 2017 Human Development Index (as defined by the United Nations Development Programme) | Countries not categorized as “very high” on the 2017 Human Development Index, as there is concern for nutritional deficiencies in developing countries
Interventions | Aspirin (≥50 mg) | Nonaspirin antiplatelet medications or aspirin combined with other potentially active interventions
Comparisons | Placebo or no treatment | Any active substance or intervention (e.g., nonaspirin medication, dietary supplements, dietary change, bed rest, or weight loss)
Outcomes | Maternal outcomes:; - Preeclampsia; Preecalmpsia with severe features; - Hemolysis, elevated liver enzymes, and low platelet count (HELLP) syndrome; - Eclampsia, puerperal cerebrovascular disorder, cerebrovascular hemorrhage, edema, or embolus; - Renal or hepatic injury/failure; - Pulmonary edema, adult respiratory distress syndrome; - Disseminated intravascular coagulation; - Mental health diagnoses or symptoms; - Maternal mortality; - Measures of well-being or quality of life; Potential treatment harms:; - Abruptio placentae; - Postpartum hemorrhage; - Gastrointestinal complications (e.g., bleeding ulcer); Fetal/neonatal/child outcomes:; - Preterm birth (<37 weeks): late preterm birth (34-36 weeks), moderate perterm birth, (32-34 weeks), very preterm birth (<32 weeks), extremely preterm birth (<28 weeks); - Mean gestational age; - Low birth weight; - Intrauterine growth restriction/small for gestational age (<10th percentile weight for gestational age); - Stillbirth or neonatal mortality; Potential treatment harms:; - Intracranial fetal bleeding; - Fetal malformations; - Nonclosure of the ductus arteriosus; - Chorioamnionitis; - Child behavioral or developmental problems | - Length of hospital stay (without indication); - Intensive care unit admission; - Neonatal intensive care unit admission
Study Designs | KQs 1, 2 (Efficacy): Randomized, controlled trial, individual participant data meta-analysis of trials; KQ 3 (Harms): Randomized, controlled trial or comparative cohort studies, individual participant data meta-analysis of trials | KQs 1, 2 (Efficacy): Any nonrandomized controlled trial; KQ 3 (Harms): Editorials, narrative review, commentary, postmarketing surveillance, or case reports
Study Quality | Good- and fair-quality studies | Poor-quality studies
Language | English | Languages other than English

Abbreviations: KQ = Key Question; USPSTF = U.S. Preventative Services Task Force

Appendix A Table 2 Study Design-Specific Quality Rating Criteria

Study Design | Adapted Quality Criteria
Randomized and non-randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods^74^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported

* Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer