# References

1 Donovan L, Hartling L, Muise M, . Screening tests for gestational diabetes: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013;159(2):115–22. doi: 10.7326/0003-4819-159-2-201307160-00657. PMID: 23712349.23712349
2 Hartling L, Dryden DM, Guthrie A, . Screening and Diagnosing Gestational Diabetes Mellitus. Evidence Report/Technology Assessment No. 210. (Contract No. 290-2007-10021-I.) AHRQ Publication No. 12(13)-E021-EF. Rockville, MD: Agency for Healthcare Research and Quality. October 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm. Accessed June 15, 2021. PMID: 2442303524423035.
3 Hartling L, Dryden DM, Guthrie A, . Benefits and harms of treating gestational diabetes mellitus: a systematic review and meta-analysis for the U.S. Preventive Services Task Force and the National Institutes of Health Office of Medical Applications of Research. Ann Intern Med. 2013;159(2):123–9. doi: 10.7326/0003-4819-159-2-201307160-00661. PMID: 23712381.23712381
4 Hartling L, Dryden DM, Guthrie A, . Diagnostic thresholds for gestational diabetes and their impact on pregnancy outcomes: a systematic review. Diabet Med. 2014;31(3):319–31. doi: 10.1111/dme.12357. PMID: 24528230.24528230
5 Moyer VA. Screening for gestational diabetes mellitus: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014;160(6):414–20. doi: 10.7326/m13-2905. PMID: 24424622.24424622
6 Report of the Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Diabetes Care. 1997;20(7):1183–97. PMID: 9203460.9203460
7 American College of Obstetricians and Gynecologists. ACOG Practice Bulletin No. 190 summary: gestational diabetes mellitus. Obstet Gynecology. 2018;131(2):406–8. doi: 10.1097/AOG.0000000000002498. PMID: 29370044.29370044
8 American Diabetes Association. 2. Classification and diagnosis of diabetes: standards of medical care in diabetes-2020. Diabetes Care. 2020;43(Suppl 1):S14–S31. doi: 10.2337/dc20-S002. PMID: 31862745.31862745
9 Metzger BE, Lowe LP, Dyer AR, . Hyperglycemia and adverse pregnancy outcomes. N Engl J Med. 2008;358(19):1991–2002. doi: 10.1056/NEJMoa0707943. PMID: 18463375.18463375
10 American College of Obstetricians and Gynecologists. ACOG Practice Bulletin No. 201: pregestational diabetes mellitus. Obstet Gynecol. 2018;132(6):E228–E48. doi: 10.1097/aog.0000000000002960. PMID: 30461693.30461693
11 Balsells M, Garcia-Patterson A, Gich I, . Maternal and fetal outcome in women with type 2 versus type 1 diabetes mellitus: a systematic review and metaanalysis. J Clin Endocrinol Metab. 2009;94(11):4284–91. doi: 10.1210/jc.2009-1231. PMID: 19808847.19808847
12 Temple R, Murphy H. Type 2 diabetes in pregnancy - An increasing problem. Best Pract Res Clin Endocrinol Metab. 2010;24(4):591–603. doi: 10.1016/j.beem.2010.05.011. PMID: 20832738.20832738
13 Lee D, Booth GL, Ray JG, . Undiagnosed type 2 diabetes during pregnancy is associated with increased perinatal mortality: a large population-based cohort study in Ontario, Canada. Diabet Med. 2020;37(10):1696–704. doi: 10.1111/dme.14250. PMID: 31994233.31994233
14 Casagrande SS, Linder B, Cowie CC. Prevalence of gestational diabetes and subsequent Type 2 diabetes among U.S. women. Diabetes Res Clin Pract. 2018;141:200–8. doi: 10.1016/j.diabres.2018.05.010. PMID: 29772286.29772286
15 DeSisto CL, Kim SY, Sharma AJ. Prevalence estimates of gestational diabetes mellitus in the united states, pregnancy risk assessment monitoring system (PRAMS), 2007-2010. Prev Chronic Dis. 2014;11. doi: 10.5888/pcd11.130415.
16 Lavery JA, Friedman AM, Keyes KM, . Gestational diabetes in the United States: temporal changes in prevalence rates between 1979 and 2010. BJOG. 2017;124(5):804–13. doi: 10.1111/1471-0528.14236. PMID: 27510598.27510598
17 Zhou T, Sun D, Li X, . Prevalence and trends in gestational diabetes mellitus among women in the United States, 2006–2016. Diabetes. 2018;67(Supplement 1). doi: 10.2337/db18-121-OR %J Diabetes.
18 Carpenter MW, Coustan DR. Criteria for screening tests for gestational diabetes. Am J Obstet Gynecol. 1982;144(7):768–73. PMID: 7148898.7148898
19 National Diabetes Data Group. Diabetes in America, 2nd ed. Bethesda, MD: National Institutes of Health; 1995.
20 Harper LM, Mele L, Landon MB, . Carpenter-Coustan compared with National Diabetes Data Group Criteria for diagnosing gestational diabetes. Obstet Gynecol. 2016;127(5):893–8. doi: 10.1097/aog.0000000000001383.27054932
21 Metzger B, Gabbe S, Persson B, . International Association of Diabetes and Pregnancy Study Groups recommendations on the diagnosis and classification of hyperglycemia in pregnancy. Diabetes Care. 2010;33(3):676–82. doi: 10.2337/dc09-1848. PMID: 20190296.20190296
22 Sacks DA, Hadden DR, Maresh M, . Frequency of gestational diabetes mellitus at collaborating centers based on IADPSG consensus panel-recommended criteria: the Hyperglycemia and Adverse Pregnancy Outcome (HAPO) Study. Diabetes Care. 2012;35(3):526–8. doi: 10.2337/dc11-1641. PMID: 22355019.22355019
23 Brown FM, Wyckoff J. Application of one-step IADPSG versus two-step diagnostic criteria for gestational diabetes in the real world: impact on health services, clinical care, and outcomes. Curr Diab Rep. 2017;10;17(10):85. doi: 10.1007/s11892-017-0922-z. PMID: 28799123.28799123
24 Farrar DS, Bryant M, Sheldon TA, . Hyperglycaemia and risk of adverse perinatal outcomes: systematic review and meta-analysis. BMJ. 2016;354:i4694. doi: 10.1136/bmj.i4694. PMID: 27624087.27624087
25 Wendland EMT, Falavigna MR, Trujillo J, . Gestational diabetes and pregnancy outcomes-a systematic review of the World Health Organization (WHO) and the International Association of Diabetes in Pregnancy Study Groups (IADPSG) diagnostic criteria. BMC Pregnancy Childbirth. 2012;12:23. doi: 10.1186/1471-2393-12-23. PMID: 22462760.22462760
26 Kawasaki MA, Miyazaki C, Mori R, . Obesity and abnormal glucose tolerance in offspring of diabetic mothers: a systematic review and meta-analysis. PLoS ONE. 2018;13(1):E0190676. doi: 10.1371/journal.pone.0190676. PMID: 29329330.29329330
27 Patro Golab BS, Voerman E, Lawlor DA, . Influence of maternal obesity on the association between common pregnancy complications and risk of childhood obesity: an individual participant data meta-analysis. Lancet Child Adolesc Health. 2018;07:07. doi: 10.1016/S2352-4642(18)30273-6. PMID: 30201470.30201470
28 Rayanagoudar GH, Zamora J, Khan KS, . Quantification of the type 2 diabetes risk in women with gestational diabetes: a systematic review and meta-analysis of 95,750 women. Diabetologia. 2016;59(7):1403–11. doi: 10.1007/s00125-016-3927-2. PMID: 27073002.27073002
29 Berger H, Crane J, Farine D, . Screening for gestational diabetes mellitus. J Obstet Gynaecol Can. 2002;24(11):894–912. PMID: 12417905.12417905
30 Feig DS, Berger H, Donovan L, . Diabetes and pregnancy. Can J Diabetes. 2018;42(Suppl 1):S255–S82. doi: 10.1016/j.jcjd.2017.10.038. PMID: 29650105.29650105
31 National Institute for Health and Care Excellence. NICE Pathway. Diabetes in pregnancy: management from preconception to the postnatal period. 2015. https://www.nice.org.uk/guidance/ng3/resources/diabetes-in-pregnancy-management-from-preconception-to-the-postnatal-period-pdf-51038446021. Accessed June 14, 2021.
32 Dennis JA. Birth weight and maternal age among American Indian/Alaska Native mothers: a test of the weathering hypothesis. SSM Popul Health. 2019;7:004–4. doi: 10.1016/j.ssmph.2018.10.004. PMID: 30560195.30560195
33 Deputy NP, Kim SY, Conrey EJ, . Prevalence and changes in preexisting diabetes and gestational diabetes among women who had a live birth - United States, 2012-2016. MMWR. 2018;67(43):1201–7. doi: 10.15585/mmwr.mm6743a2. PMID: 30383743.30383743
34 Hedderson M, Ehrlich S, Sridhar S, . Racial/ethnic disparities in the prevalence of gestational diabetes mellitus by BMI. Diabetes Care. 2012;35(7):1492–8. doi: 10.2337/dc11-2267. PMID: 22619080.22619080
35 Kim SY, Saraiva C, Curtis M, . Fraction of gestational diabetes mellitus attributable to overweight and obesity by race/ethnicity, California, 2007-2009. Am J Public Health. 2013;103(10):E65–72. doi: 10.2105/ajph.2013.301469. PMID: 23947320.23947320
36 Naylor CD, Sermer M, Chen E, . Selective screening for gestational diabetes mellitus. Toronto Trihospital Gestational Diabetes Project Investigators. N Engl J Med. 1997;337(22):1591–6. doi: 10.1056/nejm199711273372204. PMID: 9371855.9371855
37 Meltzer SJ, Snyder J, Penrod JR, . Gestational diabetes mellitus screening and diagnosis: a prospective randomised controlled trial comparing costs of one-step and two-step methods. BJOG. 2010;117(4):407–15. PMID: 20105163.20105163
38 Dickson LM, Buchmann EJ, Janse van Rensburg C, . Fasting plasma glucose and risk factor assessment: comparing sensitivity and specificity in identifying gestational diabetes in urban black African women. S Afr Med J. 2019;110(1):21–6. PMID: 31865938.31865938
39 O’Sullivan JB. Establishing criteria for gestational diabetes. Diabetes Care. 1980;3(3):437–9. PMID: 7389559.7389559
40 O’Sullivan JB, Mahan CM. Criteria for the oral glucose tolerance test in pregnancy. Diabetes. 1964;13:278–85. PMID: 14166677.14166677
41 Crowther CA, Hiller JE, Moss JR, . Effect of treatment of gestational diabetes mellitus on pregnancy outcomes. N Engl J Med. 2005;352(24):2477–86. doi: 10.1056/NEJMoa042973. PMID: 15951574.15951574
42 Landon MB, Spong CY, Thom E, . A multicenter, randomized trial of treatment for mild gestational diabetes. N Engl J Med. 2009;361(14):1339–48. doi: 10.1056/NEJMoa0902430. PMID: 19797280.19797280
43 Rasmussen SS, Glumer C, Sandbaek A, . Short-term reproducibility of impaired fasting glycaemia, impaired glucose tolerance and diabetes The ADDITION study, DK. Diabetes Res Clin Pract. 2008;80(1):146–52. doi: 10.1016/j.diabres.2007.11.003. PMID: 18082284.18082284
44 American Diabetes Association. 13. Management of diabetes in pregnancy: standards of medical care in diabetes-2018. Diabetes Care. 2018;41(Suppl 1):S137–S43. doi: 10.2337/dc18-S013. PMID: 29222384.29222384
45 American Diabetes Association. 14. Management of diabetes in pregnancy: standards of medical care in diabetes-2020. Diabetes Care. 2020;43(Suppl 1):S183–S92. doi: 10.2337/dc20-S014. PMID: 31862757.31862757
46 Blumer IH, Hadden, DR, Jovanovic, L, . Diabetes and pregnancy: an Endocrine Society clinical practice guideline. J Clin Endocrinol Metab. 2013;98(11):4227–49. doi: 10.1210/jc.2013-2465. PMID: 24194617.24194617
47 World Health Organization. Diagnostic criteria and classification of hyperglycaemia first detected in pregnancy: a World Health Organization Guideline Diagnostic criteria and classification of hyperglycaemia first detected in pregnancy. Diabets Res Clin Pract. 2014;103(3):341–363.
48 Vandorsten JP, Dodson WC, Espeland MA, . NIH Consensus Development Conference: diagnosing gestational diabetes mellitus. NIH Consens State Sci Statements. 2013;29(1):1–31. PMID: 23748438.23748438
49 Bimson BE, Rosenn BM, Morris SA, . Current trends in the diagnosis and management of gestational diabetes mellitus in the United States. J Matern Fetal Neonatal Med. 2017;30(21):2607–12. doi: 10.1080/14767058.2016.1257603. PMID: 27819164.27819164
50 Gabbe S, Gregory R, Power M, . Management of diabetes mellitus by obstetrician-gynecologists. Obstet Gynecol. 2004;103(6):1229–34.15172857
51 Gerome JM, Bucher LKM, Dogbey G. Effects of implementing International Association of Diabetes and Pregnancy Study Groups gestational diabetes screening on pregnancy outcomes at a small community teaching hospital. Clin Diabetes. 2017;35(2):84–9. PMID: 28442822.28442822
52 March MI, Modest AM, Ralston SJ, . The effect of adopting the IADPSG screening guidelines on the risk profile and outcomes of the gestational diabetes population. J Matern-Fetal Neonatal Med. 2016;29(7):1141–5. PMID: 25958989.25958989
53 Feldman RK, Tieu RS, Yasumura L. Gestational diabetes screening: the International Association of the Diabetes and Pregnancy Study Groups compared with Carpenter-Coustan screening. Obstet Gynecol. 2016;127(1):10–7. doi: 10.1097/AOG.0000000000001132. PMID: 26646142.26646142
54 Pocobelli G, Yu O, Fuller S, . One-step approach to identifying gestational diabetes mellitus: association with perinatal outcomes. Obstet Gynecol. 2018;132(4):859–67. PMID: 30130344.30130344
55 Pedula KL, Hillier TA, Ogasawara KK, . A randomized pragmatic clinical trial of gestational diabetes screening (ScreenR2GDM): study design, baseline characteristics, and protocol adherence. Contemp Clin Trials. 2019;85:105829. doi: 10.1016/j.cct.2019.105829. PMID: 31425751.31425751
56 Procedure Manual. U.S. Preventive Services Task Force (USPSTF). USPSTF Website. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual. Accessed June 14, 2021.
57 Moher D, Pham B, Klassen TP, . What contributions do languages other than English make on the results of meta-analyses? J Clin Epidemiol. 2000;53(9):964–72. PMID: 11004423.11004423
58 Morrison A, Polisena J, Husereau D, . The effect of English-language restriction on systematic review-based meta-analyses: a systematic review of empirical studies. Int J Technol Assess Health Care. 2012;28(2):138–44. doi: 10.1017/s0266462312000086. PMID: 22559755.22559755
59 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529–36. doi: 10.7326/0003-4819-155-8-201110180-00009. PMID: 22007046.22007046
60 Wells GA, O’Connell D, Petersen J, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomized studies in meta-analyses. University of Ottawa, Canada; 2000. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed June 14, 2021.
61 Higgins J, Green S (Eds). Cochrane Handbook for Systematic Reviews of Interventions.Version 5.1.0; 2011. https://training.cochrane.org/handbook/archive/v5.1/. Accessed June 14, 2021.
62 Wolff RF, Moons KGM, Riley RD, . PROBAST: a tool to assess the risk of bias and applicability of prediction model studies. Ann Intern Med. 2019;170(1):51–8. doi: 10.7326/m18-1376. PMID: 30596875.30596875
63 National Institute for Health and Care Excellence. Appendix D Methodology checklist: cohort studies. The social care guidance manual. PMG10; 2016. https://www.nice.org.uk/process/pmg10/chapter/about-this-manual Accessed June 15, 2021.
64 Sweeting MJ, Sutton AJ, Lambert PC. What to add to nothing? Use and avoidance of continuity corrections in meta-analysis of sparse data. Stat Med. 2004;15;23(9):1351–75. doi: 10.1002/sim.1761. PMID: 15116347.15116347
65 Reitsma JB, Glas AS, Rutjes AW, . Bivariate analysis of sensitivity and specificity produces informative summary measures in diagnostic reviews. J Clin Epidemiol. 2005;58(10):982–90. doi: 10.1016/j.jclinepi.2005.02.022. PMID: 16168343.16168343
66 Sterne JA, Sutton AJ, Ioannidis JP, . Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;22:343:d4002. doi: 10.1136/bmj.d4002. PMID: 21784880.21784880
67 Hivert MF, Allard C, Menard J, . Impact of the creation of a specialized clinic for prenatal blood sampling and follow-up care in pregnant women. J Obstet Gynaecol Can. 2012;34(3):311–242. PMID: 610739173.22472326
68 Stacey T, Tennant P, McCowan L, . Gestational diabetes and the risk of late stillbirth: a case-control study from England, UK. BJOG. 2019;19:19. PMID: 30891907.30891907
69 Chanprapaph P, Sutjarit C. Prevalence of gestational diabetes mellitus (GDM) in women screened by glucose challenge test (GCT) at Maharaj Nakorn Chiang Mai Hospital. J Med Assoc Thai. 2004;87(10):1141–6. PMID: 15560687.15560687
70 Solomon CG, Willett WC, Rich-Edwards J, . Variability in diagnostic evaluation and criteria for gestational diabetes. Diabetes Care. 1996;19(1):12–6. doi: 10.2337/diacare.19.1.12. PMID: 8720526.8720526
71 Daniells S, Grenyer BF, Davis WS, . Gestational diabetes mellitus: is a diagnosis associated with an increase in maternal anxiety and stress in the short and intermediate term? Diabetes Care. 2003;26(2):385–9. doi: 10.2337/diacare.26.2.385. PMID: 12547867.12547867
72 Doughty KN, Ronnenberg AG, Reeves KW, . Barriers to exclusive breastfeeding among women with gestational diabetes mellitus in the United States. JOGNN. 2018;47(3):301–15. PMID: 29510090.29510090
73 Kerbel D, Glazier R, Holzapfel S, . Adverse effects of screening for gestational diabetes: a prospective cohort study in Toronto, Canada. J Med Screen. 1997;4(3):128–32. doi: 10.1177/096914139700400303. PMID: 9368868.9368868
74 Loewenberg Weisband Y, Rausch J, Kachoria R, . Hospital supplementation differentially impacts the association between breastfeeding intention and duration among women with and without gestational diabetes mellitus history. Breastfeed Med. 2017;12(6):338–44. doi: 10.1089/bfm.2017.0019. PMID: 28631935.28631935
75 Naylor CD, Sermer M, Chen E, . Cesarean delivery in relation to birth weight and gestational glucose tolerance: pathophysiology or practice style? Toronto Trihospital Gestational Diabetes Investigators. JAMA. 1996;275(15):1165–70. PMID: 8609683.8609683
76 Oza-Frank R, Gunderson EP. In-hospital breastfeeding experiences among women with gestational diabetes. Breastfeed Med. 2017;12:261–8. doi: 10.1089/bfm.2016.0197. PMID: 28632447.28632447
77 Rumbold AR, Crowther CA. Women’s experiences of being screened for gestational diabetes mellitus. Aust N Z J Obstet Gynaecol. 2002;42(2):131–7. PMID: 12069138.12069138
78 Satodiya M, Takkar N, Goel P, . Comparison of one-step versus two-step screening for diagnosis of GDM in indian population: a randomized controlled trial. J Obstet Gynaecol India. 2017;67(3):190–5. PMID: 28546666.28546666
79 Griffin ME, Coffey M, Johnson H, . Universal vs. risk factor-based screening for gestational diabetes mellitus: detection rates, gestation at diagnosis and outcome. Diabet Med. 2000;17(1):26–32. PMID: 10691156.10691156
80 Olarinoye JK, Ohwovoriole AE, Ajayi GO. Diagnosis of gestational diabetes mellitus in Nigerian pregnant women-comparison between 75G and 100G oral glucose tolerance tests. West Afr J Med. 2004;23(3):198–201. PMID: 15587828.15587828
81 Basri NI, Mahdy ZA, Ahmad S, . The World Health Organization (WHO) versus the International Association of Diabetes and Pregnancy Study Group (IADPSG) diagnostic criteria of gestational diabetes mellitus (GDM) and their associated maternal and neonatal outcomes. Horm Mol Biol Clin Investig. 2018;34 (1):20170077. PMID: 620980761.
82 Harper LM, Jauk V, Longo S, . Early gestational diabetes screening in obese women: a randomized controlled trial. Am J Obstet Gynecol. 2020;222(5):495.E1–495.E8. doi: 10.1016/j.ajog.2019.12.021. PMID: 31926951.31926951
83 Scifres CM, Abebe KZ, Jones KA, . Gestational diabetes diagnostic methods (GD2M) pilot randomized trial. Matern Child Health J. 2015;19(7):1472–80. PMID: 25424454.25424454
84 Sevket O, Ates S, Uysal O, . To evaluate the prevalence and clinical outcomes using a one-step method versus a two-step method to screen gestational diabetes mellitus. J Matern-Fetal Neonatal Med. 2014;27(1):36–41. PMID: 23617557.23617557
85 Davis EM, Abebe KZ, Simhan HM, . Perinatal outcomes of two screening strategies for gestational diabetes mellitus: a randomized controlled trial. Obstet Gynecol. 2021;138(1). doi: 10.1097/AOG.0000000000004431.
86 Hillier T, Pedula K, Ogasawara K, . A pragmatic, randomized clinical trial of gestational diabetes screening. NEJM. 2021;384(10):895–904. doi: 10.1056/NEJMoa2026028 33704936
87 Khalifeh A, Eckler R, Felder L, . One-step versus two-step diagnostic testing for gestational diabetes: a randomized controlled trial. J Matern-Fetal Neonatal Med. 2018:1–6. PMID: 29985079.29985079
88 Saccone G, Caissutti C, Khalifeh S, . One step versus two step approach for gestational diabetes screening: systematic review and meta-analysis of the randomized trials. Journal of Maternal-Fetal & Neonatal Medicine. 2017:1–9. doi: 10.1080/14767058.2017.1408068. PMID: 29157030.29157030
89 Agarwal MM, Dhatt GS, Punnose J. Gestational diabetes: utility of fasting plasma glucose as a screening test depends on the diagnostic criteria. Diabet Med. 2006;23(12):1319–26. doi: 10.1111/j.1464-5491.2006.01987.x. PMID: 17116182.17116182
90 Agarwal MM, Hughes PF, Punnose J, . Fasting plasma glucose as a screening test for gestational diabetes in a multi-ethnic, high-risk population. Diabet Med. 2000 Oct;17(10):720–6. doi: 10.1046/j.1464-5491.2000.00371.x. PMID: 11110505.11110505
91 Agarwal MM, Hughes PF, Punnose J, . Gestational diabetes screening of a multiethnic, high-risk population using glycated proteins. Diabetes Res Clin Pract. 2001;51(1):67–73. doi: 10.1016/s0168-8227(00)00206-0. PMID: 11137184.11137184
92 Agarwal MM, Punnose J, Sukhija K, . Gestational diabetes mellitus: using the fasting plasma glucose level to simplify the International Association of Diabetes and Pregnancy Study Groups diagnostic algorithm in an adult South Asian population. Can J Diabetes. 2018;42(5):500–4. PMID: 29545111.29545111
93 Ayach W, Costa RA, Calderon Ide M, . Comparison between 100-g glucose tolerance test and two other screening tests for gestational diabetes: combined fasting glucose with risk factors and 50-g glucose tolerance test. Sao Paulo Med J. 2006;124(1):4–9. doi: 10.1590/s1516-31802006000100002. PMID: 16612455.16612455
94 Benaiges D, Flores-Le Roux JA, Marcelo I, . Is first-trimester HbA1c useful in the diagnosis of gestational diabetes? Diabetes Res Clin Pract 2017;133:85–91. PMID: 28918341.28918341
95 Benhalima K, Van Crombrugge P, Moyson C, . A modified two-step screening strategy for gestational diabetes mellitus based on the 2013 WHO criteria by combining the glucose challenge test and clinical risk factors. J Clin Med. 2018;7(10):13. PMID: 30322138.30322138
96 Bhavadharini B, Mahalakshmi MM, Deepa M, . Elevated glycated hemoglobin predicts macrosomia among Asian Indian pregnant women (WINGS-9). Indian J Endocrinol Metab. 2017;21(1):184–9. PMID: 28217520.28217520
97 Braga FO, Negrato CA, Matta M, . Relationship between inflammatory markers, glycated hemoglobin and placental weight on fetal outcomes in women with gestational diabetes. Arch Endocrinol Metab. 2019;63(1):22–9. PMID: 30864628.30864628
98 Cetin M, Cetin A. Time-dependent gestational diabetes screening values. Int J Gynaecol Obstet. 1997;56(3):257–61. doi: 10.1016/s0020-7292(96)02831-7. PMID: 9127158.9127158
99 Chevalier N, Fenichel P, Giaume V, . Universal two-step screening strategy for gestational diabetes has weak relevance in French Mediterranean women: should we simplify the screening strategy for gestational diabetes in France? Diabetes Metab. 2011;37(5):419–25. doi: 10.1016/j.diabet.2011.01.004. PMID: 21489844.21489844
100 De los Monteros AE, Parra A, Hidalgo R, . The after breakfast 50-g, 1-hour glucose challenge test in urban Mexican pregnant women: its sensitivity and specificity evaluated by three diagnostic criteria for gestational diabetes mellitus. Acta Obstet Gynecol Scand. 1999;78(4):294–8. PMID: 10203295.10203295
101 Gobl CS, Bozkurt L, Rivic P, . A two-step screening algorithm including fasting plasma glucose measurement and a risk estimation model is an accurate strategy for detecting gestational diabetes mellitus. Diabetologia. 2012;55(12):3173–81. PMID: 23001377.23001377
102 Ho YR, Wang P, Lu MC, . Associations of mid-pregnancy HbA1c with gestational diabetes and risk of adverse pregnancy outcomes in high-risk Taiwanese women. PLoS ONE. 2017;12(5):E0177563. PMID: 28505205.28505205
103 Hughes RC, Moore MP, Gullam JE, . An early pregnancy HbA1c >=5.9% (41 mmol/mol) is optimal for detecting diabetes and identifies women at increased risk of adverse pregnancy outcomes. Diabetes Care. 2014;37(11):2953–9. PMID: 25190675.25190675
104 Kauffman RP, Castracane VD, Peghee D, . Detection of gestational diabetes mellitus by homeostatic indices of insulin sensitivity: a preliminary study. Am J Obstet Gynecol. 2006;194(6):1576–84. doi: 10.1016/j.ajog.2006.01.010. PMID: 16638603.16638603
105 Khalafallah A, Phuah E, Al-Barazan AM, . Glycosylated haemoglobin for screening and diagnosis of gestational diabetes mellitus. BMJ Open. 2016;6(4):e011059. PMID: 27044587.27044587
106 Lamar ME, Kuehl TJ, Cooney AT, . Jelly beans as an alternative to a fifty-gram glucose beverage for gestational diabetes screening. Am J Obstet Gynecol. 1999;181(5 Pt 1):1154–7. doi: 10.1016/s0002-9378(99)70099-2. PMID: 10561636.10561636
107 Lekva T, Godang K, Michelsen AE, . Prediction of gestational diabetes mellitus and pre-diabetes 5 years postpartum using 75 g oral glucose tolerance test at 14-16 weeks’ gestation. Sci Rep. 2018;8(1):13392. PMID: 30190548.30190548
108 Navid S, Alam K, Tasneem S. Glucose challenge test- Is it an effective screening tool for gestational diabetes mellitus in low risk population? Rawal Medical J. 2014;39(4):428–31. PMID: 600582251.
109 Odsaeter IH, Asberg A, Vanky E, . Hemoglobin A1c as screening for gestational diabetes mellitus in Nordic Caucasian women. Diabetol Metab Syndr. 2016;8:43. PMID: 27453735.27453735
110 Olagbuji BN, Aderoba AK, Kayode OO, . Accuracy of 50-g glucose challenge test to detect International Association of Diabetes and Pregnancy Study Groups criteria-defined hyperglycemia. Int J Gynaecol Obstet. 2017;139(3):312–7. PMID: 28833075.28833075
111 Perea-Carrasco R, Perez-Coronel R, Albusac-Aguilar R, . A simple index for detection of gestational diabetes mellitus. J R Soc Med. 2002;95(9):435–9. doi: 10.1258/jrsm.95.9.435. PMID: 12205206.12205206
112 Perucchini D, Fischer U, Spinas GA, . Using fasting plasma glucose concentrations to screen for gestational diabetes mellitus: prospective population based study. BMJ. 1999;319(7213):812–5. doi: 10.1136/bmj.319.7213.812. PMID: 10496823.10496823
113 Pezeshki B, Chiti H, Arasteh P, . Early screening of gestational diabetes mellitus using hemoglobin A1C: Revising current screening guidelines. Caspian J Intern Med. 2019;10(1):16–24. PMID: 30858937.30858937
114 Poo ZX, Wright A, Ruochen D, . Optimal first trimester HbA1c threshold to identify Singaporean women at risk of gestational diabetes mellitus and adverse pregnancy outcomes: A pilot study. Obstet Med. 2019;12(2):79–84. PMID: 625513130.31217812
115 Poomalar GK, Rangaswamy V. A comparison of fasting plasma glucose and glucose challenge test for screening of gestational diabetes mellitus. J Obstet Gynaecol. 2013;33(5):447–50. PMID: 23815193.23815193
116 Rajput R, Yogesh Y, Rajput M, . Utility of HbA1c for diagnosis of gestational diabetes mellitus. Diabetes Res Clin Pract. 2012;98(1):104–7. doi: 10.1016/j.diabres.2012.02.018. PMID: 22456454.22456454
117 Saadati N, Majlesi M, Barati M, . Determination of relationship between Hba1c levels and early diagnosis of gestational diabetes. Int J Pharm Res Allied Sci. 2016;5(3):252–7. PMID: 610539753.
118 Sacks DA, Chen W, Wolde-Tsadik G, . Fasting plasma glucose test at the first prenatal visit as a screen for gestational diabetes. Obstet Gynecol. 2003;101(6):1197–203. doi: 10.1016/s0029-7844(03)00049-8. PMID: 12798525.12798525
119 Saeedi M, Hanson U, Simmons D, . Characteristics of different risk factors and fasting plasma glucose for identifying GDM when using IADPSG criteria: a cross-sectional study. BMC Pregnancy Childbirth. 2018;18(1):225. PMID: 29898685.29898685
120 Sermer M, Naylor CD, Farine D, . The Toronto Tri-Hospital Gestational Diabetes Project. A preliminary review. Diabetes Care. 1998;21(Suppl 2):B33–42. PMID: 9704225.9704225
121 Sevket O, Sevket A, Ozel A, . The use of HbA1c as an aid in the diagnosis of gestational diabetes mellitus. J Obstet Gynaecol. 2014;34(8):690–2. PMID: 25340849.25340849
122 Sham S, Bhat BPR, Kamath A. Comparative study of fasting plasma glucose concentration and glucose challenge test for screening gestational diabetes mellitus. J SAFOG. 2014;6(2):75–8. PMID: 611871078.
123 Sharma M, Nayanisri K, Jain R, . Predictive value of fasting plasma glucose on first antenatal visit before 20 weeks of gestation to diagnose gestational diabetes mellitus. J Clin Diagn Res. 2018;12(2):QC01–QC4. PMID: 620884219.
124 Siricharoenthai P, Phupong V. Diagnostic accuracy of HbA1c in detecting gestational diabetes mellitus. J Matern-Fetal Neonatal Med. 2019:1–4. PMID: 30691324.30691324
125 Soumya S, Rohilla M, Chopra S, . HbA1c: A useful screening test for gestational diabetes mellitus. Diabetes Technol Ther. 2015;17(12):899–904. PMID: 26496534.26496534
126 Trujillo J, Vigo A, Reichelt A, . Fasting plasma glucose to avoid a full OGTT in the diagnosis of gestational diabetes. Diabetes Res Clin Pract. 2014;105(3):322–6. doi: 10.1016/j.diabres.2014.06.001.25037441
127 Uncu G, Ozan H, Cengiz C. The comparison of 50 grams glucose challenge test, HbA1c and fructosamine levels in diagnosis of gestational diabetes mellitus. Clin Exp Obstet Gynecol. 1995;22(3):230–4. PMID: 7554262.7554262
128 Veres M, Creiut DI, Trutz J, . The utility of glycated hemoglobin, determined in the second trimester of pregnancy, in diagnosing gestational diabetes. Rom J Diabetes Nutr Metab Dis. 2015;22(3):233–40. PMID: 608162856.
129 Weerakiet S, Lertnarkorn K, Panburana P, . Can adiponectin predict gestational diabetes? Gynecol Endocrinol. 2006;22(7):362–8. doi: 10.1080/09513590600818919. PMID: 16864145.16864145
130 Wu K, Cheng Y, Li T, . The utility of HbA1c combined with haematocrit for early screening of gestational diabetes mellitus. Diabetol Metab Syndr. 2018;10:14. PMID: 29541163.29541163
131 Zhu WW, Fan L, Yang HX, . Fasting plasma glucose at 24-28 weeks to screen for gestational diabetes mellitus: new evidence from China. Diabetes Care. 2013;36(7):2038–40. PMID: 23536582.23536582
132 Zhu WW, Yang HX, Wei YM, . Evaluation of the value of fasting plasma glucose in the first prenatal visit to diagnose gestational diabetes mellitus in China. Diabetes Care. 2013;36(3):586–90. PMID: 368426090.23193214
133 Benhalima K, Van Crombrugge P, Moyson C, . The sensitivity and specificity of the glucose challenge test in a universal two-step screening strategy for gestational diabetes mellitus using the 2013 World Health Organization Criteria. Diabetes Care. 2018;41(7):E111–E2. PMID: 29748432.29748432
134 Agarwal MM, Dhatt GS, Punnose J, . Gestational diabetes: a reappraisal of HBA1c as a screening test. Acta Obstet Gynecol Scand. 2005;84(12):1159–63. doi: 10.1111/j.0001-6349.2005.00650.x. PMID: 16305701.16305701
135 Agarwal MM, Dhatt GS, Punnose J, . Gestational diabetes in a high-risk population: using the fasting plasma glucose to simplify the diagnostic algorithm. Eur J Obstet Gynecol Reprod Biol. 2005;120(1):39–44. doi: 10.1016/j.ejogrb.2004.07.034. PMID: 15866084.15866084
136 Balaji V, Balaji M, Anjalakshi C, . Inadequacy of fasting plasma glucose to diagnose gestational diabetes mellitus in Asian Indian women. Diabetes Res Clin Pract. 2011;94(1):e21–3. doi: 10.1016/j.diabres.2011.07.008. PMID: 21831468.21831468
137 Maegawa Y, Sugiyama T, Kusaka H, . Screening tests for gestational diabetes in Japan in the 1st and 2nd trimester of pregnancy. Diabetes Res Clin Pract. 2003;62(1):47–53. doi: 10.1016/s0168-8227(03)00146-3. PMID: 14581157.14581157
138 Ostlund I, Hanson U. Occurrence of gestational diabetes mellitus and the value of different screening indicators for the oral glucose tolerance test. Acta Obstet Gynecol Scand. 2003;82(2):103–8. doi: 10.1034/j.1600-0412.2003.00001.x. PMID: 12648169.12648169
139 Reichelt AJ, Spichler ER, Branchtein L, . Fasting plasma glucose is a useful test for the detection of gestational diabetes. Brazilian Study of Gestational Diabetes (EBDG) Working Group. Diabetes Care. 1998;21(8):1246–9. doi: 10.2337/diacare.21.8.1246. PMID: 9702428.9702428
140 Siribaddana SH, Deshabandu R, Rajapakse D, . The prevalence of gestational diabetes in a Sri Lankan antenatal clinic. Ceylon Med J. 1998;43(2):88–91. PMID: 9704548.9704548
141 van Leeuwen M, Opmeer BC, Zweers EJ, . External validation of a clinical scoring system for the risk of gestational diabetes mellitus. Diabetes Res Clin Pract. 2009;85(1):96–101. doi: 10.1016/j.diabres.2009.04.025. PMID: 19477547.19477547
142 van Leeuwen M, Zweers EJ, Opmeer BC, . Comparison of accuracy measures of two screening tests for gestational diabetes mellitus. Diabetes Care. 2007;30(11):2779–84. doi: 10.2337/dc07-0571. PMID: 17698616.17698616
143 Wijeyaratne CN, Ginige S, Arasalingam A, . Screening for gestational diabetes mellitus: the Sri Lankan experience. Ceylon Med J. 2006;51(2):53–8. doi: 10.4038/cmj.v51i2.1353. PMID: 17180809.17180809
144 Agarwal MM, Dhatt GS, Safraou MF. Gestational diabetes: using a portable glucometer to simplify the approach to screening. Gynecol Obstet Invest. 2008;66(3):178–83. doi: 10.1159/000140602. PMID: 18562798.18562798
145 Balaji V, Madhuri BS, Paneerselvam A, . Comparison of venous plasma glucose and capillary whole blood glucose in the diagnosis of gestational diabetes mellitus: a community-based study. Diabetes Technol Ther. 2012;14(2):131–4. doi: 10.1089/dia.2011.0060. PMID: 21992269.21992269
146 Berkus MD, Langer O. Glucose tolerance test periodicity: the effect of glucose loading. Obstet Gynecol. 1995;85(3):423–7. doi: 10.1016/0029-7844(94)00410-f. PMID: 7862384.7862384
147 Brustman LE, Gela BD, Moore M, . Variations in oral glucose tolerance tests: the 100- versus 75-g controversy. J Assoc Acad Minor Phys. 1995;6(2):70–2. PMID: 7772935.7772935
148 Chastang N, Hartemann-Heurtier A, Sachon C, . Comparison of two diagnostic tests for gestational diabetes in predicting macrosomia. Diabetes Metab. 2003;29(2 Pt 1):139–44. doi: 10.1016/s1262-3636(07)70020-4. PMID: 12746634.12746634
149 Jakobi P, Weissman A, Egozi J, . Perinatal significance of diagnosing glucose intolerance during pregnancy with portable glucose meter. J Perinat Med. 2003;31(2):140–5. doi: 10.1515/jpm.2003.019. PMID: 12747230.12747230
150 Mello G, Elena P, Ognibene A, . Lack of concordance between the 75-g and 100-g glucose load tests for the diagnosis of gestational diabetes mellitus. Clin Chem. 2006;52(9):1679–84. doi: 10.1373/clinchem.2005.058040. PMID: 16873295.16873295
151 Moses RG, Morris GJ, Petocz P, . The impact of potential new diagnostic criteria on the prevalence of gestational diabetes mellitus in Australia. Med J Aust. 2011;194(7):338–40. PMID: 21470082.21470082
152 Soonthornpun S, Soonthornpun K, Aksonteing J, . A comparison between a 75-g and 100-g oral glucose tolerance test in pregnant women. Int J Gynaecol Obstet. 2003;81(2):169–73. doi: 10.1016/s0020-7292(03)00031-6. PMID: 12706274.12706274
153 Ardawi MS, Nasrat HA, Jamal HS, . Screening for gestational diabetes mellitus in pregnant females. Saudi Med J. 2000;21(2):155–60. PMID: 11533772.11533772
154 Bobrowski RA, Bottoms SF, Micallef JA, . Is the 50-gram glucose screening test ever diagnostic? J Matern Fetal Med. 1996;5(6):317–20. doi: 10.1002/(sici)1520-6661(199611/12)5:6<317::aid-mfm5>3.0.co;2-s. PMID: 8972407.8972407
155 Buhling KJ, Elze L, Henrich W, . The usefulness of glycosuria and the influence of maternal blood pressure in screening for gestational diabetes. Eur J Obstet Gynecol Reprod Biol. 2004;113(2):145–8. doi: 10.1016/j.ejogrb.2003.06.013. PMID: 15063950.15063950
156 Deerochanawong C, Putiyanun C, Wongsuryrat M, . Comparison of National Diabetes Data Group and World Health Organization criteria for detecting gestational diabetes mellitus. Diabetologia. 1996;39(9):1070–3. doi: 10.1007/bf00400656. PMID: 8877291.8877291
157 Eslamian L, Ramezani Z. Evaluation of a breakfast as screening test for the detection of gestational diabetes. Acta Med Iran. 2008;46(1):43–6.
158 Gandevani SB, Garshasbi A, Dibaj S. Cut-off value of 1-h, 50-g glucose challenge test for screening of gestational diabetes mellitus in an Iranian population. J Obstet Gynaecol Res. 2011;37(6):534–7. doi: 10.1111/j.1447-0756.2010.01400.x. PMID: 21375670.21375670
159 Jensen DM, Molsted-Pedersen L, Beck-Nielsen H, . Screening for gestational diabetes mellitus by a model based on risk indicators: a prospective study. Am J Obstet Gynecol. 2003;189(5):1383–8. doi: 10.1067/s0002-9378(03)00601-x. PMID: 14634573.14634573
160 Kashi Z, Bourzouei SA, O, Moslemizadeh N, . Diagnostic value of fasting plasma glucose in screening of gestational diabetes mellitus. Int J Endrocrinol Metab. 2007;1:1–4.
161 Poyhonen-Alho MK, Teramo KA, Kaaja RJ, . 50gram oral glucose challenge test combined with risk factor-based screening for gestational diabetes. Eur J Obstet Gynecol Reprod Biol. 2005;121(1):34–7. doi: 10.1016/j.ejogrb.2004.10.008. PMID: 15989983.15989983
162 Rey E, Hudon L, Michon N, . Fasting plasma glucose versus glucose challenge test: screening for gestational diabetes and cost effectiveness. Clin Biochem. 2004;37(9):780–4. doi: 10.1016/j.clinbiochem.2004.05.018. PMID: 15329316.15329316
163 Rust O, Bofill JA, Carroll SC, . Two-hour postprandial test versus one-hour, fifty-gram glucola test as screening tools for gestational diabetes: a critical analysis. J Perinatol. 1998;18(1):49–54. PMID: 9527945.9527945
164 Soheilykhah S, Rashidi M, Mojibian M, . An appropriate test for diagnosis of gestational diabetes mellitus. Gynecol Endocrinol. 2011;27(10):785–8. doi: 10.3109/09513590.2010.540598. PMID: 21250875.21250875
165 Tan PC, Ling LP, Omar SZ. Screening for gestational diabetes at antenatal booking in a Malaysian university hospital: the role of risk factors and threshold value for the 50-g glucose challenge test. Aust N Z J Obstet Gynaecol. 2007;47(3):191–7. doi: 10.1111/j.1479-828X.2007.00717.x. PMID: 17550485.17550485
166 Yachi Y, Tanaka Y, Anasako Y, . Contribution of first trimester fasting plasma insulin levels to the incidence of glucose intolerance in later pregnancy: Tanaka women’s clinic study. Diabetes Res Clin Pract. 2011;92(2):293–8. doi: 10.1016/j.diabres.2011.02.012. PMID: 21396732.21396732
167 Yogev Y, Langer O, Xenakis EM, . Glucose screening in Mexican-American women. Obstet Gynecol. 2004;103(6):1241–5. doi: 10.1097/01.AOG.0000124781.98059.fe. PMID: 15172859.15172859
168 Hill JC, Krishnaveni GV, Annamma I, . Glucose tolerance in pregnancy in South India: relationships to neonatal anthropometry. Acta Obstet Gynecol Scand. 2005;84(2):159–65. doi: 10.1111/j.0001-6349.2005.00670.x. PMID: 15683377.15683377
169 Aberg A, Rydhstroem H, Frid A. Impaired glucose tolerance associated with adverse pregnancy outcome: a population-based study in southern Sweden. Am J Obstet Gynecol. 2001;184(2):77–83. doi: 10.1067/mob.2001.108085. PMID: 11174484.11174484
170 Adams KM, Li H, Nelson RL, . Sequelae of unrecognized gestational diabetes. Am J Obstet Gynecol. 1998;178(6):1321–32. doi: 10.1016/s0002-9378(98)70339-4. PMID: 9662318.9662318
171 Berggren EK, Boggess KA, Stuebe AM, . National Diabetes Data Group vs Carpenter-Coustan criteria to diagnose gestational diabetes. Am J Obstet Gynecol. 2011;205(3):253.E1–7. doi: 10.1016/j.ajog.2011.06.026. PMID: 22071053.22071053
172 Black MH, Sacks DA, Xiang AH, . Clinical outcomes of pregnancies complicated by mild gestational diabetes mellitus differ by combinations of abnormal oral glucose tolerance test values. Diabetes Care. 2010;33(12):2524–30. doi: 10.2337/dc10-1445. PMID: 20843973.20843973
173 Bo S, Menato G, Gallo ML, . Mild gestational hyperglycemia, the metabolic syndrome and adverse neonatal outcomes. Acta Obstet Gynecol Scand. 2004;83(4):335–40. doi: 10.1111/j.0001-6349.2004.00314.x. PMID: 15005779.15005779
174 Cheng YW, Block-Kurbisch I, Caughey AB. Carpenter-Coustan criteria compared with the national diabetes data group thresholds for gestational diabetes mellitus. Obstet Gynecol. 2009;114(2 Pt 1):326–32. doi: 10.1097/AOG.0b013e3181ae8d85. PMID: 19622994.19622994
175 Chou CY, Lin CL, Yang CK, . Pregnancy outcomes of Taiwanese women with gestational diabetes mellitus: a comparison of Carpenter-Coustan and National Diabetes Data Group criteria. J Womens Health (Larchmt). 2010;19(5):935–9. doi: 10.1089/jwh.2009.1620. PMID: 20370431.20370431
176 Cok T, Tarim E, Bagis T. Isolated abnormal value during the 3-hour glucose tolerance test: which value is associated with macrosomia? J Matern Fetal Neonatal Med. 2011;24(8):1039–41. doi: 10.3109/14767058.2010.545910. PMID: 21247232.21247232
177 Jensen DM, Damm P, Sorensen B, . Proposed diagnostic thresholds for gestational diabetes mellitus according to a 75-g oral glucose tolerance test. Maternal and perinatal outcomes in 3260 Danish women. Diabet Med. 2003;20(1):51–7. doi: 10.1046/j.1464-5491.2003.00857.x. PMID: 12519320.12519320
178 Kwik M, Seeho SK, Smith C, . Outcomes of pregnancies affected by impaired glucose tolerance. Diabetes Res Clin Pract. 2007;77(2):263–8. doi: 10.1016/j.diabres.2006.12.004. PMID: 17275121.17275121
179 Langer O, Yogev Y, Most O, . Gestational diabetes: the consequences of not treating. Am J Obstet Gynecol. 2005;192(4):989–97. doi: 10.1016/j.ajog.2004.11.039. PMID: 15846171.15846171
180 Lao TT, Ho LF. Does maternal glucose intolerance affect the length of gestation in singleton pregnancies? J Soc Gynecol Investig. 2003;10(6):366–71. doi: 10.1016/s1071-5576(03)00115-1. PMID: 12969780.12969780
181 Lao TT, Tam KF. Gestational diabetes diagnosed in third trimester pregnancy and pregnancy outcome. Acta Obstet Gynecol Scand. 2001;80(11):1003–8. doi: 10.1034/j.1600-0412.2001.801106.x. PMID: 11703196.11703196
182 Morikawa M, Yamada T, Yamada T, . Change in the number of patients after the adoption of IADPSG criteria for hyperglycemia during pregnancy in Japanese women. Diabetes Res Clin Pract. 2010;90(3):339–42. doi: 10.1016/j.diabres.2010.08.023. PMID: 20870307.20870307
183 Nord E, Hanson U, Persson B. Blood glucose limits in the diagnosis of impaired glucose tolerance during pregnancy. Relation to morbidity. Acta Obstet Gynecol Scand. 1995;74(8):589–93. doi: 10.3109/00016349509013467. PMID: 7660761.7660761
184 Pennison EH, Egerman RS. Perinatal outcomes in gestational diabetes: a comparison of criteria for diagnosis. Am J Obstet Gynecol. 2001;184(6):1118–21. doi: 10.1067/mob.2001.114918. PMID: 11349174.11349174
185 Ricart W, Lopez J, Mozas J, . Potential impact of American Diabetes Association (2000) criteria for diagnosis of gestational diabetes mellitus in Spain. Diabetologia. 2005;48(6):1135–41. doi: 10.1007/s00125-005-1756-9. PMID: 15889233.15889233
186 Sacks DA, Greenspoon JS, Abu-Fadil S, . Toward universal criteria for gestational diabetes: the 75-gram glucose tolerance test in pregnancy. Am J Obstet Gynecol. 1995;172(2 Pt 1):607–14. doi: 10.1016/0002-9378(95)90580-4. PMID: 7856693.7856693
187 Schwartz ML, Ray WN, Lubarsky SL. The diagnosis and classification of gestational diabetes mellitus: is it time to change our tune? Am J Obstet Gynecol. 1999;180(6 Pt 1):1560–71. doi: 10.1016/s0002-9378(99)70052-9. PMID: 10368504.10368504
188 Shirazian N, Mahboubi M, Emdadi R, . Comparison of different diagnostic criteria for gestational diabetes mellitus based on the 75-g oral glucose tolerance test: a cohort study. Endocr Pract. 2008;14(3):312–7. doi: 10.4158/ep.14.3.312. PMID: 18463038.18463038
189 Stamilio DM, Olsen T, Ratcliffe S, . False-positive 1-hour glucose challenge test and adverse perinatal outcomes. Obstet Gynecol. 2004;103(1):148–56. doi: 10.1097/01.aog.0000109220.24211.bd. PMID: 14704259.14704259
190 Tan PC, Ling LP, Omar SZ. The 50-g glucose challenge test and pregnancy outcome in a multiethnic Asian population at high risk for gestational diabetes. Int J Gynaecol Obstet. 2009;105(1):50–5. doi: 10.1016/j.ijgo.2008.11.038. PMID: 19154997.19154997
191 Yang X, Hsu-Hage B, Zhang H, . Women with impaired glucose tolerance during pregnancy have significantly poor pregnancy outcomes. Diabetes Care. 2002;25(9):1619–24. doi: 10.2337/diacare.25.9.1619. PMID: 12196437.12196437
192 Arbib N, Gabbay-Benziv R, Aviram A, . Third trimester abnormal oral glucose tolerance test and adverse perinatal outcome. J Matern-Fetal Neonatal Med. 2017;30(8):917–21. PMID: 27186963.27186963
193 Benhalima K, Hanssens M, Devlieger R, . Analysis of pregnancy outcomes using the new IADPSG recommendation compared with the Carpenter and Coustan criteria in an area with a low prevalence of gestational diabetes. Int J Endocrinol. 2013;2013:248121. PMID: 23365571.23365571
194 Berkus MD, Langer O, Piper JM, . Efficiency of lower threshold criteria for the diagnosis of gestational diabetes. Obstet Gynecol. 1995;86(6):892–6. doi: 10.1016/0029-7844(95)00319-m. PMID: 7501334.7501334
195 Biri A, Korucuoglu U, Ozcan P, . Effect of different degrees of glucose intolerance on maternal and perinatal outcomes. J Matern Fetal Neonatal Med. 2009;22(6):473–8. doi: 10.1080/14767050802610344. PMID: 19479645.19479645
196 Chico A, Lopez-Rodo V, Rodriguez-Vaca D, . Features and outcome of pregnancies complicated by impaired glucose tolerance and gestational diabetes diagnosed using different criteria in a Spanish population. Diabetes Res Clin Pract. 2005;68(2):141–6. doi: 10.1016/j.diabres.2004.09.009. PMID: 15860242.15860242
197 Corrado F, Benedetto AD, Cannata ML, . A single abnormal value of the glucose tolerance test is related to increased adverse perinatal outcome. J Matern-Fetal Neonatal Med. 2009;22(7):597–601. doi: 10.1080/14767050902801801. PMID: 19488948.19488948
198 Davis EM, Scifres CM, Abebe K, . Comparison of birth outcomes by gestational diabetes screening criteria. Am J Perinatol Rep. 2018;8(4):E280–E8. PMID: 30450267.30450267
199 Derks IPM, Hivert MF, Rifas-Shiman SL, . Associations of prenatal exposure to impaired glucose tolerance with eating in the absence of hunger in early adolescence. Int J Obes. 2019;43(10):1903–13. PMID: 30622313.30622313
200 Ethridge JK, Jr., Catalano PM, Waters TP. Perinatal outcomes associated with the diagnosis of gestational diabetes made by the International Association of the Diabetes and Pregnancy Study Groups criteria. Obstet Gynecol. 2014;124(3):571–8. PMID: 25162258.25162258
201 Heetchuay T, Punpuckdeekoon P. Adverse outcomes of pregnancy with single abnormal value of 100-gram oral glucose tolerance test in Phramongkutklao hospital. J Med Assoc Thai. 2017;100(5):479–87. PMID: 616837307.
202 Hillier TA, Pedula KL, Schmidt MM, . Childhood obesity and metabolic imprinting: the ongoing effects of maternal hyperglycemia. Diabetes Care. 2007;30(9):2287–92. doi: 10.2337/dc06-2361. PMID: 17519427.17519427
203 Hirst JE, Tran TS, Do MA, . Consequences of gestational diabetes in an urban hospital in Viet Nam: a prospective cohort study. PLoS Med. 2012;9(7):E1001272. PMID: 22911157.22911157
204 Kaymak O, Iskender CT, Ustunyurt E, . Retrospective evaluation of perinatal outcome in women with mild gestational hyperglycemia. J Obstet Gynaecol Res. 2011;37(8):986–91. PMID: 21463427.21463427
205 Kim HS, Chang KH, Yang JI, . Clinical outcomes of pregnancy with one elevated glucose tolerance test value. Int J Gynaecol Obstet. 2002;78(2):131–8. doi: 10.1016/s0020-7292(02)00129-7. PMID: 12175714.12175714
206 Kim MH, Kwak SH, Kim SH, . Pregnancy outcomes of women additionally diagnosed as gestational diabetes by the International Association of the Diabetes and Pregnancy Study Groups criteria. Diabetes Metab J. 2019;28:28. PMID: 30877713.30877713
207 Koivunen S, Viljakainen M, Mannisto T, . Pregnancy outcomes according to the definition of gestational diabetes. PLoS ONE. 2020;15(3):E0229496. PMID: 32134959.32134959
208 Landon MB, Mele L, Spong CY, . The relationship between maternal glycemia and perinatal outcome. Obstet Gynecol. 2011;117(2 Pt 1):218–24. doi: 10.1097/aog.0b013e318203ebe0. PMID: 21309194.21309194
209 Lapolla A, Dalfra MG, Bonomo M, . Can plasma glucose and HbA1c predict fetal growth in mothers with different glucose tolerance levels? Diabetes Res Clin Pract. 2007;77(3):465–70. doi: 10.1016/j.diabres.2007.01.022. PMID: 17350135.17350135
210 Lapolla A, Dalfra MG, Ragazzi E, . New International Association of the Diabetes and Pregnancy Study Groups (IADPSG) recommendations for diagnosing gestational diabetes compared with former criteria: a retrospective study on pregnancy outcome. Diabet Med. 2011;28(9):1074–7. doi: 10.1111/j.1464-5491.2011.03351.x. PMID: 21658125.21658125
211 Lee KH, Han YJ, Chung JH, . Treatment of gestational diabetes diagnosed by the IADPSG criteria decreases excessive fetal growth. Obstet Gynecol Sci. 2020;63(1):19–26. PMID: 31970124.31970124
212 Martinez-Cruz N, Rapisarda AMC, Soriano-Ortega KP, . Perinatal outcomes in mexican women with untreated mild gestational diabetes mellitus diagnosed by the International Association of Diabetes and Pregnancy Study Groups criteria. Diabetes Metab Syndr Obes. 2019;12:2667–74. PMID: 31908507.31908507
213 Murat Seval M, Cavkaytar S, Atak Z, . Should we interpret the results of ‘two-step’ glucose screening again according to the obstetric outcomes? J Obstet Gynaecol. 2016;36(6):705–9. PMID: 27012881.27012881
214 Park TC, Lee BH, Norwitz ER, . Maternal hyperglycemia and the 100-g oral glucose tolerance test. Taiwan J Obstet Gynecol. 2015;54(2):137–42. PMID: 25951717.25951717
215 Retnakaran R, Qi Y, Sermer M, . Glucose intolerance in pregnancy and future risk of pre-diabetes or diabetes. Diabetes Care. 2008;31(10):2026–31. doi: 10.2337/dc08-0972. PMID: 18628572.18628572
216 Rust OA, Bofill JA, Andrew ME, . Lowering the threshold for the diagnosis of gestational diabetes. Am J Obstet Gynecol. 1996;175(4 Pt 1):961–5. doi: 10.1016/s0002-9378(96)80032-9. PMID: 8885755.8885755
215 Sermer M, Naylor CD, Gare DJ, . Impact of increasing carbohydrate intolerance on maternal-fetal outcomes in 3637 women without gestational diabetes. The Toronto Tri-Hospital Gestational Diabetes Project. Am J Obstet Gynecol. 1995;173(1):146–56. doi: 10.1016/0002-9378(95)90183-3. PMID: 7631672.7631672
218 Shang M, Lin L, Ma L, . Investigation on the suitability of the International Association of Diabetes and Pregnancy Study Group diagnostic criteria for gestational diabetes mellitus in China. J Obstet Gynaecol. 2014;34(2):141–5. PMID: 372205659.24456434
219 Vambergue A, Nuttens MC, Verier-Mine O, . Is mild gestational hyperglycaemia associated with maternal and neonatal complications? The Diagest Study. Diabet Med. 2000;17(3):203–8. doi: 10.1046/j.1464-5491.2000.00237.x. PMID: 10784224.10784224
220 Wang P, Lu MC, Yan YH. Abnormal glucose tolerance is associated with preterm labor and increased neonatal complications in Taiwanese women. Taiwan J Obstet Gynecol. 2013;52(4):479–84. PMID: 24411030.24411030
221 Waters TP, Dyer AR, Scholtens DM, . Maternal and neonatal morbidity for women who would be added to the diagnosis of GDM using IADPSG criteria: a secondary analysis of the Hyperglycemia and Adverse Pregnancy Outcome Study. Diabetes Care. 2016;39(12):2204–10. PMID: 27634392.27634392
222 Wei Y, Yang H, Zhu W, . International Association of Diabetes and Pregnancy Study Group criteria is suitable for gestational diabetes mellitus diagnosis: further evidence from China. Chin Med J. 2014;127(20):3553–6. PMID: 25316228.25316228
223 Retnakaran R, Qi Y, Connelly PW, . Glucose intolerance in pregnancy and postpartum risk of metabolic syndrome in young women. J Clin Endocrinol Metab. 2010;95(2):670–7. PMID: 19926711.19926711
224 Bevier WC, Fischer R, Jovanovic L. Treatment of women with an abnormal glucose challenge test (but a normal oral glucose tolerance test) decreases the prevalence of macrosomia. Am J Perinatol. 1999;16(6):269–75. doi: 10.1055/s-2007-993871. PMID: 10586979.10586979
225 Bonomo M, Corica D, Mion E, . Evaluating the therapeutic approach in pregnancies complicated by borderline glucose intolerance: a randomized clinical trial. Diabet Med. 2005;22(11):1536–41. doi: 10.1111/j.1464-5491.2005.01690.x. PMID: 16241919.16241919
226 Garner P, Okun N, Keely E, . A randomized controlled trial of strict glycemic control and tertiary level obstetric care versus routine obstetric care in the management of gestational diabetes: a pilot study. Am J Obstet Gynecol. 1997;177(1):190–5. doi: 10.1016/s0002-9378(97)70461-7. PMID: 9240606.9240606
227 Bonomo M, Gandini ML, Farina A, . Should we treat minor degrees of glucose intolerance in pregnancy? Ann Ist Super Sanita. 1997;33(3):393–7. PMID: 9542269.9542269
228 Fassett MJ, Dhillon SH, Williams TR. Effects on perinatal outcome of treating women with 1 elevated glucose tolerance test value. Am J Obstet Gynecol. 2007;196(6):597.E1–4. doi: 10.1016/j.ajog.2007.03.017. PMID: 17547912.17547912
229 Deveer R, Deveer M, Akbaba E, . The effect of diet on pregnancy outcomes among pregnant with abnormal glucose challenge test. Eur Rev Med Pharmacol Sci. 2013;17(9):1258–61. PMID: 23690197.23690197
230 Fadl HE, Gardefors S, Hjertberg R, . Randomized controlled study in pregnancy on treatment of marked hyperglycemia that is short of overt diabetes. Acta Obstet Gynecol Scand. 2015;94(11):1181–7. PMID: 26222270.26222270
231 Hughes RCE, Rowan J, Williman J. Prediabetes in pregnancy, can early intervention improve outcomes? A feasibility study for a parallel randomised clinical trial. BMJ Open. 2018;8(3):E018493. PMID: 29502087.29502087
232 Kokanali MK, Tokmak A, Kaymak O, . The effect of treatment on pregnancy outcomes in women with one elevated oral glucose tolerance test value. Ginekol Pol. 2014;85(10):748–53. PMID: 25546925.25546925
233 Osmundson SS, Norton ME, El-Sayed YY, . Early screening and treatment of women with prediabetes: a randomized controlled trial. Am J Perinatol. 2016;33(2):172–9. PMID: 26344009.26344009
234 Simmons D, Nema J, Parton C, . The treatment of booking gestational diabetes mellitus (TOBOGM) pilot randomised controlled trial. BMC Pregnancy Childbirth. 2018;18(1):151. PMID: 29747594.29747594
235 Vinter CA, Tanvig MH, Christensen MH, . Lifestyle intervention in danish obese pregnant women with early gestational diabetes mellitus according to WHO 2013 criteria does not change pregnancy outcomes: results from the LiP (Lifestyle in Pregnancy) Study. Diabetes Care. 2018;41(10):2079–85. PMID: 30061318.30061318
236 Yang X, Tian H, Zhang F, . A randomised translational trial of lifestyle intervention using a 3-tier shared care approach on pregnancy outcomes in Chinese women with gestational diabetes mellitus but without diabetes. J Transl Med. 2014;12:290. PMID: 25349017.25349017
237 Berggren EK, Mele L, Landon MB, . Perinatal outcomes in Hispanic and non-Hispanic white women with mild gestational diabetes. Obstet Gynecol. 2012;120(5):1099–104. PMID: 23090528.23090528
238 Casey BM, Mele L, Landon MB, . Does maternal body mass index influence treatment effect in women with mild gestational diabetes? Am J Perinatol. 2015;32(1):93–100. PMID: 24839145.24839145
239 Harper LM, Mele L, Landon MB, . Carpenter-Coustan compared with National Diabetes Data Group Criteria for diagnosing gestational diabetes. Obstet Gynecol. 2016;127(5):893–8. PMID: 27054932.27054932
240 Palatnik A, Mele L, Landon MB, . Timing of treatment initiation for mild gestational diabetes mellitus and perinatal outcomes. Am J Obstet Gynecol. 2015;213(4):560.E1–8. PMID: 26071920.26071920
241 Casey BM, Rice MM, Landon MB, . Effect of treatment of mild gestational diabetes on long-term maternal outcomes. Am J Perinatol. 2019;13:13. PMID: 30866027.30866027
242 Landon MB, Rice MM, Varner MW, . Mild gestational diabetes mellitus and long-term child health. Diabetes Care. 2015;38(3):445–52. PMID: 25414152.25414152
243 Gillman MW, Oakey H, Baghurst PA, . Effect of treatment of gestational diabetes mellitus on obesity in the next generation. Diabetes Care. 2010;33(5):964–8. PMID: 20150300.20150300
244 Malcolm JC, Lawson ML, Gaboury I, . Glucose tolerance of offspring of mother with gestational diabetes mellitus in a low-risk population. Diabet Med. 2006;23(5):565–70. doi: 10.1111/j.1464-5491.2006.01840.x. PMID: 16681566.16681566
245 Farrar DS, Griffin S, Duarte A, . The identification and treatment of women with hyperglycaemia in pregnancy: an analysis of individual participant data, systematic reviews, meta-analyses and an economic evaluation. Health Technol Assess. 2016;20(86):1–348. PMID: 27917777.27917777
246 Ezell JM, Peters RM, Shill JE, . Association between prenatal one-hour glucose challenge test values and delivery mode in nondiabetic, pregnant black women. J Pregnancy. 2015;2015:835613. PMID: 26101668.26101668
247 Scholtens DM, Kuang A, Lowe LP, . Hyperglycemia and adverse pregnancy outcome follow-up study (HAPO FUS): maternal glycemia and childhood glucose metabolism. Diabetes Care. 2019;42(3):381–92. PMID: 30617141.30617141
248 Sesmilo G, Meler E, Perea V, . Maternal fasting glycemia and adverse pregnancy outcomes in a Mediterranean population. Acta Diabetol. 2017;54(3):293–9. PMID: 28044196.28044196
249 Stuebe AM, Landon MB, Lai Y, . Is there a threshold oral glucose tolerance test value for predicting adverse pregnancy outcome? Am J Perinatol. 2015;32(9):833–8. PMID: 25594222.25594222
250 Lowe LP, Metzger BE, Dyer AR, . Hyperglycemia and Adverse Pregnancy Outcome (HAPO) study: associations of maternal A1C and glucose with pregnancy outcomes. Diabetes Care. 2012;35(3):574–80. PMID: 22301123.22301123
251 Roeder H, Moore TR, Wolfson T, . Treating hyperglycemia in early pregnancy: a randomized controlled trial. Am J Obstet Gynecol. 2019;1(1):33–41.
252 Immanuel J, Simmons D. Screening and treatment for early-onset gestational diabetes mellitus: a systematic review and meta-analysis. Curr Diabetes Rep. 2017;17(11):115. PMID: 28971305.28971305
253 Sweeting AN, Ross GP, Hyett J, . Gestational diabetes mellitus in early pregnancy: evidence for poor pregnancy outcomes despite treatment. Diabetes Care. 2016;39(1):75–81. PMID: 26645084.26645084
254 Feghali MN, Abebe KZ, Comer DM, . Pregnancy outcomes in women with an early diagnosis of gestational diabetes mellitus. Diabetes Res Clin Pract. 2018;138:177–86. PMID: 29427694.29427694
255 Hong WY, Biggio JR, Tita A, . Impact of early screening for gestational diabetes on perinatal outcomes in high-risk women. Am J Perinatol. 2016;33(8):758–64. PMID: 26890436.26890436
256 Ravangard SF, Scott AE, Mastrogiannis D, . Early diabetes screening in obese women. J Matern-Fetal Neonatal Med. 2017;30(23):2784–8. PMID: 27881033.27881033
257 Mustafa M, Bogdanet D, Khattak A, . Early gestational diabetes (GDM) is associated with worse pregnancy outcomes compared to GDM diagnosed at 24-28weeks gestation despite early treatment. QJM. 2020;15:15. PMID: 32413109.32413109
258 Xiang AH, Wang X, Martinez MP, . Association of maternal diabetes with autism in offspring. JAMA. 2015;313(14):1425–34. PMID: 25871668.25871668
259 Xiang AH, Wang X, Martinez MP, . Maternal gestational diabetes mellitus, type 1 diabetes, and type 2 diabetes during pregnancy and risk of ADHD in offspring. Diabetes Care. 2018;41(12):2502–8. PMID: 30373735.30373735
260 Daly B, Toulis KA, Thomas N, . Increased risk of ischemic heart disease, hypertension, and type 2 diabetes in women with previous gestational diabetes mellitus, a target group in general practice for preventive interventions: a population-based cohort study. PLoS Med. 2018;15(1):E1002488. PMID: 29337985.29337985
261 Kaul P, Savu A, Nerenberg KA, . Impact of gestational diabetes mellitus and high maternal weight on the development of diabetes, hypertension and cardiovascular disease: a population-level analysis. Diabet Med 2015;32(2):164–73. PMID: 25407209.25407209
262 Lowe WL, Jr., Scholtens DM, Lowe LP, . Association of gestational diabetes with maternal disorders of glucose metabolism and childhood adiposity. JAMA. 2018;320(10):1005–16. PMID: 30208453.30208453
263 Savitz DA, Danilack VA, Elston B, . Pregnancy-induced hypertension and diabetes and the risk of cardiovascular disease, stroke, and diabetes hospitalization in the year following delivery. Am J Epidemiol. 2014;180(1):41–4. doi: 10.1093/aje/kwu118. PMID: 24879314.24879314
264 Wang Y, Chen L, Horswell R, . Racial differences in the association between gestational diabetes mellitus and risk of type 2 diabetes. J Women’s Health. 2012;21(6):628–33. PMID: 364989791.
265 Xiang AH, Li BH, Black MH, . Racial and ethnic disparities in diabetes risk after gestational diabetes mellitus. Diabetologia. 2011;54(12):3016–21. PMID: 22016046.22016046
266 Arnaout R, Nah G, Marcus G, . Pregnancy complications and premature cardiovascular events among 1.6 million California pregnancies. Open Heart. 2019;6(1):E000927. PMID: 30997125.30997125
267 Tobias DK, Stuart JJ, Li S, . Association of history of gestational diabetes with long-term cardiovascular disease risk in a large prospective cohort of US women. JAMA Intern Med. 2017;177(12):1735–42. PMID: 29049820.29049820
268 Goueslard K, Cottenet J, Mariet AS, . Early cardiovascular events in women with a history of gestational diabetes mellitus. Cardiovasc Diabetol. 2016;15:15. PMID: 26817691.26817691
269 Heida KY, Franx A, van Rijn BB, . Earlier age of onset of chronic hypertension and type 2 diabetes mellitus after a hypertensive disorder of pregnancy or gestational diabetes mellitus. Hypertension. 2015;66(6):1116–22. PMID: 26459420.26459420
270 Kramer CK, Campbell S, Retnakaran R. Gestational diabetes and the risk of cardiovascular disease in women: a systematic review and meta-analysis. Diabetologia. 2019;07:07. PMID: 30843102.30843102
271 Dehmer EW, Phadnis MA, Gunderson EP, . Association between gestational diabetes and incident maternal CKD: the Coronary Artery Risk Development in Young Adults (CARDIA) Study. Am J Kidney Dis. 2018;71(1):112–22. PMID: 29128412.29128412
272 Rawal S, Olsen SF, Grunnet LG, . Gestational diabetes mellitus and renal function: a prospective study with 9- to 16-year follow-up after pregnancy. Diabetes Care. 2018;41(7):1378–84. PMID: 29728364.29728364
273 Beharier O, Sergienko R, Kessous R, . Gestational diabetes mellitus is a significant risk factor for long-term ophthalmic morbidity. Arch Gynecol Obstet. 2017;295(6):1477–82. PMID: 28389884.28389884
274 Wicklow BA, Sellers EAC, Sharma AK, . Association of gestational diabetes and type 2 diabetes exposure in utero with the development of type 2 diabetes in First Nations and non-First Nations offspring. JAMA Pediatr. 2018;172(8):724–31. PMID: 29889938.29889938
275 Sellers EAC, Dean HJ, Shafer LA, . Exposure to gestational diabetes mellitus: impact on the development of early-onset type 2 diabetes in Canadian first nations and non-first nations offspring. Diabetes Care. 2016;39(12):2240–6. PMID: 613746954.27703026
276 Leybovitz-Haleluya N, Wainstock T, Landau D, . Maternal gestational diabetes mellitus and the risk of subsequent pediatric cardiovascular diseases of the offspring: a population-based cohort study with up to 18 years of follow up. Acta Diabetol. 2018;55(10):1037–42. PMID: 29936651.29936651
277 Li M, Fallin MD, Riley A, . The association of maternal obesity and diabetes with autism and other developmental disabilities. Pediatrics. 2016;137(2):E20152206. PMID: 26826214.26826214
278 Kong L, Norstedt G, Schalling M, . The risk of offspring psychiatric disorders in the setting of maternal obesity and diabetes. Pediatrics. 2018;142(3):09. PMID: 30093539.30093539
279 Nahum Sacks K, Friger M, Shoham-Vardi I, . Prenatal exposure to gestational diabetes mellitus as an independent risk factor for long-term neuropsychiatric morbidity of the offspring. Am J Obstet Gynecol. 2016;215(3):380.E1–7. PMID: 27018463.27018463
280 Schmitt J, Romanos M. Prenatal and perinatal risk factors for attention-deficit/hyperactivity disorder. Arch Pediatr Adolesc Med. 2012;166(11):1074–5. doi: 10.1001/archpediatrics.2012.1078. PMID: 22965737.22965737
281 Mann JR, Pan C, Rao GA, . Children born to diabetic mothers may be more likely to have intellectual disability. Matern Child Health J. 2013;17(5):928–32. PMID: 22798077.22798077
282 Ghassabian A, Sundaram R, Wylie A, . Maternal medical conditions during pregnancy and gross motor development up to age 24 months in the Upstate KIDS study. Dev Med Child Neurol. 2016;58(7):728–34. PMID: 26502927.26502927
283 Girchenko P, Tuovinen S, Lahti-Pulkkinen M, . Maternal early pregnancy obesity and related pregnancy and pre-pregnancy disorders: associations with child developmental milestones in the prospective PREDO Study. Int J Obes. 2018;42(5):995–1007. PMID: 621795850.
284 Shah R, Harding J, Brown J, . Neonatal glycaemia and neurodevelopmental outcomes: a systematic review and meta-analysis. Neonatology. 2019;115(2):116–26. doi: 10.1159/000492859. PMID: 30408811.30408811
285 McKinlay CJ, Alsweiler JM, Ansell JM, . Neonatal glycemia and neurodevelopmental outcomes at 2 years. N Engl J Med. 2015;373(16):1507–18. PMID: 26465984.26465984
286 McKinlay CJD, Alsweiler JM, Anstice NS, . Association of neonatal glycemia with neurodevelopmental outcomes at 4.5 years. JAMA Pediatr. 2017;171(10):972–83. doi: 10.1001/jamapediatrics.2017.1579. PMID: 28783802.28783802
287 Goode RH, Rettiganti M, Li J, . Developmental outcomes of preterm infants with neonatal hypoglycemia. Pediatrics. 2016;138(6). PMID: 27940690.27940690
288 Kerstjens JM, Bocca-Tjeertes IF, de Winter AF, . Neonatal morbidities and developmental delay in moderately preterm-born children. Pediatrics. 2012;130(2):E265–72. doi: 10.1542/peds.2012-0079. PMID: 22778308.22778308
289 Kaiser JR, Bai S, Gibson N, . Association between transient newborn hypoglycemia and fourth-grade achievement test proficiency: a population-based study. JAMA Pediatr. 2015;169(10):913–21. doi: 10.1001/jamapediatrics.2015.1631. PMID: 26301959.26301959
290 Harari Z, Zamstein O, Sheiner E, . Shoulder dystocia during delivery and long-term neurological morbidity of the offspring. Am J Perinatol. 2021;38(3):278–282. doi: 10.1055/s-0039-1696675. PMID: 31491802.31491802
291 Khambalia AZ, Algert CS, Bowen JR, . Long-term outcomes for large for gestational age infants born at term. J Paediatr Child Health. 2017;53(9):876–81. doi: 10.1111/jpc.13593. PMID: 28868781.28868781
292 Frank CE, Speechley KN, Macnab JJ, . Infants born large for gestational age and developmental attainment in early childhood. Int J Pediatr. 2018;2018:9181497. doi: 10.1155/2018/9181497. PMID: 29535788.29535788
293 Dodds L, Fell DB, Shea S, . The role of prenatal, obstetric and neonatal factors in the development of autism. J Autism Dev Disord. 2011;41(7):891–902. doi: 10.1007/s10803-010-1114-8. PMID: 20922473.20922473
294 Sparano S, Ahrens W, De Henauw S, . Being macrosomic at birth is an independent predictor of overweight in children: results from the IDEFICS study. Matern Child Health J. 2013;17(8):1373–81. doi: 10.1007/s10995-012-1136-2. PMID: 22976881.22976881
295 Goveia P, Canon-Montanez W, Santos DP, . Lifestyle intervention for the prevention of diabetes in women with previous gestational diabetes mellitus: a systematic review and meta-analysis. Front Endocrinol. 2018;9:583. PMID: 30344509.30344509
296 Ferrara A, Hedderson MM, Brown SD, . The comparative effectiveness of diabetes prevention strategies to reduce postpartum weight retention in women with gestational diabetes mellitus: the Gestational Diabetes’ Effects on Moms (GEM) cluster randomized controlled trial. Diabetes Care. 2016;39(1):65–74. PMID: 26657945.26657945
297 McManus R, Miller D, Mottola M, . Translating healthy living messages to postpartum women and their partners after gestational diabetes (GDM): body habitus, a1c, lifestyle habits, and program engagement results from the families defeating diabetes (FDD) randomized trial. Am J Health Promot. 2018;32(6):1438–46. PMID: 29108443.29108443
298 Ratner RE, Christophi CA, Metzger BE, . Prevention of diabetes in women with a history of gestational diabetes: effects of metformin and lifestyle interventions. J Clin Endocrinol Metab. 2008;93(12):4774–9. PMID: 18826999.18826999
299 Aroda VR, Christophi CA, Edelstein SL, . The effect of lifestyle intervention and metformin on preventing or delaying diabetes among women with and without gestational diabetes: the Diabetes Prevention Program outcomes study 10-year follow-up. Transl Endocrinol Metab. 2015;100(4):1646–53. PMID: 607290782.
300 Balsells M, Garcia-Patterson A, Sola I, . Glibenclamide, metformin, and insulin for the treatment of gestational diabetes: a systematic review and meta-analysis. BMJ. 2015;350:h102. doi: 10.1136/bmj.h102. PMID: 25609400.25609400
301 Guo L, Ma J, Tang J, . Comparative efficacy and safety of metformin, glyburide, and insulin in treating gestational diabetes mellitus: a meta-analysis. J Diabetes Res. 2019;2019:9804708. doi: 10.1155/2019/9804708. PMID: 31781670.31781670
302 Tarry-Adkins JL, Aiken CE, Ozanne SE. Neonatal, infant, and childhood growth following metformin versus insulin treatment for gestational diabetes: a systematic review and meta-analysis. PLoS Med. 2019;16(8):E1002848-E. doi: 10.1371/journal.pmed.1002848. PMID: 31386659.31386659
303 Hanem LGE, Salvesen Ø, Juliusson PB, . Intrauterine metformin exposure and offspring cardiometabolic risk factors (PedMet study): a 5-10 year follow-up of the PregMet randomised controlled trial. Lancet Child Adolesc Health. 2019;3(3):166–74. doi: 10.1016/s2352-4642(18)30385-7. PMID: 30704873.30704873
304 Farrar D, Simmonds M, Bryant M, . Treatments for gestational diabetes: a systematic review and meta-analysis. BMJ Open. 2017;7(6):E015557. doi: 10.1136/bmjopen-2016-015557. PMID: 28647726.28647726
305 Cornell JE, Mulrow CD, Localio R, . Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. 2014;160(4):267–70. doi: 10.7326/m13-2886. PMID: 24727843.24727843
306 Simmons D, Hague WM, Teede HJ, . Hyperglycaemia in early pregnancy: the treatment of booking gestational diabetes mellitus (TOBOGM) study. A randomised controlled trial. Medical Journal of Australia. 2018;209(9):405–6. PMID: 29793404.29793404
307 Crowther CA, Hague WM, Middleton PF, . The IDEAL study: investigation of dietary advice and lifestyle for women with borderline gestational diabetes: a randomised controlled trial - study protocol. BMC Pregnancy Childbirth. 2012;12:106. PMID: 23046499.23046499
308 NCT02728758. Efficacy of Treatment for Gestational Diabetes Diagnosed by the IADPSG Criteria. https://clinicaltrials.gov/ct2/show/NCT02708758. Accessed March 4, 2021.
309 Thompson D, Berger H, Feig D, . Diabetes and pregnancy. Can J Diabetes. 2013;37(Suppl 1):S168–83. doi: 10.1016/j.jcjd.2013.01.044. PMID: 24070943.24070943
310 Berger HG, Sermer M, Basso M, . Diabetes in pregnancy. J Obstet Gynaecol Can. 2016;38(7):667–79.E1. doi: 10.1016/j.jogc.2016.04.002. PMID: 27591352.27591352
311 Scottish Intercollegiate Guidelines Network. 116. Management of diabetes. A National Clinical Guideline. SIGN; 2017. https://www.sign.ac.uk/our-guidelines/pharmacological-management-of-glycaemic-control-in-people-with-type-2-diabetes/. Accessed June 14, 2021.
312 WHO Reproductive Health Library. WHO recommendation on the diagnosis of gestational diabetes in pregnancy. Geneva, Switzerland: World Health Organization; 2018.
313 American Diabetes Association. Diagnosis and classification of diabetes mellitus. Diabetes Care. 2011;34(Suppl 1):S62–S9. doi: 10.2337/dc11-S062. PMID: 21193628.21193628
314 Nankervis A, McIntyre HD, Moses R, . ADIPS consensus guidelines for the testing and diagnosis of hyperglycaemia in pregnancy in Australia and New Zealand. 2014. https://www.adips.org/downloads/2014ADIPSGDMGuidelinesV18.11.2014_000.pdf Accessed June 14, 2021.
315 Hod M, Kapur A, McIntyre HD. Evidence in support of the International Association of Diabetes in Pregnancy study groups’ criteria for diagnosing gestational diabetes mellitus worldwide in 2019. Am J Obstet Gynecol. 2019;221(2):109–16. doi: 10.1016/j.ajog.2019.01.206. PMID: 30682358.30682358
316 Brown CJ, Dawson A, Dodds R, . Report of the Pregnancy and Neonatal Care Group. Diabet Med. 1996;13(9 Suppl 4):S43–53. PMID: 8894455.8894455
317 American Academy of Family Physicians. Gestational diabetes. Clinical Preventive Service Recommendation. AAFP; 2018. Available from: https://www.aafp.org/family-physician/patient-care/clinical-recommendations/all-clinical-recommendations/diabetes.html.