# Acknowledgements

The authors acknowledge the following individuals: AHRQ Medical Officers Justin Mills, MD, MPH, and Iris Mabry-Hernandez, MD, MPH, and current members of the U.S. Preventive Services Task Force. The authors thank Diana Keto Lambert, MLIS, at the University of Alberta EPC, for updating the searches for key questions, and their previous librarian, Robin Featherstone, MLIS, for searching for systematic reviews to inform topic refinement and the contextual questions.