# Chapter 4 Discussion

## Summary of Review Findings

Table 25 summarizes the evidence reviewed for this update. This report differs from the 2012 USPSTF review^2^ by including additional evidence on potential harms of screening and GDM diagnosis; evaluating comparative effectiveness of different screening strategies; and focusing on screening tests and criteria currently used in the United States. To further inform USPSTF considerations, this review also addressed Contextual Questions on outcomes associated with a GDM diagnosis early in pregnancy, long-term health consequences of GDM, and effects of postpartum interventions. Although findings regarding effectiveness of screening versus no screening and treatment, as well as accuracy of screening tests were generally consistent with the prior review, new evidence found that screening using more inclusive GDM screening criteria (e.g., IADSPG) was not associated with improved health outcomes compared with CC criteria. New evidence also suggests that early (14 to 20 weeks’ gestation) versus usual timing of screening may not be associated with improved outcomes.

Table 25 Summary of Evidence

Key Question | Comparison | Studies; Observations (N); Study Designs | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
1. Does screening for gestational diabetes mellitus (GDM) reduce (a) poor health outcomes or (b) poor intermediate outcomes, and (c) do the effects vary by maternal subgroup characteristics? | Screening versus no screening | [underlined: Prior report]: 2 retrospective cohorts (N=544); [underlined: Update]: 1 case-control and 1 retrospective cohort (N=3,792) | Risk-based screening (75g 2hr OGTT NICE criteria) was associated with a reduced risk of late (≥28 weeks’ gestation) stillbirth (OR, 0.68 [95% CI, 0.47 to 0.97]).; Universal 2-step screening (50g OGCT and 75g 2hr OGTT using IADPSG), with those having risk factors screened in first trimester (51% of screened), associated with reduced risk of cesarean sections (ARD 5%), birth injuries (<1%), and admissions to the NICU (>8% admissions); and no differences for macrosomia, hypoglycemia or hyperbilirubinemia. For NICU admissions, effects for women screened in first trimester were larger than for those screened later. Two small studies from the prior review focused on selected subpopulations and showed no associations with screening. | Consistency unknown with 1 study for each outcome; Reasonably precise for stillbirth, cesarean sections, birth injuries, and NICU admissions; some imprecision for macrosomia | Observational studies without intention/offer to screen designs.; Some concerns about selection biases and confounding.; Selective outcome or analysis reporting not detected. | Insufficient | Findings mainly applicable to screening approaches with targeted screening for those with risk factors
2. What are the harms of screening for and diagnosis of GDM to the mother, fetus, or neonate? | Screening versus no screening and GDM vs. no GDM | [underlined: Prior report]: 0; [underlined: Update]: 5 cohorts and 2 cross-sectional (N= 166,082) | Evidence from observational studies on harms of screening (2 studies) or a GDM diagnosis (5 studies) was limited, but suggested that undergoing screening or receiving a false positive result may not be associated with anxiety; receiving a GDM diagnosis may result in a small, transient increase in anxiety symptoms; and that the diagnosis may have some adverse labeling effects impacting delivery management and hospital experiences associated with breastfeeding. | [underlined: Harms of screening]: reasonably consistent; some imprecision; [underlined: Harms of GDM diagnosis]: reasonably consistent (labeling); unknown consistency (anxiety) | Observational studies; not intention/offer- to-screen designs.; Findings on hospital experiences may be confounded by hospital policies, GDM treatment, and intentions before delivery. | Low for no association between undergoing screening and anxiety symptoms; Low for possible unnecessary cesarean delivery due to GDM | Studies from Canada and Australia with predominately white women; screening used the OGCT
3. What is the comparative effectiveness of different screening strategies for GDM on (a) health outcomes or (b) intermediate outcomes, and (c) do the effects vary by subgroup characteristics? | IADPSG versus CC screening | [underlined: Prior report]: 0; [underlined: Update]: 5 RCTs (N=25, 772) | One large RCT (n=23 792) accounted for 92% of patients.; [underlined: Pregnancy outcomes:] No association with primary cesarean deliveries, preeclampsia, hypertensive disorders, gestational hypertension, total cesarean deliveries, induction of labor, preterm birth, and maternal birth trauma.; [underlined: Fetal/neonatal outcomes:] No association for mortality, birth injury, shoulder dystocia, LGA, macrosomia, neonatal hypoglycemia, neonatal hyperbilirubinemia, NICU admissions, neonatal respiratory distress, Apgar scores at <7 minutes, or SGA. The large trial reported increased neonatal hypoglycemia from 1-step screening.; [underlined: Long-term outcomes]: No data | [underlined: Pregnancy outcomes]: Consistent and precise for hypertensive disorders, total cesareans, and induction of labor.; Large reliance on one trial or some inconsistency for preeclampsia, gestational hypertension, primary cesarean deliveries, preterm birth.; Imprecise for preeclampsia, gestational hypertension, and maternal birth trauma.; [underlined: Fetal/neonatal outcomes]: Consistent and precise for mortality, shoulder dystocia, macrosomia, and hyperbilirubinemia.; Some inconsistency for LGA, NICU admissions and neonatal hypoglycemia.; Imprecise for Apgar scores. | Large RCT had substantial cross-over (>25% of IADPSG group received Carpenter Coustan for diagnosis) but findings were very similar in analysis accounting for adherence.; Possible selective outcome or analysis reporting in one of the smaller trails where inconsistency between 2 publications could not be explained despite seeking author contact. | [underlined: Pregnancy outcomes]: Moderate for no association with total cesarean deliveries, induction of labor, primary cesarean deliveries, preterm birth and hypertensive disorders. Insufficient for preeclampsia, gestational hypertension, and maternal birth trauma.; [underlined: Fetal/neonatal outcomes]: Moderate for no significant association with mortality, birth injury, shoulder dystocia, macrosomia, hyperbilirubinemia, SGA, LGA and NICU admissions. Low for no significant association with neonatal hypoglycemia. Insufficient for Apgar scores. | 4 trials conducted in U.S., with fairly diverse populations; Comparison highly applicable to U.S.
3. What is the comparative effectiveness of different screening strategies for GDM on (a) health outcomes or (b) intermediate outcomes, and (c) do the effects vary by subgroup characteristics? | IADPSG versus WHO 1999 screening | [underlined: Prior report]: 0; [underlined: Update]: 1 RCT (n=502) | [underlined: Pregnancy outcomes:] No association for primary cesarean, preterm delivery, or hypertensive disorders in pregnancy; [underlined: Fetal/neonatal outcomes:] No association for shoulder dystocia, LGA, or hypoglycemia; [underlined: Long-term outcomes]: No data | [underlined: Pregnancy outcomes:] Consistency unknown; some imprecision for primary cesarean deliveries; imprecise for preterm deliveries and hypertensive disorders; [underlined: Fetal/neonatal outcomes:] Consistency unknown; imprecise; [underlined: Long-term outcomes]: No data | Open-label and possible selection biases; not intention-to-screen analysis | [underlined: Pregnancy outcomes:] Low for no association with primary cesarean delivery; insufficient for preterm delivery and hypertensive disorders; [underlined: Fetal/neonatal outcomes:] Insufficient; [underlined: Long-term outcomes]: No data | Trial from Malaysia; comparator of WHO 1999 criteria appear to be used infrequently in U.S.
3. What is the comparative effectiveness of different screening strategies for GDM on (a) health outcomes or (b) intermediate outcomes, and (c) do the effects vary by subgroup characteristics? | Early versus usual timing for CC screening | [underlined: Prior report]: 0; [underlined: Update]: 1 RCT (n=922) | [underlined: Pregnancy outcomes:] Preeclampsia (RR, 1.42 [95% CI, 0.99 to 2.05]; ARD, 4.0%); no association for gestational hypertension, hypertensive disorders in pregnancy, primary cesarean delivery, induction of labor; [underlined: Fetal/neonatal outcomes:] No association for shoulder dystocia, macrosomia, LGA, hypoglycemia, hyperbilirubinemia; [underlined: Long-term outcomes]: No data | [underlined: Pregnancy outcomes:] Consistency unknown; some imprecision; [underlined: Fetal/neonatal outcomes:] Consistency unknown; some imprecision; [underlined: Long-term outcomes]: No data | No concerns; intention-to-screen analysis | [underlined: Pregnancy outcomes:] Low for association with more preeclampsia and for no association for other outcomes; [underlined: Fetal/neonatal outcomes]: Low for no association for all outcomes; [underlined: Long-term outcomes]: No data | U.S. trial with mostly black and Hispanic population; 100% obese; excluded women with prior cesarean section; comparison highly applicable
4. a) What is the diagnostic accuracy of commonly used screening tests for GDM? b) Does the accuracy of commonly used screening tests for GDM vary according to maternal subgroup characteristics, including timing during pregnancy, body mass index, age, race/ethnicity, or prevalence of GDM? | 50 OGCT versus CC | [underlined: Prior report:] 5 studies (N=5,501); [underlined: Update:] 8 studies (n=6,190) | [underlined: Pooled estimates:]; [underlined: 140 mg/dL:] sensitivity 81.9% (95% CI, 68.3 to 90.4), specificity 81.8% (95% CI, 71.2 to 89.1); [underlined: 135 mg/dL]: sensitivity 93.3% (95% CI, 23.7 to 99.8), specificity 78.9% (95% CI, 53.3 to 92.5); [underlined: Not pooled:]; [underlined: 130 mg/dL:] sensitivities (75 to 100%) and specificities (25 to 86%) | [underlined: 140 mg/dL:] Reasonably consistent and precise; [underlined: 135 mg/dL]: Some inconsistency and imprecision; [underlined: 130 mg/dL:] Inconsistent and some imprecision | Half of the studies for each analysis were fair quality, but this did not appear to influence findings | Moderate (140 mg/dL) and low (135 mg/dL) for reasonably good accuracy; insufficient for 130 mg/dL | Studies varied widely in country of origin; screening and diagnostic test highly applicable
| 50 g OGCT versus NDDG | [underlined: Prior report]: 6 studies (n=5,375); [underlined: Update]: 0 | [underlined: Pooled estimates:]; [underlined: 140 mg/dL:] sensitivity 85.0% (95% CI, 72.0 to 92.6), specificity 81.2% (95% CI, 75.9 to 85.6); [underlined: Not pooled:]; [underlined: 135 mg/dL:] sensitivity 88.5 and 78.6%; specificities 84.3 and 46.4%; 130 mg/dL: sensitivity and specificity were 90.7 and 79.4% | [underlined: 140 mg/dL]: Reasonably consistent and precise; [underlined: 135 mg/dL]: some inconsistency in specificity; [underlined: 130 mg/dL]: unknown consistency and some imprecision | 4 of 6 studies were good quality, and quality did not appear to influence findings | Moderate (140 mg/dL) and low (135 mg/dL) for reasonably good accuracy; insufficient for 130 mg/dL | See 50g OGCT versus CC
| 50 g OGCT versus IADPSG | [underlined: Prior report:] 0; [underlined: Update]: 2 studies (n=2,091) | [underlined: Not pooled:]; Sensitivity: low (<70%) across all cutoffs; Specificity: 140 mg/dL 81.0 and 93.2%; 135 mg/dL 76.1 and 88.0%; 130mg/dL 70.2 and 84.2% | Reasonably consistent and precise | No concerns | Moderate for poor accuracy | See 50g OGCT versus CC
| Fasting plasma glucose versus CC | [underlined: Prior report]: 4 studies (N=6,889); [underlined: Update:] 3 studies (N=1,972) | [underlined: Pooled estimates:]; [underlined: FPG 79 mg/dL:] sensitivity 96% (95% CI, 92 to 98), specificity 35% (95% CI, 30 to 41); [underlined: FPG 85 mg/dL:] sensitivity 88% (95% CI, 84 to 91), specificity 73% (95% CI, 46 to 90); [underlined: FPG 90 mg/dL:] sensitivity 81% (95% CI, 75 to 85), specificity 82% (95% CI, 61 to 93); [underlined: FPG 95.5 mg/dL:] sensitivity 58% (95% CI, 32 to 81), specificity 98% (95% CI, 88 to 100); [underlined: Not pooled:]; Across all cutoffs, sensitivity appeared fairly high (>90%) using ≤80 mg/dL and specificity appeared high (≥90%) using cutoffs >90 mg/dL. | [underlined: 79, 85 and 90 mg/dL]: sensitivity reasonably consistent and precise; some inconsistency for specificity; [underlined: ≤80 mg/dL]: reasonably consistent (but most thresholds only reported by 2 studies) and precise for high sensitivity | 2 studies included in pooled estimates used selective populations (positive on OGCT or with clinical risk factors) which may have impacted findings | Low (85 & 90 mg/dL) for reasonably good accuracy; low for reasonably high sensitivity (to rule out) with ≤80 mg/dL and specificity (to rule in) with >90mg/dL | See 50g OGCT versus CC
| Fasting plasma glucose versus IADPSG | [underlined: Prior report]: 0; [underlined: Update]: 9 studies (N=59,278) | [underlined: At 24 weeks’ or greater:]; [underlined: Pooled estimate:]; [underlined: FPG 90 mg/dL]: sensitivity 79% (95% CI, 65 to 89), specificity 96% (95% CI, 95 to 97); [underlined: Not pooled]:; FPG ≤80 mg/dL: high sensitivity (> 90%), low specificity (<60%); [underlined: Early screening:]; [underlined: 85 mg/dL]: sensitivity 55 and 94% and specificity 68 and 74% | [underlined: At 24 weeks or greater]:; [underlined: FPG 90 mg/dL]: some inconsistency but precise for sensitivity; [underlined: FPG ≤80 mg/dL]: reasonably consistent (but most thresholds only reported by 2 studies) and precise for high sensitivity; [underlined: Early screening]: inconsistent sensitivity | 6 of 9 studies were fair quality, but quality did not appear to influence findings | Moderate (90 mg/dL at 24 weeks) for good accuracy; low (≤80 mg/dL) to rule out GDM; low for low accuracy when screening before 24 weeks | Studies varied in country and findings appear to be applicable to a diverse population; 90 mg/dL is very similar to the diagnostic value for FPG in this criteria which only requires one abnormal value
| HbA1c | [underlined: Prior report]: 3 studies (N=1,075); [underlined: Update]: 15 studies (n=9,413) | Against each criteria and for each time point, one or two studies contributed data for most thresholds.; At no threshold were sensitivity and specificity both high enough for use as a primary screening test; Sensitivity >90% at cutoffs of 4.5 to 5.0% (CC and NDDG) or 4.6 to 4.7% (IADPSG) in second trimester, at which may allow ruling out | Some inconsistency and imprecision | Most studies limited due to poor reporting on patient selection, selection of cutoffs, and fasting protocols | Low for poor accuracy across thresholds; low for <5.0% (CC and NDDG) and 4.7% and under (IADPSG) to rule out GDM reasonably well | See 50g OGCT versus CC
| Risk-based screening | [underlined: Prior report:] 2 studies (N=1,912); [underlined: Update:] 1 study (n=258) | Three studies compared different models with CC, NDDG and IADPSG criteria; for CC and IADPSG they incorporated FPG which seemed to increase sensitivity. All screening still used either FPG or and OGCT.; Sensitivity may be high enough (82-98%) to rule out GDM; specificity (16-80%) too low to replace OGCT | Single studies for each tool and criteria; some imprecision | No concerns; all studies used validation cohorts | Low for poor accuracy for primary screening test; but may allow rule-out | Studies from Brazil, Canada, and Austria; unknown how many clinicians use risk-based screening
5. What is the association between diagnosis and outcomes in women meeting more inclusive but not less inclusive diagnostic criteria for GDM? | GDM versus no GDM | [underlined: Prior report:] 13 observational studies (N=27,071); [underlined: Update]: 18 cohort studies (n=78,421) | [underlined: Pregnancy outcomes:] Versus NGT, women meeting more inclusive criteria but not treated for GDM are probably at increased risk of:; - Preeclampsia (60 to 93% increase; 1.5 to 3.3% more cases); - Hypertensive disorders in pregnancy (variable increased risk; 1 to 5% more cases); - Total cesarean deliveries (20 to 30% increase; 7 to 13% more cases [but NGT rates high]); - Preterm deliveries (40% increase; 0.8 to 1.8% more cases); No associations for primary cesarean delivery, induction of labor, maternal birth trauma, excessive weight gain; [underlined: Fetal/neonatal outcomes:] Versus NGT, women meeting more inclusive criteria but not treated for GDM are probably at increased risk of:; - Macrosomia (50 to 100% increase; 2.6 to 8.1% more cases); - LGA (60 to 70% increase; 4.7 to 6.0% more cases); - Neonatal hypoglycemia (60 to 150% increase; 1.4 to 2% more cases); - Hyperbilirubinemia (variable increased risk); No associations for perinatal mortality, birth injury, shoulder dystocia, NICU admissions, respiratory distress syndrome, low APGAR scores at 1 or 5 minutes; [underlined: Long-term outcomes (single studies)]:; OAV on NDDG: maternal impaired glucose tolerance at 3 months’ postpartum (RR, 2.13 [95% CI, 1.14 to 3.99]) and T2DM (RR, 19.8 [95% CI, 1.03 to 379.34]); OAV on CC: childhood obesity at 5 to 7 years (RR, 1.29 [95% CI, 0.94 to 1.64]) and at 13 years (RR, 1.03 [95% CI, 0.40 to 2.64]) | Reasonably consistent and precise for preeclampsia, total cesarean deliveries, preterm delivery, macrosomia, LGA, hypoglycemia, hyperbilirubinemia, NICU admissions; Some inconsistency for hypertensive disorders, and inconsistency and imprecision for gestational hypertension, primary cesarean delivery, induction of labor, maternal birth trauma, perinatal mortality, birth injury, shoulder dystocia, respiratory distress syndrome, low APGAR scores; [underlined: Long-term outcomes:] unknown consistency and some imprecision (childhood obesity and maternal metabolic outcomes) or high imprecision (development of T2DM) | Blinding of patients and providers to glycemic status or for outcome assessment did not occur, although no women met criteria for GDM; adjusted analyses available; Duration of followup was short for development of metabolic impairment and T2DM | Moderate for association with increased risk of preeclampsia, hypertensive disorders, total cesarean deliveries, preterm delivery, macrosomia, LGA, hypoglycemia, hyperbilirub-inemia, and for no association with NICU admissions; Low for no associations for other short-term outcomes and long-term obesity in childhood; Insufficient for metabolic impairment and development of T2DM in (high-risk) mothers | All comparisons, including some variations to what is recommended for each criteria, are considered applicable to U.S.; IADPSG excluding CC most applicable due to three large U.S. studies with diverse populations; Absolute rates for total cesarean are likely over estimated because of high rates in non-VHDI countries; >40% of participants in study of long-term maternal outcomes had a family history of T2DM
6. Does treatment of GDM during pregnancy a) reduce poor health outcomes, b) reduce poor intermediate outcomes, c) vary by maternal subgroup characteristics, including timing and criteria used for diagnosis during pregnancy, severity of hyperglycemia, body mass index, age, or race/ethnicity? | Treatment for GDM at 24 week’s gestation or later versus no treatment | [underlined: Prior report]: 5 trials; [underlined: Update]: 4 trials (N=3,982) | [underlined: Pregnancy outcomes:]; - Preeclampsia: RR, 0.60 (95% CI, 0.35 to 1.01); ARD, 1%, excluding one outlier; - Primary cesarean delivery: RR, 0.70 (95% CI, 0.54 to 0.91); ARD, 5.3%; - Preterm delivery: RR, 0.75 (95% CI, 0.56 to 1.01); ARD, 2.3%; No association with hypertensive disorders of pregnancy, gestational hypertension, total or emergency cesarean delivery, induction of labor, maternal birth trauma; [underlined: Fetal/neonatal outcomes:]; - Birth injury: Peto OR, 0.33 (95% CI, 0.11 to 0.99); ARD, 0.2%; - Shoulder dystocia: RR, 0.42 (95% CI, 0.23 to 0.77); ARD, 1.3%; - Macrosomia >4000g: RR, 0.53 (95% CI, 0.41 to 0.68); ARD, 8.9%; - LGA: RR, 0.56 (95% CI, 0.47 to 0.66); ARD, 8.4%; - NICU admissions: RR, 0.73 (95% CI, 0.53 to 0.99); ARD, 2.0%; No associations with mortality, macrosomia >4500g, respiratory distress syndrome, any hypoglycemia, hyperbilirubinemia, APGAR scores; [underlined: Long-term outcomes]: No differences in childhood overweight (BMI ≥85^th^ percentile) (4-10 years), obesity (BMI ≥95^th^ percentile) (5-11 years), metabolic impairment, or T2DM; or in maternal obesity (≥30kg/m^2^) or metabolic impairment (impaired fasting glucose), metabolic syndrome (5-10 years), or T2DM (5-10 years).; [underlined: Subgroups]: No significant interactions based on timing of treatment initiation, criteria for diagnosis/glycemic severity, BMI (only assessed for LGA), or race/ethnicity. Sensitivity analyses removing 3 trials with eligibility based on screening positive but no GDM did not impact conclusions; one new trial enrolled women with GDM based on IADPSG criteria but FPG was higher and 2-hr postload glucose levels similar to other trials in the prior review, so this did not explain any inconsistency in effect | Consistent and precise for macrosomia >4000g and LGA; Inconsistent and imprecise for preeclampsia, birth injury, and mortality; Imprecise for gestational hypertension, primary cesarean delivery, emergency cesarean, preterm delivery; Some inconsistency for induction of labor and shoulder dystocia; Large inconsistency for hypertensive disorders; Unknown consistency and large imprecision for childhood and maternal metabolic impairment and development of T2DM | Some concern for total cesarean delivery, induction of labor and NICU admissions from open-label designs; Studies of long-term outcomes had high rates of attrition. | High for reduced risk of macrosomia >4000g and LGA; Moderate for reduced risk of primary cesarean delivery, shoulder dystocia, and NICU admissions, and for no association with gestational hypertension, total cesarean deliveries, maternal birth trauma, respiratory distress syndrome, hypoglycemia, hyperbilirub-inemia; Low for reduced risk of preeclampsia, preterm labor, birth injury and for no association with hypertensive disorders, emergency cesarean delivery, induction of labor, mortality, macrosomia >4500g, and childhood obesity; Insufficient for childhood and maternal metabolic impairment and development of T2DM | Trials from various countries; 2 from the U.S. enrolled 97% and 57% Hispanic women with similar findings to the conclusions.; Most data from 3 large trials with 2-step screening for GDM diagnosis.; Eligibility criteria included singleton pregnancies for 12 trials, women without chronic hypertension in 4 trials, and women without previous GDM in the largest 2 trials
| Early GDM treatment vs usual care | [underlined: Prior report:] 0; [underlined: Update]: 4 trials (N=253) | [underlined: Pregnancy outcomes]: No associations for preeclampsia, gestational hypertension, hypertensive disorders of pregnancy, cesarean delivery, primary cesarean delivery, emergency cesarean delivery, induction of labor, preterm delivery, excessive gestational weight gain; [underlined: Fetal/neonatal outcomes]: No associations for mortality, birth injury, shoulder dystocia, macrosomia >4000g, macrosomia >4500g, LGA, NICU admissions, any hypoglycemia, hyperbilirubinemia; [underlined: Long-term outcomes]: No data; [underlined: Subgroups]: Interactions between BMI and early treatment versus usual care imprecise | Highly imprecise for all outcomes | | Insufficient for all outcomes of early treatment | Trials from Australia, New Zealand, Denmark and the U.S., largely non-minority populations
7. What are the harms of treatment of GDM, including severe maternal and neonatal hypoglycemia, delivery of neonates who are small for gestational age, and poor long-term growth and development outcomes in the child? | Treatment for GDM at 24 weeks’ gestation or later versus no treatment | [underlined: Prior report]: 5 trials; [underlined: Update]: 4 trials (N=3,982) | [underlined: Pregnancy outcomes:]; No association with severe maternal hypoglycemia; Large association with reduced risk of macrosomia (>4,000 g; RR, 0.53 [95% CI, 0.41 to 0.68]) but no association with risk of total cesarean deliveries (RR, 0.95 [95% CI, 0.83 to 1.08]); cesarean sections may be associated with GDM; [underlined: Fetal/neonatal outcomes:] No association with SGA, low birthweight, neonatal hypoglycemia requiring IV glucose therapy; [underlined: Long-term outcomes]: No data; [underlined: Subgroups]: No effect of SGA based on ethnicity or glycemic status | Highly imprecise for maternal hypoglycemia; Some imprecision and inconsistency for severe neonatal hypoglycemia (requiring IV treatment); Some imprecision for SGA | No concerns; results were consistent with those from 2 large good quality trials | Moderate for no association with SGA; Low for no association with severe neonatal hypoglycemia; Insufficient for severe maternal hypoglycemia | See Key Question 6
| Early GDM treatment vs usual care | [underlined: Prior report:] 0; [underlined: Update]: 3 trials (n=123) | No association with SGA | Highly imprecise for all outcomes | Open-label in 3 trials; 1 was not randomized and 1 had high attrition | Insufficient | See Key Question 6

Abbreviations: ARD = absolute risk difference; BMI = body mass index; CC = Carpenter-Coustan; FPG =fasting plasma glucose; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes and Pregnancy Study groups; LGA = large for gestational age; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; NICU = neonatal intensive care unit; OGCT = oral glucose challenge test; OGTT = oral glucose tolerance test; OR = odds ratio; RCT = randomized controlled trial; RR = relative risk; SGA = small for gestational age; T2DM = type 2 diabetes mellitus

As in the prior review, evidence on the benefits of screening versus no screening was sparse and limited to observational studies. Two small studies included in the previous review focused on selected subpopulations of women and found no associations with outcomes.^69,70^ Of two new studies, one^68^ found that risk-based screening (2-hour 75g OGTT NICE criteria) associated with a reduced risk of late stillbirth and the other study^67^ found universal two-step screening associated with fewer cesarean deliveries, birth injuries and NICU admission. In relation to subgroups of interest, a prespecified analysis in the latter study comparing screening in first versus second trimester found a significantly greater effect for NICU admissions from screening early, but no difference for other outcomes. However, findings from both studies were susceptible to confounding and selection bias.

New to this report, we included seven studies on harms associated with undertaking screening for or a diagnosis of GDM. Studies found no effects on depression/anxiety from screening and only a small, transient increase after diagnosis.^71,73,77^ A GDM diagnosis may lower the threshold for surgical/cesarean delivery.^75^ Three studies^72,74,76^ found some differences in hospital experiences for women with versus without GDM that may be due to labelling and impact breastfeeding outcomes, although confounding factors (e.g., breastfeeding intentions, varying hospital policies) could have impacted findings. Evidence was based on observational studies with methodological limitations, precluding strong conclusions.

Also new to this update, we examined seven trials on the comparative effectiveness of different screening strategies. In five RCTs,^83–87^ screening using one-step IADPSG versus two-step CC criteria identified on average twice as many cases of GDM (11.5% IADPSG vs. 4.9% CC) and was not associated with differences in any health outcome. Results were limited to some extent by inconsistency, especially for neonatal hypoglycemia, and were heavily weighted by one large trial^86^ that accounted for 92% of patients. Findings of higher risk of neonatal hypoglycemia in the one-step group this trial^86^ and (though not significant) from another trial^85^ may be in part due to the routine surveillance^86^ of neonates with risk factors which include maternal GDM. Apart from neonatal monitoring, one trial^85^ measuring resource use found increased rates of fetal nonstress tests in the one-step group despite no differences in health outcomes including NICU admissions. One trial^81^ comparing screening with IADPSG versus WHO 1999 criteria (both resulting in high prevalence about 36%) found no difference in outcomes but findings were imprecise. One trial^82^ in obese women found early (14 to 20 weeks’ gestation) screening with CC criteria potentially associated with increased risk of preeclampsia versus usual (after 24 weeks’) screening (NNT 25), with no differences in other outcomes. No study reported analyzing outcomes for different subgroups of interest.

In this update we included 45 prospective cohort studies evaluating the diagnostic accuracy of commonly used screening tests. As in the prior report, this update found that the OGCT has reasonably good accuracy against diagnosis with CC and NDDG criteria at 24 or more weeks’ gestation, with trade-offs between higher sensitivity (using lower cutoffs of 130 or 135 md/dL) and specificity (using 140 mg/dL cutoff). For FPG as a screening test at 24 or more weeks’ gestation, an 85 or 90 mg/dL cutoff may have reasonable accuracy for a CC diagnosis and values at or under 80 mg/dL appear useful to rule out GDM; potential advantages of FPG are that it is reproducible, preferable to those who cannot tolerate a glucose load, and correlates better with outcomes of interest. As noted in Contextual Question 1, associations with outcomes were stronger with FPG than with post-glucose load values. For HbA1c, there was no threshold associated with sufficient sensitivity and specificity to serve as a screening test. There was some evidence on the accuracy of early screening with FPG and HbA1c against early or later diagnosis, but most thresholds only had data from single studies. Few studies validated the accuracy of risk-based screening and no study reported analyzing outcomes for different subgroups of interest. Overall, the use of different reference criteria across studies complicated interpretation. Further, screening tests were evaluated for their ability to predict results of the OGTT rather than pregnancy or neonatal outcomes.

Evidence reviewed for this report indicated that women who would be considered to have GDM if diagnostic criteria were made more inclusive than those most commonly used in the United States at present (e.g., one abnormal value of CC or NDDG criteria, IADPSG but excluding those with CC or NDDG GDM) have an increased likelihood of several pregnancy and fetal/neonatal outcomes compared with women without GDM using any criteria, if untreated. Compared with the prior report, we excluded studies on outcomes for women with GDM meeting current criteria (e.g. unrecognized CC or NDDG GDM based on two abnormal values) or who were positive on screening tests but negative on all OGTT thresholds (i.e., false positives). Further, we had more evidence on outcome associations for women meeting IADPSG but not CC criteria. This report found more robust evidence for several outcomes (e.g., increased risk of hypoglycemia and preterm birth but not NICU admissions), and findings are more specific to the current dilemma of choosing which GDM criteria to apply. Similar to the prior report, evidence on long-term health outcomes was scarce. Some studies used variations to the recommended practices for each criteria (e.g., IADPSG using a 100g rather than 75g glucose load); however, such variations were thought to be applicable to clinical practice in the United States. Separate from this question, when looking at serum glucose values on a continuum (Contextual Question 1) there was a dose-dependent association with increased risk for several outcomes, without evidence of a clear glucose threshold. Despite the findings for this KQ, the evidence from the trials of comparative effectiveness failed to show benefit from implementing more versus less inclusive screening criteria.

The prior report found treatment for mild GDM at or after 24 weeks’ gestation associated with approximately 40 to 50% fewer cases of preeclampsia, shoulder dystocia, macrosomia, and LGA versus no treatment. Some evidence suggested no difference for NICU admission, neonatal hypoglycemia, cesarean deliveries, or induction of labor. The current report included eight additional trials,^229–236^ four of which evaluated early treatment. Treatment versus no treatment was associated with reduced risk of primary cesarean deliveries (number needed to treat [NNT] 19), preterm deliveries (NNT 38), shoulder dystocia (NNT 77), macrosomia (NNT 11), LGA (NNT 12), birth injuries (e.g., fracture or nerve palsies) (NNT 500), and NICU admissions (NNT 50). Findings were robust except for preterm delivery (imprecise) and birth injury (imprecise and inconsistent). Treatment versus no treatment was associated with reduced risk for preeclampsia (5 trials), after excluding an outlier trial. The outlier trial, conducted in China,^236^ found treatment versus a minimal intervention in women with relatively low BMI (23 kg/m2) associated with increased risk of preeclampsia. The analyses of NICU admissions and preeclampsia excluded data from one previously included large trial after clarifying with trial authors that the outcomes were different, specifically, neonatal nursery admission and hypertension with or without preeclampsia, respectively.^41^ No association was found for reduced risk of gestational hypertension. Similar to the previous review, this update found no association between treatment versus no treatment and risk of total cesarean deliveries (8 trials), induction of labor (5 trials), or neonatal hypoglycemia. However, there was some imprecision and inconsistency; for the outcomes of total cesarean deliveries and induction of labor different results across trials may have been due in part to lack of blinding and/or practice variation. Evidence from four studies^241–244^ indicated no effects on long-term outcomes in mothers and children but findings were limited by imprecision and attrition and the length of followup (5-10 years) may have been insufficient. There was no clear association between treatment for GDM during pregnancy and reduced risk of T2DM. Although Contextual Question 3 found an association between GDM and increased risk of long-term T2DM, pre-existing diabetes may not have been excluded and the effects of glucose control were not accounted for, which could have confounded results. Four small trials^231,233–235^ provided insufficient evidence to determine effects of treatment for GDM diagnosed early in pregnancy versus no treatment.

As with the prior review, evidence on harms of treatment was somewhat limited but did not indicate serious adverse effects; treatment was not associated with increased risk of SGA and findings for severe maternal hypoglycemia were imprecise. Similar to the findings for the question on harms of a GDM diagnosis, GDM may be associated with increased risk for cesarean deliveries. None of the trials of treatment at 24 or more weeks’ gestation used oral medications as part of their treatment protocols, so the potential harms from these medications would not have been captured. The ADA prefers insulin over metformin and glyburide because it does not cross the placenta to a measurable extent.^44^ Use of glyburide in pregnancy has been found to be associated with up to a two-fold increased risk of neonatal hypoglycemia^300,301^ and metformin may be associated with increased childhood adiposity measures.^302,303^ Some data indicate that glyburide may be used as first-line treatment by some practitioners,^49^ although review findings indicating that glyburide is the least effective treatment for GDM may change practice.^301,304^

Analyses^237–240^ of one trial^42^ found no differences in effects of GDM treatment for several maternal and fetal outcomes based on timing of treatment initiation, race/ethnicity, severity of dysglycemia, or BMI. Differences in GDM diagnostic criteria did not appear to impact findings for several outcomes or explain inconsistency across trials. However, evidence from trials using “borderline” GDM (i.e., positive on screening but not diagnostic tests) was limited; the findings overall were heavily weighted by three large trials^41,42,236^ that used two-step approaches.

Because direct evidence on the effects of GDM screening versus no screening on health outcomes remains limited, the indirect chain of evidence including diagnostic accuracy and the effects from treatment, as well as evidence on the comparative effects from different screening strategies, is also important for informing decisions about screening. Because the treatment evidence is most applicable to women with GDM diagnosed using two-step approaches, the applicability of evidence on treatment effectiveness to one-step screening approaches (i.e., IADPSG) or a standalone screening test (i.e., without a diagnostic OGTT) for diagnosis of GDM is uncertain. Regarding diagnostic accuracy, among hypothetical cohorts of women at average or higher risk for GDM (e.g., 7 and 15% prevalence), use of standalone screening tests (e.g., OGCT or FPG) at optimal thresholds would result in high negative predictive values (96 to 99%) but lower positive predictive values (e.g., 25% at 7% and 45% at 15% prevalence) (Appendix D Tables 15 and 16). Therefore, although the accuracy data helps determine which screening tests are most useful in a two-step approach—helping to accurately rule out GDM and allow many women to avoid the OGTT (reducing resources and associated side effects)—reliance on these tests alone for diagnosis and treatment would result in a high number false-positive results, especially in general-prevalence populations, and potentially result in overtreatment. The greater prevalence in gestational diabetes diagnosis resulting from one- versus two-step screening, without associated benefits, suggests potential overdiagnosis and overtreatment with a 1-step strategy. In addition, the one-step approach requires additional resources related to having all women undertake a 2-hour OGTT and provision of counseling and treatment to more women.

## Limitations

We excluded non-English language studies, which could introduce language bias. We did not formally assess for publication bias with graphical or statistical tests due to small numbers of studies and heterogeneity between studies.^66^ Studies had some methodological limitations (e.g., lack of blinding of patients and healthcare providers, potential selection biases in diagnostic accuracy studies); however, results were similar in sensitivity analyses or when quality was otherwise considered. Women with GDM, as well as women with obesity, will often have metabolic disturbances other than impaired glucose metabolism and vascular disturbances that can affect nearly all of the pregnancy outcomes of interest. Due to these potential confounding effects, RCTs are very important for evaluating the effectiveness of screening and treatment. From an anticipated lack of trials, we included observational studies for the effects of screening versus no screening and recognize the limitations from these studies including confounding. We only included trials when these were available for our questions on different screening strategies and treatment. We also sought to focus on higher quality evidence on accuracy of screening by excluding studies that only provided the reference standard to people positive on screening. For evaluating outcome associations, where observational designs are able to provide high-quality evidence, we included studies that did not adjust their analysis for confounders but reported analyses that adjusted for confounders when available. We included studies comparing women with and without a GDM diagnosis for harms of screening (e.g., cesarean deliveries, breastfeeding patterns); however, it is difficult to separate out effects of a GDM diagnosis from other factors such as GDM itself, treatment, and hospital practices.

Some studies were conducted in lower income countries in which screening and treatment for GDM as well as management of pregnancy may differ from the United States. We focused on screening and diagnostic criteria used in the United States and results appeared consistent across geographic settings. There was also variability across studies in application of GDM criteria, population characteristics, and other factors. Studies that applied older definitions for GDM, or before recommendations to screen for pre-existing diabetes early in pregnancy, would have included some women with diabetes who are expected to have worse outcomes;^13^ randomization in the trials and adjustment for key confounders in other studies would have helped to account for this factor when considering the relative effects between groups, but the absolute effects of the outcomes in studies may have been higher than expected without this confounding. Because of anticipated heterogeneity, we performed random effects analyses using the Dersimonian-Laird model. We performed sensitivity and stratified analyses to evaluate statistical heterogeneity and used an alternative random effects model (profile likelihood) when statistical heterogeneity was present.^305^ Findings were robust in sensitivity analyses based on the statistical method used and other factors.

Another limitation was that definitions of some outcomes varied or were not reported. We addressed this by contacting authors for additional information and adding specificity to our outcome definitions (e.g., separating any degree of hypoglycemia from that requiring IV treatment). In addition, we conducted sensitivity analysis based on outcome definitions used when uncertainty remained.

## Emerging Issues/Next Steps

Variability in clinical practice remains with regard to which criteria and timing to use for screening and diagnosing GDM.^46,49,8^ More evidence regarding effects of different timing of screening could reduce uncertainty in clinical practice. An ongoing trial^306^ is investigating outcomes associated with treatment of GDM diagnosed before 20 weeks’ gestation. This update identified five trials comparing IADPSG versus CC criteria, though ongoing trials of treatment for women with positive OGCT screening results but not GDM^307^ and IADPSG GDM but excluding those with two abnormal glucose values^308^ could further inform decisions. Recommendations for changes in screening approaches should consider trade-offs between benefits and harms, including possible overdiagnosis and overtreatment. Furthermore, one-step screening has previously been found to be more costly than a two-step approach in terms of glucose testing.^37^ To reduce resources required and inconvenience associated with screening, there may be increased interest in screening tests that allow some women to avoid the OGCT, including risk-based screening tools.

## Relevance for Priority Populations, Particularly Racial/Ethnic Minorities and Older Adults

Ethnic minority groups have elevated risk for GDM^14,32,33^ and its long-term consequences including development of subsequent T2DM.^260,264,265^ Evidence comparing accuracy or effects of treatment based on race/ethnicity was limited. Few studies reported subgroup analyses based on these factors; however, one large treatment trial^237^ found no subgroup effects, some studies enrolled diverse populations, and there was geographic diversity across studies (including studies conducted in Asia). The trials comparing different screening approaches enrolled diverse populations although did not compare effects between different groups. There was no indication based on the evidence in this report that findings would differ in racial/ethnic groups. None of the studies focused on or reported effects specific to Indigenous women.

The evidence is most applicable to women with singleton pregnancies and in adulthood rather than adolescence. Mean age was usually around 30 years; no study directly evaluated how effects varied according to age. Most of the treatment interventions relied on frequent self-monitoring of blood glucose and clinic visits to monitor glucose targets, which could reduce applicability of findings to women with limited or no insurance coverage, access to healthcare, or ability to perform self-monitoring.

## Future Research

Several important gaps in the current literature exist:

- Additional research is needed on potential harms associated with a label of GDM, particularly if more inclusive diagnostic criteria is considered.
- More trials are needed to clarify issues regarding earlier screening and treatment, particularly as they relate to the diagnosis, treatment, and long-term outcomes of overt diabetes.
- Further study of the long-term metabolic impact on offspring whose mothers have been treated for GDM is warranted, with a focus on the type of treatment exposure in utero.
- Based on fairly robust evidence of increased risk for T2DM and cardiovascular outcomes associated with GDM, more trials of postpartum interventions (lifestyle with or without pharmacotherapy) including longer followup would be informative. Trials that consider specific cultural practices of women with previous GDM are needed.
- A greater understanding about the potential for short-and long-term harms from treatments in pregnancy, particularly with use of oral medications, is needed.
- More evidence is needed related to screening and treatment effects based on BMI, in order to inform whether any modifications may optimize outcomes across the range of different BMIs. Further, more information is needed on effects in subgroups defined by race/ethnicity, age, and other factors (e.g., prior GDM status).
- Research on whether risk-based tools combined with glycemic measures are better predictors of GDM and treatment-responsive outcomes would also be informative.

## Conclusions

Direct evidence on effects of screening versus no screening remains very limited. Screening tests are reasonably accurate for identifying women who do not need to proceed to a diagnostic test as part of a two-step strategy, but at this time are likely inadequate to diagnose GDM. Treatment for GDM at or after 24 weeks’ gestation, in women primarily diagnosed using two-step diagnostic approaches, is associated with improvement in some maternal and several fetal/neonatal outcomes, without risk for severe harms. Diagnosis of GDM using more inclusive criteria likely identifies additional women at increased risk of adverse maternal and neonatal/fetal outcomes, but evidence does not indicate there is any short-term benefit from one- versus two-step screening. Research is needed to determine effects of GDM management on the long-term outcomes in the mother and child, to clarify effects of screening and treatment of GDM in early pregnancy and to determine if risk-based tools combined with glycemic measures are better predictors of GDM and treatment-responsive outcomes.