# Chapter 3 Results

A total of 12,304 references from electronic database searches and manual searches of recently published studies and systematic reviews were reviewed and 896 full-text papers were evaluated for inclusion. A total of 107 studies (reported in 118 publications) addressed the Key Questions; 20 were trials and 87 were observational studies. Seventy-one studies were newly identified as part of this update and 36 of 97 were carried forward from the previous review; reasons for exclusion of studies from the prior report related to modified inclusion criteria (e.g., ineligible screening tests and comparators). Study characteristics and quality ratings are detailed in Appendix B Tables 1 to 15.

## Key Question 1 a. Does Screening for GDM Reduce Poor Health Outcomes? b. Does Screening for GDM Reduce Poor Intermediate Outcomes? c. Does the Effectiveness of Screening for GDM Vary According to Maternal Subgroup Characteristics?

### Summary

- Four retrospective observational studies compared screening versus no screening. The two studies from the previous review focused on selected subpopulations of women and showed no effect of screening; however, sample sizes were small and estimates imprecise.
- Versus no screening, one new study (n=1,012) found one-step screening of at-risk women associated with a reduction in late (at least 28 weeks’ gestation) stillbirth and another new study (n=2,780) found universal two-step screening associated with fewer cesarean deliveries and some improved birth outcomes. Findings from both studies were susceptible to confounding and selection bias.

### Evidence

No trials were identified for this Key Question. Four observational studies (one case-control, three retrospective cohorts) compared screening vs. no screening; two were identified for this update^67,68^ and two were in the prior review.^2,69,70^ All studies compared women who underwent screening for GDM with women who were not screened; the studies did not analyze outcomes based on an intention/offer to screen. Screening approaches were risk-based in two studies^68,69^ and universal in the others.^67,70^ The two new studies screened for women with risk factors in early pregnancy.^67,68^ Sample sizes ranged from 93 to 2,780 (total N=4,336). Studies were conducted in the United Kingdom,^68^ Canada,^67^ Thailand,^69^ and the United States.^70^ Apart from the study in Thailand, 82-97% of the women enrolled in the studies were white. One study was rated as good quality,^69^ and three were rated as fair quality; methodological limitations in the fair-quality studies included possible selection biases,^68,70^ and not accounting for all potential confounders^67^ (Appendix B Tables 1 and 2). None of the studies reported intermediate outcomes.

Table 3 includes the evidence for this Key Question. The two retrospective cohort studies from the previous review focused on selected subgroups of women. A study from Thailand assessed women with one or more risk factors (most commonly age at least 30 years and family history of T2DM); 411 of 451 women were screened and 7.1 percent of those screened had GDM (2.9% in total population).^69^ Screening was not associated with reduction in risk of hypertensive disorders in pregnancy, gestational hypertension, cesarean delivery, or large for gestational age [LGA], or with increased risk of small for gestational age [SGA]. Authors of the second study surveyed a subset of nurses in a large U.S. cohort study.^70^ In a group of women not diagnosed with GDM (n=93), there was no difference between women who underwent screening with a 50 g OGCT versus those who had not undergone screening in risk of macrosomia (7% in both groups). Data on macrosomia in women diagnosed with GDM was not reported. Findings from these two studies were highly imprecise due to small sample sizes.

Table 3 Evidence From Observational Studies on Screening vs. No Screening for GDM (KQ1)

Author, Year, Country; Screening Strategy; Quality; Applicability | Outcome | Events/Score in Screened | Events/Score in Not Screened | Relative Risk (Odds Ratio, if specified) [95% Confidence Interval]
Stacey, 2019,^68^ United Kingdom; 2-step: screen for 1+ risk factor then 75g 2hr OGTT (NICE); Fair; Moderate (ethnic composition and risk status based on South Asian and Black Caribbean screening) | Still birth | 93 cases of stillbirth & 269 controls of 362 screened | 183 cases of stillbirth & 440 controls in 623 not screened | aOR, 0.68 [0.47 to 0.97] accounting for being “at risk”; Effects appear to be mainly within at-risk group: in women not receiving screening, being at-risk had higher odds of stillbirth aOR, 1.44 [1.01 to 2.06]
Hivert, 2012,^67^ Canada; 2-step: 50g OGCT and 75g 2hr OGTT IADPSG; early screening in those with multiple risk factors; Fair; Moderate (screening at specialized clinic offering some care and expedited referral; >93% White) | Cesarean delivery | 348/2012 (17.3%); GCT 1^st^ trimester: 160/1019; GCT 2^nd^ trimester: 188/993 | 170/768 (22.1%) | Screened vs not screened: 0.78 [0.66 to 0.92]; 1^st^ trimester screen vs not screened: 0.71 [0.58 to 0.86]; 2^nd^ trimester screen vs not screened: 0.86 [0.71 to 1.03]; Subgroup effects p=0.26
| Macrosomia (>4000 g) | 182/2012 (9%); GCT 1^st^ trimester: 95/1019; GCT 2^nd^ trimester: 87/993 | 56/768 (7.3%) | Screened vs not screened: 1.24 [0.93 to 1.65]; 1st trimester vs not screened: 1.28 [0.93 to 1.75]; 2nd trimester vs not screened: 1.20 [0.87 to 1.66]; Subgroup effects: p=0.79
| Birth injury (fracture and dislocation) | 16/2012 (0.8%); GCT 1^st^ trimester: 9/1019; GCT 2^nd^ trimester: 7/993 | 13/768 (1.7%) | Screened vs not screened: 0.47 [0.23 to 0.97]; 1st trimester vs not screened: 0.52 [0.22 to 1.21]; 2nd trimester vs not screened: 0.42 [0.17 to 1.04]
| Respiratory distress (not defined) | 201/2012 (10.0%); GCT 1^st^ trimester: 98/1019; GCT 2^nd^ trimester: 103/993 | 101/768 (13.2%) | Screened vs not screened: 0.76 [0.61 to 0.95]; 1st trimester vs not screened: 0.73 [0.56 to 0.95]; 2nd trimester vs not screened: 0.79 [0.61 to 1.02]; Subgroup effects: p= 0.74
| Hypoglycemia | 105/2012; GCT 1^st^ trimester: 51/1019; GCT 2^nd^ trimester: 54/993 | 42/768 | Screened vs not screened: 0.95 [0.67 to 1.35]; 1st trimester vs not screened: 0.92 [0.61 to 1.36]; 2nd trimester vs not screened: 0.99 [0.67 to 1.47]
| Hyperbilirubinemia | 690/2012; GCT 1^st^ trimester: 340/1019; GCT 2^nd^ trimester: 350/993 | 270/768 | Screened vs not screened: 0.98 [0.87 to 1.09]; 1st trimester vs not screened: 0.95 [0.83 to 1.08]; 2nd trimester vs not screened: 1.00 [0.88 to 1.14]
| Admission to NICU | 364/2012 (18.1%); GCT 1^st^ trimester: 157/1019; GCT 2^nd^ trimester: 207/993 | 206/768 (26.8%) | Screened vs not screened: 0.67 [0.58 to 0.78]; 1st trimester vs not screened: 0.57 [0.48 to 0.69]; 2nd trimester vs not screened: 0.78 [0.66 to 0.92]; Subgroup effects: p=0.05
Chanprapaph, 2004,^69^ Thailand; Selective 2-step: 50g OGCT (≥140 mg/dL) followed by 100g OGTT (NDDG); Good; Poor (results compared only in women with risk factors, different healthcare system) | Preeclampsia | 21/411 | 0/40 | 4.46 [0.27 to 75.00]
Chanprapaph, 2004,^69^ Thailand; Selective 2-step: 50g OGCT (≥140 mg/dL) followed by 100g OGTT (NDDG); Good; Poor (results compared only in women with risk factors, different healthcare system) | Gestational hypertension | 4/411 | 0/40 | 0.89 [0.05 to 16.91]
Chanprapaph, 2004,^69^ Thailand; Selective 2-step: 50g OGCT (≥140 mg/dL) followed by 100g OGTT (NDDG); Good; Poor (results compared only in women with risk factors, different healthcare system) | Cesarean | 81/411 | 5/40 | 1.72 [0.65 to 4.52]
Chanprapaph, 2004,^69^ Thailand; Selective 2-step: 50g OGCT (≥140 mg/dL) followed by 100g OGTT (NDDG); Good; Poor (results compared only in women with risk factors, different healthcare system) | Preterm delivery | 42/411 | 2/40 | 2.16 [0.50 to 9.29]
Chanprapaph, 2004,^69^ Thailand; Selective 2-step: 50g OGCT (≥140 mg/dL) followed by 100g OGTT (NDDG); Good; Poor (results compared only in women with risk factors, different healthcare system) | LGA (>90%ile) | 50/411 | 3/40 | 1.71 [0.51 to 5.75]
Chanprapaph, 2004,^69^ Thailand; Selective 2-step: 50g OGCT (≥140 mg/dL) followed by 100g OGTT (NDDG); Good; Poor (results compared only in women with risk factors, different healthcare system) | SGA (<10 %ile) | 42/411 | 3/40 | 1.40 [0.41 to 4.75]
Solomon, 1996,^300^ U.S.; 2-step: 50g OGCT with many using NDDG; Fair; Poor (only data for women without GDM) | Macrosomia (>4300 g) | 6/77 | 1/16 | 1.04 [0.13 to 8.30]

Abbreviations: aOR = adjusted odds ratio; IADPSG = International Association of Diabetes in Pregnancy Study Groups; LGA = large for gestational age; NDDG = National Diabetes Data Group; NICE = National Institute for Health and Care Excellence; NICU = neonatal intensive care unit; NR = not reported; OGCT = oral glucose challenge test; OGTT = oral glucose tolerance tests; SGA = small for gestational age

The two new studies evaluated screening approaches that included first-trimester screening in certain risk groups. A case-control study of late (at least 28 weeks) stillbirths included 1,012 women (291 cases) from multiple sites in the United Kingdom.^68^ Women with pre-existing T1DM and T2DM (self-reported) were excluded. Screening practices were not reported, although providers likely followed the 2015 NICE guidance. Women with at least one risk factor (South Asian or Black Caribbean ethnicity, BMI at least 30 kg/m^2^, or previous pregnancy effected by GDM or macrosomic [at least 4,500 g] birth) were supposed to be offered screening at 24 to 28 weeks. Women with previous GDM were offered screening at first visit in the first or second trimester. Thirty-six and 33 percent of cases and controls had at least one risk factor for GDM (less than 1% with previous GDM), and 38 of 371 (10.2%) screened were diagnosed. Twenty-five percent of women with at least one risk factor were not screened, and were analyzed with the women not at-risk for GDM in the control group. In the women at-risk, screening was associated with a lower risk for stillbirth (adjusted OR [aOR] 0.68, [95% CI, 0.47 to 0.97]). Although adjusted for known risk-factor status, the analysis was not able to adjust for unrecorded differences in risk profile, the participant’s engagement with health services, or variations in usual clinical practice which were noted by the authors.

A retrospective cohort study recruited 2,780 women delivering at a regional hospital in Quebec, Canada.^67^ Most screening used a universal two-step approach (OGCT with IADPSG for OGTT), and first-trimester screening was encouraged for women with multiple risk factors. Incidence of GDM was 10.7 and 5.4 percent in those screened in the first (n=1,019) and second (n=993) trimester, respectively, and 6.6 percent in those not screened (n=768; 7.8% undergoing OGTT). Women with GDM were referred to specialized centers for diabetes education and treatment. Although age and ethnicity were similar between all groups, other important potential confounders were not reported and the analysis was not adjusted. Screening was associated with decreased risk of cesarean delivery (RR, 0.78 [95% CI, 0.66 to 0.92]; ARD, 4.8% fewer [95% CI, 8.2 to 1.5), birth injuries (fracture or dislocation; RR, 0.47 [95% CI 0.23 to 0.97]; ARD, 0.9% fewer [95% CI, 1.9 fewer to 0.10 more]), and admissions to the NICU (RR, 0.67 [95% CI, 0.58 to 0.78]; ARD, 8.7% fewer [95% CI, 12.3 to 5.2]). There were no differences in rates of macrosomia (RR, 1.24 [95% CI, 0.93 to 1.65]), hypoglycemia (RR, 0.95 [95% CI, 0.67 to 1.35] or hyperbilirubinemia (RR, 0.98 [95% CI, 0.87 to 1.09]. Prespecified analyses comparing screening in first versus second trimester found a significantly greater effect for NICU admissions from screening early, but no difference for other outcomes. No data was provided in any of the studies for other subgroups.

## Key Question 2 What Are the Harms of Screening for and Diagnosis of GDM to the Mother, Fetus, or Neonate?

### Summary

- No studies on harms of screening versus no screening were included in the prior review; the current review did not limit inclusion to studies with a comparator of no screening.
- Psychosocial harms associated with screening. Two cohort studies (N=1,015) did not find undergoing screening or receiving a false positive result (i.e., positive on screening but not diagnosed) to be associated with an increase in anxiety or depressive symptoms.
- Psychosocial harms associated with receiving a diagnosis of GDM. One cohort study (n=100) found that receiving a GDM diagnosis may result in a small, transient increase in anxiety symptoms.
- Cesarean deliveries associated with a GDM diagnosis. One good-quality cohort study (n=3,778) found an association between prevalence of macrosomia and rates of cesarean deliveries in women with normoglycemia or untreated borderline GDM (status blinded to women and providers), but not in those with treated GDM where the cesarean rate was relatively high despite fewer cases of macrosomia, suggesting that the GDM diagnosis may have lowered the threshold for cesarean delivery.
- Hospital experiences potentially impacting breastfeeding outcomes. Three large studies employing survey data found some differences in hospital experiences potentially related to labelling (i.e., only related to the GDM diagnosis) and impacting breastfeeding outcomes for women with versus without GDM, although confounding factors (e.g., breastfeeding intentions, varying hospital policies, treatment effects) could have impacted findings.

### Evidence

The prior review did not include any studies of screening versus no screening with data on harms.^2^ As described in the methods section, for this review inclusion criteria were expanded to studies comparing women with versus without GDM or a false positive screening result. We included seven observational studies (Appendix B Table 3).^71–77^

#### Study Characteristics

Sample sizes ranged from 100^71^ to 157,187^76^ (median n=1,773; total N=166,082). Mean age across five studies that reported this data was 30.5 years.^71,73–75,77^ Three studies were conducted in the United States^72,74,76^ and two were conducted in each of Canada^73,75^ and Australia.^71,77^ In the five studies reporting race/ethnicity, the proportion of non-Hispanic white women ranged from 48 to 86 percent. Two studies excluded women with previous GDM^71,73^ and one included many women in the GDM groups (40%) with previous GDM.^77^ Four studies were undertaken in primary care or obstetrician offices,^71,73,75,77^ while three used survey data.^72,74,76^

Five studies used a prospective cohort design^71,73–75,77^ and two a cross-sectional design.^72,76^ Three studies provided data on potential psychosocial harms (i.e., anxiety and/or depressive symptoms) from screening or a false positive result (i.e., positive on screening test but not diagnosed),^73,77^ or from receipt of a positive diagnostic test.^71^ Three studies examined hospital experiences related to breastfeeding outcomes in women with GDM versus those without GDM.^72,74,76^ Lastly, one study examined the likelihood of cesarean deliveries due to a GDM diagnosis in relation to rates of macrosomia.^75^ The studies did not report findings for subgroup effects in relation to race/ethnicity.

Quality was rated good for three studies^72,75,76^ and fair for four^71,73,74,77^ (Appendix B Table 4). Most studies did not evaluate defined cohorts of women who underwent screening or received a GDM diagnosis, because they excluded those without follow-up assessments, which could have resulted in selection bias. The studies rated as good quality all adjusted their analysis for multiple important confounders (e.g., delivery and neonatal variables for postpartum outcomes). Ascertainment of GDM exposure was based on self-report in four studies,^72–74,76^ although we did not rate down for this because potential harms may be related to labeling and perceived consequences of a perceived GDM diagnosis, even if inaccurate.

#### Psychosocial Harms Associated With Screening for GDM

A cohort study (n=202) reported on anxiety and depressive symptoms before screening, after screening (but before receiving results), and late in pregnancy.^77^ Levels of anxiety were fairly low across the three time points in women with versus without false positives or GDM and no differences were found (Appendix D Table 1). Clinically relevant depressive symptoms were present in 17 to 21 percent of women, without significant changes over time in either group.

A larger study (n=813) measured changes in state (“reactive”) anxiety and depressive symptoms between 12-24 weeks’ (before screening) and 32 weeks’ gestation (after receiving results) in women reporting a false positive result, a negative OGCT result, or not testing (considered negative).^73^ Women with previous GDM experience were excluded. Mean changes in both groups for anxiety and depression were minimal and no significant differences were found for the false positive versus screen negative groups.

#### Psychosocial Harms Associated With Receiving a GDM Diagnosis

One small study (n=100) found that state (“reactive”) anxiety was higher for women with versus without GDM right after receiving results of the OGTT (mean 6 points on 60-point scale; p= 0.007), but that levels declined to reach similar levels to the NGT group at gestational week 36 and were stable until 6 weeks’ postpartum.^71^ Trait (“intrinsic”) anxiety was similar between groups at all three time points.

#### Cesarean Deliveries Associated With a GDM Diagnosis

In one cohort study of an ethnically diverse population, rates of macrosomia and cesarean delivery were compared among women with untreated borderline GDM (n=115), treated overt GDM (n=143), and normoglycemia (n=3,520).^75^ Patients and providers were blinded to the glycemic status of those without overt GDM. For women with untreated borderline GDM, rates of macrosomia were higher than for women with normoglycemia, and cesarean deliveries were associated with macrosomia (45.5% with vs. 23.5% without; p=0.02). Among women with treated GDM, cesarean deliveries were equally common whether the neonate was macrosomic (33% [5/15]) or not (33.6% [43/128]). On multivariate logistic regression accounting for several maternal characteristics including preeclampsia as well as fetal distress and breech, the aOR for cesarean was significant for patients with overt GDM (1.6 [95% CI, 1.0 to 2.5]), but not for those with a false positive screen (1.2 [95% CI, 0.9 to 1.5] or borderline GDM (1.2 [95% CI, 0.7 to 2.0]). Findings suggest that the diagnosis of GDM may have contributed to decisions to perform cesarean deliveries. Key Question 7 also addresses rates of cesarean deliveries versus macrosomia based on findings from GDM treatment trials.

#### Hospital Experiences Associated With a GDM Diagnosis Potentially Impacting Breastfeeding Outcomes

Three studies reported survey findings comparing hospital experiences related to breastfeeding outcomes between women with versus without GDM; the studies adjusted for various maternal, delivery, and neonatal factors.

One large survey of an ethnically diverse population (n=157,187)^76^ found that women with GDM were about 15 to 20 percent less likely to report breastfeeding in the first hour, feeding only breast milk in the hospital, and/or feeding on demand, and were more likely to receive a formula gift pack compared with those without GDM. Although multiple variables were accounted for in the analysis (e.g., NICU admission, mode of delivery), neonatal hypoglycemia was not accounted for and residual confounding from BMI as well as variability in implementation of the initiatives by hospitals may have impacted results. In the second study (n=1,733),^72^ women with versus without GDM had similar rates of breastfeeding within the first hour but had fewer neonates (without an NICU admission) staying in their mother’s room (aOR, 0.55 [95% CI, 0.36 to 0.85]). The third study found GDM associated with higher likelihood of hospital supplementation (aOR, 1.86 [95% CI, 1.27 to 2.72]) versus no GDM; GDM also associated with shorter duration of breastfeeding, but this appeared to be mediated more by exclusive breastfeeding intentions in the third trimester than by supplementation.^74^

## Key Question 3 a. What Is the Comparative Effectiveness of Different Screening Strategies for GDM on Health Outcomes? b. What Is the Comparative Effectiveness of Different Screening Strategies for GDM on Intermediate Outcomes? c. Does the Comparative Effectiveness of Different Screening Strategies Vary According to Maternal Subgroup Characteristics, Including Timing During Pregnancy, Previous GDM Diagnosis, Family History of Type 2 Diabetes Mellitus, BMI, Age, or Race/Ethnicity?

### Summary

- IADPSG versus CC screening. Based on five RCTs (N=25,772), screening with IADPSG versus CC criteria was associated with an increased prevalence of GDM (on average 11.5% vs 4.9%) but no difference in health outcomes.
- IADPSG versus WHO 1999. One RCT (n=502) comparing IADPSG versus WHO 1999 criteria found that there may be no differences in primary cesarean or preterm delivery rates. Findings for other outcomes were imprecise.
- Early versus usual timing for CC screening. An RCT (n=922) enrolling obese women found early versus usual screening with CC criteria potentially associated with increased risk of preeclampsia, though the difference was not statistically significant (RR, 1.42 [95% CI, 0.99 to 2.05]; ARD, 4.0% more [0.0 to 8.0]). There were no differences in risk of several other maternal and fetal/neonatal outcomes, though some estimates were imprecise.

### Evidence

The prior review did not include a Key Question on the comparative effectiveness of different screening strategies.^2^ This review included seven RCTs (Table 4 and Appendix B Tables 5 and 6). Three RCTs^78–80^ were excluded because they did not present data by randomized screening arm.

Table 4 Summary of Trials Comparing Different GDM Screening Strategies (KQ3)

Author, Year; Country; Study Design; Quality | Inclusion Criteria | Exclusion Criteria | Screening Strategy Group 1 | Screening Strategy Group 2 | Treatment Differences Gestational Weeks (wGA) at Delivery | # Enrolled; # Analyzed
Davis 2021^85^; US; RCT; Good | Women 18-45 yrs and at 18- 28 6/7 wGA receiving care at one of 10 obstetric clinics | Pre-existing DM (≥200 mg/dL [< 11.1 mmol/L] on OCGT during baseline visit), diabetes diagnosed before 24 wGA, multifetal gestation, hypertension requiring medications, any corticosteroid use 30 d before enrollment, major congenital anomaly, anticipated preterm delivery before 28 wGA, inability to complete the glucose testing before 30 wks of gestation, human immunodeficiency virus (HIV) infection, liver disease, and a history of gastric bypass surgery or other conditions that precluded OGTT consumption | IADPSG (universal, 75g 1-step) 25-32 wGA; (n=461, GDM = 14.4%) | CC (universal, 100g 2-step; OGCT 130 mg/dL) with OGTT at 25-32 wGA; (n=460, GDM = 4.5%) | Gestational diabetes treatment occurred per routine clinical care; individualized nutritional counseling by CDE in group or individual setting, SMBG, medical management as per treating physician. Medication use among participants: G1 9.3% vs G2 2.4%; wGA at delivery G1 38.7±2.1 vs G2 39.1±1.8 | 921; 855
Hillier 2021^86^; US; RCT; Fair (open label and high cross-over, but adjusted results very similar) | All pregnant women ≥18 yrs who were receiving care at two large health maintenance organizations | Pre-existing diabetes (before randomization); post-randomization exclusions of 33.1% (of 35,579) mainly due to miscarriage (31.8%) but also multiple gestation, age <18 yrs, previous bariatric surgery, and change in insurance. Baseline characteristics very similar between groups. | IAPSG (universal, 75g 1-step) 24-28 wGA, or in 1^st^ trimester if obese or high- risk (criteria NR; 10% using HbA1c or FPG); (n=11,922, gestational diabetes=1,967 [16.5%]); 25% received CC as diagnostic test | CC (universal, 100g 2-step; OGCT ≥130 or 140 mg/dL) 24-28 wGA, or in 1st trimester if obese or high-risk (criteria NR; 9% using HbA1c or FPG); (n=11,870, gestational diabetes=1,009 [8.5%]) | Same treatment protocol between groups; referred to a dietician for individually-tailored diet and lifestyle recommendations, and SMBG, with medication (90% insulin) added when targets not met. Insulin/medication among those with gestational diabetes: G1 42.6% vs G2 45.6%.; CC women (n=165) with isolated FPG ≥95 md/dL on OGTT received treatment but were not diagnosed with gestational diabetes; sensitivity analysis for LGA showed no evidence of effect from re-classifying these women as having gestational diabetes.; wGA at delivery NR | 35,579 (randomized at first prenatal visit); 23,792 (see exclusion criteria)
Khalifeh 2018^87^; US; RCT; Fair (open label; 79% women analyzed) | Women without preexisting diabetes | Women with history of pre-existing diabetes or a history of bariatric surgery; failure to attend screening (after randomization; n=35) | IADPSG (universal, 75g 1-step) 24-28 wGA, or at initial prenatal visit if ≥ 1 risk factor^a^ (and repeated at 24-28 wGA if –ve); (n=123, gestational diabetes=10 [8.1%]) | CC (universal, 100g 2-step; OGCT ≥135mg/dL) 24-28 wGA, or at initial prenatal visit if ≥ 1 risk factors^a^ (and repeated at 24-28 wGA if –ve); (n=126, gestational diabetes=7 [5.6%]) | Treatment for gestational diabetes was the same regardless of group allocation; delivery at 39 0/7 to 39 6/7 week was recommended to all women with gestational diabetes; medication or insulin G1 4.1% vs G2 3.2%; wGA at delivery NR | 284; 226
Scifres 2015^83^; US; RCT; Good | 18-45 years old, singleton pregnancy between 18-24 wGA receiving prenatal care at an outpatient obstetrical clinic at a large academic teaching hospital | OGCT >200mg/dL (n=0), pre-existing diabetes or +ve screen for diabetes within 1^st^ trimester (<24 wGA), multiple gestations, corticosteroid use 30 days prior to enrollment, gastric bypass surgery, use of fertility treatments to conceive, plan to deliver at different hospital, inability to complete testing before 30 completed wGA, or anticipated preterm delivery for maternal or fetal indications | IADPSG (universal, 75g 1-step) 24-28 wGA; (n=24, gestational diabetes=1 [4%]); All patients first given OGCT and if >200mg/dl excluded and not randomized | CC (universal, 100g 2-step; OGCT ≥130 mg/dL) 24-28 wGA; (n=23, gestational diabetes=0 [0%]); Initial OGCT, if >200mg/dl excluded and not randomized | Treatment for gestational diabetes performed according to clinical care standards of each participant’s provider; SMBG; first line medication glyburide or insulin (n=0); wGA at delivery G1 39.3 ± 1.1 vs. G2 39.6 ± 1.3 | 47; 47
Sevket 2014^84^; Turkey; RCT; Fair (unclear allocation concealment; open label) | Women 24-28 wGA, referred for gestational diabetes screening and coming for screening visit | Multiple pregnancies, pre-existing diabetes, fetal anomalies diagnosed prenatally, delivery <28 wGA, those who made errors in protocol | IADPSG (universal, 75g 1-step) 24-28 wGA; (n=386, gestational diabetes=56 [14.5%]) | CC (universal, 100g 2-step; OGCT ≥140mg/dL) 24-28 wGA; (n=400, gestational diabetes=24 [6%]) | Treatment for gestational diabetes was the same regardless of group allocation; endocrinologists with SMBG, diet, and, if needed, medication; protocol for delivery NR; wGA at delivery NR | 856; 786; Publication only presents results for non-gestational diabetes patients. Saccone et al. obtained missing data by contacting study authors.
Harper 2020^82^; US; RCT; Good (open label but blinded assessment of gestational hypertension and preeclampsia) | Obese (≥30 kg/m^2^), non-anomalous, singleton gestations, receiving prenatal care <20 wGA at the university hospital | Pre-existing diabetes, major medical illness (cardiac disease, HIV, hemoglobinopathy, oxygen requirement), bariatric surgery, prior cesarean section, known fetal anomalies, chronic prednisone use | Early screening by CC (universal, 100g 2-step; OGCT ≥135 mg/dL) 14-20 wGA. If negative underwent repeat screening at 24-28 wGA; (n=454, gestational diabetes=69 [17.8%]); All had HbA1c at 14-20 wGA and 24-28 wGA with >6.5%=gestational diabetes; if 6.2-6.5% underwent 2-step screening for gestational diabetes; 84.3% received early screening | Routine screening by CC (universal, 100g 2-step; OGCT ≥135 mg/dL) 24-28 wGA; (n=458, gestational diabetes=56 [12.6%]; 1 gestational diabetes before 24 wks); All had HbA1c at 14-20 wGA and 24-28 wGA with >6.5%=gestational diabetes; if 6.2-6.5% underwent 2-step screening for gestational diabetes; 95.9% received screening | Treatment for gestational diabetes was the same regardless of group allocation (diabetes educator and SMBG; insulin, glyburide or metformin chosen at discretion of provider if glucose targets not met); insulin G1 2.4% vs G2 0.7%, p=0.03; any diabetic medication G1 6.8% vs G2 4.3%, p=0.34; wGA at delivery G1 36.7 ± 4.5 vs. G2 38.7 ± 1.7 | 962; 922
Basri 2018^81^; Malaysia; Fair (failure to report randomization and allocation methods) | ≥1 risk factors^b^ for GDM at 14-17 wGA and attending tertiary hospital and referral center | Multiple pregnancies, previously diagnosed type 1 DM or type 2 DM, inability to complete OGTT | IADPSG 2010 (universal, 75g 1-step, no 1hr value) <28 wGA. If results were –ve or new risk factor emerged, repeated testing between 28-32 wGA.; (n=259, GDM=100 [38.6%]) | WHO 1999 (universal, 75g 1-step; FPG ≥6.1 mmol/L and/or 2 h ≥7.8 mmol/L) <28 wGA. If results were –ve or new risk factor emerged, repeated testing between 28-32 wGA.; (n=261, GDM=99 [37.9%]) | Treatment for GDM is the same regardless of group allocation (dietary and SMBG with medication or insulin if blood sugar profile unsatisfactory); insulin use G1 8% vs G2 6.1.1%, oral hypoglycemic medications G1 4% vs G2 4%; wGA at delivery NR | 520; 502

Abbreviations: CC = Carpenter and Coustan; DM = diabetes mellitus; g = gram(s); GDM = gestational diabetes mellitus; HIV = human immunodeficiency virus; IADPSG = International Association of Diabetes in Pregnancy Study Groups; NDDG = National Diabetes Data Group; NR = not reported; OGCT = oral glucose challenge test; OGTT = oral glucose tolerance test; RCT = randomized controlled trial; SMBG = self-monitoring of blood glucose; wGA = weeks’ gestation; WHO = World Health Organization

a Risk factors included: ≥30kg/m^2^, previous GDM, history of macrosomic baby (>4kg), or polycystic ovarian syndrome.

b Risk factors included: history of GDM, first degree relative with DM, BMI >27, age 25 years and above, current obstetric problem, (essential hypertension, pregnancy-induced hypertension, polyhydramnios, current steroid use), previous macrosomic infant (>4kg), previous unexplained stillbirth, fetus with congenital anomaly, persistent glycosuria, recurrent urinary tract infection or vaginal discharge.

#### Study Characteristics

Sample sizes ranged from 47 to 23,792 (median 786; total N=27,196) and mean age from 25.4 to 31.9 years (median 28.7). Six trials reported mean BMIs ranging from 25.7 to 37.1 kg/m^2^ (median 27.1).^81–86^ Five trials were conducted in the United States,^82,83,85–87^ one in Turkey,^84^ and one in Malaysia.^81^ Three studies reported on the proportion of women with prior GDM (2.0 to 5.3%),^85–87^ and one reported on history of T2DM. The U.S. trials enrolled diverse populations.

Five RCTs (N=25,772)^83–87^ compared one-step IADPSG versus two-step CC screening, one RCT (n=502)^81^ compared IADPSG (omitting one-hour value) versus WHO 1999 (FPG value 6.1 mmol/L or greater and/or 2-hour 7.8 mmol/L or greater) criteria, and another RCT (n=922)^82^ compared early (14 to 20 weeks’ gestation) versus usual (24 weeks or later) timing of screening with a two-step CC approach. Except for the comparison of early versus usual screening,^82^ the trials evaluated screening at 24 to 28 weeks’ gestation, with two^86,87^ also offering early screening for women with one or more risk factors. Screening was applied universally, although one trial^81^ only enrolled women with one or more risk factors (including BMI over 27 and age over 24) and another^82^ only enrolled obese (BMI 30 kg/m^2^ or greater) women. In the two-step CC screening approaches, the OGCT thresholds were 130,^83,85^ 135,^82,87^ 140 mg/dL,^84^ and either 130 or 140 mg/dL.^86^ All trials excluded women with a known history of preexisting diabetes. They also reported similar treatment between arms for women diagnosed with GDM. Four of the trials^81,83,84,87^ analyzed women who undertook screening, whereas three others^82,85,86^ included women regardless of their screening uptake. None of the studies reported data for intermediate outcomes or evaluated effects in subgroups.

Two of the trials^83,85^ were rated good quality and the other five trials were rated fair quality. In the good quality trials,^83,85^ women were blinded to study group by having all women undertake the 50g OGCT at enrollment (also helping exclude those with presumed T2DM) and telling participants that their OGTT visit would last between 2 and 4 hours; providers were only told which patients were diagnosed with GDM and not the relevant screening criteria or test values. Methodological limitation in the fair-quality trials were open-label design, unclear risk for selection biases,^81,84^ high attrition,^87^ and possible selective reporting^84^ (Appendix B Table 6). The largest trial (n=23 792)^86^ had substantial cross-over, with 25% of women allocated to one-step screening with IADPSG receiving two-step CC screening, although results remained similar in intention-to-treat analysis adjusted for gestational diabetes and adherence. Further, women allocated to the two-step CC group who had an isolated fasting plasma glucose ≥95 mg/dL (n=165; 1.4%) were provided some treatment even though they were not diagnosed as having gestational diabetes which required two abnormal values of the OGTT. The authors performed sensitivity analysis for the outcome of LGA and findings showed no evidence that this reclassification affected results. Data from another trial (n=786)^84^ were obtained from a systematic review^88^ and could not be verified.

#### IADPSG vs. CC Screening

##### Pregnancy Outcomes

Screening with IADPSG versus CC criteria was not associated with differences in preeclampsia (3 RCTs, N=1,059; RR, 0.66 [95% CI, 0.15 to 2.98]; I^2^=76%),^83,84,87^ gestational hypertension (2 RCTs, N=833; RR, 0.98 [95% CI, 0.70 to 1.38]),^85,86^ hypertensive disorders in pregnancy (2 RCTs, N=22,746; RR, 1.01 [95% CI, 0.95 to 1.08]; I^2^=0%),^85,86^ primary cesarean deliveries (3 RCTs, N=24,302; RR, 0.87 [95% CI, 0.67 to 1.13]; I^2^=57%,^83,84,86^ total cesarean deliveries (3 RCTs, N=1,151; RR, 1.04 [95% CI, 0.87 to 1.26]; I^2^=0%),^83,85,87^ induction of labor (3 RCTs, N=23,742; RR, 1.00 [95 CI, 0.96 to 1.04]; I^2^=0%),^83,86,87^ maternal birth trauma (third or fourth degree vaginal lacerations) (3 RCTs, N=1,151; RR, 0.65 [95% CI, 0.30 to 1.44); I^2^=0%),^83,85,87^ or excessive weight gain (2 RCTs, N=18,419; RR, 0.97 [95% CI, 0.94 to 1.00]; I^2^=0%).^83,86^ (Table 5 and Appendix C Figures 1 to 8). There was some inconsistency for preeclampsia, and preterm and primary cesarean deliveries, with statistically significant findings favoring IADPSG screening one of the smaller RCTs.^84^ Findings for preeclampsia, gestational hypertension and maternal birth trauma were imprecise.

Table 5 Effects From Trials Comparing Different GDM Screening Strategies on Pregnancy Outcomes (KQ3)

Outcome | Comparison | Number of Studies | Proportion of Events in Group 1* (or incidence % [95% CI]) | Proportion of Events in Group 2 (or incidence % [95% CI]) | Relative Risk [95% CI]; I^2^ (unless stated otherwise)
Preeclampsia | IADPSG vs CC | 3^83,84,87^ | 16/520 | 34/539 | 0.66 [0.15 to 2.98]; 76%
Preeclampsia | IADPSG vs CC (sensitivity analysis with profile likelihood) | 3^83,84,87^ | 16/520 | 34/539 | 0.61 [0.13 to 4.13]; 59%
Preeclampsia | Early vs usual timing with CC | 1^82^ | 62/459 | 44/463 | 1.42 [0.99 to 2.05]; NA
Gestational hypertension | IADPSG vs CC | 2^83,84^ | 57/410 | 60/423 | 0.98 [0.70 to 1.38]; NA; ARD, −0.00 [−0.04 to 0.04]
Gestational hypertension | Early vs usual timing with CC | 1^82^ | 74/459 | 58/463 | 1.29 [0.94 to 1.77]; NA
Hypertensive Disorders in Pregnancy | IADPSG vs CC | 2^85,86^ | 1548/11425 | 1518/11321 | 1.01 [0.95 to 1.08]; 0%
Hypertensive Disorders in Pregnancy | IADPSG vs. WHO 1999 | 1^81^ | 14/249 | 15/253 | 0.95 [0.47 to 1.92]; NA
Hypertensive Disorders in Pregnancy | Early vs usual timing with CC | 1^82^ | 136/459 | 151/463 | 0.91 [0.75 to 1.10]; NA
Total cesarean deliveries | IADPSG vs CC | 3^83,85,87^ | 168/585 | 156/566 | 1.04 [0.87 to 1.26]; 0%
Primary cesarean deliveries | IADPSG vs CC | 3^83,84,86^ | 2891/12165 | 2980/12137 | 0.87 [0.67 to 1.13]; 57%
Primary cesarean deliveries | IADPSG vs CC (sensitivity analysis with profile likelihood) | 3^83,84,86^ | 2891/12165 | 2980/12137 | 0.97 (0.71 to 1.04); 0%
Primary cesarean deliveries | IADPSG vs. WHO 1999 | 1^81^ | 66/249 | 64/253 | 1.05 [0.78 to 1.41]; NA
Primary cesarean deliveries | Early vs usual timing with CC | 1^82^ | 79/459 | 93/463 | 0.86 [0.65 to 1.12]; NA
Induction of Labor | IADPSG vs CC | 3^83,86,87^ | 3730/11889 | 3728/11853 | 1.00 [0.96, 1.04]; 0%
Induction of Labor | Early vs usual timing with CC | 1^82^ | 212/454 | 229/458 | 0.93 [0.82 to 1.07]
Preterm delivery | IADPSG vs CC | 4^83,84,86,87^ | 743/11740 | 753/11700 | 0.86 [0.53 to 1.39]; 66%; ARD, −0.01 [−0.04 to 0.02]
Preterm delivery | IADPSG vs CC (sensitivity analysis with profile likelihood) | 4^83,84,86,87^ | 743/11740 | 753/11700 | 0.99 (0.57 to 1.27); 0%
Preterm delivery | IADPSG vs. WHO 1999 | 1^81^ | 16/249 | 18/253 | 0.90 [0.47 to 1.73]; NA
Maternal birth trauma | IADPSG vs CC | 2^85,87^ | 10/585 | 15/566 | 0.65 [0.30 to 1.44]; 0%
Excessive gestational weight gain | IADPSG vs CC | 2^83,84,86^ | 4170/9263 | 4265/9156 | 0.97 [0.94 to 1.00]; 0%

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes in Pregnancy Study Groups; NA = not applicable; WHO = World Health Organization

##### Fetal/Neonatal Outcomes

Screening using IADSPG versus CC criteria was not associated with differences in perinatal mortality (5 RCTs, N=24,381; Peto OR, 0.83 [95% CI, 0.60 to 1.14]; I^2^=0%),^83–87^ birth injury (1 RCT, n=22,381; RR, 1.27 [95% CI, 0.90 to 1.80),^86^ shoulder dystocia (including brachial plexus injury in one RCT^85^) (4 RCTs, N=23,583; Peto OR 1.08 [95% CI, 0.90 to 1.30); I^2^=0%),^83,85–87^ LGA infants (5 RCTs, N=23,951; RR, 0.82 [95% CI, 0.61 to 1.10]; I^2^=35%),^83–87^ macrosomia (≥4,000 g) (5 RCTs, N=22,524; RR, 0.87 [95% CI, 0.64 to 1.20); I^2^=41%)^83–87^, neonatal hypoglycemia (5 RCTs, N=24,318; RR, 1.00 [95% CI, 0.68 to 1.46); I^2^=67%),^83–87^ hyperbilirubinemia (4 RCTs, N=24,271; RR, 1.02 [95% CI, 0.78 to 1.36]; I^2^=32%),^84–87^ or NICU admissions (4 RCTs, N=24,092; RR, 0.95 [95% CI, 0.64 to 1.40); I^2^=78%)^83–86^ (Figures 2 to 5 and Appendix C Figures 9 to 11). There was some statistical heterogeneity in some analyses where a fair-quality trial^84^ found significant associations favoring one-step screening, though findings from one good-quality trial^86^ and the largest (fair quality) trial^86^ were similar. In the largest trial,^86^ one-step screening significantly increased risk for neonatal hypoglycemia versus two-step screening (Figure 5).

Figure 2 Meta-Analysis of Trials: Large for Gestational Age, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel

Figure 2 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies on large-for-gestational age infants. Our meta-analysis (5 trials, 23951 subjects) found the pooled relative risk was 0.82 with a 95% CI of 0.61 to 1.10; I2=35%.

Figure 3 Meta-Analysis of Trials: Macrosomia >4,000 g, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel

Figure 3 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies on macrosomia (>4000 grams). Our meta-analysis (5 trials, 22524 subjects) found the pooled relative risk was 0.87 with a 95% CI of 0.64 to 1.20; I2=41%.

Figure 4 Meta-Analysis of Trials: NICU Admission, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel

Figure 4 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies on NICU admissions. Our meta-analysis (4 trials, 24,092 subjects) found the pooled relative risk was 0.95 with a 95% CI of 0.64 to 1.40; I2=78%.

Figure 5 Meta-Analysis of Trials: Neonatal Hypoglycemia, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel

Figure 5 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies on neonatal hypoglycemia. Our meta-analysis (5 trials, 24318 subjects) found the pooled relative risk was 1.00 with a 95% CI of 0.68 to 1.46; I2=67%. The largest trial by Hillier and colleagues (2021) found a statistically significant effect with a relative risk of 1.23 with a 95% CI of 1.12 to 1.34.

##### Harms From Screening

In one trial (n=921),^85^ in which all women randomized to two-step screening underwent the 100 g OGTT (to assist with blinding), two-step screening was associated with significantly more testing-related adverse events than one-step screening (reactive hypoglycemia, vomiting, nausea). However, these findings overestimate harms of two-step screening in clinical practice, in which only those with an abnormal 50 g OGCT would undergo the 100 g OGTT. The authors report that when considering only the women who would have undergone the OGTT in practice, 4% rather than the 35.7% found in the trial, of women in the CC group would have had one or more adverse events, compared with the 13% of all women screened by IADPSG criteria.

#### IADPSG vs. WHO 1999 Criteria

##### Pregnancy Outcomes

One RCT (n=502)^81^ found IADSPG and the WHO 1999 criteria associated with similar likelihood of primary cesarean deliveries (RR, 1.05 [95% CI, 0.78 to 1.41]) or preterm delivery (RR, 0.90 [95% CI, 0.47 to 1.73], though estimates were imprecise. Findings for hypertensive disorders in pregnancy were imprecise (Table 5).

##### Fetal/Neonatal Outcomes

Findings for shoulder dystocia, LGA and hypoglycemia in one RCT^81^ were imprecise (Table 6).

Table 6 Effect From Trials Comparing Different GDM Screening Strategies on Fetal/Neonatal Outcomes (KQ3)

Outcome | Comparison | Number of Studies | Proportion of Events in Group 1^*^ (or incidence % [95% CI]) | Proportion of Events in Group 2 (or incidence % [95% CI]) | Relative Risk [95% CI]; I^2^ (unless stated otherwise)
Perinatal mortality (still birth or neonatal death) | IADPSG vs CC | 4^84–87^ | 69/12223 | 83/12158 | Peto odds ratio: 0.83 [0.60, 1.14] ; 0%
Birth injury (fracture or nerve palsy) | IADPSG vs CC | 1^86^ | 73/11220 | 57/11161 | 1.27 [0.90 to 1.80]; NA
Shoulder dystocia | IADPSG vs CC (includes brachial plexus injury for 1 RCT^85^) | 4^83,85–87^ | 248/11835 | 228/11748 | Peto odds ratio: 1.08 [0.90 to 1.30] ; 0%
Shoulder dystocia | IADPSG vs. WHO 1999 (includes birth injury) | 1^81^ | 1/249 | 0/253 | 3.05 [0.12 to 74.46]; NA
Shoulder dystocia | Early vs usual timing with CC | 1^82^ | 30/459 | 32/463 | 0.96 [0.49 to 1.86]; NA
Macrosomia > 4000 grams | IADPSG vs CC | 5^83–87^ | 1228/11283 | 1251/11241 | 0.87 [0.64 to 1.20]; 41%
Macrosomia > 4000 grams | IADPSG vs CC (sensitivity analysis with profile likelihood) | 5^83–87^ | 1228/11283 | 1251/11241 | 0.98 (0.70 to 1.08); 0%
Macrosomia > 4000 grams | Early vs usual timing with CC | 1^82^ | 25/459 | 21/463 | 1.20 [0.68 to 2.11]
Large for gestational age | IADPSG vs CC | 5^83–87^ | 1026/11999 | 1084/11952 | 0.82 [0.61 to 1.10]; 35%
Large for gestational age | IADPSG vs. WHO 1999 | 1^81^ | 7/249 | 3/253 | 2.37 [0.62 to 9.06]; NA
Large for gestational age | Early vs usual timing with CC | 1^82^ | 27/459 | 26/463 | 1.05 [0.62 to 1.77]; NA
Neonatal respiratory distress | IADPSG vs CC | 1^86^ | 225/11220 | 227/11161 | 0.99 [0.82 to 1.18]; NA
Neonatal hypoglycemia | IADPSG vs CC | 4^83–87^ | 1105/12191 | 908/12127 | 1.00 [0.68 to 1.46]; 67%
Neonatal hypoglycemia | IADPSG vs CC (sensitivity analysis with profile likelihood) | 4^84–87^ | 1105/12191 | 908/12127 | 1.21 (0.63 to 1.34); 0%
Neonatal hypoglycemia | IADPSG vs. WHO 1999 | 1^81^ | 3/249 | 4/253 | 0.76 [0.17 to 3.37]; NA
Neonatal hypoglycemia | Early vs usual timing with CC | 1^310^ | 22/459 | 19/463 | 1.17 [0.64 to 2.13]; NA
Neonatal hyperbilirubinemia | IADPSG vs CC | 4^84,86,87^ | 530/12167 | 525/12104 | 1.02 [0.78 to 1.36]; 32%
Neonatal hyperbilirubinemia | Early vs usual timing with CC | 1^82^ | 90/459 | 72/463 | 1.26 [0.95 to 1.67]; NA
Admission to NICU | IADPSG vs CC | 4^83–86^ | 606/12081 | 558/12011 | 0.95 [0.64 to 1.40]; 78%; ARD, −0.00 [−0.04 to 0.03]
Admission to NICU | IADPSG vs CC (sensitivity analysis with profile likelihood) | 3^84–86^ | 606/12081 | 558/12011 | 0.95 (0.49 to 1.63); 75%
APGAR score <7 at 5 minutes | IADPSG vs CC | 1^87^ | 1/110 | 2/116 | 0.53 [0.05 to 5.73]; NA
Small for gestational age | IADPSG vs CC | 4^83–86^ | 1004/11889 | 966/11836 | 1.03 [0.95, 1.12]; 0%

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes in Pregnancy Study Groups; NA = not applicable; NDDG = National Diabetes Data Group; NICU = neonatal intensive care unit; WHO = World Health Organization

* Peto odds ratio was used when pooling studies with very rare or no events.

#### Early vs. Usual Timing of CC Screening

##### Pregnancy Outcomes

An RCT (n=922)^82^ enrolling obese women found early versus usual screening with CC criteria potentially associated with increased risk of preeclampsia, though the difference was not statistically significant (RR, 1.42 [95% CI, 0.99 to 2.05]; ARD, 4.0% more [0.0 to 8.0]) (Table 5). No associations were found for gestational hypertension (RR, 1.29 [95% CI, 0.94 to 1.77]), hypertensive disorders in pregnancy (RR, 0.91 [95% CI, 0.75 to 1.10]), primary cesarean deliveries (RR, 0.86 [95% CI, 0.65 to 1.12]), or induction of labor (RR, 0.93 [95% CI, 0.82 to 1.07]). All findings had some imprecision. Although preterm delivery rates were not compared, average delivery times were earlier in the early screening group (36.7 ± 4.5 vs. 38.7 ± 1.7 weeks’ gestation, respectively).

##### Fetal/neonatal Outcomes

No associations were found between early and usual timing of CC screening for shoulder dystocia (RR, 0.96 [95% CI, 0.49 to 1.86]), macrosomia (RR, 1.20 [95% CI, 0.68 to 2.11]), LGA (RR, 1.05 [95% CI, 0.62 to 1.77]), hypoglycemia (RR, 1.17 [95% CI, 0.64 to 2.13]), or hyperbilirubinemia (RR, 1.26 [95% CI, 0.95 to 1.67]); findings were limited by imprecision (Table 6).

## Key Question 4 a. What Is the Diagnostic Accuracy of Commonly Used Screening Tests for GDM? b. Does the Accuracy of Commonly Used Screening Tests for GDM Vary According to Maternal Subgroup Characteristics, Including Timing During Pregnancy, BMI, Age, Race/Ethnicity, or Prevalence of GDM?

### Summary

- For the 50 g OGCT versus CC criteria, the joint pooled estimates of sensitivity and specificity for the 140 mg/dL cutoff (8 studies, N=6,190) were 81.9 (95% CI, 68.3 to 90.4) and 81.8 percent (95% CI, 71.2 to 89.1). Sensitivity was higher but specificity lower at 135 mg/dL (4 studies, N=1,554; 93.3% [95% CI, 23.7 to 99.8] and 78.9 percent [95% CI, 53.3 to 92.5]). Findings for 130 mg/dL were inconsistent from three studies.
- For the 140 mg/dL OGCT cutoff with NDDG criteria (6 studies, N=5,375), the sensitivity was slightly higher (85% [95% CI, 72.0 to 92.6]) and specificity similar (81.2% [95% CI, 75.9 to 85.6]) compared with the CC criteria. Sensitivity for the OGCT compared with IADPSG criteria was relatively low across all cutoffs; specificity for the OGCT at the 140 mg/dL cutoff versus IADPSG criteria was fairly high (81% and 93% in two studies).
- For FPG versus CC criteria, sensitivities and specificities were fairly similar using cutoffs of 85 mg/dL (4 studies, N=2,233; 88% [95% CI, 84 to 91] and 73% [95% CI, 46 to 90]) and 90 mg/dL (4 studies, N=2,233; 81% [95% CI, 75 to 85) and 82% [95% CI, 61 to 93]). Across all cutoffs, sensitivity appeared fairly high (above 90%) using 80 mg/dL or lower and specificity appeared high (90% or above) using cutoffs over 90 mg/dL.
- For FPG versus IADPSG criteria at 24 weeks’ gestation or later, thresholds at or below 80 mg/dL appeared to have high sensitivity but low specificity. Specificity did not exceed 90 percent at thresholds below 90 mg/dL.
- HbA1c screening was not associated with high enough sensitivity and specificity at any threshold (18 studies). Screening with HbA1c at 24 weeks’ gestation may allow for ruling out GDM (i.e., sensitivity above 90%) at cutoffs of 4.5 to 5.0 percent (CC and NDDG) or 4.6 to 4.7 percent (IADPSG), but findings were based on a small number of studies. A good-quality study (n=1,158) of early screening versus NDDG criteria suggested that the rule-out cutoffs may also apply (i.e., sensitivity was over 95% at 4.5 to 4.8% HbA1c).
- Single studies found different risk-based tools (some in combination with FPG) may have high enough sensitivity to rule out GDM and allow some women to avoid the OGCT; however, specificity was low.

### Evidence

The prior review^1,2^ included 51 prospective cohort studies on the accuracy of screening tests for GDM. It found the 50g OGCT with a glucose threshold of either 130 mg/dL or 140 mg/dL to be accurate; the 130 mg/dL cutoff improved sensitivity and reduced specificity (99% vs. 85% and 77% vs. 86%, respectively). The sensitivity and specificity for FPG at a threshold of 85 mg/dL were 87 (95% CI, 81 to 91) and 52 percent (95% CI, 50 to 55), respectively. Eight studies examined risk factor-based screening using different diagnostic criteria but sensitivity and specificity varied widely. Limited evidence found that HbA1c as a screening test was associated with low accuracy. Sparse evidence was found for early screening for GDM and for screening with IADPSG criteria. The prior review noted limitations in the evidence, including partial verification bias (patients with negative tests did not undergo the reference standard) and use of index tests and diagnostic criteria not commonly used in the United States.

This review included 45 prospective cohort studies^38,89–132^ (with two associated papers^36,133^). Sixteen studies^89–91,93,98–100,104,106,111,112,116,118,120,127,129^ (with 1 associated paper^36^) were carried over from the prior review, and 29 studies^38,92,94–97,101–103,105,107–110,113–115,117,119,121–126,128,130–132^ (1 associated publication^133^) were added in this review. Because of revised eligibility criteria, 35 studies from the prior review were excluded due to the use of an ineligible diagnostic criterion (n=10),^134–143^ ineligible index test (n=9),^144–152^ not performing the reference standard on at least a sample of the women with a negative screening result (n=15),^153–167^ or (for risk models) not evaluating accuracy in a validation cohort (n=1).^168^ In all studies, the entire population that undertook the index test of interest was offered the OGTT reference standard; in some studies the OGCT was used to select patients for screening with the FPG and HbA1c. No study reported on differences in accuracy for the subgroups of interest.

#### 50g OGCT Screening Test

##### Carpenter and Coustan Criteria

Eight studies evaluated screening with a 1-hour 50 g OGCT against CC diagnostic criteria with a 100 g OGTT (Appendix B Table 7).^93,100,108,112,115,120,122,129^ Sample sizes ranged from 89 to 3,836 (median 402; total N=6,190). Mean age ranged from 25 to 31.8 years in three studies that reported this data,^112,122,129^ and BMI was 23.2^129^ and 23.8 kg/m^2112^ in two studies. Two studies were conducted in India;^115,122^ and one study was conducted in each of Brazil,^93^ Canada,^120^ Mexico,^100^ Pakistan,^108^ Switzerland,^112^ and Thailand.^129^ One study^108^ enrolled a low-risk population; another study only included women with at least one risk factor for GDM;^129^ other studies enrolled unselected populations. Two studies screened some women earlier than 24 weeks’ gestation (as early as 21^129^ and 22^115^ weeks). Prevalence of GDM ranged between 4.0 and 16.7 percent. Five studies were rated good quality,^93,100,112,120,129^ and three fair quality,^108,115,122^ due to potential selection biases (e.g., excluding some patients without outcome data due to others purposes of study), inadequate description of the reference standard (e.g., failure to provide details on fasting protocol), and/or issues related to flow and timing (e.g., some variation in timing of OGTT) (Appendix B Tables 8 and 9).

Eight studies (N=6,190) provided data for a 140 mg/dL threshold.^93,100,108,112,115,120,122,129^ The joint pooled estimates of sensitivity and specificity were 81.9 (95% CI, 68.3 to 90.4) and 81.8 percent (95% CI, 71.2 to 89.1) (Figure 6 and Table 7). Four studies (N=1,554) used a cutoff value of 135 mg/dL.^100,112,115,122^ The joint pooled estimates of sensitivity and specificity were 93.3 (95% CI, 23.7 to 99.8) and 78.9 percent (95% CI, 53.3 to 92.5); statistical heterogeneity was present for both parameters. Three studies (N=1,034) provided data for an OGCT cutoff value of 130 mg/dL.^100,115,122^ Sensitivities and specificities ranged from 75 to 100 percent, and 25 to 86 percent, respectively (Figure 6).

Figure 6 Forest Plots of Sensitivity and Specificity of 50-g Oral Glucose Challenge Test by Carpenter and Coustan Diagnostic Criteria (KQ4)

Abbreviations: CI = confidence interval; CC = Carpenter and Coustan; FN = false negative; FP = false positive; g = grams; OGCT = oral glucose challenge test; TN = true negative; TP = true positive

Figure 6 depicts a forest plot of studies reporting the sensitivity and specificity of the 50g OGCT by CC diagnostic criteria. At 130mg/dL (3 studies, 1034 subjects) the sensitivity ranged from 0.75 to 1.00, and specificity ranged from 0.25 to 0.81. At 135 mg/dL (4 studies, 1554 subjects) the sensitivity ranged from 0.60 to 1.00, and specificity ranged from 0.31 to 0.90. At 140mg/dL (8 studies, 6190 subjects) the sensitivity ranged from 0.58 to 1.00, and the specificity ranged from 0.44 to 0.92.

Table 7 Joint Estimates of Sensitivity and Specificity of GDM Screening Tests From Pooled Analyses (KQ4)

Criteria | Index Test and Cutoff | Timing of Index Test (Weeks’ GA) | Sensitivity (95% CI) | Specificity (95% CI)
CC | 50 g OGCT 135 mg/dL | 24-28 | 93 (24 to 100) | 79 (53 to 93)
CC | 50 g OGCT 140 mg/dL | 21-28 (most 24-28) | 82 (68 to 90) | 82 (71 to 89)
CC | FPG 79 mg/dL | 24-28 | 96 (92 to 98) | 35 (30 to 41)
CC | FPG 85 mg/dL | 22-28 | 88 (84 to 91) | 73 (46 to 90)
CC | FPG 90 mg/dL | 22-28 | 81 (75 to 85) | 82 (61 to 93)
CC | FPG 95.5 mg/dL | 24-28 | 58 (32 to 81) | 98 (88 to 100)
NDDG | 50 g OGCT 140 mg/dL | 24-28 | 85 (72 to 93) | 81 (76 to 86)
IADPSG | FPG 90 mg/dL | 24-28 | 79 (65 to 89) | 96 (95 to 97)

Abbreviations: CC=Carpenter and Coustan; CI=confidence interval; FPG=fasting plasma glucose; GA=gestational age; IADPSG= International Association of Diabetes and Pregnancy Study Groups; NDDG=National Diabetes Data Group; OGCT=oral glucose challenge test

##### NDDG Criteria

Six studies evaluated screening with a 1-hour 50 g OGCT against NDDG diagnostic criteria with a 100g OGTT.^98,100,106,111,120,127^ Sample sizes ranged from 42 to 3,836 (median 360; total N=5,375). Mean age ranged from 26 to 27.8 years. One study enrolled a high proportion (43%) of women with family history of DM;^100^ others enrolled unselected populations. Two studies were conducted in Turkey;^98,127^ and one study was conducted in each of Canada,^120^ Mexico,^100^ Spain,^111^ and the United States.^106^ Five studies performed the OGCT at 24 to 28 weeks’ gestation,^98,100,106,111,120,127^ and one at 25 to 27 weeks’ gestation.^120^ Prevalence of GDM ranged from 3.7 to 33 percent. Four studies were rated good quality,^98,100,106,120^ and two fair quality,^111,127^ due to potential issues with patient selection (e.g., exclusion of overt diabetes unclear), and either some concern about the index test (i.e., pre-specification of threshold not reported)^127^ or flow and timing (i.e., exact timing of OGTT not reported).^111^

Six studies (N=5,375) provided data for 50 g OGCT screening with a 140 mg/dL cutoff (Figure 7).^98,100,106,111,120,127^ Joint pooled estimates of sensitivity and specificity were 85.0 percent (95% CI, 72.0 to 92.6) and 81.2 percent (95% CI, 75.9 to 85.6), respectively (Table 7). Two studies (N=487) provided data for a cutoff value of 135 mg/dL.^100,127^ The sensitivities were 88.5^100^ and 78.6 percent^127^, and specificities were 84.2^100^ and 46.4^127^ (Figure 7). One study (n=445) used an OGCT cutoff value of 130 mg/dL.^100^ Sensitivity and specificity were 90.7 and 79.4 percent, respectively (Appendix D Table 3).

Figure 7 Forest Plots of Sensitivity and Specificity of 50-g Oral Glucose Challenge Test by NDDG Diagnostic Criteria (KQ4)

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; g = grams; KQ = key question; NDDG = National Diabetes Data Group; OGCT = oral glucose challenge test; TN = true negative; TP = true positive

Figure 7 depicts a forest plot of studies reporting the sensitivity and specificity of the 50g OGCT by NDDG diagnostic criteria. At 135 mg/dL (2 studies, 487 subjects) the sensitivity ranged from 0.79 to 0.88. At 140 mg/dL (6 studies, 5375) the sensitivity ranged from 0.65 to 0.98, and specificity ranged from 0.54 to 0.88.

##### IADPSG Criteria

Two good-quality studies evaluated screening with the 50g OGCT against IADPSG criteria using a 2-hour 75g OGTT in unselected populations.^95,110,133^ One study reported in two publications (n=1,811) took place in Belgium.^95,133^ Mean age was 30.8 years and BMI was 24.1 kg/m^2^. The OGCT was performed at 24 to 28 weeks’ gestation. The second study (n=280) from Nigeria performed the index test at 24 to 31 weeks’ gestation.^110^ Women had a mean age of 30.4 years and BMI of 27.2 kg/m^2^; 13.2 percent had a family history of DM. Prevalence of GDM was 12.6^95,133^ and 16.4 percent.^110^

Both studies reported on all three cutoff values.^95,110,133^ Sensitivities were low (below 70%) at all cutoffs; specificities were 81.0 and 93.2 percent (140 mg/dL), 76.1 and 88.0 percent (135 mg/dL), and 70.2 and 84.2 percent (130 mg/dL) (Figure 8).

Figure 8 Forest Plots of Sensitivity and Specificity of 50-g Oral Glucose Challenge Test by IADPSG Diagnostic Criteria (KQ4)

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; g = grams; IADPSG = International Association of the Diabetes and Pregnancy Study Groups; KQ = key question; OGCT = oral glucose challenge test; TN = true negative; TP = true positive

Figure 8 depicts a forest plot of studies reporting the sensitivity and specificity of the 50g OGCT by IADPSG diagnostic criteria. At 130 mg/dL (2 studies, 2093 subjects) the sensitivity ranged from 0.48 to 0.72, and the specificity ranged from 0.70 to 0.84. At 135 mg/dL (2 studies, 2093 subjects) the sensitivity ranged from 0.39 to 0.66, and the specificity ranged from 0.76 to 0.88. At 140 mg/dL (2 studies, 2093 subjects) the sensitivity ranged from 0.37 to 0.60, and the specificity ranged from 0.81 to 0.93.

##### Sacks Criteria

One good-quality study (n=445), conducted in Mexico, assessed accuracy of the OGCT versus a diagnosis of GDM at 24 to 28 weeks’ gestation using Sacks 1989 criteria (requiring two abnormal values using thresholds of FPG at 95 mg/dL, 1-hour 170 mg/dL, 2-hour 151 mg/dL, or 3-hour 130 mg/dL).^100^ Forty-three percent had a family history of DM. Prevalence of GDM was 13.9 percent.

The study provided data for cutoffs of 140, 135, and 130 mg/dL (Appendix D Table 2).^100^ Sensitivities were 82.3, 83.9, and 88.7 percent, respectively, and specificities were 88.0, 87.2, and 82.2 percent.

#### Fasting Plasma Glucose

##### Carpenter and Coustan Criteria

Seven studies evaluated screening with FPG against CC criteria with a 3-hour 100g OGTT;^89,90,99,104,112,115,122^ one study used a 2-hour 75g OGTT.^89^ Sample sizes ranged from 89 to 4,602 (median 520; total N=8,661). Mean age was 29.1 years in the five studies reporting this data,^89,90,99,112,122^ and mean BMI in two studies was 23.8^112^ and 28.1 kg/m^2^.^99^ Two studies were conducted in each of India^115,122^ and the United Arab Emirates;^89,90^ and one in each of France,^99^ Switzerland,^112^ and the United States.^104^ FPG was measured at 24 to 28 weeks’ gestation in all studies. One study only included low-risk women;^104^ two studies only included women with a positive OGCT,^90,99^ or who were determined to be at high risk based on clinical risk factors;^90^ the remaining four studies enrolled unselected populations. Prevalence of GDM ranged from 7.2 to 31.8 percent. Two studies were rated good quality,^104,112^ and five fair quality,^89,90,99,115,122^ due to one or more concerns about patient selection (e.g., using selective populations), reference standard (e.g., no clear description of fasting protocol) and/or flow and timing (e.g., some variation in timing of OGTT).

The studies provided data to pool estimates for test characteristics of FPG at four cutoffs: 79,^90,112,122^ 85,^90,115,122^ 90,^90,115,122^ and 95.5 mg/dL^90,99,115^ (Figure 9 and Table 7). Joint estimates of sensitivity and specificity, respectively, were:

- 79 mg/dL: 96 percent (95% CI, 92 to 98) and 35 percent (95% CI, 30 to 41)
- 85 mg/dL: 88 percent (95% CI, 84 to 91) and 73 percent (95% CI, 46 to 90)
- 90 mg/dL: 81 percent (95% CI, 75 to 85) and 82 percent (95% CI, 61 to 93)
- 95.5 mg/dL: 58 percent (95% CI, 32 to 81) and 98 percent (95% CI, 88 to 100)

Figure 9 Forest Plots of Sensitivity and Specificity of Fasting Plasma Glucose by Carpenter and Coustan Diagnostic Criteria (KQ4)

Abbreviations: CI = confidence interval; CC = Carpenter and Coustan; FN = false negative; FP = false positive; FPG = fasting plasma glucose; KQ = key question; OGCT = oral glucose challenge test; TN = true negative; TP = true positive

Figure 9 depicts a forest plot of studies reporting the sensitivity and specificity of FPG by CC diagnostic criteria. At 76 mg/dL (3 comparisons in 2 studies, 1875 subjects) the sensitivity ranged from 0.73 to 1.00, and specificity ranged from 0.12 to 0.32. At 79 mg/dL (4 comparisons in 3 studies, 22,253 subjects) the sensitivity ranged from 0.92 to 1.00, and specificity ranged from 0.28 to 0.47. At 80 mg/dL (2 studies, 589 subjects) the sensitivity ranged from 0.89 to 0.92, and specificity ranged from 0.51 to 0.94. At 85 mg/dL (4 comparisons in 3 studies, 2233 subjects) the sensitivity ranged from 0.67 to 0.91, and specificity ranged from 0.51 to 0.95. At 86 mg/dL (3 studies, 1109 subjects) the sensitivity ranged from 0.67 to 0.81, and specificity ranged from 0.73 to 0.96. At 90 mg/dL (4 comparisons in 3 studies, 2233 subjects) the sensitivity ranged from 0.67 to 0.85, and specificity ranged from 0.66 to 0.97. At 92 mg/dL (3 studies, 1595 subjects) the sensitivity ranged from 0.26 to 0.76, and specificity ranged from 0.90 to 0.95. At 95.5 mg/dL (4 comparisons in 3 studies, 3527 subjects) the sensitivity ranged from 0.19 to 0.79, and specificity ranged from 0.91 to 1.00.

There was insufficient data to pool at other specific cutoffs. However, results were consistent with the pooled findings. Across cutoffs, sensitivity was below 80% for thresholds 90 mg/dL or higher and above 90% for cutoffs 80 mg/dL or lower and specificity was above 90% for cutoffs above 90 mg/dL and below 35% for cutoffs below 80 mg/dL. At an FPG cutoff of 92 mg/dL (the threshold used in the IADPSG criteria) sensitivity from three studies^99,104,122^ was inconsistent (range 26 to 76%) (Figure 9 and Appendix D Table 3).

##### NDDG Criteria

One good-quality U.S. study (n=123) evaluated FPG screening against NDDG criteria at 24 to 28 weeks’ gestation.^104^ The study included low-risk women 19 to 40 years old with no prior history of GDM; 40 percent were Mexican-American. Prevalence of GDM was 13.0 percent. At a 93 mg/dL cutoff, sensitivity and specificity were 81.3 and 87.9 percent, respectively.

##### IADPSG Criteria

Nine studies diagnosed GDM using IADPSG criteria.^38,92,107,113,119,123,126,131,132^ Sample sizes ranged from 246 to 24,854 (median 3,616; total N=59,278). Mean age was 27.7 years. Two studies were conducted in each of China^131,132^ and India;^92,123^ and one study in each of Brazil,^126^ Iran,^113^ Norway,^107^ Sweden,^119^ and South Africa.^38^ Mean BMI was 24.6 kg/m^2^ in six studies that reported this data.^38,107,113,119,123,126^ Six studies measured FPG at 24 to 28 weeks’ gestation;^38,92,107,119,126,131^ one at 20 to 24 weeks’ gestation;^113^ one at below 20 weeks’ gestation;^123^ and one at median 13.4 weeks’ gestation.^132^ The OGTT was measured at 24 weeks’ gestation or longer, except in one study where the FPG and OGTT were undertaken at 20 to 24 weeks.^113^ Two studies only included low-risk women;^113,119^ none selectively included at-risk women. Prevalence of GDM ranged from 7.0 to 18.3 percent. Three studies were rated good quality,^92,107,132^ and six fair quality,^38,113,119,123,126,131^ due to minor issues in patient selection (e.g., excluding those with self-reported pre-existing diabetes), index test (e.g., pre-specification of cutoffs not reported), reference standard (e.g., no clear description of fasting protocol) and timing (e.g., some variation in timing of the OGTT).

Four studies provided data to pool estimates at the 90 mg/dL cutoff measured at 24 weeks’ gestation or longer (Figure 10).^92,119,126,131^ Joint estimates of sensitivity and specificity were 79 (95% CI, 65 to 89) and 96 percent (95% CI, 95 to 97) (Table 7). The 90 mg/dL cutoff is similar to the level of FPG (92 mg/dL) that is diagnostic using this criteria, based on one abnormal value. All thresholds at or below 80 mg/dL appeared to have sensitivity over 90 percent, to rule-out GDM, whereas the specificity did not reach over 90 percent at cutoffs under 90 mg/dL (Figure 10 and Appendix D Table 3).

Figure 10 Forest Plots of Sensitivity and Specificity of Fasting Plasma Glucose by IADPSG Diagnostic Criteria (KQ4)

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; FPG = fasting plasma glucose; IADPSG = International Association of the Diabetes and Pregnancy Study Groups; KQ = key question; OGCT = oral glucose challenge test; TN = true negative; TP = true positive

Figure 10 depicts a forest plot of studies reporting the sensitivity and specificity of FPG by IADPSG diagnostic criteria. At 76 mg/dL (2 studies, 31377 subjects) the sensitivity ranged from 0.93 to 0.98, and specificity ranged from 0.26 to 0.29. At 77.5 mg/dL (2 studies, 31374 subjects) the sensitivity ranged from 0.91 to 0.96, and specificity ranged from 0.35 to 0.44. At 79 mg/dL (3 studies, 34990 subjects) the sensitivity ranged from 0.88 to 0.96 and specificity ranged from 0.46 to 0.57. At 81 mg/dL (2 studies, 25443 subjects) the sensitivity ranged from 0.88 to 0.98, and specificity ranged from 0.46 to 0.80. At 83 mg/dL (2 studies, 28470 subjects) the sensitivity ranged from 0.79 to 0.95, and specificity was 0.67 in both studies. At 85 mg/dL (3 studies, 36300 subjects) the sensitivity ranged from 0.74 to 0.92, and specificity ranged from 0.76 to 0.82. At 86.5 mg/dL (2 studies, 28470 subjects) the sensitivity ranged from 0.69 to 0.91, and specificity ranged from 0.84 to 0.85. At 90 mg/dL (4 studies, 39916 subjects) the sensitivity ranged from 0.60 to 0.89, and specificity ranged from 0.95 to 0.98.

Two studies provided data for test characteristics of FPG measured before 24 weeks at 79^113,132^ and 85 mg/dL^123,132^ cutoffs (Figure 11). Studies reporting on the 79 mg/dL cut-off used different timing for the OGTT (Appendix D Table 3). Findings from two studies of early screening with a FPG of 85 mg/dL versus the OGTT at 24 to 28 weeks were inconsistent.

Figure 11 Forest Plots of Sensitivity and Specificity of Early Fasting Plasma Glucose by IADPSG Diagnostic Criteria (KQ4)

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; FPG = fasting plasma glucose; IADPSG = International Association of the Diabetes and Pregnancy Study Groups; KQ = key question; OGCT = oral glucose challenge test; TN = true negative; TP = true positive

Figure 11 depicts a forest plot of studies reporting the sensitivity and specificity of early FPG against IADPSG diagnostic criteria applied later in pregnancy. At 79.5 mg/dL (2 studies, 17542 subjects) the sensitivity ranged from 0.77 to 0.78, and specificity ranged from 0.38 to 0.76. At 85 mg/dL (2 studies, 17432 subjects) the sensitivity ranged from 0.55 to 0.94, and the specificity ranged from 0.55 to 0.68.

##### Sacks Criteria

One good-quality U.S. study (n=4,507) evaluated FPG screening versus a diagnosis of GDM using Sacks criteria.^118^ Median age was 28.3 years and 69.3 percent were Latina. One-third had a family history of DM. Women were screened early in pregnancy (mean 10.7 weeks’ gestation). Prevalence of GDM was 6.7 percent.

The study provided data for FPG at six cutoffs: 70, 75, 80, 85, 90, and 95 mg/dL.^118^ Sensitivity and specificity ranged from 34.0 (95 mg/dL cutoff) to 100 percent (70 mg/dL cutoff) and 2.0 (70 mg/dL cutoff) to 92.0 percent (95 mg/dL cutoff) (Appendix D Table 3).

##### HAPO 2.0 Criteria

One fair-quality study (n=3,616) conducted among low-risk women in Sweden, screened with FPG at 24 to 28 weeks and confirmed a diagnosis of GDM using modified HAPO 2.0 criteria (no 1-hour glucose value).^119^ Mean age was 27.9 years and BMI was 23.8 kg/m^2^; 89 percent were of Nordic origin. Prevalence of GDM was 7.2 percent.

The study provided data for FPG at five cutoffs: 79, 83, 86.5, 90, and 94 mg/dL^119^ (Appendix D Table 3) Sensitivity and specificity ranged from 89.0 (94 mg/dL cutoff) to 96.0 percent (79 mg/dL and 83 mg/dL cutoffs) and 54.0 (79 mg/dL cutoff) to 98.0 percent (94 mg/dL cutoff), respectively. The optimal cutoff was 90 mg/dL, where sensitivity and specificity were 91.0 and 92.0 percent.

#### Hemoglobin A1c

Eighteen studies evaluated screening with HbA1c.^91,94,96,97,102,103,105,109,113,114,116,117,121,124,125,127,128,130^ Sample sizes ranged from 42 to 1,989 (median 453; total N=10,488). Mean age was 29.1 years (range 26.1 to 32.7) and mean BMI was 24.2 kg/m^2^ (ranged 22.4 to 25.7 kg/m^2^). Three studies were conducted in India;^96,116,125^ two studies were from each of China,^102,130^ Turkey,^121^ Iran,^113,117^ and Australasia;^103,105^ and single studies were conducted in Brazil,^97^ Norway,^109^ Spain,^94^ Romania,^128^ Singapore,^114^ Thailand,^124^ and the United Arab Emirates.^91^

Five studies evaluated HbA1c screening against CC criteria with both tests done at or after 24 weeks’ gestation.^91,97,102,116,128^ Four studies used a 3-hour 100g OGTT and one study^116^ used a 2-hour 75g OGTT. Three studies only enrolled women with a positive OGCT,^91,102^ or clinical risk factors.^91,128^ Prevalence of GDM ranged from 7.1 to 29 percent. One study was rated good quality,^116^ and four were rated fair quality. Frequent methodological limitations included poor reporting of fasting protocols and pre-specification of index test thresholds.^91,97,102,128^

Three studies evaluated screening with HbA1c versus NDDG criteria.^94,124,127^ Two small studies (N=156) measured HbA1c at or after 24 weeks’ gestation,^124,127^ and another (n=1,158)^94^ measured HbA1c in the first trimester. One study only enrolled women with abnormal OGCT results.^124^ GDM prevalence ranged from 13 to 33 percent. One study was rated good quality,^94^ and two were fair quality,^124,127^ due to no pre-specification of the index test threshold, and (in one^127^) not reporting patient recruitment methods.

For HbA1c screening against IADPSG criteria, four studies performed screening at 24 to 28 weeks’ gestation,^105,116,121,125^ three performed screening prior to 20 weeks’ gestation (with diagnosis of GDM at 24 to 28 weeks),^113,114,130^ and four screened at broad time points or throughout pregnancy.^96,103,109,117^ All studies enrolled unselected populations. Prevalence ranged from 7.2 to 29 percent (mean 14.8%). One study was rated good quality^116^ and ten were rated fair quality,^105,121,125^ due to one or more concerns related to poor reporting on patient selection, selection of the cutoffs, and fasting protocols.

Against each criteria and for each time point, one or two studies contributed data for most thresholds (Appendix D Tables 4 to 6). Three studies contributed data for screening at the 5.2 and 5.7 percent HbA1c thresholds versus IADPSG at 24 to 28 weeks (Figures 12 and 13). Findings at the 5.2 percent cutoff were inconsistent; at the 5.7 percent cutoff the median specificity was 91 percent; and at cutoffs currently used for diagnosis (6.0 and 6.1 percent HbA1c) specificity was over 97 percent. Overall, the evidence does not suggest that there is a threshold for which sensitivity and specificity would both be high enough to replace the OGCT as a screening test. Sensitivity was above 90 percent for the 4.5 and 5.0 percent cutoffs against CC and NDDG criteria, and for the 4.6 and 4.7 percent cutoffs against IADPSG when screening was within the second trimester (e.g., more than 18 weeks’ gestation), suggesting a potential role as a rule-out threshold to determine who might be able to avoid an OGCT (Appendix D Tables 4 and 6). A good-quality study (n=1,158) of early screening with HbA1c versus NDDG criteria suggested that the rule-out cutoffs may also apply (i.e., sensitivity was over 95% at 4.5 to 4.8% HbA1c) (Appendix D Table 5).

Figure 12 Forest Plot of Sensitivity and Specificity: HbA1c vs. IADPSG 2010 at 24 to 28 Weeks’ Gestation, Lower Thresholds (KQ4)

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; IADPSG = International Association of the Diabetes and Pregnancy Study Groups; KQ = key question; OGCT = oral glucose challenge test; TN = true negative; TP = true positive

Figure 12 depicts a forest plot of studies reporting the sensitivity and specificity of HbA1c by IADPSG diagnostic criteria at lower thresholds (4.6% to 5.4%). At 4.6% (2 studies, 819 subjects) the sensitivity was 0.96 for both studies, and specificity ranged from 0.04 to 0.23. At 4.7% (1 study, 480 subjects) the sensitivity was 0.96, and specificity was 0.10. At 4.8% (1 study, 480 subjects) the sensitivity was 0.82, and specificity was 0.18. At 4.9% (1 study, 480 subjects) the sensitivity was 0.74, and specificity was 0.31. At 5.0% (1 study, 480 subjects) the sensitivity was 0.70, and specificity was 0.52. At 5.1% (1 study, 480 subjects) the sensitivity was 0.61, and specificity was 0.68. At 5.2% (3 studies, 1426 subjects) the sensitivity ranged from 0.54 to 0.83, and specificity ranged from 0.41 to 0.80. At 5.3% (2 studies, 980 subjects) the sensitivity ranged from 0.35 to 0.96, and specificity ranged from 0.51 to 0.88. At 5.4% (1 study, 480 subjects) the sensitivity was 0.26, and specificity was 0.96.

Figure 13 Forest Plots of Sensitivity and Specificity: HbA1c vs. IADPSG 2010 at 24 to 28 Weeks’ Gestation, Higher Thresholds (KQ4)

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; HbA1c = hemoglobin A1c; IADPSG = International Association of the Diabetes and Pregnancy Study Groups; KQ = key question; TN = true negative; TP = true positive

Figure 13 depicts a forest plot of studies reporting the sensitivity and specificity of HbA1c by IADPSG diagnostic criteria at higher thresholds (5.5% to 6.1%). At 5.5% (1 study, 480 subjects) the sensitivity was 0.23, and specificity was 0.98. At 5.6% (1 study, 480 subjects) the sensitivity was 0.12, and specificity was 0.99. At 5.7% (3 studies, 1319 subjects) the sensitivity ranged from 0.11 to 0.73, and specificity ranged from 0.76 to 1.00. At 5.8% (1 study, 480 subjects) the sensitivity was 0.09, and specificity was 1.00. At 5.9% (1 study, 480 subjects) the sensitivity was 0.05, and specificity was 1.00. At 6.0% (2 studies, 1087 subjects) the sensitivity ranged from 0.04 to 0.12, and specificity ranged from 0.97 to 1.00. At 6.1% (2 studies, 980 subjects) the sensitivity ranged from 0.02 to 0.47, and specificity ranged from 0.95 to 1.00.

#### Risk Factor-Based Screening

##### Carpenter and Coustan Criteria

One fair-quality study (n=341)^93^ from the prior review validated a risk-based tool developed in Brazil against CC criteria (source unavailable) (Appendix B Tables 7, 10 and 11). The screening test was positive with a FPG of 90 mg/dL or greater (assessed before 20 weeks’ or during the OGTT at 24 to 28 weeks’ gestation [mean timing not reported]) and/or one or more of several risk factors (Table 8). Women with previous GDM were excluded. Fifty-four percent of women screened positive. Sensitivity was 84.6 percent and specificity was 47.3 percent. GDM prevalence was 3.8 percent.

Table 8 Evidence on Accuracy of Risk-Factor Screening for GDM (KQ4)

Diagnostic Criteria | Author, Year; Country | Risk-Factor Based Index Test | Timing of Index & Timing of OGTT (Weeks’ Gestation) | Number Analyzed | Prevalence (%) | Sensitivity (%) | Specificity (%) | Accuracy (%)
CC | Ayach, 2006^93^; Brazil | FPG ≥ 90 mg/dL and/or ≥ 1 risk factor (age ≥ 30 years, pre-gestational BMI ≥ 27 kg/m^2^, previous gestational diabetes, family history of DM, macrosomia, fetal death with no apparent cause, recurrent miscarriages and malformation); Validating: Rudge & De Luca (1981-1994) | Risk factors and/or FPG: <20 or 24-28; OGTT: 24-28 | 341 | 3.8 | 84.6 | 47.3 | 48.7
NDDG 1979 | Naylor, 1997^36^; Canada | OGCT + clinical risk factors: age (≤30: 0 points, 31-34: 1 point, ≥35: 2 points), BMI (≤ 22: 0 points, 22.1−25.0: 2 points, ≥ 25.1: 3 points), race (white: 0 points, Black: 0 points, Asian: 5 points, Other: 2 points) +; OGCT (≥128, 130, or 140 mg/dL by clinical risk score); Scores 0 and 1 are not screened with OGCT.; [underlined: Strategy A] used a risk score of 2-3 and a 50g OGCT cutoff of ≥140 mg/dl or a score above 3 and a 50g OGCT cutoff at ≥128 mg/dl to predict GDM; [underlined: Strategy B] used the same 50g OGCT threshold for a risk score of 2-3 but for those with a score above 3 the 50g OGCT cutoff was ≥130 mg/dl.; Validating: model developed within the study | OGCT + risk factors: 25-27; OGTT: 27-29 | 1571 | 4.4 | Strategy A: 82.6; Strategy B: 81.2 | Strategy A: 80.3; Strategy B: 80.9 | Strategy A: 84.0; Strategy B: 84.9
IADPSG | Gobl, 2012^101^; Austria | Risk model (0.2 cut-off with FPG <5.1 mmol/L), incorporating: history of GDM, glycosuria, age, relative with type 2 DM, preconception dyslipidemia, ethnicity, FPG; Validating: development cohort model within study | Risk factors: 1^st^ visit; OGTT: ≥ 24 (indicates allows for Dx <24 wGA but #s NR) | 258 | 22.9 (29/59 by FPG; 30/59 by FPG <5.1 and risk model at 0.2 cut-off) | 98.3 | 16.6 | 35.3

Abbreviations: CC = Carpenter Coustan; CDA = Canadian Diabetes Association; DM = diabetes mellitus; FPG = fasting plasma glucose; GDM = gestational diabetes; IADPSG = International Association of Diabetes and Pregnancy Study Groups; NA = not applicable; NR = not reported; NDDG = National Diabetes Data Group; OAV = one abnormal value; OGTT = oral glucose tolerance test

##### NDDG Criteria

One good-quality study from Canada,^36,120^ evaluated risk-based screening in a large cohort study with confirmation of GDM with NDDG criteria.^36^ Scores for age, BMI, and race/ethnicity were combined with OGCT thresholds that varied by risk score and two slightly different models were developed (Table 8). Women with scores from risk factor assessment of 0 or 1 (out of maximum 10) were not screened with the OGCT. Performance of the risk scoring strategies was evaluated using an internal validation cohort (n=1,571) that was not used to develop the risk score. In the validation cohort, the index and diagnostic tests were performed at 25 to 27 and 27 to 29 weeks’ gestation, respectively, and GDM prevalence was 4.4 percent. For the two different strategies, sensitivities were 82.6 and 81.2 percent, and specificities were 80.3 and 80.9 percent. Both risk models performed with greater accuracy than the 50g OGCT on its own in this study; using the risk-based scoring allowed for 34.6 percent of women to avoid the OGCT.

##### IADPSG Criteria

A fair-quality study in Austria (n=258) validated a two-step screening algorithm against IADPSG criteria at 24 weeks’ gestation or later for diagnosis.^101^ The risk model was developed for use in women not meeting IADPSG criteria based on FPG of 5.1 mmol/L (92 mg/dL); scoring combined FPG under 5.1 mmol/L with several risk factors (history of GDM, glycosuria, age, relative with T2DM, preconception dyslipidemia, ethnicity) and a score of 0.2 was used as the cutoff (Table 8). GDM prevalence was 23 percent. Sensitivity and specificity were 98.3 and 16.6 percent.

## Key Question 5 What Is the Association Between Diagnosis of GDM and Outcomes in Women Meeting More Inclusive But Not Less Inclusive Diagnostic Criteria for GDM?

### Summary

- Women with untreated GDM using more inclusive criteria are probably at increased risk for preeclampsia (11 studies), hypertensive disorders in pregnancy (9 studies), total cesarean deliveries (20 studies), and preterm deliveries (17 studies) versus women with NGT. Findings for primary (first) cesarean delivery, induction of labor, maternal birth trauma, and excessive weight gain were generally inconsistent and imprecise.
- There were robust associations between a diagnosis of GDM using more inclusive criteria (including IADPSG) and increased risks of macrosomia (22 studies), LGA (21 studies), neonatal hypoglycemia (13 studies) and hyperbilirubinemia (10 studies); associations persisted after adjustment for confounding.
- Estimates for the associations between a diagnosis of GDM using more inclusive criteria and risk of perinatal mortality, birth injury, and shoulder dystocia were generally imprecise or not statistically significant after controlling for confounders.
- There was no association between more inclusive GDM criteria versus NGT for risk for NICU admissions (11 studies), including analyses that adjustment for potential confounding.
- Estimates for the associations between a diagnosis of GDM using more inclusive criteria and risk of respiratory distress syndrome and low APGAR scores at 1 or 5 minutes were imprecise and inconsistent.
- For long-term outcomes, GDM using one abnormal value (OAV) on CC criteria may not be associated with childhood (5 to 13 years) obesity versus NGT, but OAV on NDDG may be associated with increased risk of maternal impaired glucose tolerance at 3 months’ postpartum. Findings for maternal development of T2DM and metabolic syndrome were from single studies and imprecise.

### Evidence

The prior review^2^ included 38 observational studies found associations with increased risk for women with various criteria of GDM or dysglycemia (e.g., OGCT positive but no GDM) versus normal glucose tolerance (NGT) of caesarean deliveries, shoulder dystocia, macrosomia (except for IADPSG criteria), and LGA. Higher levels of glycemia did not consistently demonstrate greater risk for these outcomes.

Twenty-five studies^9,153,169–191^ from the prior report were excluded because they did not compare diagnostic criteria of interest. This review includes 31 cohort studies^192–222^ (with one associated publication^223^) comparing outcomes (often retrospectively) between women with NGT and those meeting more inclusive GDM criteria than routinely used in the United States (Appendix B Table 12). Thirteen studies were carried forward from the prior report.^194–197,202,205,208–210,215–217,219^

#### Study Characteristics

Sample sizes ranged from 131 to 22,804 (median 1,927; total N=105,492), mean age from 22.7 to 34.7 years (median 31.1 and 30.1 years in GDM and NGT groups, respectively), and mean BMI from 21.1 to 35.6 kg/m^−2^ (median 23.7) in the GDM groups and from 20.5 to 32.7 kg/m^−2^ (median 23.7) in the NGT groups. Seven studies were conducted in the United States (one also including Canadian participants in HAPO cohort);^194,198,200,202,208,216,221^ two in Canada;^215,217^ one in Mexico,^212^ seven in Europe,^193,196,197,207,209,210,219^ ninet in Asia,^201,203,205,206,211,214,218,220,222^ and four in the Middle East.^192,195,204,213^ Of eight studies reporting on family history of T2DM,^197,201,203,211,212,215,219,221^ the proportion in women with GDM ranged from 9.6 to 59 percent and in NGT women was 5.8 to 44.3 percent. Few studies reported on previous GDM, and only one study excluded women with previous GDM.^208^ Except for eight studies,^193,196,209,213,215–217,222^ all limited inclusion to women with singleton pregnancies. Of the five U.S. studies reporting race, four^200,202,208,221^ had diverse study populations (50% or fewer white women) and one had 71 percent white women.^198^ When reported, the large majority of women in the studies from Europe^193,197,219^ and Canada^215^ were white.

Eleven studies were prospective^194,199,203,205,206,208,209,215,217,219,221^ and 20 were retrospective cohort studies. Four main GDM exposure (but untreated) groups were compared with an NGT group: women meeting OAV on NDDG criteria but not NDDG GDM (6 studies),^194,195,205,215,217,220^ OAV on CC criteria but not CC GDM (14 studies),^192,196,197,199,201,202,204,208,209,213,214,216,219,220^ IADPSG but not CC criteria (11 studies),^193,198,200,203,206,207,210–212,218,221^ and IADPSG but not NDDG criteria (1 study).^222^ One study reported on outcomes for women meeting both OAV on NDDG (but not NDDG GDM) and OAV on CC (but not CC GDM) criteria.^220^ Within these broad categories, some deviations to the recommended screening or diagnostic tests (e.g., one- versus two-step CC, two-step IADPSG) were noted; in addition, the NGT groups sometimes included those only positive or negative on the OGCT. These variations were considered in analyzing the results. In seven of the eleven studies of IADSPG criteria, the criteria were applied to an OGTT within a two-step approach and in four of these seven a 100 g 3-hour OGTT was used.^193,198,200,210^ Timing of screening was 24-28 weeks in most studies.

The definitions of outcomes varied or were often not reported, with the most uncertainty for neonatal hypoglycemia. None of the studies reporting on hypertension indicated (or standardized) the timing of the outcome measurement.

Twenty-six studies were rated fair quality and five good quality (Appendix B Table 13).^208,216,217,219,221^ In fair-quality studies, blinding of patients and providers to glycemic status or for outcome assessment did not occur; risk for selection bias was also common.

#### Pregnancy Outcomes

Women with GDM meeting more inclusive criteria had between a 15 and 100 percent increased risk of hypertensive disorders in pregnancy versus women with NGT (9 studies, N=27,852; absolute effects showing between 1 to 5% more cases) (Table 9 and Figure 14).^197,198,200,204,207,208,212,219,220^ These findings may relate to an increased risk of preeclampsia (11 studies, N=32,879; 60 to 93% relative increase with 1.5 to 3.3% more cases) (Figure 15)^193,195,201,203,205,206,210,212,217,218,221^ rather than gestational hypertension; the associations between GDM diagnosis meeting more inclusive criteria versus NGT and risk of hypertension from five studies on hypertension were inconsistent and imprecise (Appendix C Figure 12).^193,201,210,212,222^ Findings were similar, but somewhat less precise, after adjustment for numerous variables, including family history of hypertension, gestational age at the OGTT, and maternal urinary tract infection (Appendix D Table 7).

Table 9 Evidence From Observational Studies on the Association Between a Diagnosis of GDM and Pregnancy Outcomes in Women Meeting More But Not Less Inclusive Diagnostic Criteria (KQ5)

Outcome | Comparison | Number of Studies | Inclusive GDM Group (events/N) | NGT Group (events/N) | Relative Risk [95% CI]; I^2^ | Absolute Risk Difference of Significant Findings [95% CI]
Preeclampsia | OAV (CC) vs NGT | 1^201^ | 18/395 | 20/790 | 1.80 [0.96 to 3.36]; NA | NA
Preeclampsia | OAV (NDDG) vs NGT | 3^195,205,217^ | 8/264 | 46/2335; (Data and numbers per group were not provided by one study (n=3,637)^217^ | OR 1.65 [1.09 to 2.50]; 0%; (RR 1.62 [1.09 to 2.41]) | 0.015 [0.002 to 0.039]
Preeclampsia | IADPSG (excluding CC) vs NGT | 7^193,203,206,210,212,218,221^ | 185/1961 | 829/22198 | 1.93 [1.34 to 2.77]; 69% | 0.0328 [−0.0044 to 0.0700]
Gestational hypertension | OAV (CC) vs NGT | 1^201^ | 13/395 | 32/790 | 0.88 [0.47 to 1.62]; NA | NA
Gestational hypertension | IADPSG (excluding CC) vs NGT | 3^193,210,212^ | 21/554 | 304/8442 | 1.01 [0.45 to 2.24]; 61% | NA
Gestational hypertension | IADPSG (excluding NDDG) vs NGT | 1^222^ | 52/1175 | 749/21629 | 1.28 [0.97 to 1.68]; NA | NA
Hypertensive disorders of pregnancy | OAV (CC) vs NGT | 5^197,204,208,219,220^ | 95/904 | 391/9458 | 2.09 [1.53 to 2.86]; 40% | 0.050 [0.030 to 0.070]
Hypertensive disorders of pregnancy | OAV (NDDG) vs NGT | 1^220^ | 17/225 | 210/6992 | 2.52 [1.56 to 4.05]; NA | 0.046 [0.019 to 0.080]
Hypertensive disorders of pregnancy | IADPSG (excluding CC) vs NGT | 4^198,200,207,212^ | 101/1133 | 1200/16357 | 1.15 [0.93 to 1.41]; 0% | NA
Total cesarean deliveries | OAV (CC) vs NGT | 10^192,196,197,201,209,213,214,216,219,220^ | 525/1312 | 5308/17343 | 1.29 [1.13 to 1.47]; 52% | 0.078 [0.034 to 0.123]
Total cesarean deliveries | OAV (NDDG) vs NGT | 4^195,205,217,220^ | 217/489 | 3399/9327; (Data and numbers per group were not provided by one study (n=3,637)^217^ | OR 1.48 [1.27 to 1.72]; 0%; (RR 1.28 [1.17 to 1.39) | 0.092 [0.056 to 0.129]
Total cesarean deliveries | IADPSG (excluding CC) vs NGT | 6^193,207,210–212,218^ | 532/1153 | 7004/19084 | 1.20 [1.05 to 1.38]; 77% | 0.0695 [0.0131 to 0.1258]
Total cesarean deliveries | IADPSG (excluding NDDG) vs NGT | 1^222^ | 732/1175 | 10689/21629 | 1.26 [1.20 to 1.32]; NA | 0.129 [0.100 to 0.157]
Primary cesarean deliveries | OAV (CC) vs NGT | 1^204^ | 30/80 | 218/880 | 1.51 [1.12, 2.05]; NA | 0.127 [0.017 to 0.237]
Primary cesarean deliveries | IADPSG (excluding CC) vs NGT | 5^198,200,203,206,221^ | 433/1707 | 4591/21687 | 1.10 [0.91, 1.34]; 77% | NA
Primary cesarean deliveries | IADPSG (excluding CC) vs NGT (adjusted) | 4^198,203,206,221^ | 1426 | 13916 | aOR 0.94 [0.69 to 1.28]; 73% | NA
Induction of Labor | OAV (CC) vs NGT | 1^192^ | 0/32 | 1/277 | 2.81 [0.12 to 67.54]; NA | NA
Induction of Labor | IADPSG (excluding CC) vs NGT | 3^203,206,207^ | 93/906 | 648/6809 | 1.13 [0.93 to 1.39]; 0% | NA
Preterm delivery | OAV (CC) vs NGT | 6^201,204,213,214,219,220^ | 97/1023 | 760/10888 | 1.42 [1.14 to 1.77]; 0% | 0.018 [−0.032 to 0.068]
Preterm delivery | OAV (NDDG) vs NGT | 3^195,205,220^ | 32/489 | 534/9327 | 1.37 [0.97 to 1.94]; 0% | 0.012 [−0.0043 to 0.029]
Preterm delivery | IADPSG (excluding CC) vs NGT | 9^193,198,203,206,207,211,212,218,221^ | 220/2617 | 3322/31764 | 1.19 [0.97 to 1.46]; 45% | 0.0076 [−0.0084 to 0.0236]
Preterm delivery | IADPSG (excluding CC) vs NGT (adjusted) | 5^198,203,206,211,221^ | 1628 | 16474 | aOR 1.43 [1.16 to 1.75]; 0% | NA
Maternal birth trauma | OAV (CC) vs NGT | 1^220^ | 289 | 5971 | aOR 1.01 [0.49 to 2.08]; NA | NA
Maternal birth trauma | OAV (NDDG) vs NGT | 1^220^ | 225 | 5971 | aOR 1.61 [0.80 to 3.24]; NA | NA
Maternal birth trauma | IADPSG (excluding CC) vs NGT | 4^198,200,203,211^ | 27/900 | 522/17885 | 1.19 [0.81 to 1.76]; 0% | NA
Excessive gestational weight gain | IADPSG (excluding CC) vs NGT | 1^198^ | 63/181 | 1748/5485 | 1.09 [0.89 to 1.34]; NA | NA

Abbreviations: aOR = adjusted odds ratio; CC = Carpenter Coustan; IADPSG = International Association of Diabetes and Pregnancy Study Groups; NA = not applicable; NGT = normal glucose tolerance; NDDG = National Diabetes Data Group; OAV = one abnormal value; OGCT = oral glucose challenge test

Figure 14 Forest Plots for Associations Between Inclusive GDM Criteria and Hypertensive Disorders in Pregnancy (KQ5)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes in Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance

Figure 14 depicts the results of a forest plot for observational studies on the association between more but not less inclusive criteria for GDM and hypertensive disorders of pregnancy. One abnormal value (OAV) on CC versus NGT meta-analysis (5 studies, 10362 subjects) showed an estimated association with increased risk of 2.09 with a 95% CI of 1.53 to 2.86; I2=40%. The OAV on NDDG versus NGT study (7217 subjects) showed an estimated association with increased risk of 2.52 with a 95% CI of 1.56 to 4.05; I2=NA. The IADPSG excluding CC vs NGT meta-analysis (4 studies, 17490 subjects) showed an estimated association with increased risk of 1.15 with a 95% CI of 0.93 to 1.41; I2=0.

Figure 15 Forest Plots for Associations Between Inclusive GDM Criteria and Preeclampsia (KQ5)^*^ * OAV on NDDG was analyzed using inverse variance method because Sermer 1995 (n=3,637) only provided and odds ratio and 95% CI but not events rates or sample sizes per group; these are crude analyses.

Abbreviations: Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes in Pregnancy Study Groups; IV = inverse variance; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value

Figure 15 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and preeclampsia. One abnormal value (OAV) on CC versus NGT study (1185 subjects) showed an estimated association with increased risk of 1.80 with a 95% CI of 0.96 to 3.36; I2=NA. The OAV on NDDG versus NGT meta-analysis (3 studies, 6236 subjects) showed an estimated association with increased odds of 1.65 with a 95% CI of 1.09 to 2.50; I2=0%. The IADPSG excluding CC versus NGT meta-analysis (7 studies, 24159 subjects) showed an estimated association with increased risk of 1.93 with a 95% CI of 1.34 to 2.77; I2=69%.

Results consistently found diagnosis of GDM using more inclusive criteria associated with 20 to 30 percent increased risk for total cesarean deliveries (20 studies, N=64,520)^192,193,195–197,201,205,209–214,216–220^ (Figure 16). The absolute difference was 7 to 13 percent more cesarean deliveries. However this may overestimate the effects in the United States as four studies^201,212,218,220^ from non-VHDI countries reported high event rates in the NGT group (32 to 74%). GDM using more inclusive criteria was associated with an approximate 40 percent higher risk (1 to 2% higher in absolute terms) for preterm deliveries versus NGT (17 studies, N=49,116) (Figures 17 and 18);^193,195,198,201,203–207,211–214,218–221^ there was consistency across diagnostic criteria and in adjusted analyses (Appendix D Table 7). Findings for primary cesarean deliveries (6 studies, N=24,354),^198,200,203,204,206,221^ induction of labor (4 studies, N=8,024),^192,203,206,207^ and maternal birth trauma (5 studies, N=25,270)^198,200,203,211,220^ were limited by inconsistency and/or imprecision but suggested no associations between GDM diagnosis using more inclusive criteria and increased risk (Table 9 and Appendix C Figures 13 to 15).

Figure 16 Forest Plots for Associations Between Inclusive GDM Criteria and Total Cesarean Deliveries (KQ5)^*^ * OAV on NDDG was analyzed using inverse variance method because Sermer 1995 (n=3,637) only provided and odds ratio and 95% CI but not events rates or sample sizes per group; these are crude analyses.

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes in Pregnancy Study Groups; IV = inverse variance; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value

Figure 16 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and total cesarean deliveries. One abnormal value (OAV) on CC versus NGT meta-analysis (10 studies, 18655 subjects) showed an estimated association with increased risk of 1.29 with a 95% CI of 1.13 to 1.47; I2=52%. The OAV on NDDG versus NGT meta-analysis (4 studies, 13452 subjects) showed an estimated association with increased odds of 1.48 with a 95% CI of 1.27 to 1.72; I2=0%. The IADPSG excluding CC versus NGT meta-analysis (6 studies, 20237 subjects) showed an estimated association with increased risk of 1.20 with a 95% CI of 1.05 to 1.38; I2=77%. The OAV on NDDG versus NGT meta-analysis (4 studies, 13452 subjects) showed an estimated association with increased odds of 1.48 with a 95% CI of 1.27 to 1.72; I2=0%. The IADPSG excluding NDDG versus NGT study (22804 subjects) showed an estimated association with increased risk of 1.26 with a 95% CI of 1.20 to 1.32; I2=NA.

Figure 17 Forest Plots for Crude Associations Between Inclusive GDM Criteria and Preterm Deliveries (KQ5)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes in Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value

Figure 17 depicts the results of a forest plot comparing observational studies on the crude association between more but not less inclusive criteria for GDM and preterm deliveries. One abnormal value (OAV) on CC versus NGT meta-analysis (6 studies, 11911 subjects) showed an estimated association with increased risk of 1.42 with a 95% CI of 1.14 to 1.77; I2=0%. The OAV on NDDG versus NGT meta-analysis (3 studies, 9816 subjects) showed an estimated association with increased risk of 1.37 with a 95% CI of 0.97 to 1.94; I2=0%. The IADPSG excluding CC versus NGT meta-analysis (9 studies, 34381 subjects) showed an estimated association with increased risk of 1.19 with a 95% CI of 0.97 to 1.46; I2=45%.

Figure 18 Forest Plots for Adjusted Associations Between Inclusive GDM Criteria and Preterm Deliveries (KQ5)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes in Pregnancy Study Groups; IV = inverse variance; KQ = key question; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value; SE = standard error

Figure 18 depicts the results of a forest plot comparing observational studies on the adjusted association between more but not less inclusive criteria for GDM and preterm deliveries. One abnormal value (OAV) on CC versus NGT study (6260 subjects) showed an estimated association with increased odds of 1.53 with a 95% CI of 1.03 to 2.27; I2=NA. The OAV on NDDG versus NGT study (6196 subjects) showed an estimated association with increased odds of 1.37 with a 95% CI of 0.86 to 2.18; I2=NA. The IADPSG excluding CC versus NGT meta-analysis (5 studies, 18102 subjects) showed an estimated association with increased odds of 1.43 with a 95% CI of 1.16 to 1.75; I2=0%.

#### Fetal/Neonatal Outcomes

There were robust associations between more inclusive GDM criteria versus NGT and increased risk of macrosomia (22 studies, N=89,661; about 50-100% increased risk and absolute effects ranging from 2.6 to 8.1% more cases)^192–198,200–202,204,206,209–213,217–220,222^ (Figure 19) and LGA (21 studies, N=52,649; 60-70% increase with 4.7 to 6.0% more cases)^192–196,198,200,201,203–212,216,219,221^ in crude (Figure 20) and adjusted analyses (Appendix D Table 8); unlike the prior report, this finding was consistent with studies that used the most inclusive GDM criteria (IADPSG) likely due to the availability of more studies. More inclusive GDM criteria were also associated with increased risk of neonatal hypoglycemia (13 studies, N=45,369)^192,195–197,201,203–206,216,219,221,222^ (Figure 21) and hyperbilirubinemia (10 studies, N=26,973)^195,196,201,203,204,206,211,217,219,221^ (Appendix C Figure 16), though the latter had some variability in the degree of increased risk.

Figure 19 Forest Plots for Associations Between Inclusive GDM Criteria and Macrosomia (KQ5)^*^ * OAV on NDDG was analyzed using inverse variance method because Sermer 1995 (n=3,637) only provided and odds ratio and 95% CI but not events rates or sample sizes per group; these are crude analyses.

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes in Pregnancy Study Groups; IV = inverse variance; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value; SE = standard error

Figure 19 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and macrosomia. One abnormal value (OAV) on CC versus NGT meta-analysis (10 studies, 28086 subjects) showed an estimated association with increased risk of 1.47 with a 95% CI of 1.16 to 1.87; I2=18%. The OAV on NDDG versus NGT meta-analysis (4 studies, 13414 subjects) showed an estimated association with increased odds of 1.85 with a 95% CI of 1.44 to 2.38; I2=0%. The IADPSG excluding CC versus NGT meta-analysis (8 studies, 32716 subjects) showed an estimated increased risk of 1.70 with a 95% CI of 1.35 to 2.14; I2=37%. The IADPSG excluding NDDG versus NGT study (22437 subjects) showed an estimated association with increased risk of 2.20 with a 95% CI of 1.90 to 2.55; I2=NA.

Figure 20 Forest Plots for Associations Between Inclusive GDM Criteria and Large for Gestational Age (KQ5)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes in Pregnancy Study Groups; IV = inverse variance; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value

Figure 20 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and large for gestational age. One abnormal value (OAV) on CC versus NGT meta-analysis (8 studies, 10637 subjects) showed an estimated association with increased risk of 1.64 with a 95% CI of 1.25 to 2.15; I2=49%. The OAV on NDDG versus NGT meta-analysis (3 studies, 3259 subjects) showed an estimated association with increased risk of 1.68 with a 95% CI of 1.28 to 2.21; I2=0%. The IADPSG excluding CC versus NGT meta-analysis (10 studies, 38838 subjects) showed an estimated association with increased risk of 1.69 with a 95% CI of 1.42 to 2.01; I2=65%.

Figure 21 Forest Plots for Associations Between Inclusive GDM Criteria and Neonatal Hypoglycemia (KQ5)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes in Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value

Figure 21 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and neonatal hypoglycemia. One abnormal value (OAV) on CC versus NGT meta-analysis (7 studies, 9578 subjects) showed an estimated association with increased risk of 1.61 with a 95% CI of 1.20 to 2.15; I2=0%. The OAV on NDDG versus NGT meta-analysis (2 studies, 2599 subjects) showed an estimated association with increased risk of 6.64 with a 95% CI of 2.52 to 17.49; I2=0%. The IADPSG excluding CC versus NGT meta-analysis (3 studies, 10388 subjects) showed an estimated association with increased risk of 2.51 with a 95% CI of 1.72 to 3.68; I2=0%. The IADPSG excluding NDDG versus NGT study (22804 subjects) showed an estimated association with increased risk of 2.17 with a 95% CI of 1.50 to 3.16; I2=NA.

More inclusive GDM criteria were not associated with increased risk of mortality versus NGT (8 studies, N=42,303; 161 events),^196,200,201,203–205,219,222^ although findings had some imprecision (Appendix C Figure 17). One good-quality study (n=3,637)^217^ found no association between having OAV on NDDG criteria versus NGT and risk of birth injury (Table 10). Findings across criteria did not show an association versus NGT for increased risk of shoulder dystocia (10 studies, N=32,969),^192,193,198,200,201,204,208,211,219,220^ though there was some inconsistency (Table 10 and Appendix C Figure 18). There was no association between more inclusive GDM criteria versus NGT for risk for NICU admissions (11 studies, N=39,452)^193,200,201,203,204,206,211,213,219–221^, including analyses that adjustment for potential confounding (Table 10 and Appendix C Figure 19).

Table 10 Evidence From Observational Studies on the Association Between a Diagnosis of GDM and Fetal/Neonatal Outcomes in Women Meeting More But Not Less Inclusive Diagnostic Criteria (KQ5)

Outcome | Comparison | Number of Studies | Inclusive GDM Group (events/N) | NGT Group (events/N) | Relative Effects [95% CI]; I^2^; (RR unless otherwise stated) | Absolute Risk Difference of Significant Findings [95% CI]
Mortality: All outcomes and studies | All studies | 8^196,200,201,203–205,219,222^ | 13/2629 | 148/39674 | 1.66 [0.93 to 2.95]; 0% | NA
Birth injury | OAV (NDDG) vs NGT | 1^217^ | 3,637 | | OR 1.10 [0.60 to 2.02]; NA; (RR not estimable) | NA
Shoulder dystocia | OAV (CC) vs NGT | 5^192,201,204,208,219^ | 10/890 | 26/3131 | 1.55 [0.60 to 3.98]; 28% | NA
Shoulder dystocia | OAV (NDDG) vs NGT | 1^220^ | 225 | 5971 | aOR 2.21 [0.51 to 9.58]; NA | NA
Shoulder dystocia | IADPSG (excluding CC) vs NGT | 4^193,198,200,211^ | 14/674 | 269/22078 | 1.79 [1.02 to 3.15]; 9% | 0.0054 [−0.0083 to 0.0191]
Shoulder dystocia | IADPSG (excluding CC) vs NGT(adjusted) | 1^198^ | 181 | 5485 | aOR [1.29 [0.40 to 4.19]; NA | NA
Macrosomia (>4000g) | OAV (CC) vs NGT | 10^192,196,197,201,202,204,209,213,219,220^ | 125/1564 | 1697/26522 | 1.47 [1.16 to 1.87]; 18% | 0.026 [−0.008 to 0.059]
Macrosomia (>4000g) | OAV (NDDG) vs NGT | 4^194,195,217,220^ | 454 | 9323; (Events and numbers per group were not provided by one study (n=3,637)^217^ | OR 1.85 [1.44 to 2.38]; 3.2%; (RR 1.76 [1.40 to 2.19]) | 0.048 [0.025 to 0.074]
Macrosomia (>4000g) | IADPSG (excluding CC) vs NGT | 8^193,198,200,206,210–212,218^ | 127/1357 | 2156/31359 | 1.70 [1.35 to 2.14]; 37% | 0.0357 [0.0099 to 0.0614]
Macrosomia (>4000g) | IADPSG (excluding CC) vs NGT (adjusted) | 3^198,206,211^ | 364 | 8758 | aOR 2.21 [1.49 to 3.29]; 0% | NA
Macrosomia (>4000g) | IADPSG (not NDDG) vs NGT | 1^222^ | 170/1151 | 1428/21286 | 2.20 [1.90 to 2.55]; NA | 0.081 [0.060 to 0.101]; NA
Large for gestational age | OAV (CC) vs NGT | 8^192,196,201,204,208,209,216,219^ | 152/1075 | 506/9562 | 1.64 [1.25 to 2.15]; 49% | 0.047 [0.018 to 0.076]
Large for gestational age | OAV (NDDG) vs NGT | 3^194,195,205^ | 52/351 | 266/2908 | 1.68 [1.28 to 2.21]; 0% | 0.053 [−0.0013 to 0.106]
Large for gestational age | IADPSG (excluding CC) vs NGT | 10^193,198,200,203,206,207,210–212,221^ | 435/2851 | 3465/35987 | 1.69 [1.42 to 2.01]; 64% | 0.0595 [0.0337 to 0.0853]
Large for gestational age | IADPSG (excluding CC) vs NGT (adjusted) | 6^198,203,206,207,211,221^ | 2016 | 18605 | aOR 1.73 [1.41 to 2.11]; 42% | NA
NICU Admissions | OAV (CC) vs NGT | 5^201,204,213,219,220^ | 47/958 | 634/10795 | 1.15 [0.84 to 1.57]; 0% | NA
NICU Admissions | OAV (NDDG) vs NGT | 1^220^ | 19/225 | 477/6992 | 1.24 [0.80 to 1.92]; NA | NA
NICU Admissions | IADPSG (excluding CC) vs NGT | 6^193,200,203,206,211,221^ | 145/1885 | 2083/25589 | 1.17 [0.99 to 1.38]; 0% | 0.0091 [−0.0031 to 0.0214]
NICU Admissions | IADPSG (excluding CC) vs NGT (adjusted) | 4^203,206,211,221^ | 1444 | 10975 | aOR 1.02 [0.81 to 1.28]; 0% | NA
Respiratory Distress Syndrome | OAV (CC) vs NGT | 3^192,201,219^ | 4/558 | 10/1175 | 0.65 [0.18 to 2.35]; 0% | NA
Respiratory Distress Syndrome | OAV (NDDG) vs NGT | 1^205^ | 11/122 | 25/577 | 2.00 [1.02 to 3.94] | 0.045 [−0.0085 to 0.099]
Hypoglycemia | OAV (CC) vs NGT | 7^192,196,197,201,204,216,219^ | 76/927 | 331/8651 | 1.61 [1.20 to 2.15]; 0% | 0.019 [0.0022 to 0.040]
Hypoglycemia | OAV (NDDG) vs NGT | 2^195,205^ | 7/264 | 11/2335 | 6.64 [2.52 to 17.49]; 0%; One study (n=3637): no association found for IV for hypoglycemia (data NR)^217^ | 0.020 [0.002 to 0.038]
Hypoglycemia | IADPSG (excluding CC) vs NGT | 3^203,206,221^ | 37/1392 | 91/8996 | 2.51 [1.72 to 3.68]; 0% | 0.016 [0.0072 to 0.025]
Hypoglycemia | IADPSG (excluding NDDG) vs NGT | 1^222^ | 30/1175 | 254/21629 | 2.17 [1.50 to 3.15]; NA | 0.014 [0.005 to 0.023]
Hyperbilirubinemia | OAV (CC) vs NGT | 4^196,201,204,219^ | 137/665 | 388/7545 | 1.21 [1.02 to 1.45]; 0% | NA
Hyperbilirubinemia | OAV (NDDG) vs NGT | 2^195,217^ | 142 | 1758; (Events and numbers per group were not provided by one study (n=3,637)^217^ | OR 2.04 [1.47 to 2.84]; 0%; (RR 1.97 [1.45 to 2.68]) | 0.031 [0.014 to 0.054]
Hyperbilirubinemia | IADPSG (excluding CC) vs NGT | 4^203,206,211,221^ | 140/1444 | 1513/11473 | 1.32 [1.13 to 1.54]; 0% | 0.0213 [−0.0040 to 0.0467]
APGAR score <7 at 1 minute | OAV (CC) vs NGT | 1^201^; 1^219^ | 12/395; 6/131 | 22/790; 0/108 | 1.09 [0.55 to 2.18]; NA; 10.73 [0.61 to 88.43]; NA | NA
APGAR score <7 at 1 minute | OAV (NDDG) vs NGT | 1^205^ | 6/122 | 12/577 | 2.36 [0.91 to 6.18]; NA | NA
APGAR score <7 at 1 minute | IADPSG (excluding CC) vs NGT | 2^200,211^ | 26/333 | 676/10248 | 1.11 [0.76 to 1.62]; 0% | NA
APGAR score <7 at 5 minutes | OAV (CC) vs NGT | 3^201,204,219^ | 8/606 | 31/1778 | 1.63 [0.70 to 3.83]; 0% | NA
APGAR score <7 at 5 minutes | OAV (NDDG) vs NGT | 1^205^ | 4/122 | 5/577 | 3.78 [1.03 to 13.89]; NA | 0.024 [−0.0084 to 0.057]
APGAR score <7 at 5 minutes | IADPSG (excluding CC) vs NGT | 3^193,200,211^ | 5/493 | 223/16593 | 0.97 [0.30 to 3.11]; 29% | NA

Abbreviations: aOR = adjusted odds ratio; CC = Carpenter Coustan; IADPSG = International Association of Diabetes and Pregnancy Study Groups; NA = not applicable; NGT = normal glucose tolerance; NDDG = National Diabetes Data Group; OAV = one abnormal value; OGCT = oral glucose challenge test

Findings for the association between more inclusive GDM criteria and risk of respiratory distress syndrome (4 studies, N=2,432)^192,201,205,219^ or low APGAR scores at 1 minute (5 studies, N=12,586)^200,201,205,211,219^ or 5 minutes (7 studies, N=20,169)^193,200,201,204,205,211,219^ were imprecise and inconsistent (Appendix C Figures 20 to 22).

#### Long-Term Maternal and Childhood Outcomes

Two U.S. studies (n=9,941)^199,202^ found no associations between OAV on CC versus NGT and risk for childhood (at 5 to 7 years^202^ and 3 years^199^) obesity (BMI over 85^th^ and 95^th^ percentiles) (Table 11). A study from Canada (n=350)^215^ found associations between OAV on NDDG and increased risk of impaired glucose tolerance (RR, 2.13 [95% CI, [1.14 to 3.99]) and T2DM (RR, 19.8 [95% CI, 1.03 to 379.34]) at 3 months’ postpartum. Diagnosis of GDM using OAV on NDDG criteria was associated with higher risk (75%) metabolic syndrome versus NGT, though estimates were imprecise.

Table 11 Evidence From Observational Studies on the Association Between a Diagnosis of GDM and Long-Term Outcomes in Women Meeting More But Not Less Inclusive Diagnostic Criteria (KQ5)

Outcome | Comparison | Number of Studies | Number of Patients (n/N) | | Relative Risk [95% CI] | Absolute Risk Difference for Significant Findings [95% CI]
Outcome | Comparison | Number of Studies | Experimental | Control | Relative Risk [95% CI] | Absolute Risk Difference for Significant Findings [95% CI]
Childhood overweight (>85^th^ percentile) - 5-7 years | OAV (CC) vs NGT | 1^202^ | 77/288 | 2021/8608 | 1.14 [0.94 to 1.38] | NA
Childhood overweight (>85^th^ percentile) - 5-7 years | OAV (CC) vs NGT | 1^202^ | 288 | 6071 | aOR 1.37 [1.01 to 1.86] | NA
Childhood overweight (85^th^ - <95^th^ percentile) - 13 years | OAV (CC) vs NGT | 1^199^ | 2/36 | 137/1009 | 0.51 [0.13 to 2.00] | NA
Childhood obesity (>95th percentile) - 5-7 years | OAV (CC) vs NGT | 1^202^ | 44/288 | 1056/8608 | 1.25 [0.94 to 1.64] | NA
Childhood obesity (>95th percentile) - 5-7 years | OAV (CC) vs NGT | 1^202^ | 288 | 6071 | aOR 1.30 [0.89 to 1.90] | NA
Childhood obsity (>85th percentile) - 13 years | OAV (CC) vs NGT | 1^199^ | 4/36 | 109/1009 | 1.03 [0.40 to 2.64] | NA
Maternal development of type 2 diabetes | OAV (NDDG) vs NGT | 1^215^ | 3/91 | 0/259 | 19.78 [1.03 to 379.34] | 0.033 [−0.0065 to 0.0724]
Maternal development of Impaired glucose tolerance or diabetes | OAV (NDDG) vs NGT | 1^215^ | 15/91 | 20/259 | 2.13 [1.14 to 3.99] | 0.0876 [0.0047 to 0.1705]
Maternal development of Impaired glucose tolerance or diabetes | OAV (NDDG) vs NGT (adjusted) | 1^215^ | 91 | 93 | aOR 5.70 [1.60 to 20.31] | NA
Maternal development of metabolic syndrome (IDF) ** | OAV (NDDG) vs NGT | 1^223^ | 16/91 | 26/259 | 1.75 [0.99 to 3.11] | NA
Maternal development of metabolic syndrome (IDF) ** | OAV (NDDG) vs NGT (adjusted) | 1^223^ | 91 | 259 | aOR 2.16 [1.05 to 4.44] | NA
Maternal development of metabolic syndrome (AHA/NHLBI) ** | OAV (NDDG) vs NGT | 1^223^ | 14/91 | 23/259 | 1.73 [0.93 to 3.22] | NA

Abbreviations: aOR = adjusted odds ratio; CC = Carpenter Coustan; IADPSG = International Association of Diabetes and Pregnancy Study Groups; NA = not applicable; NGT = normal glucose tolerance; NDDG = National Diabetes Data Group; OAV = one abnormal value; OGCT = oral glucose challenge test

* Bulleted lines are for sensitivity analysis: i) removing countries not classified as Very High Development Index countries (Wang 2013, Heethcuay 2017, Shang 2014, Hirst 2012, and Wei 2014),^201,203,218,220,222^ ii) only using blinded studies (Landon 2011, Sermer 1995, Waters 2016, Chico 2005, Rust 1996, Vambergue 2000);^196,208,216,217,219,221^ removing studies that did not define hypoglycemia (Arbib 2017, Heetchuay 2017, Kaymak 2011, Landon 2011, Rust 1996, Wei 2014),^192,201,204,208,216,222^ and removing Arbib 2017^192^ which applied screening in the third trimester after women screened negative at 24-28 weeks.

** AHA/NHLBI metabolic syndrome is defined as the presence of three or more of the following five disorders: 1) waist circumference of at least 88 cm; 2) serum triglycerides of at least 1.7 mmol/liter or drug treatment for hypertriglyceridemia; 3) HDL cholesterol below 1.29 mmol/liter or drug treatment for low HDL; 4) elevated blood pressure, defined as blood pressure of at least 130/85 mm Hg or use of antihypertensive drug treatment in a patient with a history of hypertension; and 5) dysglycemia, defined as fasting glucose of at least 5.6 mmol/liter or previously diagnosed diabetes or use of drug treatment for hyperglycemia. The IDF definition of metabolic syndrome in women differs from the AHA/NHLBI version in that it requires the presence of waist circumference of at least 80 cm (≥90 cm in Japanese women), accompanied by at least two of the other four disorders (elevated triglycerides, low HDL, hypertension, dysglycemia; all defined in the same way as per AHA/NHLBI criteria.

## Key Question 6 a. Does Treatment of GDM During Pregnancy Reduce Poor Health Outcomes? b. Does Treatment of GDM During Pregnancy Reduce Poor Intermediate Outcomes? c. Does the Effectiveness of Treatment of GDM Vary According to Maternal Subgroup Characteristics, Including Timing and Criteria Used for Diagnosis During Pregnancy, Severity of Hyperglycemia, BMI, Age, or Race/Ethnicity?

### Summary

- Treatment of GDM at or after 24 weeks’ gestation was associated with decreased risk of primary (first) cesarean deliveries (3 trials; RR, 0.70 [95% CI, 0.54 to 0.91]; I^2^=0%; ARD, 5.3% fewer [95% CI, 10.3 to 0.24]) and preterm deliveries (4 trials; RR, 0.75 [95% CI, 0.56 to 1.01]; I^2^=0%; ARD, 2.6% fewer [95% CI, 4.9 fewer to 0.02 more]) versus no treatment, although the latter finding had some imprecision.
- There might be an association between treatment for GDM versus no treatment and decreased risk of preeclampsia (5 trials, N=1,384; RR, 0.60 [95% CI, 0.35 to 1.01]; I^2^=3%; ARD, 1.0% fewer [95% CI, 4.5 fewer to 2.4 more]), after excluding an outlier trial. For hypertensive disorders in pregnancy, there was marked inconsistency between trials and no association with reduced risk (3 trials, N=2,626; RR, 0.85 [95% CI, 0.50 to 1.43]; I^2^=80%]. Treatment was not associated with reduced risk of gestational hypertension (2 trials; with some imprecision).
- Treatment for GDM was not associated with reduced risk of total cesarean deliveries (8 trials), emergency cesarean deliveries (1 trial), induction of labor (5 trials), or maternal birth trauma (2 trials).
- In terms of fetal/neonatal outcomes, treatment for GDM at or after 24 weeks’ gestation, versus no treatment, was associated with reduced risk of shoulder dystocia (4 trials; RR, 0.42 [95% CI, 0.23 to 0.77]; I^2^= 0%; ARD, 1.3% fewer [95% CI, 4.3 to 1.6]), macrosomia (8 trials; RR, 0.53 [95% CI, 0.41 to 0.68]; I^2^=42%; ARD, 8.9% fewer [12.0 to 5.9]), LGA (7 trials; RR, 0.56 [95% CI, 0.47 to 0.66]; I^2^=0%; ARD, 8.4% fewer [95% CI, 10.8 to 6.1]), and NICU admissions (5 trials; RR, 0.73 [95% CI, 0.53 to 0.99]; I^2^=0%; ARD, 2.0% fewer [95% CI, 4.5 fewer to 0.5 more]). Treatment for GDM was associated with reduced risk of birth injury (e.g., fracture or nerve palsies) in three trials reporting events (OR, 0.33 [95% CI, 0.11 to 0.99]; I^2^=0%) but not when combining data from seven trials reporting on the outcome (ARD, 0.2% fewer [95% CI, 0.6 fewer to 0.2 more]).
- There was no association between treatment for GDM and risk of mortality, respiratory distress syndrome, neonatal hypoglycemia, hyperbilirubinemia, or APGAR scores; though results for many of these outcomes were heterogeneous and/or imprecise.
- One trial found no association between treatment for GDM versus no treatment and maternal impaired fasting glucose, obesity, metabolic syndrome or T2DM at 5 to 10 years. No study measured effects of treatment for GDM on long-term quality of life, cardiovascular outcomes, or mortality or major morbidity from T2DM.
- For long-term intermediate and health outcomes in the child, treatment of mothers for GDM, versus no treatment, was not associated with reduced risk of overweight/obesity (over 4 to 7 years), obesity (7 to 9 years), impaired glucose tolerance (median 9 years) or impaired fasting glucose (median 7 to 9 years). Evidence on T2DM was too sparse to determine effect of treatment of mothers for GDM. No study measured cardiovascular or neurocognitive outcomes.
- There was insufficient evidence to determine effects of treatment versus no treatment for GDM in early pregnancy (using HbA1c or IADPSG criteria before 14 to 15 week’s gestation); findings from four small trials were highly imprecise and limited by risk of bias.
- Subgroup analyses from one trial found no differences in effects of GDM treatment for several maternal and fetal outcomes based on timing of treatment initiation, race/ethnicity, severity of dysglycemia, or BMI. Across trials, differences in GDM diagnostic criteria did not appear to impact findings for several outcomes or explain inconsistency. Findings are most applicable to two-step screening approaches.

### Evidence

The prior review^2^ found that treatment for GDM at or after 24 weeks’ gestation was associated with reduced risk of preeclampsia (3 RCTs, N=2,014; RR, 0.62 [95% CI, 0.43 to 0.89]), macrosomia (5 RCTs, N=2,643; RR, 0.50 [95% CI, 0.35 to 0.71]), LGA (3 RCTs, N=2,261; RR, 0.56 [95% CI, 0.45 to 0.69], and shoulder dystocia (3 RCTs, N=2,044; RR, 0.42 [95% CI, 0.23 to 0.77]) versus no treatment. No associations were found between GDM treatment and risk of neonatal hypoglycemia, cesarean deliveries, or induction of labor. Findings were based on 5 RCTs^41,42,224–226^ and 6 cohort studies^75,170,175,179,227,228^, and were largely driven by two large RCTs of women with GDM.^41,42^ For outcomes for which results were inconsistent between studies, different study glucose threshold entry criteria did not explain the variation.

The current review excluded cohort studies because more RCT evidence is now available. We included the previous five RCTs, and added eight new trials^229–236^ and six associated papers^237–242^ reporting subgroup analyses or long-term followup (Tables 12 and 13, and Appendix B Table 14).

Table 12 Summary of Trials of Treatment vs. No Treatment for GDM at 24 Weeks’ Gestation or Later (KQs 6 and 7)

Author, Year, Country; Quality | # Randomized; # Analyzed | Age (years; mean ± SD); BMI (kg/m^2^; mean ± SD) | Glycemic Status at Enrollment (mean ± SD), mg/dl or % | Ethnicity Majority | Inclusion Criteria (level of glycemia and others as relevant) | Timing of Randomization Intervention Components; Insulin Requirements Gestational Age at Birth
Bevier, 1999^224^; U.S.; Fair (no blinding and 19.5% IOD) | 103; 83 (35 vs 48) | G1: 26.3 ± 6.0; G2: 27.4 ± 5.4; Weight (kg); G1: 68.2 ± 11.4; G2: 72.4 ± 12.0 | G1: HbA1c at 28 wGA (%): 4.7 ± 0.6; G2: HbA1c at 32 wGA (%): 4.7 ± 0.7 | 94% Hispanic | OGCT+ve and OGTT-ve on OGTT by O’Sullivan and Mahan criteria; *No hypertension, history of preterm delivery or SGA | 24-28 wGA; G1: Diet, SMBG, and insulin if needed; RBG weekly and HbA1 testing at 28 and 32 wks; G2: Regular RBG with insulin if needed; HbA1c testing at 28 and 32 wks; repeat OGTT at 30-32 wks; G1: Insulin 1/35 vs. G2: 4/48; G1: 39.6 ± 1.3 vs G2: 39.4 ± 1.5 wks
Bonomo, 2005^225^; Italy; Fair (no blinding) | 300; 300 (150 vs 150; replaced 21) | G1: 31.1 ± 4.7; G2: 30.7 ± 5.1; G1: 23.1 ± 4.4; G2: 23.0 ± 4.5 | OGCT: 8.44 ± 0.89 mmol/L; Fasting: 84.7 ± 9.0; HbA1C: 4.9 ± 0.5% | 100% Caucasian | OGCT+ve and OGTT-ve on CC (OAV excluded) | At booking for those with risk factors; 24-28 wGA for those without risk factors; repeated at 30-34 wGA for those –ve on OGTT which excluded 15 after randomization; G1: Diet, SMBG, biweekly blood work including FPG and HbA1C; G2: reassured and no extra management; Medication NR; G1: 39.4 ± 1.2 vs G2: 39.6 ± 1.7 wks
Deveer, 2013^229^; Turkey; Fair but considering CCT (no blinding or allocation concealment; inadequate sequence generation) | 100; 100 (50 vs. 50) | G1: 29.5 ± 5.8; G2: 31.2 ± 5.6; G1: 28.0 ± 3.6; G2: 29.1 ± 4.8 | OGCT: 153.2 ± 28.8 | NR | OGCT+ve and OGTT-ve; *No history of T2DM or GDM, or stillbirth | 24- 28 wGA; G1: Diet; G2: No additional management; Medication NR; G1: 38.7 ± 1.2 vs. G2: 38.9 ± 1.1 wks
Crowther, 2005^41^; Australia; Good (Fair for 4-5 yr followup in Gillman 2010 due to n=199) | 1000; 1000 (490 vs. 510; 506 vs 524 infants) | G1: 30.9 ± 5.4; G2: 30.1 ± 5.5; G1: 26.8 (23.3–31.2); G2: 26.0 (22.9–30.9) | Fasting: 86.5 ± 12.6; 2hr: 153.2 ± 14.4 | 75.2% Caucasian | ≥1 risk factors for GDM on selective screen or OGCT+ve, and OGTT at 24-34 wGA with fasting <140mg/dl and 2h 140-198 mg/dl; *Excluded those with a history of GDM; did not excluded twins | 24-34 wGA; G1: Diet, SMBG QID, insulin as needed; G2: Routine care with OGTT if indications (at provider discretion); G1: 20% insulin vs. G2 3%; G2: 39.0 (IQR 38.1-40) vs G2: 39.3 (IQR 38.3-40.4) wks; p=0.01
Fadl, 2015^230^; Sweden; Good (Fair for outcomes with potential SOR [shoulder dystocia, neonatal hypoglycemia, preterm deliveries]) | 72; 69 (33 vs. 36 [34 with exclusion of early miscarriage]) | G1: 32.6 ± 5.9; G2: 30.6 ± 5.5 (62% obese); G1: 31.3 ± 6.4; G2: 32.6 ± 5.9 | OGTT results (mg/dl):; G1: fasting 102.7 ± 10.8; 2h 191.0 ± 9.7; G2: fasting 102.7 ± 12.6; 2h 192.8 ± 9.0 (capillary blood) | 71% Nordic | OGTT before 34 wGA (criteria 1+ risk factor or RBG >9.0mmol/L); 75g capillary OGTT: fasting <126 mg/dlL or 2hr value ≥180 to <220 mg/dl | If early RBG >9 mmol/L, then given early OGTT (n=NR), if normal RBG then OGTT done at 28-32 wGA; G1: Diet, SMBG QID, insulin as needed; G2: Routine care; G1: 67% insulin vs.G2 NR; G1: 275 (range 258-288) vs G2: 273 (221-209) days
Kokanali, 2014^232^; Turkey; Fair (blinding NR, allocation concealment NR) | 201; 201 (99 vs 102) | At delivery; G1: 27.9 ± 5.8; G2: 27.9 ± 5.8; Pre-gestational:; G1: 26.4 ± 2.7; G2: 26.7 ± 3.45 | NR | NR | OGCT+ve and one abnormal value (OAV) on CC | 24-28 wGA; G1: Diet therapy with dietician, SBMG (details NR), insulin as needed; G2: Routine care; G1 NR insulin vs G2 NR; G1: 269.1 ± 12.5 vs G2: 286.8 ± 13.4 days
Landon, 2009^42^; U.S.; Good* (Good for subgroup analysis for timing of treatment initiation^240^ and level of glycemia^239^, but fair for subgroups on BMI^238^ and race/ethnicity^237^ and long-term followup^241,242^) | 958 (485 vs. 473); 931 for most except hypoglycemia [n=738; 77%]) | G1: 29.2 ± 5.7; G2: 28.9 ± 5.6; G1: 30.1 ± 5.0 vs. G2: 30.2 ± 5.1 | G1: FPG 86.6 ± 5.7; 1h 191.8 ± 21.9; 2h 173.7 ± 21.8; 3h 137.3 ± 29.0; G2: FPG 86.3 ± 5.7; 1h 193.4 ± 19.3; 2h 173.3 ± 19.6; 3h 134.1 ± 31.5 | 57% Hispanic | Between 24-31 wGA; >135 on OGCT; FPG <95 mg/dL and 2 or 3 abnormal on CC OGTT; *Excluded women with chronic hypertension, previous GDM, stillbirth | 24-31 (mean 28.8 ± 1.6 wGA); G1: Diet, SMBG, insulin as needed (50% or greater of fasting or postprandial levels elevated); G2: Routine care, RPG at provider discretion; G1: 7.6% insulin vs. G1 0.4%; G1: 39.0 ± 1.8 vs. G2: 38.9 ± 1.8 wks
Garner, 1997^226^; Canada; Fair (insufficient blinding of patients); Fair for 7-11 Year followup^244^ | 300; 299 (149 vs. 150) | G1: 30.7 ± 4.8; G2: 30.7 ± 4.6; Pre-pregnancy weight (kg); G1: 68.9 ± 16.9; G2: 71.2 ± 19.8 | 75g OGCT (mg/dl):; 182.0 ± 28.8 | 91% Caucasian | +ve 75g OGCT and GDM criteria (FPG 4.8 mmol/ l, 1-h 10.9 mmol/ l and 2-h 9.6 mmol/l [number abnormal NR]) diagnosed between 24–32 wGA; otherwise low-risk pregnancy; *Excluded women with chronic hypertension | 24-32 wGA; G1: Tertiary care center follow up with obstetrician and endocrinologist; Diet, daily SMBG, biweekly fetal monitoring, insulin as needed [13 (7.8%) met T2DM criteria]; G2: Primary care provider; twice weekly SMBG (results sent to independent observer); no fetal monitoring unless indicated [16 (10.6%) women meeting T2DM criteria were given treatment]; G1: 24% insulin vs. G2 NR but 10.6% T2DM; Gestational age NR
Yang, 2014^236^; China; Fair (unclear sequence generation; no blinding or patients or providers) | 948 (130 vs 112 excluded from break in protocol from renovations); 700 (361 vs. 339) | G1: 29.9 ± 3.5; G2: 29.7 ± 3.2; Pre-pregnancy BMI:; G1: 22.9 ± 3.6; G2: 23.4 ± 3.9 | OGTT results (mg/dl):; G1: fasting 91.9 ± 10.8; 1h 182.0 ± 25.2; 2h 151.4 ± 21.6; G2: fasting 90.1 ± 9.0; 1h 180.2 ± 23.4; 2h 151.4 ± 25.2 | 97% Han Chinese | GDM diagnosed with 2-step IADPSG 2010 criteria (with 50g OGCT)(not meeting T2DM criteria using FPG and HbA1c); *Excluded those with chronic hypertension | 24-29 wks; mean 26.3 ± 1.4 wGA; G1: Shared care system (primary care hospital then obstetric hospitals) with team of nurses and doctors; diet, physical activity, SMBG; G2: One hospital-based education session by diabetes educator (diet and physical activity but no SMBG); insulin if HbA1c >6.5% at 34 wks; G1: 1.2% insulin vs G2: 0.3%; G1: 39.2 ± 2.1 vs. G2: 39.4 ± 2.9; p=0.24

Abbreviations: BMI = body mass index; CC = Carpenter Coustan; CCT = controlled clinical trial; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes and Pregnancy Study Groups; IQR = interquartile range; NR = not reported; OGCT = oral glucose challenge test; OGTT = oral glucose tolerance test; QID = quater in die (four times daily); RBG = random blood glucose; SD = standard deviation; SMBG = self-monitoring blood glucose; SOR = selective outcome reporting; T2DM = type 2 diabetes mellitus; wGA = weeks’ gestation; wk(s) = week(s); yr(s) = year(s)

Table 13 Summary of Trials of Treatment vs. No Treatment for GDM in Early Pregnancy (KQs 6 and 7)

Author, Year, Country; Quality (concerns) | # Randomized; # Analyzed | Age (years; mean ± SD); BMI (kg/m^2^; mean ± SD) (unless stated otherwise) | Glycemic Status at Enrollment (mean ± SD), mg/dl or % | Ethnicity majority | Inclusion criteria (Level of glycemia and others as relevant) | Timing of Randomization Intervention Components; Insulin Requirements Gestational Age at Birth
Hughes, 2018^231^; New Zealand; Fair (unclear for baseline imbalances; no blinding) | 47; 44 (23 vs. 21) | Age at expected delivery date:; G1: 30.5 (28.0-34.5); G2: 32.0 (29.5-36.0); BMI at baseline:; G1: 29.6 (24.1-35.6); G2: 30.3 (27.1-38.4) | HbA1c at booking:; G1: 42 (41-45); G2: 42 (41-45); (6.0% ± 2.4%) | 51% Asian | HbA1c 5.9%-6.4% (41-46 mmol/mol) at booking | <14 wGA; G1: Diabetes clinic and lead maternity carer (midwife or obstetrician): ongoing lifestyle education, daily SMBG (before and after each meal), and medication as required (metformin and/or insulin); G2: Standard care with lead maternity caregiver and 75g OGTT screening at 24 wGA (IADPSG or New Zealand criteria: FBG ≥5.5 mmol/L [99 mg/dL]) or 2hr BG ≥9.0 mmol/L [162 mg/dL]), with referral if GDM; G1: 17/23 (metformin in 14 and insulin in 15 women)[all before 24 wks] vs G2: 11/22 (metformin in 3 and insulin in 11 women); Gestational age NR
Osmundson, 2016^233^; U.S.; Fair (no blinding, significant loss to followup, and some possible selective outcome reporting) | 95 (50 vs 45); 83 (42 vs 41); 74 with delivery data (37 vs 37) | G1: 32.4 ± 5.1; G2: 34.3 ± 5.2; Pre-pregnancy BMI:; G1: 27.2 (24.8-33.2); G2: 27.4 (22.6-32.7) | HbA1c (%); G1: 5.8 (5.7-5.9); G2: 5.8 (5.7-5.9) | 45% Hispanic; 37% Asian | HbA1c 5.7-6.4% before 14 wGA; *Excluded women with a prior infant with birth injury or shoulder dystocia possibly attributable to diabetes, or prior macrosomic infant | <14 wGA (mean 11.1 wks); G1: Diet with Certified Diabetes Educator, SMBG QID, insulin as needed; OGTT at 26-28 wks with negatives continuing dietary but reduced SMBG; G2: Routine prenatal care with screening OGTT at 26-28 wks; G1: 35.9% insulin vs. G2: 26.3%; G1: 38.3 ± 2.3 vs. G2: 38.2 ± 2.0 wks
Simmons, 2018^234^; New Zealand; Good | 21; 20 (11 vs 9) | G1: 29 ± 5; G2: 30 ± 7; G1: 32.3 ± 7.8; G2: 33 ± 7.0 | Early (<20wGA) OGTT results (mmol/L):; G1: fasting 91.9 ± 7.2; 1h 144.1 ± 30.6; 2h 126.1 ± 34.2; G2: fasting 93.7 ± 5.4; 1h 151.4 ± 28.8; 2h 122.5 ± 30.6 | 55% Caucasian | With risk factors and GDM on 75g OGTT by IADPSG criteria, <20wGA | 4-20 wGA; G1: Education, diet, SMBG, metformin or insulin as needed; G2: Routine prenatal care, with screening at 24-28 wGA; G1: 36% insulin or metformin vs. G2: 40%; G1: 38.7 ± 1.4 vs G2: 39.2 ± 0.6 wks
Vinter, 2018^235^ Denmark; CCT (subgroup analysis of GDM prevention RCT); Fair (not randomized) | 90; 90 (36 vs 54) | 29.0 ± 4.4; 34.5 ± 4.3 (pre-pregnancy or 1st trimester) | Venous fasting: 93.7 ± 3.6; Capillary 2hr: 117.1 ± 19.8 (1^st^ trimester) | 100% Caucasian | BMI 30-40 kg/m^2^ (pre-pregnancy or 1^st^ measured weight in pregnancy); diagnosed retrospectively with GDM by modified WHO 2013 criteria in early pregnancy (12-15 wGA; (venous FPG ≥5.1 mmol/L and/or 2h capillary ≥8.5 mmol/L), but not meeting Danish criteria for GDM (2h capillary ≥9.0 mmol/L) at any time (12-15, 28-30 or 34-36 wGA) | 12-15 wGA; G1: Lifestyle intervention: 4 diet counseling sessions with a trained dietician, encouraged to perform 30-60 min daily exercise with a free full membership to a fitness center for 6 months until delivery (included closed exercise classes with a physiotherapist 1h weekly); no SMBG or insulin assessment per protocol; G2: Routine care; Both groups were monitored with fasting blood samples, OGTTs, sonographic fetal biometry, and measurements of maternal weight and blood pressure; G1: NR vs G2: NR (unlikely); G1: 40 (39-41.3) vs G1: 40.7 (39-41.3)

Abbreviations: BMI = body mass index; CCT = controlled clinical trial; CC = Carpenter Coustan; G = group; FPG = fasting plasma glucose; GDM = gestational diabetes mellitus; IQR = interquartile range; OAV = one abnormal value; OGCT = oral glucose challenge test; OGTT = oral glucose tolerance test; NR = not reported; QID = quarter in die (i.e. four times daily); RBG = random blood glucose; SGA = small for gestational age; SMBG = self-monitoring blood glucose; T2DM = type 2 diabetes mellitus; wk(s) = week(s); wGA = weeks’ gestation; yr(s) = year(s)

#### Study Characteristics

Sample sizes ranged from 21 to 1000 (median 103; total N=4,235), with three trials each having 700 to 1000 participants.^41,42,236^ Mean ages ranged from 26.8 to 33.3 years (median 30.3) and BMI from 23.1 to 34.5 kg/m^2^ (median 28.6). Three trials were conducted in each of the United States,^42,224,233^ and Europe,^225,230,235^ two in Australia^41,234^ and Turkey,^229,232^ and one in Canada,^226^ New Zealand,^231^ and China.^236^ Two of the U.S. trials included a diverse population of women,^42,233^ whereas one included 94 percent Hispanic women.^224^ A large RCT from Australia included 75 percent white women.^41^ Few trials reported on the proportion of women with a family history of T2DM or prior GDM. Two trials excluded women with previous GDM,^42,229^ and all but one^41^ excluded multiple gestations.

Eleven RCTs, and two CCTs (one prospective trial without random allocation and one subgroup analysis of an RCT of GDM prevention [examining those getting GDM])^229,235^ were included. Seven trials examined standard treatment after testing for GDM at or after 24 weeks’ gestation,^41,42,224,226,229,232,236^ two enrolled women after diagnosis in early pregnancy or at or after 24 weeks,^225,230^ and four studied treatment of early GDM (before 14 or 15 weeks’ gestation).^231,233–235^ The glycemic criteria in three trials was not mild GDM, but a positive OGCT with a negative OGTT on CC criteria.^224,225,229^ One of the new trials used a 2-step screening approach with a 50g OGCT and OGTT with IADSPG criteria.^236^ In the three largest trials,^41,42,236^ there were some differences between baseline levels of glycemia; the older two trials had similar FPG but different 2-hour postload levels (i.e., FPG 86.5 mg/dL in both and 2-hour levels of 153 mg/dL^41^ and 173 mg/dL^42^), and a third trial^236^ had slightly higher FPG but lower 2-hour levels (i.e., FPG 91 mg/dL and 2-hour 151 mg/dL). In the four early pregnancy treatment studies, two used HbA1c for diagnosis of hyperglycemia,^231,233^ and the other two used IADPSG/WHO 2013 criteria.^234,235^ The interventions of all trials included dietary/medical nutrition therapy. Three trials did not report protocols for providing insulin or oral medication;^225,229,235^ eight reported using insulin when needed to maintain set glucose targets,^41,42,224,226,230,232,233,236^ and two (both of early treatment)^231,234^ reported using insulin or metformin as needed. All trials except for two^229,235^ included regular self-monitoring of blood glucose. The control interventions were routine pregnancy care, except in three trials^224,226,236^ that included regular monitoring of blood glucose and/or some form of basic education. Outcome definitions varied to some extent. Apart from two trials that did not report data,^226,231^ weeks’ gestation at delivery was similar between groups in all trials.

Quality was rated good for three blinded RCTs of treatment at or after 24 weeks,^41,42,230^ and fair for all other trials (Appendix B Table 15). The trials rated as fair quality^224–226,229,231–236^ were open-label; other limitations included inadequate information regarding randomization and allocation concealment methods.

#### Treatment at or After 24 Weeks’ Gestation

##### Pregnancy Outcomes

###### Preeclampsia

Six trials found no association between GDM treatment versus no treatment and risk of preeclampsia, but there was statistical heterogeneity and some imprecision in the pooled estimate (N=2,084; RR, 0.99 [95% CI, 0.46 to 2.16]; I^2^=59%)^42,224,229,230,232,236^ (Table 14 and Figure 22). Heterogeneity was not well explained by any single variable, but decreased substantially when one outlier study was removed (5 trials, N=1,384; RR, 0.60 [95% CI, 0.35 to 1.01]; I^2^=3%; ARD, 1.0% fewer [95% CI, 4.5 fewer to 2.4 more]) (Appendix D Table 9). The outlier was an RCT from China,^236^ which found treatment versus minimal intervention in women with relatively low BMI (mean 23 kg/m^2^) associated with an increased risk of preeclampsia.

Table 14 Effects from Trials of Treatment vs. No Treatment for GDM at 24 Weeks’ Gestation or Later on Pregnancy Outcomes (KQ6)

Outcome | Analysis | Number of Trials with Events | Number of Events/ Treated | Number of Events/ Untreated | Relative Risk [95% CI]; I^2^ (unless stated otherwise) | Absolute Risk Difference of Significant Findings [95% CI]
Preeclampsia | All studies | 6^42,224,229,230,232,236^ | 42/1032 | 48/1052 | 0.99 [0.46 to 2.16]; 59% | NA
Preeclampsia | Removing nonVHDI studies | 5^42,224,229,230,232^ | 24/693 | 40/691 | 0.60 [0.35 to 1.01]; 3% | −0.010 [−0.045 to 0.024]
Gestational hypertension | All studies | 2^42,236^ | 38/815 | 45/816 | 0.82 [0.54 to 1.25]; 0% | NA
Hypertensive disorders of pregnancy | All studies | 3^41,42,236^ | 126/1305 | 171/1326 | 0.85 [0.50 to 1.43]; 80% | NA
Hypertensive disorders of pregnancy | Only blinded and VHDI studies | 2^41,42^ | 99/966 | 155/965 | 0.64 [0.51 to 0.81]; 0% | −0.057 [−0.086 to −0.027]
Cesarean delivery | All studies | 8^41,42,224–226,230,232,236^ | 638/1771 | 684/1812 | 0.95 [0.83 to 1.08]; 43% | NA
Primary cesarean delivery | All studies | 3^42,224,229^ | 81/561 | 113/553 | 0.70 [0.54 to 0.91]; 0% | −0.0525 [−0.103 to −0.0024]
Emergency cesarean delivery | All studies | 1^41^ | 80/490 | 103/510 | 0.81 [0.62 to 1.05]; NA | NA
Induction of Labor | All studies | 5^41,42,224,230,236^ | 338/1373 | 285/1410 | 1.18 [0.92 to 1.52]; 45% | NA
Preterm delivery | All studies | 4^42,229,232,236^ | 69/965 | 92/968 | 0.75 [0.56 to 1.01]; 0% | −0.023 [−0.049 to 0.002]
Maternal birth trauma | All studies | 2^41,229^ | 255/540 | 255/560 | 1.04 [0.92 to 1.18]; 0% | NA

Abbreviations: CI = confidence interval; NA = not applicable; VHDI = Very High Development Index country

Figure 22 Meta-Analysis of Trials: Preeclampsia, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Figure 22 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for preeclampsia. Our meta-analysis (6 trials, 2084 subjects) found the pooled relative risk was 0.99 with a 95% CI of 0.46 to 2.16; I2=59%. There was high heterogeneity, with estimates from two large RCTs indicating benefit from treatment and one other large trial showing harm.

###### Gestational Hypertension

Two RCTs from the United States^42^ and China^236^ found that treatment for GDM was not associated with reduced risk for gestational hypertension, though there was some imprecision (N=1,631; RR, 0.82 [95% CI, 0.54 to 1.25]; I^2^=0%) (Appendix C Figure 23).

###### Hypertensive Disorders in Pregnancy

There was no difference between treatment for GDM versus no treatment and risk of hypertensive disorders in pregnancy (3 trials, N=2,626; RR, 0.85 [95% CI, 0.50 to 1.43]; I^2^=80%] (Figure 23); heterogeneity was high, with two trials^41,242^ showing an association with decreased risk (N=1,931; RR 0.64 [0.51 to 0.81]; I^2^=0%) and one trial^236^ showing an association with increased risk (n=700; RR, 1.80 [95% CI, 0.99 to 3.28]). The reason for this discrepancy was not clear. In all trials, hypertensive disorders were defined as gestational hypertension with or without preeclampsia.

Figure 23 Meta-Analysis of Trials: Hypertensive Disorders of Pregnancy, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Figure 23 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for hypertensive disorders of pregnancy. Our meta-analysis (3 trials, 2631 subjects) found the pooled relative risk was 0.85 with a 95% CI of 0.50 to 1.43; I2=80%. There was high heterogeneity, with estimates from two large RCTs indicating benefit from treatment and one other large trial showing harm.

###### Total Cesarean Deliveries

Treatment for GDM was not associated with reduced risk of any cesarean delivery (8 RCTs, N=3,583; RR, 0.95 [95% CI, 0.83 to 1.08]; I^2^=43%)^41,42,224–226,230,232,236^ (Figure 24). Findings were similar in sensitivity analyses (Appendix D Table 9). Results may have been impacted by differing practice patterns; in one RCT,^42^ treatment was associated with a reduced risk of cesarean deliveries without an increase in labor inductions, whereas in another RCT^41^ there was no association between treatment and fewer cesareans, but an association with increased likelihood of induced labors.

Figure 24 Meta-Analysis of Trials: Total Cesarean Deliveries, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Figure 24 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for total cesarean deliveries. Our meta-analysis (8 trials, 3583 subjects) found the pooled relative risk was 0.95 with a 95% CI of 0.83 to 1.08; I2=43%.

###### Primary Cesarean Delivery

Three trials found treatment for GDM associated with decreased risk of primary cesarean deliveries versus no treatment (N=1,114; RR, 0.70 [95% CI, 0.54 to 0.91]; I^2^=0%; ARD, 5.3% fewer [95% CI, 10.3 to 0.24])^42,224,229^ (Appendix C Figure 24).

###### Emergency Cesarean Delivery

Only one trial reported on emergency cesarean deliveries; the point estimate favored treatment but was not statistically significant (n=1,000; RR, 0.81 [95% CI, 0.62 to 1.05]).^41^

###### Induction of Labor

Treatment for GDM was not associated with decreased risk of induction of labor (5 RCTs, N=2,783; RR, 1.18 [95% CI, 0.92 to 1.52]; I^2^=45%)^41,42,224,230,236^ (Appendix C Figure 25). Sensitivity analyses had no impact on findings. Indications for induction of labor may have varied across trials.

###### Preterm Delivery

Treatment was associated with decreased risk of preterm delivery versus no treatment, although the difference was just below the threshold for statistical significance (4 trials, N=1,933; RR, 0.75 [95% CI, 0.56 to 1.01]; I^2^=0%; ARD, 2.3 fewer [95% CI, 4.9 fewer to 0.02 more])^42,229,232,236^ (Figure 25).

Figure 25 Meta-Analysis of Trials: Preterm Delivery, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Figure 25 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for preterm delivery. Our meta-analysis (4 trials, 1933 subjects) found the pooled relative risk was 0.75 with a 95% CI of 0.56 to 1.01; I2=0%.

###### Maternal Birth Trauma

Treatment for GDM was not associated with reduced risk of maternal birth trauma versus no treatment (2 trials; N=1,100; RR, 1.04 [95% CI, 0.92 to 1.18]; I^2^=0%)^41,229^ (Appendix C Figure 26). One trial (n=1,000)^41^ contributed almost all events and defined the outcome as any perineal trauma.

##### Fetal/Neonatal Outcomes

###### Mortality

Two trials (n=1,730)^41,236^ found no association between treatment for GDM versus no treatment and risk of fetal/neonatal mortality (Peto OR, 0.49 [95% CI, 0.16 to 1.45]; I^2^=68%), but there were few mortality events (Table 15 and Appendix C Figure 27). One RCT (n=1,030 neonates) reported 5 events in the no treatment group (3 stillbirth, 2 neonatal),^42^ and another (n=700) reported 4 events in both groups (all perinatal).^236^

Table 15 Effects from Trials of Treatment vs. No Treatment for GDM at 24 Weeks’ Gestation or Later on Fetal/Neonatal Outcomes (KQ6)

Outcome | Number of Trials with Events | Number of Events/ Treated | Number of Events/Untreated | Relative Risk [95% CI]; I^2^ (unless stated otherwise) | Absolute Risk Difference [95% CI]
Mortality | 2^41,236^ | 4/845 | 9/885 | Peto OR 0.49 [0.16 to 1.45]; 68% | NA
Birth injury | 3^41,42,230^ | 3/1015 | 10/1013 | Peto OR 0.33 [0.11, 0.99] | −0.002 [−0.006 to −0.002]
Shoulder dystocia | 3^41,42,224^ | 15/1017 | 36/1027 | 0.42 [0.23 to 0.77]; 0% | −0.013 [−0.043 to 0.016]
Macrosomia (>4000g) | 8^41,42,224–226,229,232,236^ | 164/1805 | 330/1839 | 0.53 [0.41 to 0.68]; 42% | −0.089 [−0.120 to −0.059]
Macrosomia (>4500g) | 3^226,230,236^ | 16/521 | 23/545 | 0.72 [0.39 to 1.35]; 0% | NA
Large for gestational age | 7^41,42,225,229,230,232,236^ | 174/1654 | 322/1675 | 0.56 [0.47 to 0.66]; 0% | −0.084 [−0.108 to −0.061]
NICU admission | 5^42,225,229,230,232^ | 63/809 | 84/791 | 0.73 [0.53 to 0.99]; 0% | −0.020 [−0.045, 0.0051]
Respiratory distress syndrome | 2^41,42^ | 36/983 | 32/979 | 1.05 [0.48 to 2.28]; 58% | NA
Any hypoglycemia | 5^42,225,226,232,236^ | 91/1118 | 80/1120 | 1.10 [0.83 to 1.45]; 0% | NA
Hypoglycemia requiring IV treatment | 2^41,42^ | 60/981 | 58/979 | 1.02 [0.60 to 1.76]; 58% | NA
Hyperbilirubinemia | 5^41,42,225,226,230^ | 101/1288 | 119/1276 | 0.84 [0.65 to 1.08]; 0% | NA
Apgar score <7 at 1 min | 1^236^ | 0/339 | 7/361 | 0.07 [0.00 to 1.24]; NA | NA
Apgar score <7 at 5 min | 2^41,232^ | 9/605 | 15/626 | 0.62 [0.27 to 1.41]; 0% | NA

Abbreviations: CI = confidence interval; NA = not applicable; NICU = neonatal intensive care unit

###### Birth Injury and Shoulder Dystocia

Treatment versus no treatment for GDM was associated with a decreased risk of birth injury (i.e., bone fractures or nerve palsies) when analyzing trials with events (3 trials with events; N=2,028; Peto OR, 0.33 [95% CI, 0.11 to 0.99]; I^2^=0%)^41,42,230^ but not when using absolute rates and adding the four trials without events (7 trials, N=3,328; ARD, 0.2% fewer [95% CI, 0.6 fewer to 0.2 more]) (Figure 26).^41,42,226,229,230,232,236^ In one trial (n=700)^236^ the lack of birth injury events was attributed to the high prevalence (over 60%) of cesarean deliveries in both groups. Similarly, treatment versus no treatment for GDM was associated with a decreased risk of shoulder dystocia in trials with events (3 trials; N=2,028; RR, 0.42 [95% CI, 0.23 to 0.77]; I^2^= 0%),^41,42,224^ but not when adding the trial (n=700)^236^ without events and high prevalence of cesarean deliveries (ARD, 1.3% [95% CI, 4.3 fewer to 1.6 more]) (Figure 27).

Figure 26 Meta-Analysis of Trials: Birth Injury, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question

Figure 26 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for birth injury. Our meta-analysis (3 trials, 2028 subjects) found the pooled Peto odds ratio was 0.33 with a 95% CI of 0.11 to 0.99; I2=0%. Four other RCTs had zero events in both groups.

Figure 27 Meta-Analysis of Trials: Shoulder Dystocia, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Figure 27 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for shoulder dystocia. Our meta-analysis (4 trials, 2744 subjects) found the pooled relative risk was 0.42 with a 95% CI of 0.23 to 0.77; I2=0%.

###### Macrosomia

Treatment for GDM was associated with decreased risk of macrosomia (greater than 4,000 grams) versus no treatment (8 trials, N=3,644; RR, 0.53 [95% CI, 0.41 to 0.68]; I^2^=42%; ARD, 8.9% fewer [95% CI, 12.0 to 5.9])^41,42,224–226,229,232,236^ (Figure 28). The magnitude of effect remained similar in all sensitivity analyses (Appendix D Table 10). For macrosomia defined as greater than 4,500 grams, the estimate suggested decreased risk with treatment but was imprecise (3 RCTs, N=1,066; RR, 0.72 [95% CI, 0.39 to 1.35]; I^2^=0%)^226,230,236^ (Appendix C Figure 28).

Figure 28 Meta-Analysis of Trials: Macrosomia (>4,000 g), Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Figure 28 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for macrosomia (>4000g). Our meta-analysis (8 trials, 3644 subjects) found the pooled relative risk was 0.53 with a 95% CI of 0.41 to 0.68; I2=42%.

###### Large for Gestational Age

Seven trials consistently found treatment for GDM associated with decreased risk of LGA versus no treatment (N=3,329; RR, 0.56 [95% CI, 0.47 to 0.66]; I^2^=0%; ARD, 8.4% fewer [95% CI, 10.8 to 6.1])^41,42,225,229,230,232,236^ (Figure 29).

Figure 29 Meta-Analysis of Trials: Large for Gestational Age, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Figure 29 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for large for gestational age. Our meta-analysis (7 trials, 3329 subjects) found the pooled relative risk was 0.56 with a 95% CI of 0.47 to 0.66; I2=0%.

###### Admission to Neonatal Intensive Care Unit

Treatment for GDM was associated with reduced risk for NICU admissions versus no treatment (5 trials, N=1,600; RR, 0.73 [95% CI, 0.53 to 0.99]; I^2^=0%; ARD, 2.0% fewer [95% CI, 4.5 fewer to 0.5 more])^42,225,229,230,232^ (Figure 30). One large (n=1,000) trial found treatment associated with increased risk of neonatal nursery admissions (70.5 vs. 61.3%; RR, 1.15 [95% CI, 1.05 to 1.26]).^41^

Figure 30 Meta-Analysis of Trials: NICU Admission, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel; NICU = neonatal intensive care unit

Figure 30 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM and NICU admission. Our meta-analysis (5 trials, 1600 subjects) found the pooled relative risk was 0.73 with a 95% CI of 0.53 to 0.99; I2=0%.

###### Respiratory Distress Syndrome

Only two RCTs reported on this outcome; one estimate favored treatment^42^ and the other favored no treatment^41^ (Appendix C Figure 29). Pooled results found no association but were limited by heterogeneity and imprecision (RR, 1.05 [95% CI, 0.48 to 2.28]; I^2^=58%).

###### Neonatal Hypoglycemia or Hyperbilirubinemia

Five trials found no association between treatment for GDM versus no treatment and hypoglycemia (any severity), although there was some imprecision (N=2,238; RR, 1.10 [95% CI, 0.83 to 1.45]; I^2^=0%).^42,225,226,232,236^ Findings from sensitivity analyses were similar to the main analysis. Two good-quality RCTs^41,42^ found no association between treatment at or after 24 weeks’ gestation versus no treatment and increased risk of hypoglycemia requiring intravenous treatment, although the estimate was imprecise (N=981; RR, 1.02 [0.60 to 1.76]; I^2^=58%) (Table 15). Findings were very similar for hyperbilirubinemia (5 RCTs, N=2,564; RR, 0.84 [95% CI, 0.65 to 1.08]; I^2^=0%).^41,42,225,226,230^ (Appendix C Figures 30 and 31).

###### APGAR Scores

One trial reported on APGAR scores below 7 at 1 minute; findings were imprecise with zero events in the treatment group and seven in the group receiving a minimal intervention (n=700; RR, 0.07 [95% CI, 0.00 to 1.24]).^236^ Findings were similar and consistent for scores above 7 at 5 minutes reported in two RCTs (N=1,231; RR, 0.62 [95% CI, 0.27 to 1.41]; I^2^=0%)^41,232^ (Appendix C Figure 32).

##### Long-term Maternal Outcomes

###### Long-Term Intermediate Outcomes: Metabolic Impairment and Obesit

A followup study to one of the included RCTs^42^ (n=457; 48% of the original study population) found no association between treatment versus no treatment and reduced risk of impaired fasting glucose (RR, 1.08 [95% CI, 0.79 to 1.47]), obesity (RR, 1.09 [95% CI, 0.87 to 1.38]), or metabolic syndrome (RR, 0.93 [95% CI, 0.71 to 1.22]) at a median 7 years’ followup (Table 16).^241^ Findings for metabolic syndrome were very similar after adjusting for race/ethnicity and time since diagnosis.

Table 16 Effects from Trials of Treatment vs. No Treatment for GDM at 24 Weeks’ Gestation or Later on Long-Term Outcomes (KQ6)

Outcome | Number of Trials | Number of Events/Treated | Number of Events/Untreated | Relative Risk [95% CI]; I^2^ (unless stated otherwise) | Absolute Risk Difference for Significant Findings [95% CI]
Childhood overweight or obese (BMI ≥85^th^ percentile)(4-10 years) | 2^242,243^ | 117/358 | 120/341 | 0.96 [0.69 to 1.33]; 49% | NA
Childhood obesity (BMI ≥95^th^ percentile) (5-11 years) | 2^242,244^ | 63/297 | 62/288 | 1.02 [0.66 to 1.59]; 24% | NA
Childhood metabolic impairment | 1 (IGT)^244^; 2 (IFG)^242,244^ | 4/47; 12/257 | 0/25; 13/205 | 4.88 [0.27 to 87.06]; 0.79 [0.37 to 1.69] | NA
Childhood development of T2DM | 2^242,244^ | 1/265 | 0/214 | NA | NA
Long-term maternal development of metabolic impairment (Impaired Fasting Glucose) | 1^241^ | 66/243 | 54/214 | 1.08 [0.79 to 1.47]; NA | NA
Long-term maternal development of T2DM (5-10 years) | 1^241^ | 21/243 | 17/214 | 1.09 [0.59 to 2.01]; NA | NA
Long-term maternal development of metabolic syndrome (5-10 years) | 1^241^ | 73/243 | 69/214 | 0.93 [0.71 to 1.22]; NA; After adjustment for race-ethnicity and time since diagnosis: 0.95 [0.73 to 1.25] | NA
Long-term maternal obesity (≥30kg/m^2^) | 1^241^ | 98/243 | 79/214 | 1.09 [0.87 to 1.38]; NA | NA

Abbreviations: BMI = body mass index; CI = confidence interval; GDM = gestational diabetes mellitus; IFG = impaired fasting glucose; IGT = impaired glucose tolerance; NA = not applicable; T2DM = type 2 diabetes mellitus

###### Long-Term Health Outcomes

The long-term followup from an RCT described above also found no association between treatment versus no treatment and risk of T2DM, though the estimate was imprecise (RR, 1.09 [95% CI, 0.59 to 2.01]).^241^ No study measured long-term quality of life, cardiovascular outcomes, or mortality or major morbidity from T2DM.

##### Long-Term Childhood Outcomes

###### Long-Term Intermediate Outcomes: Obesity and Metabolic Impairment

Three trials reported long-term followup of children born to mothers with GDM.^242–244^ There was no association between maternal treatment versus no treatment and risk of childhood overweight over 4 to 10 years (2 studies, N=699; RR, 0.96 [95% CI, 0.69 to 1.33]; I^2^=49%),^242,243^ or obesity over 5 to 11 years (2 studies, N=585; RR, 1.02 [95% CI, 0.66 to 1.59]; I^2^=24%)^242,244^ (Appendix C Figures 33 and 34). Two studies reported imprecise estimates for impaired fasting glucose^242,244^ and impaired glucose tolerance^244^ over 5 to 11 years.

###### Long-Term Health Outcomes

Two studies reported only one case of childhood T2DM after 5 to 11 years^242,244^ (Table 16). No study measured cardiovascular outcomes or neurocognitive outcomes.

#### Treatment in Early Pregnancy

Four trials^231,233–235^ on early treatment (before 14 or 15 weeks’ gestation) versus usual care (i.e., screening at 24-28 weeks with treatment if diagnosed with GDM) reported on excessive weight gain in pregnancy and several short-term health outcomes including preeclampsia, hypertensive disorders in pregnancy, cesarean deliveries, induction of labor, preterm delivery, shoulder dystocia, macrosomia, LGA, NICU admissions, hypoglycemia, and hyperbilirubinemia. However, findings for all outcomes were highly imprecise (largest analysis N=229 with few events) (Tables 17 and 18 and Appendix C Figures 35 to 50).

Table 17 Effects from Trials of Treatment vs. No Treatment for GDM in Early Pregnancy on Pregnancy Outcomes (KQ6)

Outcome | Number of Trials | Number of Events/Treated | Number of Events/Untreated | Relative Effects [95% CI]; I^2^ | Absolute Risk Difference for Significant Findings [95% CI]
Preeclampsia | 3^231,233,235^ | 4/109 | 8/120 | 0.69 [0.21, 2.23]; 0% | NA
Gestational hypertension | 2^233,235^ | 7/74 | 12/90 | 0.75 [0.31, 1.84]; 0% | NA
Hypertensive disorders of pregnancy | 3^233–235^ | 14/85 | 17/99 | 0.92 [0.46, 1.81]; 0% | NA
Cesarean delivery | 4^231,233–235^ | 34/107 | 41/121 | 0.91 [0.56, 1.48]; 35% | NA
Primary cesarean delivery | 1^233^ | 5/37 | 10/37 | 0.50 [0.19, 1.32]; NA | NA
Emergency cesarean delivery | 3^231,234,235^ | 12/70 | 16/84 | 0.81 [0.37, 1.78]; 11% | NA
Induction of labor | 3^231,233,234^ | 33/71 | 27/67 | 1.12 [0.76, 1.67]; 3% | NA
Preterm delivery | 2^231,235^ | 3/59 | 3/75 | 1.27 [0.27, 6.07]; 0% | NA
Excessive gestational weight gain | 2^233,235^ | 15/70 | 31/89 | 0.65 [0.37, 1.15]; 6% | NA

Abbreviations: CI = confidence interval; NA = not applicable

Table 18 Effects from Trials of Treatment vs. No Treatment for GDM in Early Pregnancy on Fetal/Neonatal Outcomes (KQ6)

Outcome | Number of Trials | Number of Event/Treated | Number of Events/Untreated | Relative Effects [95% CI]; I^2^ (RR unless otherwise) | Absolute Risk Difference of Significant Findings [95% CI]
Mortality | 3^231,233,234^ | 0/71 | 2/67 | Peto OR 0.12 [0.01 to 1.95] | NA
Birth injury | 1^231^ | 0/23 | 0/21 | Not estimable | NA
Shoulder dystocia | 3^231,234,235^ | 0/70 | 2/84 | Peto OR 0.11 [0.00 to 5.57 | NA
Macrosomia (>4000g) | 2^233,235^ | 15/73 | 21/91 | 0.89 [0.33, 2.42]; 42% | NA
Macrosomia (>4500g) | 1^235^ | 0/36 | 3/54 | 0.21 [0.01, 3.99]; NA | NA
Large for gestational age | 3^231,234,235^ | 8/70 | 13/84 | 0.68 [0.18, 2.54]; 35% | NA
NICU admission | 3^231,234,235^ | 10/70 | 12/84 | 0.98 [0.28, 3.43]; 29% | NA
Any hypoglycemia | 3^231,233,234^ | 10/63 | 6/60 | 1.77 [0.62, 5.03]; 0% | NA
Hyperbilirubinemia | 2^231,233^ | 10/59 | 6/57 | 1.57 [0.65 to 3.82]; 0% | NA

Abbreviations: CCT = controlled clinical trial; CI = confidence interval; NA = not applicable; NICU = neonatal intensive care; OR = odds ratio; RR = relative risk

#### Subgroup Effects Based on Maternal Characteristics

##### Timing of Diagnosis

A secondary analysis of one RCT (n=932; 97% of RCT population)^240^ found no interaction between timing of treatment initiation and cesarean deliveries, NICU admissions, or LGA. Although there was an interaction between timing of treatment initiation and hypertensive disorders, there was not a clear time trend (e.g., progressively earlier treatment initiation was not associated with progressively decreased risk) (Appendix D Tables 9 and 10).

##### Criteria for Diagnosis/Glycemic Severity

Subgroup analyses of one RCT (n=931)^239^ showed no impact of different criteria (i.e., NDDG vs. CC excluding NDDG, all with FPG under 95 mg/dL) for diagnosis/glycemic severity on various maternal, pregnancy, and neonatal outcomes (Appendix D Tables 9 and 10). Three of the included trials (N=483)^224,225,229^ had eligibility criteria of lower levels of glycemia (i.e., OGCT positive); sensitivity analysis in which these trials were removed did not change conclusions (Appendix D Tables 9 and 10). Of three large trials,^41,42,236^ with inconsistency in findings for preeclampsia and hypertensive disorders in pregnancy (Figures 22 and 23), one^236^ used more inclusive criteria than the others for eligibility (i.e., IADPSG which uses OAV for diagnosis), though levels of FPG were slightly higher (i.e., 91 vs. 86.5 mg/dL) and 2-hour postload levels similar (i.e, 151 vs. 153^41^ and 173 mg/dL^42^) at baseline between trials so this variable did not seem to explain the inconsistency. Baseline glycemia was similar between groups in all three trials.

##### BMI

One trial^238^ found no interaction between BMI and effects of treatment on LGA (Appendix D Table 10). Sample sizes in some of the BMI categories were very small.

##### Race/Ethnicity

One RCT^237^ compared effects of treatment for GDM in for Hispanic (n=371) and non-Hispanic white women (n=397). It found no significant subgroup effects for hypertensive disorders in pregnancy, preterm delivery, macrosomia, LGA, NICU admissions, any hypoglycemia, and hyperbilirubinemia (Appendix D Tables 9 and 10).

Early treatment studies. Estimates from one RCT were too imprecise to determine interactions between BMI and early treatment versus usual care^233^ (Appendix D Tables 11 and 12).

## Key Question 7 What Are the Harms of Treatment of GDM, Including Severe Maternal and Neonatal Hypoglycemia, Delivery of Neonates Who Are Small for Gestational Age, and Poor Long-Term Growth and Development Outcomes in the Child?

### Summary

- Treatment at 24 week’s gestation or later is probably not associated with increased risk of SGA; findings for maternal hypoglycemia were imprecise.
- Findings from small RCTs of early treatment versus usual care were imprecise or not reported (maternal hypoglycemia).
- Treatment at 24 or greater weeks’ gestation was associated with a large reduction in macrosomia (RR, 0.53 [95% CI, 0.41 to 0.68]) but no association with total cesarean deliveries (RR, 0.95 [95% CI, 0.83 to 1.08]). Because these outcomes would be expected to have an effect in the same direction, some cesareans that could have been avoidable due to the effects of improved glycemia in reducing macrosomia may still have been undertaken.

### Evidence

Data for the trials included for Key Question 6 also addressed harms from treatment for GDM (Tables 12 and 13, and Appendix B Table 14).

#### Maternal Hypoglycemia

One RCT (n=69)^230^ that allocated women with GDM (fasting under 7.0 mmol/L or 2-hour value 10.0 to less than 12.2 mmol/L) to treatment including insulin as needed (61% in treatment group) or to routine care reported that no women in either group had severe hypoglycemia (requiring the assistance of another person).

#### Small for Gestational Age and Low Birth Weight

Treatment at or after 24 weeks’ gestation was not associated with increased risk of SGA versus no treatment (6 trials, N=2,646; RR, 1.10 [0.83 to 1.47]; I^2^=0%)^41,42,224,225,229,232^ (Appendix C Figure 51). Findings were similar, with slightly fewer events in the treated group, in one large trial^41^ that reported fairly high use of insulin in the treatment group (i.e., 20% vs. 3% in controls). Subgroup analyses of one RCT^42^ also found no difference in risk of SGA based on ethnicity (Hispanic versus non-Hispanic white women)^237^ or glycemic status^239^ (Appendix D Table 13). One RCT found no association between treatment and risk of low birth weight (n=700; RR, 1.06 [95% CI, 0.52 to 2.20])^236^ (Table 19). Two of the early treatment RCTs (n=64) reported on small for gestational age, but findings were highly imprecise (Appendix C Figure 52).^231,234^

Table 19 Harms From Trials of Treatment vs. No Treatment for GDM (KQ7)

Outcome | Number of Trials with Events | Number of Events/Treated (n/N) | Number of Events/Untreated | Relative Effects (RR) [95% CI]; I^2^ | Absolute Risk Difference [95% CI]
Small for gestational age | 6^41,42,224,225,229,232^ | 92/1317 | 84/1329 | 1.10 [0.83 to 1.47]; 0% | NA
Low birthweight | 1^236^ | 14/339 | 14/361 | 1.06 [0.52 to 2.20]; NA | NA

Abbreviations: CI = confidence interval; NA = not applicable; RR = relative risk

#### Cesarean Deliveries

Interpreting effects of treatment on cesarean deliveries requires consideration of effects on macrosomia. A cohort study^75^ on the association between a GDM diagnosis and cesarean deliveries in discussed in Key Question 2.

Eight RCTs (N=3,583) of treatment at 24 weeks’ gestation or later reported on rates of total cesarean deliveries and nine reported on macrosomia (>4,000g in 8 RCTs and >4,500g in 1 RCT).^41,42,224–226,229,230,232,236^ Comparing pooled results, there was a large association with reduced risk of macrosomia (>4,000 g, N=3,614; RR, 0.53 [95% CI, 0.41 to 0.68]; I^2^=42%) but no association with risk of total cesarean deliveries (N=3,582; RR, 0.95 [95% CI, 0.83 to 1.08]; I^2^=43%). Results within individual studies agree with this finding (Appendix D Table 14). When examining data on primary cesarean deliveries, where macrosomia may contribute more as an indicator, findings (primarily from one trial^42^) indicated a reduction in risk of both cesarean deliveries and macrosomia, but less so for primary cesarean deliveries. Findings from RCTs of early treatment versus usual care were too inconsistent and imprecise to determine effects on likelihood of cesarean deliveries.^231,233–235^

#### Poor Long-Term Growth and Development Outcomes in the Child

None of the trials reported on these outcomes.

## Contextual Questions

### Contextual Question 1 What Is the Association Between Measures of Serum Glucose (e.g., Fasting and Postload Glucose Concentrations, Percent HbA1c) and Outcomes, and Does It Differ Based on Timing of Measurement?

We examined one 2016 systematic review (including 28 studies with up to 64,851 participants and most studies from high-income Western countries)^24,245^ and five studies having adjusted analyses (N=31,945 participants)^246–250^ that addressed the associations between glucose levels and health outcomes in women not treated for hyperglycemia. The systematic review and four studies evaluated hyperglycemia based on serum blood glucose and one study based on serum HbA1c. All findings are likely only applicable to the standard timing of GDM screening at 24 weeks’ gestation or later.

#### Serum Glucose and Pregnancy Outcomes

Tables 20 and 21 provide a summary of unadjusted and adjusted results for pregnancy outcomes from the systematic review.^24,245^ Postload glucose concentrations had positive linear associations (ORs 1.19 to 1.37 per mmol/L increase in serum glucose) with preeclampsia; findings for hypertensive disorders in pregnancy and cesarean delivery were inconsistent but suggest there may associations. Associations with increasing FPG were stronger for these three outcomes (ORs 1.6 to 2.15). For preterm delivery, no associations with postload glucose values (after adjustment for confounders) were found in the review; an adjusted analysis for FPG also found no association. Few studies in the review reported on labor induction, but significant associations were found for FPG (OR 1.31) and postload serum glucose (ORs 1.1 to 1.3). Adjusted analyses from the review for all outcomes and associations with serum glucose indicated that associations remained but attenuated particularly between FPG values and preeclampsia (aOR 1.58). The review found that there was no clear evidence of a threshold effect. Studies published since the review also found linear associations between hypertensive disorders in pregnancy and postload serum glucose (n=1,360 untreated women in a large blinded GDM treatment RCT)^249^ or FPG (n=5,230 women from Spain),^248^ but no associations between cesarean delivery and serum values 1 hour after the OGCT (n=158 black U.S. women)^246^ or based on FPG (n=5,230 women from Spain).^248^ Findings from the study in Spain^248^ agreed with those from the review on prematurity.

Table 20 Contextual Question 1 Evidence, Pooled Odds Ratio (95% Confidence Interval) for Associations Between a 1-mmol/L Increase in Glucose Concentration and Pregnancy Outcomes, by Test^*^

Test | Preeclampsia | | Hypertensive disorders of pregnancy | | Cesarean delivery | | Preterm delivery | | Induction of labor
Test | Study count; N | OR [95% CI] | Study count; N | OR [95% CI] | Study count; N | OR [95% CI] | Study count; N | OR [95% CI] | Study count; N | OR [95% CI]
1-h post-50g OGCT | 6; 58,270 | 1.25 [1.13 to 1.39] | 1; 1,157 | 1.02 [0.75 to 1.38] | 7; 36,616 | 1.35 [1.23 to 1.49] | 2; 27,126 | 1.06 [0.96 to 1.17] | 1; 13,902 | 1.30 [1.20 to 1.41]
Fasting (before 75g or 100g load) | 4; 39,345 | 2.15 [1.45 to 3.19] | 3; 5,551 | 1.91 [1.49 to 2.43] | 6; 47,746 | 1.59 [1.49 to 1.70] | 3; 17,257 | 0.77 [0.62 to 0.96] | 2; 12,484 | 1.31 [1.14 to 1.50]
1-h post-load (75g or 100g)** | 2; 22,732 | 1.19 [1.15 to 1.24] | - | - | 2; 24,684 | 1.18 [1.15 to 1.20] | - | - | - | -
2-h post-75g OGTT | 3; 35,720 | 1.22 [1.14 to 1.30] | 2; 4,174 | 1.21 [1.08 to 1.35] | 7; 41,130 | 1.10 [0.98 to 1.24] | 5; 18,816 | 1.07 [1.00 to 1.15] | 2; 12,485 | 1.11 [1.03 to 1.19]
2-h post-100g OGTT | 1; 3,628 | 1.37 [1.14 to 1.65] | 1; 1,358 | 1.14 [0.96 to 1.35] | 2; 3,915 | 1.14 [1.04 to 1.25] | 1; 249 | 0.87 [0.41 to 1.87] | - | -
2-h post-load (75g or 100g)** | 4; 39,348 | 1.23 [1.18 to 1.29] | 3; 5,532 | 1.19 [1.08 to 1.30] | 9; 45,045 | 1.10 [0.96 to 1.25] | 6; 19,065 | 1.07 [0.99 to 1.15] | 2; 12,485 | 1.10 [1.04 to 1.16]

Abbreviations: CI = confidence interval; g = gram; h = hour; N = number; OGCT = oral glucose challenge test; OGTT = oral glucose tolerance test; OR=odds ratio

* Adapted From Farrar et al.^24,245^

Table 21 Pooled Adjusted^*^ Odds Ratios [95% Confidence Interval] for Associations Between a 1-mmol/L Increase in Glucose Concentration From Three Cohorts^†^

Test | Preeclampsia | Cesarean delivery | Preterm delivery | Macrosomia | LGA | Shoulder dystocia
Fasting | 1.58 [1.38 to 1.81] | 1.26 [1.17 to 1.35] | 0.93 [0.71 to 1.23] | 1.90 (1.64 to 2.20) | 1.84 (1.60 to 2.12) | 1.68 (1.32 to 2.13)
2-h post-75g OGTT | 1.16 [1.06 to 1.27] | 1.06 [1.03 to 1.08] | 1.11 [1.02 to 1.20] | 1.12 (1.05 to 1.20) | 1.09 (1.04 to 1.15) | 1.19 (1.10 to 1.27)

Abbreviations: CI = confidence interval; g = gram; h = hour; LGA = large for gestational age; OGTT = oral glucose tolerance test

* The review authors analyzed individual patient data from two cohorts, and adjusted for BMI, age, ethnicity; for the HAPO cohort all models adjusted for field center, age, BMI, height, smoking status, alcohol use, family history of diabetes, gestational age at OGTT, infant’s sex, hospitalization before delivery, mean arterial pressure, parity (not included in primary cesarean delivery model), cord-blood plasma glucose level. These findings were combined with adjusted analysis from the HAPO cohort

† Adapted from Farrar et al.^24,245^

#### Serum Glucose and Fetal/Neonatal Outcomes

Tables 21 and 22 provide a summary of adjusted and unadjusted results for fetal outcomes from the systematic review.^24,245^ Macrosomia and LGA were associated with postload serum glucose values (ORs 1.14 to 1.32) and, to a greater extent, with FPG (ORs 2.06 and 2.11). Review findings for shoulder dystocia and neonatal hypoglycemia also showed linear associations with postload and fasting glucose values, although FPG may not have as strong of n association with hypoglycemia (OR 1.37). Associations with macrosomia, LGA, and shoulder dystocia were larger for FPG than after a glucose load. The observed associations persisted in adjusted analyses from the review for all outcomes and associations with serum glucose. Similar to pregnancy outcomes, the review did not find a clear threshold effect. Subsequently published studies also found a significant linear association for LGA across values during the 3-hour OGTT^249^ and for FPG.^248^ No association (n=5,203) was found between FPG and macrosomia in one study;^248^ another study (n=1,360)^249^ only found associations between shoulder dystocia and postload glucose concentrations, but not FPG.

Table 22 Contextual Question 1 Evidence, Pooled Odds Ratio (95% Confidence Interval) for Associations Between a 1-mmol/L Increase in Glucose Concentration and Fetal Outcomes, by Test^*^

Test | Macrosomia | | LGA | | Shoulder dystocia | | Neonatal hypoglycemia
Test | Study count; N | OR [95% CI] | Study count; N | OR [95% CI] | Study count; N | OR [95% CI] | Study count; N | OR [95% CI]
1-h post-50g OGCT | 7; 64,851 | 1.14 [1.10 to 1.18] | 4; 30,626 | 1.32 [1.19 to 1.46] | 2; 27,688 | 1.26 [1.10 to 1.43] | 3; 15,619 | 1.38 [1.00 to 1.92]
Fasting (before 75g or 100g load) | 6; 28,303 | 2.06 [1.86 to 2.28] | 7; 46,680 | 2.11 [1.73 to 2.58] | 4; 18,615 | 1.97 [1.36 to 2.85] | 2; 19,998 | 1.37 [1.20 to 1.57]
1-h post-load (75g or 100g) ^†^ | - | - | 2; 24,684 | 1.24 [1.20 to 1.27] | - | - | - | -
2-h post-75g OGTT | 5; 19,524 | 1.19 [1.14 to 1.25] | 9; 48,321 | 1.20 [1.13 to 1.28] | 3; 17,260 | 1.41 [1.03 to 1.92] | 2; 19,998 | 1.13 [1.09 to 1.18]
2-h post-100g OGTT | 2; 3,877 | 1.29 [1.15 to 1.44] | 2; 1,645 | 1.35 [1.17 to 1.55] | 2; 1,645 | 1.56 [1.21 to 1.99] | 1; 287 | 1.09 [0.66 to 1.80]
2-h post-load (75g or 100g) * | 7; 23,401 | 1.21 [1.16 to 1.26] | 11; 49,966 | 1.22 [1.19 to 1.25] | 5; 18,905 | 1.38 [1.22 to 1.56] | 3; 20,285 | 1.13 [1.09 to 1.18]

Abbreviations: LGA = large for gestational age; OGTT = oral glucose tolerance test; OR=odds ratio

* Adapted from Farrar et al.^24,245^

† Too few studies precluded pooled analysis of 1-hour postload glucose levels for the 75g OGTT and 100g OGTT. Combining glucose levels from the 75g and 100g OGTT led to similar findings to those from the 75g OGTT alone, aligning with assumptions that the associations between glucose and outcomes will be the same for both tests

#### Serum Glucose and Long-Term Childhood Outcomes

A followup of 4,160 children enrolled in the multinational HAPO cohort found few (n=10) events of T2DM at 10 to 14 years of age.^247^

#### Serum HbA1c and Pregnancy Outcomes

Analysis of data from the multinational HAPO cohort (n=21,062)^250^ found associations between a 1 SD increase in HbA1c (0.4%) and preeclampsia (OR, 1.27 [95 CI, 1.19 to 1.37]), primary cesarean deliveries (OR, 1.09 [95% CI, 1.04 to 1.13]), and preterm delivery (OR, 1.17 ]95 CI, 1.10 to 1.24]).^250^ The magnitudes of association were similar to those for a 1 SD increase in serum glucose from the 2-hour OGTT results.

#### Serum HbA1c and Fetal/Neonatal Outcomes

In the HAPO cohort,^250^ associations were found between HbA1c and the outcomes of LGA and clinical neonatal hypoglycemia (ORs per 1 SD increase 1.15 [95% CI, 1.09 to 1.21] and 1.13 [95% CI, 1.02 to 1.25], respectively). The association for LGA was smaller than those found for serum glucose values from the 2-hr OGTT (ORs for FPG, 1-hour, and 2-hour values were 1.39, 1.45, and 1.38, respectively).

### Contextual Question 2 What Is the Association Between GDM Diagnosed Before 24 Weeks of Gestation and Outcomes, and Does It Differ Based on Screening Strategy, Timing of Diagnosis, and Severity of Risk Factors?

One retrospective cohort study (n=2,780)^67^ examined in Key Question 1 comparing screening versus no screening found the association for reduced risk of NICU admission more pronounced for women screened in the first versus second trimester (RR, 0.57 [95% CI, 0.48 to 0.69] vs. RR, 0.78 [95% CI, 0.66 to 0.92], respectively; subgroup effect p=0.05). The effects for other outcomes were not significant, and findings were not adjusted for important confounders.

One small U.S. RCT (n=202 with 22% early dropout) compared early (under 15 weeks’ gestation) versus later (at 28 weeks) treatment for women with hyperglycemia in early pregnancy.^251^ A similar number of women in each group required oral medication or insulin use (34.2 vs. 33%; p=0.84). No significant differences between arms were found for macrosomia (1.5% vs. 5.0%; p=0.84) or cesarean delivery (31.0% vs. 27.0%; p=0.64).

Four small trials from Key Question 6 allocated women with hyperglycemia early in pregnancy to treatment or usual care.^231,233–235^ All findings were highly imprecise (largest analysis N=229 with rare events), precluding any reliable conclusions.

A 2017 systematic review included 13 cohort studies (N=15,260) evaluating outcomes in women treated for GDM before 24 weeks’ gestation versus women treated later.^252^ Table 23 provides a summary of results from the systematic review. In meta-analyses, women treated early were at higher risk for perinatal mortality (RR 3.58) and neonatal hypoglycemia (RR 1.61) than women treated later. Likelihood of insulin use was significantly greater among early-onset women (RR 1.71) indicating more severe hyperglycemia. Event rates were higher with early treatment for some other outcomes (hypertensive disorders in pregnancy, shoulder dystocia, SGA) but these associations were not statistically significant. No associations were seen for cesarean delivery, LGA, macrosomia, NICU admissions, preterm delivery, hyperbilirubinemia, or respiratory distress syndrome. Findings are difficult to interpret because analyses did not account for confounders and because of heterogeneity between studies. The largest included study from that review (n=4873)^253^ found no independent association for risk of LGA and macrosomia when adjusting for confounders.

Table 23 Contextual Question 2 Evidence, Pooled Estimates for the Association Between Timing of GDM Diagnosis and Outcomes^*^

Outcome | Study Count; Total N | Relative Risk [95% Confidence Interval] | Absolute Risk Difference for Early vs. Late Treatment of GDM | Quality of Evidence (GRADE)^†^
Hypertensive disorders in pregnancy | 10, N=10,091 | 1.34 [0.98 to 1.82] | 32 more per 1000 (2 less to 76 more) | Very low; (I^2^=73%; selective screening of high-risk women in few studies)
Caesarean delivery | 9, N=9,685 | 1.09 [0.94 to 1.26] | 28 more per 1000 (19 fewer to 81 more) | Very low; I^2^=76%
LGA | 7, N=9,622 | 1.07 [0.86 to 1.35] | 13 more per 1000 (26 fewer to 66 more) | Low
Macrosomia | 10, N=9,966 | 1.05 [0.77 to 1.41] | 5 more per 1000 (25 fewer to 44 more) | Low
Shoulder dystocia | 2, N=2,936 | 1.76 [0.96 to 3.24] | 12 more per 1000 (1 fewer to 26 more) | Very low; Few events
SGA | 5, N=5,900 | 1.27 [0.92 to 1.75] | 20 more per 1000 (6 fewer to 55 more) | Low
NICU admission | 5, N=7,992 | 1.16 [0.90 to 1.49]; Developed countries (4 studies):; 1.12 [1.04 to 1.22] | 33 more per 1000 (21 fewer to 102 more) | Low
Preterm delivery | 7, N=7,039 | 1.16 [0.84 to 1.61] | 13 more per 1000 (13 fewer to 49 more) | Low
Neonatal hypoglycemia | 7, N=6,818 | 1.61 [1.02 to 2.55]; Developed countries:; 1.47 [0.82 to 2.64]; 5 | 82 more per 1000 (3 more to 207 more | Low
Hyperbilirubinemia | 7, N=9,231 | 1.16 [0.91 to 1.48] | 21 more per 1000 (12 fewer to 62 more) | Low
Respiratory distress syndrome | 5, N=6,351 | 1.00 [0.76 to 1.32] | 0 fewer per 1000 (9 fewer to 12 more) | Very low; Few events
Perinatal mortality | 7, N=9,130 | 3.58 [1.91 to 6.71]; Developed countries (6 studies):; 3.61 [1.90 to 6.84] | 6 more per 1000 (2 more to 14 more) | Low

Abbreviations: ADHD = Attention-deficit and Hyperactivity Disorder; ASD = Autism Spectrum Disorder; GRADE = Grading of Recommendations, Assessment, Development, and Evaluation; GA = gestational age; HDP = hypertensive disorders of pregnancy; LGA = large for gestational age; OR = odds ratio; RDS = respiratory distress syndrome; RD = risk difference; RR = risk ratio; SGA = small for gestational age

* Adapted from Immanuel and Simmons^252^

† As determined by authors; observational studies stared at low quality

Four additional retrospective cohort studies (total N=3,461) from the United States^254–256^ and Ireland^257^ with adjusted analyses were examined. All studies included selectively screening high-risk women in early pregnancy. Results suggest there may be large increased risks for some pregnancy and neonatal outcomes, though there was some inconsistency. In one U.S. cohort of 1,369 women with GDM (167 [12.3%] diagnosed prior to 24 weeks gestation [early]), a significant increased risk of macrosomia was found among women with early-onset GDM (aOR, 2.0 [95% CI, 1.00 to 4.15]) but no differences were found for other outcomes (including preterm delivery, LGA, hypertensive disorders of pregnancy, NICU admission, and neonatal morbidity composite).^254^ One of the other U.S. studies found no significant associations for risk of cesarean delivery, preeclampsia, macrosomia, LGA, SGA, or birth injury between women screened and diagnosed (n=85) early in pregnancy (before 20 weeks’ gestation, via risk factors) and women screened and diagnosed (n=457) later.^255^ However, risk for preterm delivery was higher in women with early- versus late-GDM (aOR, 1.78 [95% CI, 1.01 to 3.15]). A U.S. study of obese (BMI greater than or equal to 30 kg/m^2^) women compared outcomes between a GDM diagnosis at or before 20 weeks’ gestation compared with after 20 weeks.^256^ Earlier GDM diagnosis was associated with an increased risk for NICU admission after accounting for BMI, age, gestational age, and chronic hypertension (aOR, 6.50 [95% CI, 1.37 to 30.83]), but there were no associations for several other outcomes including preterm delivery and macrosomia. In the study from Ireland (n=1,471), an early versus routine timing for GDM diagnostic tests was associated with an increased risk for gestational hypertension (aOR 2.3 [95% CI, 1.46 to 3.62), LGA (aOR 2.7 [95% CI, 1.82 to 4.05]), NICU admissions (aOR 1.83 [95% CI, 1.2 to 2.8), and preterm delivery (aOR 2.25 [95% CI, 1.14 to 4.43), but not with risk for preeclampsia or stillbirth.^257^

Over a median 5.5 years’ followup, one large U.S. multiethnic cohort study (n=322,323; 7.8% GDM-exposed) demonstrated an association between the development of autism spectrum disorder (ASD) among children (n=3,388 with ASD) when GDM was diagnosed at 26 weeks’ gestation or earlier versus no GDM diagnosis (aHR, 1.40 [95% CI, 1.14 to 1.72]), but not when GDM was diagnosed after 26 weeks’ gestation versus no GDM diagnosis (aHR, 0.86 [95% CI, 0.73 to 1.02]).^258^ Another study using the same cohort (n=333,182; 8.8% GDM-exposed) found no association between timing of GDM and subsequent attention-deficit and hyperactivity disorder (ADHD) in children (4 to 8.9 years old; n=17,415 with ADHD) after adjusting for potential confounders like gestational age at birth (p=0.16).^259^

### Contextual Question 3 What Are the Long-Term Health Consequences, for the Mother From a Diagnosis of GDM, and for the Child From Their Mother’s GDM Diagnosis, Neonatal Hypoglycemia, Shoulder Dystocia, or Fetal Overgrowth?

#### Long-Term Maternal and Childhood Health Consequences From GDM

For this section we examined studies on health outcomes occurring 6 months or longer after delivery in women diagnosed with GDM or their children. We prioritized studies that accounted in their analysis for key confounders (i.e., BMI for development of T2DM or CVD, gestational age at delivery for childhood neurocognitive outcomes). Most systematic reviews did not provide result based on adjusted study findings. Most studies examined were large and conducted in U.S.-relevant countries. All findings are in comparison with women without GDM.

#### Long-Term Health Consequences of GDM for the Mother

Six observational studies (over 62,000 women with previous GDM) consistently found that GDM was associated with increased risk of subsequent T2DM (aORs 5.44 to 22.6).^260–265^ The variation in magnitude of estimates may have been due to different followup periods (1 to 11.4 years with larger risk based on shorter periods), comparison groups (higher risk when compared with women who were not overweight), surveillance bias (i.e., more women with GDM screened/tested for T2DM), and different degrees of attrition. One of the studies (with median followup of 5.3 years) found that risk of T2DM was substantively elevated in women who were both overweight and had prior GDM, suggesting an interaction between these factors (incidence 36% vs 1.1%; aHR, 40.1 [95% CI, 34.4 to 46.6]).^261^ Three studies found statistically significant interaction effects indicating black women had a higher likelihood than non-Hispanic white women of incident T2DM after a GDM diagnosis.^260,264,265^

Seven retrospective cohort studies (237,993 women with previous GDM) suggested that GDM versus no GDM is associated with increased risk (aHRs 1.45 to 2.8) of ischemia heart disease and myocardial infarction over the long term; findings over the short term^266^ and for risks of stroke and heart failure were inconsistent.^260,261,263,266–269^ A systematic review that analyzed adjusted data for a composite CVD outcome, or from data on the most prevalent CVD outcome in each study, found that GDM associated with increased risk of CVD versus no GDM (9 studies, N= 5,390,591; aHR 1.59 [95% CI, 1.35 to 1.85], I^2^ = 86.3%).^270^ Risk for CVD outcomes may be mediated by development of T2DM; for example, one study found an increased risk of myocardial infarction in women with GDM who had developed T2DM was over double that for those who did not develop T2DM (aHR, 3.71 [95% CI, 1.70 to 7.67] vs. aHR, 1.32 [95% CI, 0.92 to 1.89]; both versus no GDM).^267^

Two small studies (n=2,046) found no association between GDM and risk of kidney disease.^271,272^ One large prospective cohort study from Israel (n=104,751; 9,888 with GDM) reported higher incidence of several ophthalmic outcomes (e.g., glaucoma, diabetic retinopathy, retinal detachment) in those with previous GDM versus no GDM after mean 12 years of follow-up (for ophthalmic morbidity: aHR, 2.1 [95% CI, 1.5 to 2.8]) (the risk was greater for those who had also experienced preeclampsia).^273^

#### Long-Term Health Consequences of Mother’s GDM for the Child

A followup of children born to mothers in the HAPO cohort (n=4,160) over 10 to 14 years found very few events (n=10) of T2DM,^262^ whereas two large Canadian studies (n=358,480^274^ and n=321,008^275^) reported increased risk for T2DM over 17.7 and 15.1 years (0.80 vs. 0.26 cases per 1000 person years and HR, 3.03 [95% CI, 2.44 to 3.76], respectively).^274^ These Canadian studies^274,275^ found that although First Nations status did not modify the risk for T2DM after exposure to GDM, the incidence of GDM has higher in First Nations women and the independent effects of both GDM and First Nation status for development of T2DM makes First Nations children particularly disproportionally affected. A population-based cohort study (n=216,197) found an association between a mother’s diet-controlled GDM (n=9,460) and increased risk of hospitalization for cardiovascular-related disease over 18 years (aHR, 1.6 [95% CI, 1.2 to 2.2]).^276^

Nine cohort studies examined childhood neurocognitive outcomes.^258,259,277–283^ Three cohort studies found no association when examining GDM overall and risk for ASD; although results suggested differential risk depending upon timing of GDM diagnosis and maternal prepregnancy BMI.^258,277,278^ Four studies did not find a clear association between exposure to GDM overall and development of ADHD in offspring, or consistent modification of risk based on maternal weight or timing of GDM diagnosis.^259,277,278,280^ Single studies found that severity of hyperglycemia^259^ and SES^280^ may impact the association between GDM and neurocognitive outcomes. Two cohort studies found no association between maternal GDM and early childhood intellectual disability (ID) (at 6^277^ and 3^281^ years) in multiethnic, low income populations. As with ASD, risk was mediated by maternal obesity. Four studies found no clear association between GDM and developmental delay (DD) though studies varied in respect of timing, outcomes and findings.^277,278,282,283^ As with other outcomes, risk may be mediated by maternal obesity.^277^

#### Long-Term Childhood Health Consequences From Neonatal Hypoglycemia, Shoulder Dystocia, or Fetal Overgrowth

In this section, we examine studies on associations between exposure to neonatal hypoglycemia, shoulder dystocia, or fetal overgrowth and risk for long-term health outcomes. We did not identify any studies that examined these exposures in children of mothers with GDM or that accounted for the mother’s GDM status. Large U.S-relevant studies that adjusted for important confounders were sought.

##### Long-Term Health Consequences for the Child From Neonatal Hypoglycemia

Table 24 presents results from a systematic review examining the association between neonatal hypoglycemia and long-term neurodevelopmental outcomes.^284^ Adjustment for confounders was not a study inclusion criterion although these results were used when available. No association was found between neonatal hypoglycemia and risk of neurodevelopment impairment (validated scales of developmental or intelligence) over 2 to 5 years, though associations (ORs 2 to 3.5) were found for visual-motor impairment and executive dysfunction (at 2 to 5 years), as well as low language and low numeracy (at 6 to 11 years). Studies reporting adjusted estimates were also available. A longitudinal prospective cohort study found no differences in a number of different neurodevelopmental outcomes at ages 2^285^ or 4.5^286^ years in over 400 children with or without neonatal hypoglycemia. This same study found that children who had neonatal hypoglycemia were at increased risk of visual impairment compared with those without neonatal hypoglycemia (aRR, 3.67 [95% CI, 1.15 to 11.69]); all other auditory, visual processing, emotional/behavioral difficulty and communication scores were not significantly different between groups. Secondary analyses of an RCT (n=745) that followed premature (37 or less weeks’ gestation) and low birthweight (2500g or greater) children found no differences in intellectual or academic achievement at 3, 8 and 18 years of age between those with and without neonatal hypoglycemia.^287^ Conversely, two studies found associations between exposure to neonatal hypoglycemia and lower proficiency in literacy and mathematics among children at 3.5 to 4 years (n=832; all premature)^288^ and 10 years of age (n=1,395).^289^

Table 24 Contextual Question 3 Evidence, Estimates for the Association Between Neonatal Hypoglycemia and Long-Term Neurodevelopmental Outcomes^*^

Outcome | Study Count, Total N | Odds Ratio [95% CI] | Quality of Evidence (GRADE)^†^
Early childhood (2-5 years); Neurodevelopmental impairment | 6, N=1,657 | 1.16 [0.86 to 1.57] | Very low; 4 studies high ROB in several domains; only 2 adjusted
Early childhood (2-5 years); Visual-motor impairment | 2, N=508 | 3.46 [1.13 to 10.57] | Low
Early childhood (2-5 years); Executive dysfunction | 1; N=463 | 2.50 [1.20 to 5.22] | Low
Early childhood (2-5 years); Any cognitive impairment | 3, N=746 | 1.11 [0.73 to 1.69] | Very low; 2 studies high ROB, 1 adjusted
Early childhood (2-5 years); Epilepsy | 4, N=772 | 1.93 [0.76 to 4.85] | Very low; 2 studies high ROB, results imprecise, 1 adjusted
Early childhood (2-5 years); Low language/literacy | 1, N=37 | 5.23 [0.26 to 105.50] | Very low
Mid-childhood (6-11 years); Neurodevelopmental impairment | 2, N=54 | 3.62 [1.05 to 12.42] | Very low; Both studies high ROB imprecise results
Mid-childhood (6-11 years); Visual-motor impairment | - | - | No data
Mid-childhood (6-11 years); Executive dysfunction | - | - | No data
Mid-childhood (6-11 years); Any cognitive impairment | - | - | No data
Mid-childhood (6-11 years); Epilepsy | - | - | No data
Mid-childhood (6-11 years); Low language/literacy | 1, N=1,395 | 2.04 [1.20 to 3.47] | Low
Mid-childhood (6-11 years); Low numeracy | 1, N=1,395 | 2.04 [1.21 to 3.44] | Low

Abbreviations: CI = confidence interval; ROB=risk of bias; GRADE=Grading of Recommendations Assessment, Development and Evaluation.

* Adapted from Shah et al.^284^

† As determined by Shah et al; all observational studies started at low certainty

##### Long-Term Health Consequences for the Child From Shoulder Dystocia

One study from Israel of children with (n=343) and without (n=206,388) shoulder dystocia found no differences in rates of hospitalizations for a variety of psychiatric and neurological disorders up to age 18.^290^

##### Long-Term Health Consequences for the Child From LGA or Macrosomia

One Australian study (n=449,857) found no association between increased risk of poorer developmental and educational outcomes at 4 to 7 and 7 to 9 years of age and being born LGA (n=49,439) versus appropriate for gestational age; in fact, LGA may have been associated with decreased risk.^291^ Another study from Canada (n=1,685) found no association between being born LGA (n=311) and poor verbal ability or externalizing behavior problems (hyperactivity/inattention, conduct disorder/physical aggression, and indirect aggression) at 4 to 5 years of age.^292^ Two cohort studies from the United States^277^ and Canada^293^ found no association between exposure to LGA or macrosomia and a variety of developmental disabilities (e.g., autism, intellectual disability, ADHD). One study of several European countries (n=10,468) examined associations between LGA/macrosomia at birth (n=1,340) and cardiovascular outcomes at 2 to 8 years of age, and found no differences in total cholesterol, HDLs, LDLs, triglycerides, or systolic and diastolic blood pressure.^294^

### Contextual Question 4 Are Postpartum Interventions Effective for Reducing Incidence of Long-Term Health Outcomes in Women Previously Diagnosed With GDM and/or Their Children?

#### Lifestyle Interventions

The most recent systematic review we identified included eight postpartum RCTs measuring incidence of T2DM from lifestyle interventions compared with usual care.^295^ Meta-analysis found a nonsignificant reduction in diabetes incidence over about 1 to 2 years among women with prior GDM who received various postpartum lifestyle interventions (most including diet and exercise) versus usual care (8 studies, N=1,742 [180 events]; RR, 0.75 [95% CI, 0.55 to 1.03]). Interventions that were initiated within 6 months of delivery were associated with reduced risk (5 studies, N=1,015; RR, 0.61 [95% CI, 0.40 to 0.94]). Two other RCTs not included in the review, from the United States (telephone intervention derived from Diabetes Prevention Program (DPP); n=2,280)^296^ and Canada,^297^ did not find an association between postpartum interventions and reductions in 12 month incidence of prediabetes or diabetes (n=2,280; HR, 0.90 [95% CI, 0.78 to 1.04]) or diabetes (n=97; OR, 0.12 [95% CI, 0.01 to 1.97]). The interventions were fairly intensive lifestyle programs; attrition was high in both trials.

A planned subgroup analysis of the U.S. DPP RCT comparing an intensive lifestyle program, metformin, and placebo with a standard lifestyle program examined development of T2DM over 3 years based on history of GDM (n=350 with and n=1,416 without).^298^ Compared with placebo, the intensive lifestyle program was associated with similar impact on risk reduction for T2DM in the GDM (n=117) and no GDM groups (n=465) (ARD, 53.4 vs. 49.2%, interaction p = 0.74). In another age-adjusted analysis after 10 years of followup, the DPP Outcomes Study (DPPOS) included 288 women with prior GDM (82% of original) and found that women who had been randomized to the lifestyle intervention were 35.2% (p<0.05) less likely to develop diabetes compared with those assigned to placebo, for a number needed to treat of 11.3 to prevent one case of diabetes in 10 years.^299^

#### Pharmacological Interventions

As described above, subgroup analysis of the DPP RCT found that women with prior GDM randomized to 850 mg of metformin twice daily were 50 percent less likely to develop diabetes over 3 years compared to similar women taking placebo (p=0.002).^298^ Metformin was associated with greater impact on risk reduction (compared with placebo) in the GDM compared with the no GDM group (n=465) (50.4 vs. 14.4%, interaction p = 0.06), despite similar glucose levels at baseline. After 10 years of followup, women randomized to metformin were 40.4 percent (p<0.05) less likely to develop diabetes compared with placebo (NNT=7.2 to prevent one case of diabetes in 10 years).^299^