# Chapter 2 Methods

## Considerations for This Update

The previous USPSTF recommendation mainly focused on the use of two-step screening approaches, and recognized the importance of accurate screening tests (e.g., 50 g OGCT, FPG) within these approaches. For this report, the complexity and variability in current practice and recommendations required additional examination related to one versus two-step screening approaches as well as which diagnostic criteria to apply within these approaches. To address more inclusive screening approaches (e.g., one-step IADPSG, one versus two abnormal values in two-step screening using CC or NDDG criteria), this report (i) focused its question on outcome associations to examine health outcomes for the additional women who would be diagnosed with GDM—without treatment and versus women with normal glucose tolerance—using these more inclusive screening approaches (i.e., indicating less severe hyperglycemia) rather than those most commonly used in the past (two-step CC or NDDG with two abnormal values), and (ii) added a question about outcomes from different screening approaches (one- vs. two-step, using IADSPG vs. CC criteria, timing in pregnancy [after or being 24 weeks’ gestation]). Further, for screening test accuracy within two-step screening approaches, this report focuses on the main screening tests (i.e., OGCT, FPG, HbA1c, risk-factors) and diagnostic criteria currently considered for use in the United States.

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,^56^ the Evidence-based Practice Centers developed the scope and Key Questions in collaboration with the USPSTF and AHRQ. The investigators created an analytic framework depicting the Key Questions and the patient populations, interventions, and outcomes reviewed (Figure 1). The research plan was externally reviewed and modified prior to finalization.

Figure 1 Analytic Framework and Key Questions

Abbreviations: GDM = gestational diabetes mellitus; IGT = impaired glucose tolerance; KQ = key question; T2DM = type 2 diabetes mellitus

* No assumptions will be made about whether hyperglycemia first discovered early in pregnancy (e.g., in the first trimester) is GDM or some other form of diabetes; the term GDM will be used to include all women with hyperglycemia but not meeting criteria for overt diabetes at any time point during pregnancy.

^†^ Screening using two-step (screening first and, when indicated, diagnostic tests second) or one-step (diagnostic tests only) strategies, each based on various criteria and thresholds, and offering treatment to patients diagnosed with GDM.

Key Questions:

1. a. Does screening for GDM reduce poor health outcomes? b. Does screening for GDM reduce poor intermediate outcomes? c. Does the effectiveness of screening for GDM vary according to maternal subgroup characteristics, including timing during pregnancy, previous GDM diagnosis, family history of type 2 diabetes mellitus, body mass index, age, or race/ethnicity?
2. What are the harms of screening for and diagnosis of GDM to the mother, fetus, or neonate?
3. a. What is the comparative effectiveness of different screening strategies for GDM on health outcomes? b. What is the comparative effectiveness of different screening strategies for GDM on intermediate outcomes? c. Does the comparative effectiveness of different screening strategies vary according to maternal subgroup characteristics, including timing during pregnancy, previous GDM diagnosis, family history of type 2 diabetes mellitus, body mass index, age, or race/ethnicity?
4. a. What is the diagnostic accuracy of commonly used screening tests for GDM?
  b. Does the accuracy of commonly used screening tests for GDM vary according to maternal subgroup characteristics, including timing during pregnancy, body mass index, age, race/ethnicity, or prevalence of GDM?
5. What is the association between diagnosis of GDM and outcomes in women meeting more inclusive but not less inclusive diagnostic criteria for GDM?
6. a. Does treatment of GDM during pregnancy reduce poor health outcomes? b. Does treatment of GDM during pregnancy reduce poor intermediate outcomes? c. Does the effectiveness of treatment of GDM vary according to maternal subgroup characteristics, including timing and criteria used for diagnosis during pregnancy, severity of hyperglycemia, body mass index, age, or race/ethnicity?
7. What are the harms of treatment of GDM, including severe maternal and fetal/neonatal hypoglycemia, delivery of neonates who are small for gestational age, and poor long-term growth and development outcomes in the child?

Figure 1 displays an analytical framework for the key questions evaluating screening for gestational diabetes mellitus. The figure displays a high level description of the populations, interventions, and outcomes related to KQs 1, 3, 5 and 6: intermediate outcomes (pregnancy: excessive weight gain during pregnancy), long-term outcomes for ≥6 months follow-up (maternal and childhood development of metabolic impairment (IGT) or obesity), health outcomes (pregnancy: pre-eclampsia/maternal hypertension, cesarean delivery, induced labor; fetal/neonatal: mortality, birth injury, fetal overgrowth, shoulder dystocia, acute morbidity); long-term outcomes (maternal: development of T2DM, cardiovascular outcomes, mortality or major morbidity from T2DM and/or cardiovascular disease, quality of life; long-term childhood: development of T2DM, cardiovascular outcomes, neurocognitive outcomes. It displays that outcomes for KQ2 are harms of screening tests or a diagnosis are sought, for KQ4 relate to diagnostic accuracy of screening tests, and for KQ7 are harms of treatment.

### Key Questions

1. a. Does screening for GDM reduce poor health outcomes?
  b. Does screening for GDM reduce poor intermediate outcomes?
  c. Does the effectiveness of screening for GDM vary according to maternal subgroup characteristics, including timing during pregnancy, previous GDM diagnosis, family history of type 2 diabetes mellitus, body mass index, age, or race/ethnicity?
2. What are the harms of screening for and diagnosis of GDM to the mother, fetus, or neonate?
3. a. What is the comparative effectiveness of different screening strategies for GDM on health outcomes?
  b. What is the comparative effectiveness of different screening strategies for GDM on intermediate outcomes?
  c. Does the comparative effectiveness of different screening strategies vary according to maternal subgroup characteristics, including timing during pregnancy, previous GDM diagnosis, family history of type 2 diabetes mellitus, body mass index, age, or race/ethnicity?
4. a. What is the diagnostic accuracy of commonly used screening tests for GDM?
  b. Does the accuracy of commonly used screening tests for GDM vary according to maternal subgroup characteristics, including timing during pregnancy, body mass index, age, race/ethnicity, or prevalence of GDM?
5. What is the association between diagnosis of GDM and outcomes in women meeting more inclusive but not less inclusive diagnostic criteria for GDM?
6. a. Does treatment of GDM during pregnancy reduce poor health outcomes?
  b. Does treatment of GDM during pregnancy reduce poor intermediate outcomes?
  c. Does the effectiveness of treatment of GDM vary according to maternal subgroup characteristics, including timing and criteria used for diagnosis during pregnancy, severity of hyperglycemia, body mass index, age, or race/ethnicity?
7. What are the harms of treatment of GDM, including severe maternal and fetal/neonatal hypoglycemia, delivery of neonates who are small for gestational age, and poor long-term growth and development outcomes in the child?

### Contextual Questions

Four Contextual Questions were also requested by the USPSTF to help inform the report. Contextual Questions are not reviewed using systematic review methodology.

1. What is the association between measures of serum glucose (e.g., fasting and postload glucose concentrations, percent hemoglobin A1c) and outcomes, and does it differ based on timing of measurement?
2. What is the association between GDM diagnosed before 24 weeks of gestation and outcomes, and does it differ based on screening strategy, timing of diagnosis, and severity of risk factors?
3. What are the long-term health consequences, for the mother from a diagnosis of GDM, and for the child from their mother’s GDM diagnosis, neonatal hypoglycemia, shoulder dystocia, or fetal overgrowth?
4. Are postpartum interventions effective for reducing incidence of long-term health outcomes in women previously diagnosed with GDM or their children?

## Search Strategies

We searched MEDLINE (via Ovid), Embase (via Ovid) and CINAHL (via EBSCOhost) from 2010 to May 22, 2020. Searches were restricted by language to include full texts published in English.^57,58^ We also searched ClincialTrials.gov (2017 to 2019), and reviewed reference lists of included studies and of systematic reviews. Search strategies are available in Appendix A1. All studies included in the 2012 report^2^ were screened for eligibility for this review. We also reviewed the 2012 review’s excluded studies list and scanned reference lists for relevance to the Key Questions and scope addressed in this review. Ongoing surveillance was conducted through June 2021to identify major studies published since May 2020 that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation.

All results of the database searches were imported into an EndNote^®^ database (Thomson Reuters, New York, NY) for reference citation, and, after duplicate removal, into DistillerSR (Evidence Partners Inc., Ottawa, Canada) for screening and selection procedures.

## Study Selection

All titles and abstracts identified through the database searches were independently reviewed by two trained members of the research team using broad criteria. Studies marked for possible inclusion by either reviewer and all studies from the previous report underwent full-text review. Each full-text article possibly relevant to a Key Question was independently reviewed by two trained members of the research team for inclusion or exclusion on the basis of the eligibility criteria, organized by PICOTS (population, intervention, comparator, outcome, timing, study design) (Appendix A2). Conflicts were resolved by discussion and consensus or by consulting another member of the team including the clinical lead. Results of the full-text review were tracked in EndNote®, including the reason for exclusion for excluded full-text publications. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists the included studies, and Appendix A5 lists the excluded studies with reasons for exclusion.

Appendix A2 contains detailed eligibility criteria. For screening effectiveness and test accuracy (Key Questions 1, 3 and 4), we included studies of pregnant women without known preexisting diabetes mellitus. The term GDM was defined as hyperglycemia not meeting criteria for overt diabetes at any time point during pregnancy. For studies on harms from screening or a GDM diagnosis (Key Question 2), outcome associations (Key Question 5), or treatment of GDM (Key Questions 6 and 7), studies could enroll some or only women with GDM or known hyperglycemia.

For the benefits and harms of screening, comparative effectiveness of screening approaches, and screening test accuracy (Key Questions 1 to 4), we included studies using one- or two-step screening strategies at any time during pregnancy. In two-step strategies, the screening test needed to be one of the following: FPG, a 50 g OGCT, a risk factor–based tool (clinical or historical using one or more factors), or HbA1c. For benefits and harms of screening (Key Questions 1 and 2) the comparison was no screening. When assessing the harms of screening or a GDM diagnosis, we also included studies that compared women with GDM aware of their diagnosis versus those unaware and studies comparing outcomes before and after a GDM diagnosis. To further evaluate potential harms related to labeling (i.e., from the diagnosis of GDM rather than its consequences), we also included studies comparing women diagnosed with GDM versus those without GDM and effects on use of delivery interventions and interventions related to formula use, separation of infant and mother, or breastfeeding challenges/failure. The prior review only compared harms of screening versus no screening. For comparative effectiveness (Key Question 3), the comparator was an alternative screening approach, based on tests and criteria used, timing during pregnancy, or eligibility for the intervention (selective/risk-based vs. universal screening). For Key Question 4 on accuracy, the comparator was currently recommended diagnostic tests. For Key Question 5 on outcome associations, the exposure was a diagnosis of GDM based on more inclusive criteria (i.e., IADPSG or one abnormal value [OAV] of CC or NDDG) but not treated for GDM or meeting criteria used for routine care (i.e.. CC or NDDG with two abnormal values) and the comparator was no GDM (normal glucose tolerance [NGT]). For Key Questions 6 and 7, standard treatments, provided after diagnosis until delivery, were included. The comparator was no treatment/routine prenatal care.

Intermediate outcomes were excessive maternal weight gain in pregnancy and long-term maternal or childhood development of metabolic impairment. Health outcomes were defined mainly by their timing and subject: i) during pregnancy, including preeclampsia/gestational hypertension, cesarean delivery, induction of labor, preterm delivery (live birth before 37 weeks’ gestation), and maternal birth trauma (latter two added, based on clinical input, after the final research plan but before analysis); ii) to the fetus/neonate, including mortality, birth injury, shoulder dystocia, fetal overgrowth (large for gestational age [LGA; least 90^th^ percentile in weight], macrosomia at 4000 and 4500g birthweight), and acute morbidity (hypoglycemia, hyperbilirubinemia, NICU admission, respiratory distress syndrome); and iii) over the long term for the mother (i.e., development of T2DM, cardiovascular outcomes, mortality or major morbidity from T2DM or cardiovascular disease [CVD], and quality of life) and their offspring during childhood (e.g., development of T2DM, cardiovascular outcomes, and neurocognitive outcomes). Harms from screening or a GDM diagnosis included adverse effects from screening tests (e.g., vomiting, anxiety from false positive) and consequences from the label of GDM to the woman, fetus or neonate, such as unnecessary delivery interventions (e.g., only indication being the GDM diagnosis), additional interventions with formula, separation of infant and mother, or breastfeeding challenges/failure. Harms from treatment were severe maternal or neonatal hypoglycemia, delivery of neonate who is small for gestational age (SGA; 10^th^ percentile of weight or lower) or low birth weight (2500 g or less), and poor long-term growth and development of the child. We did not exclude studies without a predefined definition of outcomes, but performed sensitivity analyses where applicable. We included studies published on or after 1995. We included settings applicable to primary care, and studies from any country.

Randomized (RCTs) and nonrandomized controlled trials (CCTs, e.g., prospective trials without randomization, controlled before-after studies; where allocation to the study groups is prospective and based on investigator decision) were included for Key Questions 1, 2, 3, 6 and 7; controlled observational studies were included for Key Questions 1 and 2, and for outcomes or comparisons without trial data for Key Questions 6 and 7. Prospective cohort studies were included for Key Question 4; the protocol was also modified to only include studies where all (or at least a sample) of women screening negative were given the reference standard OGTT, and (for risk-factor based screening models) when examining a validation rather than development cohort. For Key Question 5, retrospective or prospective cohort studies comparing women with GDM versus those without GDM were included for Key Question 5. Studies of risk-factor based screening in KQ4 had to use a validation rather than development cohort to assess accuracy. For harms related to the labelling effects of a GDM diagnosis on the mother or neonate, we required studies to compare outcomes in women with versus without GDM and make adjustments for multiple potential confounders.

## Data Abstraction and Quality Rating of Studies

For studies meeting inclusion criteria, we updated the previous review’s data abstraction tables to summarize characteristics of study populations, interventions, comparators, outcomes (including their definitions), study designs, settings, and methods. One reviewer conducted data abstraction, which was reviewed for completeness and accuracy by another team member. Reviewers resolved discrepancies by discussion and consensus.

Design-specific appraisal tools were used to assess the quality (internal validity) of individual studies.^59–62^ For studies on outcome associations for untreated GDM diagnosed using different criteria, we added a question to assess whether groups received the same standard of care (i.e., whether patients and providers were blind to OGTT results).^63^ We tested each quality assessment tool on a sample of studies and developed guidelines for assessing the remaining studies. Based on the assessments and guidance by the USPSTF methods, we then rated studies as “good,” “fair,” or “poor”, depending on the seriousness of the methodological shortcomings.^56^ For each study, quality assessment was performed independently by two team members. Disagreements were resolved by consensus. We assessed the applicability of the evidence using USPSTF guidance, in terms of populations, setting, and intervention/diagnostic characteristics.

## Data Synthesis

The outcome of preeclampsia/gestational hypertension was divided into preeclampsia, gestational hypertension, and hypertensive disorders in pregnancy (composite of former two); we considered sensitivity analysis when there was uncertainty about how these outcomes were defined or measured. For cesarean delivery, we prioritized primary (first) cesarean deliveries but also analyzed total (due to any indication) and emergency cesarean rates if reported; sensitivity analyses were conducted on the definitions used for cesarean deliveries. Stillbirth, neonatal death, and perinatal mortality were analyzed separately and as a composite. We analyzed shoulder dystocia and birth injury separately. We analyzed macrosomia separately at 4000 g and 4500 g thresholds. We analyzed outcomes related to acute neonatal morbidity separately (NICU admissions, respiratory distress syndrome, hypoglycemia, hyperbilirubinemia, APGAR scores under 7 at 1 and 5 minutes). For neonatal hypoglycemia, many studies did not report their definition or used a biochemical definition of neonatal hypoglycemia (i.e., values under 30 or 40 mg/dL) without mention of signs of hypoglycemia or the use of medical interventions. We did sensitivity analysis based on whether authors reported using a biochemical definition for neonatal hypoglycemia; further, when able, we also performed analysis for hypoglycemia defined as requiring intravenous therapy. Hyperbilirubinemia was usually defined as requiring phototherapy.

Evidence was synthesized narratively, unless data were suitable for pooling. The decision to pool was based on the judgment that the included studies were clinically and methodologically similar. We explored heterogeneity with sensitivity and subgroup analyses, using our predefined variables for the population (e.g., severity of dysglycemia), interventions (e.g., no treatment vs. minimal intervention in control groups), and setting (i.e., removing studies from countries not categorized as very high on the Human Development Index 2019 [VHDI] (Appendix A2 Table 1), as well as for study quality and uncertain outcome definitions. For nonrandomized studies on intervention effects, we used the inverse-variance method for meta-analysis, using the most adjusted results from each study when available. For the association between additional GDM cases diagnosed using more inclusive criteria and health outcomes, our primary analysis relied on crude event rates, to reflect the results when only glycemic status, but no other patient characteristics, such as BMI or age, would be considered by clinicians. We then compared these findings to those from studies that provided adjusted findings. Meta-analyses were conducted using random effects models in Review Manager, version 5.1 (The Cochrane Collaboration, Copenhagen, Denmark). When moderate or greater heterogeneity (I^2^ 40 percent or greater) was observed, we performed sensitivity analysis using the profile likelihood method in Stata version 14.2 (StataCorp, College Station, Texas). For meta-analyses with few events and fairly equal sizes between arms, we used the Peto method.^64^ Results are reported in relative risks (RR) or odds ratios (OR), depending of what was used for the analysis, and include 95 percent confidence intervals (95% CI). Pooled absolute risk differences (ARD) were calculated for statistically significant results and when analyses include one or more zero event studies. When interpreting the direction of association, if findings did not quite reach statistical significance (e.g., upper limit of 95% CI 1.00 or 1.01 for an association with reduce risk) but the magnitude of the association could be clinically important (e.g., more than 20 to 25 percent) we concluded that there may be an association but comment on this imprecision. Otherwise imprecision is noted in the case of small sample sizes.

For diagnostic accuracy, we constructed 2×2 tables and calculated sensitivity, specificity, accuracy (true positive plus true negative divided by the total sample) and yield (i.e., GDM prevalence) of the screening tests. Where applicable, analyses were stratified by the timing of the index test in pregnancy. If studies were clinically homogenous (e.g., similar screening tools, diagnostic thresholds, timing) and more than three studies were included for a particular comparison, we pooled sensitivities and specificities using bivariate analysis (accounting for their correlation) and constructed hierarchical summary receiver operator characteristic curves.^65^ When considering the various thresholds used in the studies, we pooled data for slightly different thresholds, while using a conservative approach (e.g., FPG of 79 mg/dL with 79.5 mg/dL, and 90 mg/dL with 89.5 mg/dL). We used the metandi program in Stata version 14.2 to fit the models and produce the pooled estimates. Using pooled point estimates for sensitivity and specificity, or the median of a range of estimates when no meta-analysis was conducted, we calculated corresponding positive and negative predictive values (PPV and NPV) for hypothetical cohorts with GDM prevalences of 7, 15 and 25 percent.

For analysis of trials with at least 10 studies, we assessed publication bias (small study effects) graphically with the funnel plot and quantitatively using Egger’s test.^66^

For all Key Questions, the overall quality of evidence was determined using the approach described in the USPSTF Procedure Manual.^56^ Evidence was rated “good”, “fair”, or “poor” based on study quality, consistency of results between studies, precision of estimates, risk of reporting bias, applicability, and other study limitations. A summary of evidence table was developed to assess the overall quality of evidence for each Key Question using the approach described in the USPSTF Procedure Manual.^56^

## Expert Review and Public Comment

The draft Research Plan was posted for public comment on the USPSTF Web site from February 28 to March 27, 2019. Based on the comments it received, some intermediate outcomes were re-classified as health outcomes; added additional subgroups to Key Questions 1, 3, and 6; revised Contextual Questions 3 and 4 to focus on specific outcomes of interest; clarified that Key Question 2 requires no comparator and that interventions for Key Questions 6 and 7 would be offered during pregnancy. The population was revised to include studies of populations in which less than 20 percent had known preexisting diabetes mellitus, recognizing that screening studies for GDM will likely include some women with unrecognized diabetes mellitus.

The draft version of this report was reviewed by content experts (Appendix A6), representatives of Federal partners and posted for public comment on the USPSTF website from February 16, 2021 to March 15, 2021. Edits were made for clarity and accuracy; however, no changes were made to the evidence or to our conclusions.