# Chapter 1 Introduction and Background

## Purpose

This report updates a 2012 systematic review on screening for gestational diabetes mellitus (GDM) conducted by the Agency of Healthcare Research and Quality (AHRQ).^1–4^ It will be used by the United States Preventive Services Task Force (USPSTF) to update their 2014 recommendations.^5^

In 2014, the USPSTF recommended screening for GDM in asymptomatic pregnant women after 24 weeks of gestation^5^ (B recommendation). This recommendation was based on the USPSTF assessment of adequate evidence that primary care providers could accurately detect GDM and that treatment of screen-detected GDM can significantly reduce maternal and fetal complications (preeclampsia, macrosomia, and shoulder dystocia), with small or no harm. The USPSTF concluded that the evidence was insufficient to assess the balance of benefits and harms of screening for GDM in asymptomatic pregnant women before 24 weeks of gestation (I statement).

## Condition Background

### Condition Definition

GDM was originally defined as glucose intolerance first discovered in pregnancy.^6^ Because this definition does not clearly distinguish between GDM and women with preexisting, overt diabetes (unknown until pregnancy), GDM is now defined by the development of diabetes during pregnancy.^7–9^ The latter definition will be used for this report, recognizing that it can be difficult to distinguish between GDM and preexisting diabetes. Pregnant women with preexisting diabetes (type 1 or 2) have more complex care needs and risks for serious complications (e.g., exacerbation of diabetes-related complications, such as retinopathy and nephropathy; congenital malformations; stillbirth) compared with women having GDM;^10–13^ detection and management of preexisting diabetes during pregnancy is beyond the scope of this report.

### Prevalence and Burden of Disease/Illness

The prevalence of GDM in the United States has been in the past estimated at 5.6 to 9.2 percent.^14–17^ These estimates are largely based on use of the widely adopted “two-step” screening approach, which refers to the application of a screening test and, if indicated, a diagnostic test using either Carpenter Coustan (CC)^18^ or National Diabetes Data Group (NDDG)^19^ criteria. Prevalence varies depending on which criterion is used, as NDDG leads to about 30-50% fewer diagnoses than CC criteria.^20^ Estimates are also likely most applicable to women who have accessed prenatal care. Comparing the U.S. prevalence to that in other countries is difficult, due to population characteristics (e.g., race/ethnicity, maternal age) and/or different screening approaches. Prevalence may be lower if selective/risk-based approaches are used rather than universal screening; they will be higher when “one-step” screening with a diagnostic test is applied without an initial screening test, and/or more inclusive diagnostic criteria (i.e., lower threshold to diagnose GDM) are used. In 2010, the International Association of Diabetes and Pregnancy Study Group (IADPSG) Consensus Panel released recommendations for a new one-step screening approach using “outcome-based” criteria,^21^ informed by data from the landmark, international Hyperglycemia and Adverse Pregnancy Outcome (HAPO) Study of glucose-outcome associations.^9^ Across the study centers of the HAPO study, applying the IADPSG criteria resulted in a prevalence of GDM of 17.8 percent.^22^ Data from other studies in countries that previously used two-step approaches with the CC or NDDG criteria indicate that the absolute rates of GDM increase by 8 to 33 percent (1.03 to 3.78-fold rise) when using the IADPSG criteria.^23^

A large cohort of over 125 million pregnancies in the United States found that the prevalence of GDM increased from 0.3 to 5.8 percent during the period between 1979-1980 and 2008-2010.^16^ This increase is likely related to increased awareness and screening for GDM, some diagnoses being based on lower thresholds (e.g., changing from NDDG to CC criteria), and a true increase in prevalence, largely from increasing maternal age and body mass index (BMI). Between 2006 and 2016, there was an absolute increase in GDM of 3.6 percent from National Health Interview Survey data; changes were most marked in groups categorized as overweight, low income, ages 45 to 64 years, not white or Hispanic, and having insufficient physical activity.^17^

### Etiology and Natural History

GDM usually arises after 20 weeks’ gestation when placental hormones with the opposite effect of insulin increase substantially. Women with adequate insulin secreting capacity overcome this insulin resistance of pregnancy by secreting more insulin in order to maintain normal blood glucose. Women with less pancreatic reserve are unable to produce adequate insulin to overcome the increase in insulin resistance, and glucose intolerance results.

Evidence from the HAPO and other studies has demonstrated a continuous linear association between (untreated) plasma serum glucose levels—both fasting and postload—and adverse perinatal outcomes including large for gestational age (LGA) neonates, shoulder dystocia, primary cesarean delivery, preeclampsia, neonatal hypoglycemia.^2,4,9,24^ Reviews examining associations based on differing diagnostic thresholds have generally found a GDM diagnosis associated with poorer perinatal outcomes, though most included studies did not use the newest, more inclusive IADPSG criteria.^2,4,25^ GDM has also been associated with increased risk of several long-term intermediate (e.g., obesity) and health outcomes (e.g., development of type 2 diabetes [T2DM], neurodevelopment in childhood) in both women and their offspring. In some analyses, confounding from factors such as parental BMI, gestational age at birth, lifestyle, and socioeconomic status could have impacted the findings.^26–28^ For some outcomes, such as perinatal death, previous syntheses have found that studies were generally underpowered to determine accurate effects.^2,4,9^ The associations between GDM and long-term health outcomes are addressed in more detail in both a Key Question (related to different criteria for GDM) and Contextual Question 3.

### Risk Factors

Risk factors for GDM include greater maternal age (e.g., 35 years or older), elevated BMI, member of an ethnic group at increased risk for development of type 2 diabetes mellitus (T2DM), past history of GDM, macrosomia in a previous pregnancy, history of unexplained stillbirth, T2DM in a first degree relative, polycystic ovary syndrome, and metabolic syndrome.^29–31^ There is some variation between U.S. reports on the prevalence of GDM by race/ethnicity, although American Indian/Alaska Native, Asian, Native Hawaiian/Pacific Islander, and Hispanic women are at higher risk for GDM than non-Hispanic white women.^14,32,33^ Although higher BMI increases risk of GDM across racial and ethnic groups, the association varies.^34,35^ For example, in Asian Americans the prevalence of GDM at a BMI of 22 to under 25 kg/m^2^ is similar to the risk in Hispanic, non-Hispanic White, and Black persons with higher (over 28 kg/m^2^) BMI.^34^ The risk in different ethnic groups may also be due in part to social risk factors such as low socioeconomic status or structural racism although these associations are not examined in the current evidence. Factors associated with decreased risk of GDM include young age (25 or 30 years and younger), non-Hispanic white ethnicity, normal BMI (25 kg/m^2^ or less [with the exception of Asian women]), no history of previous glucose intolerance or adverse pregnancy outcomes associated with GDM, and no first degree relative with known diabetes.^31,36^

### Rationale for Screening/Screening Strategies

GDM is usually asymptomatic and preventing consequences by detecting and treating GDM during pregnancy could improve pregnancy and neonatal outcomes. Identification and treatment of GDM during pregnancy may also improve long-term maternal or childhood outcomes and facilitate other preventive interventions after delivery.

Screening women for GDM involves either a two- or one-step approach (Table 1). In two-step screening, the screening test is often a 50 g oral glucose challenge test (OGCT) administered in a nonfasting state, and patients who meet or exceed a screening threshold (usually 130 mg/dL or 140 mg/dL) at one hour receive the diagnostic oral glucose tolerance test (OGTT) in which a 75 g or 100 g oral glucose load is administered in a fasting state and plasma glucose levels are evaluated at fasting and after 1, 2, and sometimes 3 hours. A diagnosis of GDM is made when one or two glucose values fall at or above the specified glucose thresholds, depending on the diagnostic criteria. Alternatives to the OGCT as the first step in some two-step screening strategies include assessment of risk factors (e.g., the National Institute for Health and Care Excellence in the United Kingdom^31^) for targeted, or selective, screening, or testing of fasting plasma glucose (FPG). Risk-factor based approaches may also be used to determine who receives a two-step strategy, using for example applying an OGCT and then an OGTT, when indicated, only in select populations. A one-step screening method does not use a screening test, but administers the OGTT in all patients.

Table 1 Current Screening Strategies^*^ and Thresholds for GDM

| Development of Criteria | Current Use in Guidance | Glucose Load | Minimum Number of Abnormal Values | Fasting Threshold | 1hr Threshold | 2hr Threshold | 3hr Threshold
In two-step screening after positive (i.e., 130-140 mg/dL/7.2-7.8 mmol/L) OGCT | Carpenter Coustan 1982^18^ | ACOG 2013-2018^7^; NIH 2013^48^; ADA 2000-2020^8^ | 100 g | 2 | 95 mg/dL; 5.3 mmol/L | 180 mg/dL; 10.0 mmol/L | 155 mg/dL; 8.6 mmol/L | 140 mg/dL; 7.8 mmol/L
In two-step screening after positive (i.e., 130-140 mg/dL/7.2-7.8 mmol/L) OGCT | NDDG 1997^19^ | ACOG 2013-2018^7^; NIH 2013^48^ | 100 g | 2 | 105 mg/dL; 5.8 mmol/L | 190 mg/dL; 10.5 mmol/L | 165 mg/dL; 9.1 mmol/L | 145 mg/dL; 8.0 mmol/L
In two-step screening after positive (i.e., 130-140 mg/dL/7.2-7.8 mmol/L) OGCT | DC (a.k.a. CDA) 2013^309^-2018^30^ (HAPO 2.0) | DC 2013^309^-2018^30^; SOGC 2016^310^ | 75 g | 1 | 95 mg/dL; 5.3 mmol/L | 191 mg/dL; 10.6 mmol/L | 160 mg/dL; 9.0 mmol/L | -
In two-step screening after risk-factor assessment | NICE 2018^31^ | NICE 2018^31^ | 75 g | 1 | 101 mg/dL; 5.6 mmol/L | - | 140 mg/dL; 7.8 mmol/L | -
In two-step screening after risk-factor assessment | SIGN 2017^311^ | SIGN 2017^311^ | See IADPSG
One-step screening only using diagnostic test | IADPSG^21^ (HAPO 1.75) | WHO 2013^47^-2018^312^; ADA 2011^313^-2020^8^; Endocrine Society 2013-2018^46^; DC 2013^309^-2018^30^ (alternative) & SOGC 2016^310^ (alternative); ADIPS 2014^314^; FIGO^315^ | 75 g | 1 | 92 mg/dL; 5.1 mmol/L | 180 mg/dL; 10.0 mmol/L | 153 mg/dL; 8.5 mmol/L
One-step screening only using diagnostic test | EASD 1996^316^ | - | 75 g | 1 | 108 mg/dL; 6.0 mmol/L | - | 162 mg/dL; 9.0 mmol/L | -

Abbreviations: ACOG = American College of Obstetricians and Gynecologists; ADA = American Diabetes Association; ADIPS = Australasian Diabetes in Pregnancy Society; DC = Diabetes Canada; EASD = European Association for the Study of Diabetes; FIGO = International Federation of Gynecology and Obstetrics; HAPO = Hyperglycemia and Adverse Pregnancy Outcome; IADPSG = International Association of Diabetes in Pregnancy Study Groups; NDDG = National Diabetes Data Group; NICE = National Institute for Health and Care Excellence; NIH = U.S. National Institutes for Health; OGCT = oral glucose challenge test; SIGN = Scottish Intercollegiate Guidelines Network; SOGC = Society of Obstetricians and Gynaecologists of Canada; WHO = World Health Organization

* This table includes the currently recommended screening strategies that were included in this review. One study included for Key Question 3 compared IADPSG criteria to WHO 1999 criteria, which uses thresholds of FPG ≥6.1 mmol/L and/or 2 hr ≥7.8 mmol/L.

While a universal two-step method using an OGCT is widely performed in the United States, much of the rest of the world utilizes targeted two-step screening or a one-step screening method.^23^ The potential advantages of a two-step over a one-step screening approach are the ease of use and lower resources required,^37^ but its utility depends on the ability of a negative screen to accurately rule out GDM and on adherence to the second step of the screening. One-step approaches reduce false negative and positive screening results since only the reference standard is used; these approaches may appear desirable for a high-risk population, but may be limited by requiring a fasting state for all women. With either approach, using more inclusive criteria (e.g., lower glucose threshold or requiring one rather than two glucose values above the threshold) could result in overdiagnosis and associated overtreatment and other potential harms. Different countries and ethnicities have been shown to have differences in whether GDM diagnostic criteria are more likely to be met on the fasting or post-glucose load measurement (e.g., majority of diagnoses based on fasting glucose in South African, Latino and Middle Eastern populations but on post-glucose load measurements in Chinese and Thai populations).^22,38^ At this time it is not clear if this is a result of racial differences in glucose handling or reflective of per/kg body weight differences of the glucose load used for testing and if this should impact which criteria and approach used for a given population.

The first two-step screening approach (a 50 g 1-hour OGCT then a 100g 3-hour OGTT with two abnormal OGTT values required for diagnosis) was proposed in 1964 by O’Sullivan and Mahan, after validation against the development of future T2DM (up to 60% cumulative increase after 16 years) in the mother.^39,40^ The NDDG modified the diagnostic criteria in 1979, for measuring glucose in plasma rather than whole blood,^19,23^ and in 1982 Carpenter and Coustan (CC) further modified the criteria in order to incorporate considerations related to use of more modern analytic methods.^18^ For over three decades it has been common globally to use a two-step procedure with the OGTT criteria of NDDG (i.e., 2 abnormal values with thresholds at fasting 105 mg/dL [5.8 mmol/L], and/or postglucose load at 1 hour 190 mg/dL [10.5 mmol/L], 2 hours 165 mg/dL [9.1 mmol/L], or 3 hours 145 mg/dL [8.0 mmol/L]), or of CC (i.e., 2 abnormal values at fasting 95 mg/dL [5.3 mmol/L], and/or post-glucose load at 1 hour 180 mg/dL [10 mmol/L], 2 hours 155 mg/dL [8.6 mmol/L], or 3 hours 140 mg/dL [7.8 mmol/L]) (Table 1). Because of evidence that elevated glucose levels that do not meet NDDG or CC thresholds for GDM are also associated with adverse health outcomes (e.g. HAPO study),^9^ and that treatment for women with lesser degrees of dysglycemia appears to improve outcomes,^41,42^ alternative two-step and one-step approaches and criteria have been developed over the years by professional, national, or international organizations. Most of these two- and one-step approaches are more inclusive (i.e., result in diagnosis of more women with GDM), requiring one rather than two abnormal values on the OGTT for diagnosis. The one-step IADPSG criteria which has lower glucose thresholds and uses one abnormal value (75 g 2-hour OGTT with fasting 92 mg/dL [5.1 mmol/L], or postglucose load at 1 hour 180 mg/dL [10 mmol/L] or 2 hours 153 mg/dL [8.5 mmol/L]) is currently endorsed internationally by several societies and guideline communities as the recommended diagnostic test or as a diagnostic option (Table 1).

Interest has grown about the usefulness of FPG as an alternative to the OGCT in two-step screening for GDM for a number of reasons. First, the IADPSG has proposed the use of a high-threshold FPG of 126 mg/dL (7.0 mmol/L) as soon as pregnancy is confirmed in women at high risk of T2DM as a means of identifying women with preexisting (overt) diabetes. It has been proposed that lesser degrees of fasting glucose elevation could be used to screen for GDM if this test is already being done to rule out preexisting diabetes. Second, the reproducibility of fasting glucose measurement is superior to postglucose load measurements.^43^ Third, some women do not tolerate the oral glucose drinks. Apart from FPG, a glycated hemoglobin [HbA1c] concentration greater than 6.5 percent (as used in the non-pregnant population) is also applied for detecting T2DM in early pregnancy.^8^ There is not yet clarity about whether FPG and HbA1c values in early pregnancy indicating hyperglycemia, but below thresholds used for diagnosis of T2DM, can predict later GDM or lead to interventions that improve outcomes.

Without a universally accepted “gold standard” for GDM diagnosis, and because of alternatives that apply diagnostic tests alone for screening, decisionmaking about screening involves understanding whether a screening test can predict GDM in a two-step approach, as well as about which diagnostic criteria to apply, based on the magnitude of their associations with poor outcomes and of effects after treatment. The most appropriate timing for screening is also uncertain; waiting too long may miss the window of opportunity to provide beneficial treatment, but whether screening early in pregnancy provides more benefit than harm is being actively investigated.

### Interventions/Treatment

The treatment of GDM during pregnancy aims to lower and stabilize blood glucose levels, in order to reduce complications during pregnancy, delivery, and postpartum for the mother and neonate. Risk identification for prevention and surveillance of longer-term maternal outcomes, such as development of T2DM or cardiovascular disease, is often a secondary goal, with the potential for interventions to prevent or delay the development of these associated conditions. Preventing the development of T2DM before subsequent pregnancies may offer significant benefit for future offspring. Contextual Questions 3 and 4 address the long-term development of T2DM and the effects from postpartum interventions in women with previous GDM, respectively.

Initial treatment for GDM typically involves medical nutrition therapy, glucose monitoring, physical activity, and weight management depending on pregestational weight.^44^ When this treatment does not achieve desired glucose targets, insulin or oral glucose lowering medications may be used. The American Diabetes Association currently recommends insulin over metformin and glyburide as first-line treatment.^45^ Women diagnosed with GDM may also undergo increased prenatal surveillance or changes in delivery management, depending on fetal size and the effectiveness of measures to control glucose.

### Current Clinical Practice/Recommendations of Other Groups

Major guidelines from the United States generally recommend universal, rather than selective/risk-based screening at 24 to 28 weeks’ gestation (Table 2). Guidelines differ with respect to the number of tests and the diagnostic criteria applied. The Endocrine Society^46^ recommends a one-step approach using the IAPSG thresholds^21^ (also adopted by the World Health Organization in 2013^47^), while the American Diabetes Association^8^ recommends either one-step (using IADPSG criteria) or two-step (using CC criteria) screening, and the American College of Obstetricians and Gynecologists^7^ and National Institutes of Health^48^ recommend a two-step approach using the CC or NDDG thresholds. The American College of Obstetricians and Gynecologists has stated that one rather than two abnormal values on the OGTT may be used with the CC or NDDG criteria.

Table 2 Major Recommendations on Screening for GDM in the United States

Group | Recommendation
USPSTF^5^ | The USPSTF recommends screening for GDM in asymptomatic pregnant women after 24 weeks of gestation. (B recommendation); The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of screening for GDM in asymptomatic pregnant women before 24 weeks of gestation. (I statement); No recommendation for screening approach.
ADA^8^ | Test for gestational diabetes mellitus at 24–28 weeks of gestation in pregnant women not previously known to have diabetes. (A Recommendation); The ADA recommends using the IADPSG criteria, or a 2-step approach with a 50g non-fasting screening test follows by a 100g OGTT with at least 2 glucose values meeting or exceeding the diagnostic thresholds described by CC.
ACOG^7^ | All pregnant women should be screened for GDM with a laboratory-based screening test(s) using blood glucose levels. Screening for GDM generally is performed at 24–28 weeks of gestation.; Two-step screening is recommended.; For the screening test, practitioners are advised to select a single, consistent threshold (between 130-140 mg/dL), based on factors such as community prevalence rates of GDM.; For diagnosis, a 3-hr OGTT using CC or NDDG criteria are recommended, based on considerations of baseline prevalence of diabetes in specific communities and the availability of resources to appropriately manage women in whom GDM will be diagnosed by any given protocol.; Individual practices and institutions may choose to use the IADPSG’s recommendation, if appropriate, for the population they serve.
NIH Consensus Development Program^48^ | The panel recommends that the two-step approach be continued.
Endocrine Society^46^ | Recommends that pregnant women not previously identified (either during testing performed early in pregnancy or at some other time before 24 weeks’ gestation) with overt diabetes or gestational diabetes be tested for gestational diabetes by having a 2-hour, 75-g OGTT performed at 24 to 28 weeks’ gestation. (Level 1; moderate quality); Recommends that gestational diabetes be diagnosed on this test using the IADPSG criteria (majority opinion of this committee). (Level 1; moderate quality)
AAFP^317^ | The AAFP supports the 2014 recommendations of the USPSTF.

Abbreviations: AAFP = American Academy of Family Physicians; ACOG = American College of Obstetricians and Gynecologists; ADA = American Diabetes Association; CC = Carpenter Coustan; IADPSG = International Association of Diabetes in Pregnancy Study Groups; NDDG = National Diabetes Data Group; NIH = U.S. National Institutes for Health; OGTT = oral glucose tolerance

A 2014-15 survey of members of the Society for Maternal-Fetal Medicine found that 90.6 percent of respondents recommend a two-step screening approach, with the most common screening test the 140 mg/dL OGCT (39% vs. 24% and 37% using 130 and 135 mg/dL, respectively), and the most common diagnostic test the OGTT (83%) based on two abnormal values using CC criteria.^49^ Practitioners in the Western United States were more likely to use a one-step approach (24% vs. 4-6% in other regions). These figures differ somewhat from a previous (2004) survey, which found that nearly 60 percent of American College of Obstetricians and Gynecologists fellows used the NDDG criteria.^50^ Data on current practices are limited, but several U.S. studies have evaluated outcomes before and after adoption of the IADPSG one-step screening criteria, suggesting that this approach is being considered in various regions of the country.^51–54^ During a very large (n = 23,792) recently completed multicenter trial in the United States comparing screening with one-step IADPSG versus two-step CC strategies (but allowing for providers to “opt out” of one to receive an alternative test), a greater proportion of care providers used the two-step approach, particularly for women they thought were at high-risk, because the lack of need for fasting (and thus a subsequent visit) was thought to improve the likelihood of their patients completing at least one screen.^55^