# Appendix D Supplemental Analyses and Subgroup Findings

Appendix D Table 1 Evidence on Harms From Observational Studies on Screening vs. No Screening for GDM (KQ2)

Outcome Group | Author, Year, Country; Sample Size; Study Design; Quality | Outcome | Results (GDM vs. no GDM Unless Stated Otherwise) | Analysis
Psychosocial Harms Associated with Screening | Rumbold 2002,^77^ Australia; N=212 (21 with GDM); Prospective cohort; Fair | Anxiety (Short-form STAI range 6-24) & Depressive symptoms (EPDS ≥12); A. Harms of screening in OGCT-ve: Before screening (mixed sample) vs after screening (before OGTT) vs. late in pregnancy; B. Harms of False Positives (FP) & GDM Dx (OGCT-ve vs FPs vs GDM late in pregnancy) | A. Across time in OGCT-ve; [underlined: Anxiety]:; Before: 10 ± 3.0, n=158; After: 11 ± 3.0, n=124; Late pregnancy: 11 ±4.0, n=95; [underlined: Depressive symptoms]:; Before: 33/158 (21%); After: 21/124 (17%); Late pregnancy: 17/95 (18%); B. Across time in OGCT –ve, OGCT +ve (FP) & GDM Dx; [underlined: Anxiety]:; Before: 10 ± 3.0, n=158; After:; OGCT-ve 11 ± 3.0, n=124; OGCT+ve 11 ±4, n=62; Late in pregnancy:; OGCT-ve 11 ± 4, n=95; OGCT+ 12 ±4, n=29; GDM 11± 4, n=21; [underlined: Depressive symptoms]:; Before: 33/158 (21%); After:; OGCT-ve 21/124 (17%); OGCT+ve 11/62 (18%); Late in pregnancy:; OGCT-ve 17/95 (18%); OGCT+ 6/29 (21%); GDM 4/21 (19%); Nonsignificant differences across any comparisons over time | No adjustments
Psychosocial Harms Associated with Screening | Kerbel, 1997,^73^ Canada; N=813 (False positive 88 vs negative or perceived negative 725); Prospective cohort; Fair | Harms of false positives (FP); State anxiety (STAI 20-80) (MID 5 points); Depressive symptoms CES-D (0-60) | Change from baseline (12-24 wks) to 32 weeks (after OGTT) in False positive vs no GDM:; [underlined: State Anxiety]:; FP (n=88): 0.88 ± 9.7 vs. perceived test negative/not tested (n=725) 0.16 ±11.4 (p=0.57) (p=0.55 after adjusting for potentially confounding variables).; [underlined: Depressive symptoms]: FP: 0.95 ± 4.1 vs perceived -ve/not tested 0.13 ± 5.7 (p=0.093) Still nonsignificant after adjustment (p value NR) | Multivariate linear regression model.; Not adjusted for BMI.; Powered for 5 point difference in state anxiety.
Psychosocial Harms Associated with Receiving a GDM Diagnosis | Daniells, 2003,^71^ Australia; N=100 (50 with GDM); Prospective double cohort (50 GDM vs 50 NGT); Fair | Mean STAI scores on; State anxiety (range 20-80) (“reactive”); Trait anxiety (range 20-80) (“intrinsic”); Assessed in 3^rd^ trimester (~30 wks; after screening/Dx), antepartum (~36 wks) and 6 wks postpartum | [underlined: State Anxiety:]; Wk 30: GDM 40.6 ± 13.3 vs. NGT 34.2 ±9.9 (p= 0.007); Wk 36: GDM 33.7 ±10.9 vs NGT 35.3 ±9.1 (p 0.43); 6 wks Postpartum: GDM 31.7 ± 10.6 vs NGT 34.1 ±10.9 (p=0.28); Higher State anxiety right after diagnosis, but attenuated by delivery and remained into postpartum period; Subgroups:; At 36 wk no difference (p=0.87) in State anxiety between GDM treated vs not with insulin; At 30 wk no difference (p=0.64) in State Anxiety between groups from Australia vs. not; No difference when based on age (p value NR) or country of origin; [underlined: Trait Anxiety]:; Wk 30: GDM 39.5 ± 10.3 vs NGT 38.3 ± 10.2 (p=0.58); Wk 36: GDM 36.0 ±9.0 vs NGT 37.8 ±10.4 (p= 0.35); 6 wks postpartum: GDM 34.4± 10.5 vs NGT 36.7± 9.5 (p=0.24) | Scale 20-80 (higher more anxiety).; Not adjusted for variables; age and BMI higher in GDM vs. no-GDM, p=0.02.
Cesarean Deliveries Associated with a GDM Diagnosis | Naylor, 1996,^75^ Canada; N=3,778 (143 with GDM); Prospective cohort; Good | Risk for cesarean, accounting for macrosomia | [underlined: Cesarean]:; GCT- 20.2% (585/2940); GCT+ 23.9% (136/580); Untreated borderline GDM 29.6% (34/115); GDM 33.6% (48/143); [underlined: Macrosomia >4000g:]; GCT- 13.7% (395/2940); GCT+ 14.0% (80/580); Untreated borderline GDM 28.7% (33/115); GDM 10.5% (15/143); Stratified analysis:; Overall, macrosomia was associated with an increased rate of cesarean delivery after controlling for the level of glucose tolerance (P<.001 by stratified analysis) (Table 4). However, among women with treated GDM, cesarean delivery births were equally common whether the neonate was macrosomic (33% [5/15]) or not (33.6% [43/128]). (Macrosomia had no impact on patients with known treated GDM); Multivariable, vs negative screenees:; GDM: aOR for cesarean 1.6 (95% CI 1.0-2.5) (same in models for 4000, 4500, birth weight); FPs: 1.2 (0.9-1.5),; Borderline GDM 1.2 (0.7-2.0) | A stratified analysis (2x3x4) was used to examine the effects of macrosomia (present/absent) on mode of delivery (cesarean, other interventions, spontaneous vaginal) after controlling for glucose tolerance (the four groups). This categorical bivariate analysis was followed by a multivariate logistic regression, including maternal characteristics associated with cesarean delivery (P<.05) on univariate comparisons (maternal age, race, parity, body mass index, history of preeclampsia, current preeclampsia, gestational age, and previous cesarean delivery, breech, dystocia, previous cesarean, fetal distress) to assess whether macrosomia was an independent risk factor for cesarean delivery. Sensitivity analysis using >4500 g and birth weight vs. >4000 g macrosomia.; Indications for cesarean delivery assessed via hospital discharge data (92% complete) (previous cesarean, breech presentation, dystocia, fetal distress)
Hospital Experiences Potentially Impacting Breastfeeding Outcomes | Oza-Frank, 2017,^76^ U.S.; N=157,187 (14,409 with GDM); Cross-sectional; Good | CDC’s Pregnancy Risk Assessment Monitoring System (PRAMS) survey based on Baby-Friendly Hospital Initiative Practices | Women with GDM were less likely to report:; - Breastfeeding in the first hour (aOR, 0.83 [95% CI, 0.73 to 0.94]); - Feeding only breast milk in the hospital (aOR, 0.73 [95% CI, 0.65 to 0.82]); - Feeding on demand (aOR, 0.86 [95% CI, 0.74 to 0.99]); Women with GDM were significantly more likely to report:; - Receiving a pump (aOR 1.28 [95% CI, 1.07 to 1.53]); - Receiving a formula gift pack (aOR, 1.17 [95% CI, 1.03 to 1.34]).; (Receiving a pump was the only positive practice); No significant difference in aOR for:; - Hospital staff gave me information about breastfeeding; - My baby stayed in the same room with me at the hospital; - I breastfed my baby in the hospital; - Hospital staff helped me learn how to breastfeed; - The hospital gave me a telephone number to call for help with breastfeeding; - My baby used a pacifier in the hospital | Weighted multivariable logistic regression. Adjusted models: maternal age, maternal race, maternal education, Medicaid status, prepregnancy BMI, parity, mode of delivery, gestational age, pregnancy intention, NICU admission, and proportion of women delivering multiples.; Current U.S. maternity care practices do not universally include all 10 BFHI steps, and the level to which individual hospitals implement any, some, or all steps may vary widely, which may contribute to the observed disparities by GDM.
Hospital Experiences Potentially Impacting Breastfeeding Outcomes | Doughty, 2018,^72^ U.S.; N=1,733 (107 with GDM); Cross-sectional; Good | U.S. Infant Feeding Practices Study II (consumer opinion panel; secondary analysis from prenatal and neonatal questionnaires) on Hospital experiences (neonatal factors and hospital experiences that could affect exclusive breastfeeding); Problems with breastfeeding in 1^st^ 2 wks (17 questions regardless of breastfeeding); Delayed onset of lactation (>72 hrs) | GDM vs noGDM differences:; - Newborn staying in the mother’s hospital room (except for doctor visits, bathing, or other treatments; among infants with no NICU stay) (43.7% vs 58.7%; aOR 0.55, 95% CI [0.36, 0.85]); - Mother reporting that the newborn had trouble sucking (43.9% vs 32.1%; aOR 1.66, 95% CI [1.08, 2.54]); - Baby not interested in breastfeeding (13.1 vs. 7.3%; aOR 2.06, 95% CI [1.07, 3.98] (when using inverse probability-weighting, not interested in breastfeeding changed aOR 1.97, 0.97 to 4.01); - (Perceived delay in lactation): Took too long for milk to come in 20.5% vs 1.9% p=0.05; No differences in; - Getting help with breastfeeding within 1 hr of delivery (15% vs. 23.4%; aOR 0.64 (0.36 to 1.15),; - Delayed onset of lactation [>72hrs postpartum) (29.9% vs 23.7%; aOR 1.26, 0.79 to 2.01) or; - Other breastfeeding problems (not specified; aOR 0.23 (0.05 to 0.99); - Baby fed sugar (8.8% vs 11.8%, p=0.35, not adjusted); - Baby given a pacifier (51% v 56.5%, p=0.28, not adjusted); - Tried to breastfeed within 1 hour (54.7% vs 59.8% p=0.3, not adjusted); Some other reasons from prenatal sample:; Less likely to say only breastfeeding is the best way to feed a newborn (59% vs 71%); More likely to say that their doctors believed infants should be formula fed (aOR 2.82, 95% CI [1.17-6.79]). | Multivariable logistic regression models: maternal age, race/ethnicity, and BMI regardless of significance; other variables maternal age, race (White vs. non-White), education, income, parity, marital status, Supplemental Nutrition Program for Women, Infants and Children (WIC) participation, smoking status, and employment status, gestational weight gain, type of delivery, medication during labor, infant birth weight, gestational age, birth weight category, and sex.
Hospital Experiences Potentially Impacting Breastfeeding Outcomes | Loewenberg Weisband, 2017,^74^ U.S.; N=2,263 (160 with GDM); Prospective cohort; Fair; Moderate (some lack of representativeness in sample) | Mediation analysis to assess whether hospital supplementation mediated the association between exclusive breastfeeding intention and (any) breastfeeding duration, by GDM. | Intending to exclusively BF: GDM 51.9% vs nonGDM 63.0%; aOR 0.71; 95% CI, 0.51–0.99; Supplementation (water, formula or sugar if breastfed): 63.5% vs 46.4% p<0.001; aOR 1.86 95% CI 1.27-2.72; Duration of any breastfeeding: 21.4 ± 21.2 wks vs 24.6 ± 20.8 wks (p=0.04); Not having exclusive breastfeeding intentions was associated with increased odds of hospital supplementation in both women with GDM and women with NDM (GDM: aOR 3.52; 95% CI [1.44–8.57], NDM: aOR 3.66; 95% CI [2.93–4.56]).; Breastfeeding duration was similar by exclusive breastfeeding intentions (GDM aOR 22.3 95% CI 16.6 to 28.0 vs no GDM 20.7 95% CI 19.1-22.3) and by hospital supplementation (GDM 13.1 95% CI 5.8 to 20.4 vs no GDM 10.1 95% CI 8.3 to 11.8), regardless of GDM; Hospital supplementation partially mediated the association between exclusive breastfeeding intentions and duration in NDM women (total effect: 14.54, indirect effect 2.03, p < 0.001), but it did not mediate the association in women with GDM (total effect: 14.76, indirect effect 1.31, p = 0.22).; Differences in supplementation between these groups were primarily driven by differences in intentions to breastfeed exclusively | Logistic regression for crude and adjusted associations between GDM history and exclusive breastfeeding intention. Multivariable logistic regression for association between breastfeeding intention and hospital supplementation.; Mediation analysis to assess whether hospital supplementation mediated the association between exclusive breastfeeding intention and breastfeeding duration, also by GDM.; Potential confounders considered: maternal age (years), race/ethnicity (White, Black, Hispanic, or other), marital history (currently married versus not currently married), mother received WIC support while pregnant (yes versus no), household income as a percentage of federal poverty level (<185%, 185–349%, ‡350%), smoking during third trimester (yes versus no), planning to go back to work (yes versus no), first birth (yes versus no), and prepregnancy body mass index (BMI; kg/m2) by using self-reported height and weight (as a continuous variable or grouped as a three-level categorical variable—; Normal weight: 18.5 kg/m^2^ to <25 kg/m^2^; Overweight 25 kg/m^2^ to <30 kg/m2; Obese ‡30 kg/m^2^) according to Institute of Medicine criteria.; All analyses were adjusted for prepregnancy BMI; none for delivery/infant complications

Abbreviations: aOR = adjusted odds ratio; BMI = body mass index; CDC = Centers for Disease Control and Prevention; CESD = Center for Epidemiological Studies Depression; CG = control group; Dx = diagnosis; EPDS = Edinburgh Postnatal Depression Scale (EPDS); GDM = gestational diabetes mellitus; hr(s) = hour(s); IG = intervention group; IGT = impaired glucose tolerance; IQR = interquartile range; kg = kilogram; mo(s) = month(s); NGT = normal glucose intolerance; NICU = neonatal intensive care unit; NR = not reported; OGCT = oral glucose challenge test; OGTT = oral glucose tolerance test; PPD = postpartum depression; RCT = randomized controlled trial; RR = risk ratio; SD = standard deviation; STAI = State-Trait Anxiety Inventory; wk(s) = week(s); WIC = Women, Infants and Children Program.

Appendix D Table 2 Evidence for Accuracy of Oral Glucose Challenge Test Screening (KQ4)

Diagnostic criteria | Criteria (OGCT) | Author, Year | Country | Timing (Weeks’ Gestation) | Number Analyzed | Prevalence (%) | Sensitivity (%) | Specificity (%) | Accuracy (%)
CC | 130 mg/dL | De Los Monteros, 1999^100^ | Mexico | 24-28 | 445 | 11.7 | 90.4 | 80.9 | 82.0
CC | 130 mg/dL | Poomalar 2013^115^ | India | 22-28^b^ | 500 | 7.2 | 75.0 | 86.4 | 85.6
CC | 130 mg/dL | Sham, 2014^a^,^122^ | India | 24-28 | 89 | 13.5 | 100.0 | 24.7 | 34.8
CC | 135 mg/dL | De Los Monteros, 1999^100^ | Mexico | 24-28 | 445 | 11.7 | 88.4 | 86.1 | 86.3
CC | 135 mg/dL | Perucchini, 1999^112^ | Switzerland | 24-28 | 520 | 10.2 | 60.4 | 88.0 | 85.2
CC | 135 mg/dL | Poomalar, 2013^115^ | India | 22-28^b^ | 500 | 7.2 | 75.0 | 90.1 | 89.0
CC | 135 mg/dL | Sham, 2014^c^,^122^ | India | 24-28 | 89 | 13.5 | 100.0 | 31.2 | 40.4
CC | 140 mg/dL | Ayach, 2006^93^ | Brazil | 24-28 | 341 | 3.8 | 76.9 | 86.6 | 86.2
CC | 140 mg/dL | De Los Monteros, 1999^100^ | Mexico | 24-28 | 445 | 11.7 | 88.5 | 87.0 | 87.2
CC | 140 mg/dL | Navid, 2014^108^ | Pakistan | 24-28 | 100 | 4.0 | 1.00 | 84.4 | 85.0
CC | 140 mg/dL | Perucchini, 1999^112^ | Switzerland | 24-28 | 520 | 10.2 | 58.5 | 91.0 | 87.7
CC | 140 mg/dL | Poomalar, 2013^115^ | India | 22-28^b^ | 500 | 7.2 | 75.0 | 92.0 | 90.8
CC | 140 mg/dL | Sermer, 1998^120^ | Canada | 25-27 | 3836 | 6.9 | 67.4 | 83.5 | 82.4
CC | 140 mg/dL | Sham, 2014^d^,^122^ | India | 24-28 | 89 | 13.5 | 100.0 | 44.2 | 51.7
CC | 140 mg/dL | Weerakiet, 2006^129^ | Thailand | 21-27 | 359 (with risk factors | 16.7 | 90.0 | 61.0 | 65.9
IADPSG | 130 mg/dL | Benhalima, 2018^95^ | Belgium | 24-26 | 1811 | 12.6 | 72.4 | 70.2 | 70.5
IADPSG | 130 mg/dL | Olagbuji, 2017^110^ | Nigeria | 24-31 | 280 | 16.4 | 47.8 | 84.2 | 78.2
IADPSG | 135 mg/dL | Benhalima, 2018^95^ | Belgium | 24-26 | 1811 | 12.6 | 66.2 | 76.1 | 74.8
IADPSG | 135 mg/dL | Olagbuji, 2017^110^ | Nigeria | 24-31 | 280 | 16.4 | 39.1 | 88.0 | 80.0
IADPSG | 140 mg/dL | Benhalima, 2018^95^ | Belgium | 24-26 | 1811 | 12.6 | 59.7 | 81.0 | 78.3
IADPSG | 140 mg/dL | Olagbuji, 2017^110^ | Nigeria | 24-31 | 280 | 16.4 | 37.0 | 93.2 | 83.9
NDDG | 130 mg/dL | De Los Monteros, 1999^100^ | Mexico | 24-28 | 445 | 9.7 | 90.7 | 79.4 | 80.4
NDDG | 135 mg/dL | De Los Monteros, 1999^100^ | Mexico | 24-28 | 445 | 9.7 | 88.5 | 84.2 | 84.7
NDDG | 135 mg/dL | Uncu, 1995^127^ | Turkey | 24-28 | 42 | 33.0 | 78.6 | 46.4 | 57.1
NDDG | 140 mg/dL | Cetin, 1997^98^ | Turkey | 24-28 | 274 | 6.2 | 64.7 | 87.5 | 86.1
NDDG | 140 mg/dL | De Los Monteros, 1999^100^ | Mexico | 24-28 | 445 | 9.7 | 88.4 | 85.3 | 85.6
NDDG | 140 mg/dL | Lamar, 1999^106^ | United States | 24-28 | 136 | 3.7 | 80.0 | 82.4 | 82.4
NDDG | 140 mg/dL | Perea-Carrasco, 2002^111^ | Spain | 24-28 | 642 | 16.4 | 98.1 | 75.0 | 76.9
NDDG | 140 mg/dL | Sermer, 1998^120^ | Canada | 25-27 | 3836 | 3.8 | 76.6 | 82.2 | 82.0
NDDG | 140 mg/dL | Uncu, 1995^127^ | Turkey | 24-28 | 42 | 33.0 | 78.6 | 53.6 | 61.9
Sacks | 130 mg/dL | De Los Monteros, 1999^100^ | Mexico | 24-28 | 445 | 13.9 | 88.7 | 82.2 | 83.1
Sacks | 135 mg/dL | De Los Monteros, 1999^100^ | Mexico | 24-28 | 445 | 13.9 | 83.9 | 87.2 | 86.7
Sacks | 140 mg/dL | De Los Monteros, 1999^100^ | Mexico | 24-28 | 445 | 13.9 | 82.3 | 88.0 | 87.2

Abbreviations: CC = Carpenter Coustan; IADPSG = International Association of Diabetes and Pregnancy Study Groups; mg/dl = milligrams per deciliter; NDDG = National Diabetes Data Group; OGCT = oral glucose challenge test

a Used a 131 mg/dL cutoff.

b Some up to 37 weeks’ GA.

c Used a 135.5 mg/dL cutoff.

d Used a 141 mg/dL cutoff.

Appendix D Table 3 Evidence for Accuracy of Fasting Plasma Glucose Screening (KQ4)

Diagnostic criteria | Criteria (FPG) | Author, Year | Country | Timing (Weeks’ Gestation) | Number Analyzed | Prevalence (%) | Sensitivity (%) | Specificity (%) | Accuracy (%)
CC | 67 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 100.0 | 0.0 | 3.3
CC | 69 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 100.0 | 1.3 | 3.5
CC | 70 mg/dL | Agarwal, 2000^a^,^90^ | United Arab Emirates | 24-28 | 1276 (+ hx) | 31.0 | 99.2 | 7.0 | 35.7
CC | 70 mg/dL | Agarwal, 2000^a^,^90^ | United Arab Emirates | 24-28 | 368 (+ OGCT) | 31.8 | 99.1 | 4.4 | 34.5
CC | 70.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 100.0 | 2.6 | 3.8
CC | 71.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 100.0 | 3.9 | 4.1
CC | 72.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 100.0 | 16.9 | 6.8
CC | 73.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 100.0 | 19.5 | 7.3
CC | 75 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 100.0 | 38.2 | 11.3
CC | 76 mg/dL | Agarwal, 2006^b^,^89^ | United Arab Emirates | 24-28 | 4528 | 14.7 | 99.2 | 10.8 | 22.5
CC | 76 mg/dL | Agarwal, 2000^a^,^90^ | United Arab Emirates | 24-28 | 1276 (+ hx) | 31.0 | 73.2 | 17.0 | 42.2
CC | 76 mg/dL | Agarwal, 2000^a^,^90^ | United Arab Emirates | 24-28 | 368 (+ OGCT) | 31.8 | 98.3 | 12.4 | 39.7
CC | 76.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 100.0 | 32.5 | 10.1
CC | 77.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 91.7 | 37.7 | 10.9
CC | 78.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 91.7 | 40.3 | 11.4
CC | 79 mg/dL | Agarwal, 2000^a^,^90^ | United Arab Emirates | 24-28 | 1276 (+ hx) | 31.0 | 94.7 | 32.4 | 51.7
CC | 79 mg/dL | Agarwal, 2000^a^,^90^ | United Arab Emirates | 24-28 | 368 (+ OGCT) | 31.8 | 96.6 | 27.9 | 49.7
CC | 79 mg/dL | Agarwal, 2006^b^,^89^ | United Arab Emirates | 24-28 | 4528 | 14.7 | 97.0 | 29.4 | 38.4
CC | 79 mg/dL | Perucchini, 1999^112^ | Switzerland | 24-28 | 520 | 10.2 | 100.0 | 39.0 | 45.2
CC | 79.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 91.7 | 46.8 | 12.8
CC | 80 mg/dL | Poomalar, 2013^115^ | India | 22-28 | 500 | 7.2 | 88.0 | 94.0 | 93.6
CC | 80.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 91.7 | 50.6 | 56.1
CC | 81.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 83.3 | 55.8 | 14.4
CC | 82.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 75.0 | 62.3 | 15.5
CC | 83.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 66.7 | 67.5 | 16.3
CC | 85 mg/dL | Agarwal, 2006^b^,^89^ | United Arab Emirates | 24-28 | 4528 | 14.7 | 89.7 | 53.0 | 57.9
CC | 85 mg/dL | Agarwal, 2000^a^,^90^ | United Arab Emirates | 24-28 | 1276 (+ hx) | 31.0 | 88.1 | 52.6 | 63.6
CC | 85 mg/dL | Agarwal, 2000^a^,^90^ | United Arab Emirates | 24-28 | 368 (+ OGCT) | 31.8 | 91.5 | 51.4 | 64.1
CC | 85 mg/dL | Poomalar, 2013^115^ | India | 22-28 | 500 | 7.2 | 88.0 | 95.0 | 94.5
CC | 85 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 66.7 | 71.4 | 17.1
CC | 86 mg/dL | Poomalar, 2013^115^ | India | 22-28 | 500 | 7.2 | 80.0 | 96.0 | 94.8
CC | 86.5 mg/dL | Perucchini, 1999^112^ | Switzerland | 24-28 | 520 | 10.2 | 81.1 | 76.0 | 76.5
CC | 86.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 66.7 | 72.7 | 17.4
CC | 87.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 66.7 | 75.3 | 17.9
CC | 88 mg/dL | Agarwal, 2006^b^,^89^ | United Arab Emirates | 24-28 | 4528 | 14.7 | 84.7 | 70.6 | 72.5
CC | 88.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 66.7 | 81.8 | 19.3
CC | 89.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 66.7 | 84.4 | 19.8
CC | 90 mg/dL | Agarwal, 2006^b^,^89^ | United Arab Emirates | 24-28 | 4528 | 14.7 | 82.6 | 76.1 | 76.9
CC | 90 mg/dL | Agarwal, 2000^a^,^90^ | United Arab Emirates | 24-28 | 1276 (+ve hx) | 31.0 | 82.1 | 74.8 | 77.0
CC | 90 mg/dL | Agarwal, 2000^a^,^90^ | United Arab Emirates | 24-28 | 368 (+ve OGCT) | 31.8 | 84.6 | 72.1 | 76.1
CC | 90 mg/dL | Poomalar, 2013^115^ | India | 22-28 | 500 | 7.2 | 72.0 | 97.0 | 95.2
CC | 90 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 66.7 | 66.7 | 66.7
CC | 90.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 66.7 | 87.0 | 20.4
CC | 91.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 66.7 | 89.6 | 20.9
CC | 92 mg/dL | Kauffman, 2006^104^ | Unites States | 24-28 | 123 | 20.3 | 76.0 | 89.8 | 87.0
CC | 92 mg/dL | Chevalier, 2011^a^,^99^ | France | 24-28 | 1383 | 23.9 | 26.4 | 95.2 | 78.8
CC | 92.5 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 50.0 | 96.1 | 21.7
CC | 94 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 41.7 | 97.4 | 21.7
CC | 95 mg/dL | Chevalier, 2011^a^,^99^ | France | 24-28 | 1383 | 23.9 | 19.4 | 97.7 | 79.0
CC | 95 mg/dL | Poomalar, 2013^115^ | India | 22-28 | 500 | 7.2 | 61.0 | 100.0 | 97.2
CC | 95.5 mg/dL | Agarwal, 2006^b^,^89^ | United Arab Emirates | 24-28 | 4528 | 14.7 | 69.0 | 89.8 | 87.1
CC | 95.5 mg/dL | Agarwal, 2000^a^,^90^ | United Arab Emirates | 24-28 | 1276 (+ hx) | 31.0 | 73.5 | 94.0 | 87.6
CC | 95.5 mg/dL | Agarwal, 2000^a^,^90^ | United Arab Emirates | 24-28 | 368 (+ OGCT) | 31.8 | 79.5 | 90.8 | 87.2
CC | 96 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 41.7 | 98.7 | 22.0
CC | 98 mg/dL | Sham, 2014^122^ | India | 24-28 | 89 | 13.5 | 33.3 | 98.7 | 21.7
IADPSG | 72 mg/dL | Zhu, 2013a^131^ | China | 24-28 | 24854 | 12.7 | 97.3 | 12.4 | 23.2
IADPSG | 72 mg/dL | Zhu, 2013b^132^ | China | Median (SD); 13.4 (3.5) | 17186 | 17.5 | 95.0 | 9.0 | 24.0
IADPSG | 74 mg/dL | Zhu, 2013a^131^ | China | 24-28 | 24854 | 12.7 | 95.8 | 18.3 | 28.1
IADPSG | 74 mg/dL | Zhu, 2013b^132^ | China | Median (SD); 13.4 (3.5) | 17186 | 17.5 | 93.0 | 14.0 | 27.8
IADPSG | 76 mg/dL | Agarwal, 2018^92^ | India | 80% 24-28 | 6520 | 18.3 | 97.8 | 28.6 | 41.3
IADPSG | 76 mg/dL | Zhu, 2013a^131^ | China | 24-28 | 24854 | 12.7 | 93.5 | 26.0 | 34.6
IADPSG | 76 mg/dL | Zhu, 2013b^132^ | China | Median (SD); 13.4 (3.5) | 17186 | 17.5 | 89.0 | 22.0 | 33.7
IADPSG | 77.5 mg/dL | Agarwal, 2018^92^ | India | 80% 24-28 | 6520 | 18.3 | 95.6 | 43.9 | 53.3
IADPSG | 77.5 mg/dL | Zhu, 2013a^131^ | China | 24-28 | 24854 | 12.7 | 91.1 | 35.5 | 42.5
IADPSG | 77.5 mg/dL | Zhu, 2013b^132^ | China | Median (SD); 13.4 (3.5) | 17186 | 17.5 | 84.0 | 29.0 | 38.6
IADPSG | 78.5 mg/dL | Pezeshki, 2019^113^ | Iran | 24-48 | 356 | 8.4 | 63.3 | 73.0 | 72.2
IADPSG | 79 mg/dL | Agarwal, 2018^92^ | India | 80% 24-28 | 6520 | 18.3 | 92.6 | 55.7 | 62.4
IADPSG | 79 mg/dL | Saeedi, 2018^c^,^119^ | Sweden | 24-28 | 3616 | 11.7 | 96.0 | 57.0 | 61.6
IADPSG | 79 mg/dL | Zhu, 2013a^131^ | China | 24-28 | 24854 | 12.7 | 87.8 | 45.8 | 51.1
IADPSG | 79 mg/dL | Zhu, 2013b^132^ | China | Median (SD); 13.4 (3.5) | 17186 | 17.5 | 78.0 | 38.0 | 45.0
IADPSG | 79.5 mg/dL | Pezeshki, 2019^113^ | Iran | 20-24 | 356 | 8.4 | 76.7 | 76.1 | 76.1
IADPSG | 80 mg/dL | Trujillo, 2014^126^ | Brazil | 24-28 | 4926 | 18.0 | 96.9 | 55.0 | 62.5
IADPSG | 81 mg/dL | Dickson, 2019^38^ | South Africa | 24-28 | 589 | 7.0 | 98.0 | 80.0 | 81.0
IADPSG | 81 mg/dL | Zhu, 2013a^131^ | China | 24-28 | 24854 | 12.7 | 83.7 | 56.3 | 59.8
IADPSG | 81 mg/dL | Zhu, 2013b^132^ | China | Median (SD); 13.4 (3.5) | 17186 | 17.5 | 71.0 | 48.0 | 52.0
IADPSG | 82 mg/dL | Lekva, 2018^107^ | Norway | 14-16 | 985 | 24.5 | 44.1 | 97.9 | 91.5
IADPSG | 83 mg/dL | Saeedi, 2018^c^,^119^ | Sweden | 24-28 | 3616 | 11.7 | 95.0 | 67.0 | 70.3
IADPSG | 83 mg/dL | Zhu, 2013a^131^ | China | 24-28 | 24854 | 12.7 | 78.9 | 67.0 | 68.5
IADPSG | 83 mg/dL | Zhu, 2013b^132^ | China | Median (SD); 13.4 (3.5) | 17186 | 17.5 | 63.0 | 58.0 | 58.9
IADPSG | 84.5 mg/dL | Sharma, 2018^123^ | India | <20 | 246 | 6.5 | 93.8 | 74.3 | 75.6
IADPSG | 85 mg/dL | Agarwal, 2018^92^ | India | 80% 24-28 | 6520 | 18.3 | 82.1 | 81.6 | 81.7
IADPSG | 85 mg/dL | Trujillo, 2014^126^ | Brazil | 24-28 | 4926 | 18.0 | 92.5 | 78.4 | 80.9
IADPSG | 85 mg/dL | Zhu, 2013a^131^ | China | 24-28 | 24854 | 12.7 | 74.1 | 76.4 | 76.1
IADPSG | 85 mg/dL | Zhu, 2013b^132^ | China | Median (SD); 13.4 (3.5) | 17186 | 17.5 | 55.0 | 68.0 | 65.7
IADPSG | 86.5 mg/dL | Saeedi, 2018^c^,^119^ | Sweden | 24-28 | 3616 | 11.7 | 91.0 | 85.0 | 85.7
IADPSG | 86.5 mg/dL | Zhu, 2013a^131^ | China | 24-28 | 24854 | 12.7 | 69.1 | 84.1 | 82.2
IADPSG | 86.5 mg/dL | Zhu, 2013b^132^ | China | Median (SD); 13.4 (3.5) | 17186 | 17.5 | 47.0 | 76.0 | 70.9
IADPSG | 88 mg/dL | Zhu, 2013a^131^ | China | 24-28 | 24854 | 12.7 | 64.7 | 90.8 | 87.5
IADPSG | 88 mg/dL | Zhu, 2013b^132^ | China | Median (SD); 13.4 (3.5) | 17186 | 17.5 | 39.0 | 83.0 | 75.3
IADPSG | 90 mg/dL | Agarwal, 2018^92^ | India | 80% 24-28 | 6520 | 18.3 | 70.1 | 97.9 | 92.8
IADPSG | 90 mg/dL | Saeedi, 2018^c^,^119^ | Sweden | 24-28 | 3616 | 11.7 | 88.9 | 96.0 | 95.2
IADPSG | 90 mg/dL | Trujillo, 2014^126^ | Brazil | 24-28 | 4926 | 18.0 | 88.3 | 95.1 | 93.9
IADPSG | 90 mg/dL | Zhu, 2013a^131^ | China | 24-28 | 24854 | 12.7 | 59.8 | 96.0 | 91.4
IADPSG | 90 mg/dL | Zhu, 2013b^132^ | China | Median (SD); 13.4 (3.5) | 17186 | 17.5 | 31.0 | 89.0 | 78.9
HAPO 2.0 | 79 mg/dL | Saeedi, 2018^119^ | Sweden | 24-28 | 3616 | 7.2 | 96.0 | 54.0 | 58.1
HAPO 2.0 | 83 mg/dL | Saeedi, 2018^119^ | Sweden | 24-28 | 3616 | 7.2 | 96.0 | 64.0 | 67.1
HAPO 2.0 | 86.5 mg/dL | Saeedi, 2018^119^ | Sweden | 24-28 | 3616 | 7.2 | 93.0 | 81.0 | 82.2
HAPO 2.0 | 90 mg/dL | Saeedi, 2018^119^ | Sweden | 24-28 | 3616 | 7.2 | 91.0 | 92.0 | 91.9
HAPO 2.0 | 94 mg/dL | Saeedi, 2018^119^ | Sweden | 24-28 | 3616 | 7.2 | 89.0 | 98.0 | 97.1
NDDG | 93 mg/dL | Kauffman, 2006^104^ | United States | 24-28 | 123 | 13.0 | 81.3 | 87.9 | 87.0
Sacks | 70 mg/dL | Sacks, 2003^118^ | United States | Mean (SD) 10.7 (4.9) | 4507 | 6.7 | 100.0 | 2.0 | 8.6
Sacks | 75 mg/dL | Sacks, 2003^118^ | United States | Mean (SD) 10.7 (4.9) | 4507 | 6.7 | 97.0 | 9.0 | 14.9
Sacks | 80 mg/dL | Sacks, 2003^118^ | United States | Mean (SD) 10.7 (4.9) | 4507 | 6.7 | 89.0 | 25.0 | 29.3
Sacks | 85 mg/dL | Sacks, 2003^118^ | United States | Mean (SD) 10.7 (4.9) | 4507 | 6.7 | 74.0 | 52.0 | 53.5
Sacks | 90 mg/dL | Sacks, 2003^118^ | United States | Mean (SD) 10.7 (4.9) | 4507 | 6.7 | 52.0 | 78.0 | 76.3
Sacks | 95 mg/dL | Sacks, 2003^118^ | United States | Mean (SD) 10.7 (4.9) | 4507 | 6.7 | 34.0 | 92.0 | 88.1

Abbreviations: CC = Carpenter Coustan; FPG = fasting plasma glucose; Hx = history (clinical); HAPO = Hyperglycemia and Adverse Pregnancy Outcomes Study Group; IADPSG = International Association of Diabetes and Pregnancy Study Groups; NDDG = National Diabetes Data Group; OGCT = oral glucose challenge test; SD = standard deviation.

a High-risk population (In Agarwal 2000, all referred for OGTT had either a positive OGCT (+OGCT) or were referred on clinical grounds (+hx); in Chevalier 2011, all had post-load glycaemia >130 mg/dL on 50 g GCT)

b Used 75g glucose load, 2 hour testing interval

c Modified IADPSG criteria due to absence of a 1-hour value

Appendix D Table 4 Evidence for Accuracy of Hemoglobin A1C Screening vs. OGTT Both at 24 to 28 Weeks of Gestation (KQ4)

Diagnostic Criteria | Threshold (HbA1c) | Author, Year | Country | Timing of Index & Timing of OGTT (Weeks’ Gestation) | Number Analyzed | Prevalence (%) | Sensitivity (%) | Specificity (%) | Accuracy (%)
CC | ≥4.5% | Agarwal, 2001^91^ | United Arab Emirates | HbA1c: 27.1 ± 6.1; OGTT: NR | 337 (+ve Hx); 93 (+ve GCT) | 27.0 | 98.3 | 4.5 | 29.6
CC | ≥5.0% | Agarwal, 2001^91^ | United Arab Emirates | HbA1c: 27.1 ± 6.1; OGTT: NR | 337 (+ve Hx); 93 (+ve GCT) | 27.0 | 92.1 | 27.6 | 44.8
CC | ≥5.1% | Braga, 2019^97^ | Brazil | 24-28 | 176 | 44.3 | 70.9 | 71.6 | 71.0
CC | ≥5.1% | Veres, 2015^128^ | Romania | 24-28 | 132 (+ Hx) | 19.7 | 100.0 | 79.3 | 83.3
CC | ≥5.5% | Agarwal, 2001^91^ | United Arab Emirates | HbA1c: 27.1 ± 6.1; OGTT: NR | 337 (+ve Hx); 93 (+ve GCT) | 27.0 | 72.8 | 66.0 | 67.8
CC | ≥5.7% | Ho, 2017^102^ | China | HbA1c: 22-29; OGTT: 21-36 | 1989 (+ve GCT) | 29.0 | 45.2 | 84.1 | 72.8
CC | ≥5.7% | Veres, 2015^128^ | Romania | 24-28 | 132 (+ Hx) | 19.7 | 57.4 | 91.5 | 84.8
CC | ≥6.0% | Agarwal, 2001^91^ | United Arab Emirates | HbA1c: 27.1 ± 6.1; OGTT: NR | 337 (+ve Hx); 93 (+ve GCT) | 27.0 | 34.2 | 91.0 | 75.8
CC 75g 2h | ≥5.5% | Rajput, 2012^116^ | India | 24-28 | 607 | 7.1 | 85.7 | 61.1 | 62.9
CC 75g 2h | ≥5.95% | Rajput, 2012^116^ | India | 24-28 | 607 | 7.1 | 28.6 | 97.2 | 92.3
NDDG | ≥4.5% | Siricharoenthai, 2019^124^ | Thailand | 28.9 ± 5.2 | 114 (+ve GCT) | 30.7 | 100.0 | 7.6 | 36.0
NDDG | ≥5.8% | Siricharoenthai, 2019^124^ | Thailand | 28.9 ± 5.2 | 114 (+ve GCT) | 30.7 | 17.1 | 100.0 | 74.6
NDDG | ≥7.2% | Uncu, 1995^127^ | Turkey | 24-28 | 42 | 33.3 | 64.0 | 64.0 | 64.3
IADPSG | ≥4.6% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 95.9 | 4.6 | 15.4
IADPSG | ≥4.6% | Sevket, 2014^121^ | Turkey | 24-28 | 339 | 15.6 | 96.2 | 23.0 | 34.5
IADPSG | ≥4.7% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 95.9 | 10.0 | 20.2
IADPSG | ≥4.8% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 81.6 | 18.0 | 25.6
IADPSG | ≥4.9% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 73.5 | 31.4 | 36.5
IADPSG | ≥5.0% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 69.4 | 51.9 | 54.2
IADPSG | ≥5.1% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 61.2 | 67.6 | 66.9
IADPSG | ≥5.2% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 55.1 | 79.7 | 76.7
IADPSG | ≥5.2% | Rajput, 2012^116^ | India | 24-28 | 607 | 23.7 | 83.1 | 40.5 | 50.7
IADPSG | ≥5.2% | Sevket, 2014^121^ | Turkey | 24-28 | 339 | 15.6 | 64.2 | 67.5 | 67.0
IADPSG | ≥5.3% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 34.7 | 88.4 | 82.1
IADPSG | ≥5.3% | Soumya, 2015^125^ | India | 24-28 | 500 | 9.0 | 95.6 | 51.0 | 55.0
IADPSG | ≥5.4% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 26.5 | 95.4 | 87.3
IADPSG | ≥5.5% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 22.4 | 98.2 | 89.2
IADPSG | ≥5.6% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 12.2 | 99.0 | 88.8
IADPSG | ≥5.7% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 10.2 | 99.5 | 89.0
IADPSG | ≥5.7% | Sevket, 2014^121^ | Turkey | 24-28 | 339 | 15.6 | 26.4 | 90.5 | 80.5
IADPSG | ≥5.7% | Soumya, 2015^125^ | India | 24-28 | 500 | 9.0 | 73.3 | 75.6 | 75.4
IADPSG | ≥5.8% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 8.2 | 99.7 | 89.0
IADPSG | ≥5.9% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 6.1 | 99.7 | 88.5
IADPSG | ≥6.0% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 4.1 | 99.7 | 88.1
IADPSG | ≥6.0% | Rajput, 2012^116^ | India | 24-28 | 607 | 23.7 | 11.9 | 97.1 | 76.9
IADPSG | ≥6.1% | Khalafallah, 2016^105^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 2.0 | 99.7 | 88.1
IADPSG | ≥6.1% | Soumya, 2015^125^ | India | 24-28 | 500 | 9.0 | 46.7 | 95.0 | 90.6
CC | ≥4.5% | Agarwal, 2001^18^ | United Arab Emirates | HbA1c: 27.1 ± 6.1; OGTT: NR | 337 (+ve Hx); 93 (+ve GCT) | 27.0 | 98.3 | 4.5 | 29.6
CC | ≥5.0% | Agarwal, 2001^18^ | United Arab Emirates | HbA1c: 27.1 ± 6.1; OGTT: NR | 337 (+ve Hx); 93 (+ve GCT) | 27.0 | 92.1 | 27.6 | 44.8
CC | ≥5.1% | Braga, 2019^26^ | Brazil | 24-28 | 176 | 44.3 | 70.9 | 71.6 | 71.0
CC | ≥5.1% | Veres, 2015^59^ | Romania | 24-28 | 132 (+ Hx) | 19.7 | 100.0 | 79.3 | 83.3
CC | ≥5.5% | Agarwal, 2001^18^ | United Arab Emirates | HbA1c: 27.1 ± 6.1; OGTT: NR | 337 (+ve Hx); 93 (+ve GCT) | 27.0 | 72.8 | 66.0 | 67.8
CC | ≥5.7% | Ho, 2017^32^ | China | HbA1c: 22-29; OGTT: 21-36 | 1989 (+ve GCT) | 29.0 | 45.2 | 84.1 | 72.8
CC | ≥5.7% | Veres, 2015^59^ | Romania | 24-28 | 132 (+ Hx) | 19.7 | 57.4 | 91.5 | 84.8
CC | ≥6.0% | Agarwal, 2001^18^ | United Arab Emirates | HbA1c: 27.1 ± 6.1; OGTT: NR | 337 (+ve Hx); 93 (+ve GCT) | 27.0 | 34.2 | 91.0 | 75.8
CC 75g 2h | ≥5.5% | Rajput, 2012^46^ | India | 24-28 | 607 | 7.1 | 85.7 | 61.1 | 62.9
CC 75g 2h | ≥5.95% | Rajput, 2012^46^ | India | 24-28 | 607 | 7.1 | 28.6 | 97.2 | 92.3
NDDG | ≥4.5% | Siricharoenthai, 2019^55^ | Thailand | 28.9 ± 5.2 | 114 (+ve GCT) | 30.7 | 100.0 | 7.6 | 36.0
NDDG | ≥5.8% | Siricharoenthai, 2019^55^ | Thailand | 28.9 ± 5.2 | 114 (+ve GCT) | 30.7 | 17.1 | 100.0 | 74.6
NDDG | ≥7.2% | Uncu, 1995^58^ | Turkey | 24-28 | 42 | 33.3 | 64.0 | 64.0 | 64.3
IADPSG | ≥4.6% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 95.9 | 4.6 | 15.4
IADPSG | ≥4.6% | Sevket, 2014^52^ | Turkey | 24-28 | 339 | 15.6 | 96.2 | 23.0 | 34.5
IADPSG | ≥4.7% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 95.9 | 10.0 | 20.2
IADPSG | ≥4.8% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 81.6 | 18.0 | 25.6
IADPSG | ≥4.9% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 73.5 | 31.4 | 36.5
IADPSG | ≥5.0% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 69.4 | 51.9 | 54.2
IADPSG | ≥5.1% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 61.2 | 67.6 | 66.9
IADPSG | ≥5.2% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 55.1 | 79.7 | 76.7
IADPSG | ≥5.2% | Rajput, 2012^46^ | India | 24-28 | 607 | 23.7 | 83.1 | 40.5 | 50.7
IADPSG | ≥5.2% | Sevket, 2014^52^ | Turkey | 24-28 | 339 | 15.6 | 64.2 | 67.5 | 67.0
IADPSG | ≥5.3% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 34.7 | 88.4 | 82.1
IADPSG | ≥5.3% | Soumya, 2015^56^ | India | 24-28 | 500 | 9.0 | 95.6 | 51.0 | 55.0
IADPSG | ≥5.4% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 26.5 | 95.4 | 87.3
IADPSG | ≥5.5% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 22.4 | 98.2 | 89.2
IADPSG | ≥5.6% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 12.2 | 99.0 | 88.8
IADPSG | ≥5.7% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 10.2 | 99.5 | 89.0
IADPSG | ≥5.7% | Sevket, 2014^52^ | Turkey | 24-28 | 339 | 15.6 | 26.4 | 90.5 | 80.5
IADPSG | ≥5.7% | Soumya, 2015^56^ | India | 24-28 | 500 | 9.0 | 73.3 | 75.6 | 75.4
IADPSG | ≥5.8% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 8.2 | 99.7 | 89.0
IADPSG | ≥5.9% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 6.1 | 99.7 | 88.5
IADPSG | ≥6.0% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 4.1 | 99.7 | 88.1
IADPSG | ≥6.0% | Rajput, 2012^46^ | India | 24-28 | 607 | 23.7 | 11.9 | 97.1 | 76.9
IADPSG | ≥6.1% | Khalafallah, 2016^35^ | Australia | 25.7 ± 3.3 | 480 | 11.9 | 2.0 | 99.7 | 88.1
IADPSG | ≥6.1% | Soumya, 2015^56^ | India | 24-28 | 500 | 9.0 | 46.7 | 95.0 | 90.6

Abbreviations: CC = Carpenter Coustan; GCT = glucose challenge test; Hx = history; IADPSG = International Association of Diabetes and Pregnancy Study Groups; NDDG = National Diabetes Data Group; OGTT = oral glucose tolerance test

Appendix D Table 5 Evidence for Accuracy of Hemoglobin A1C Screening, Early HbA1c and OGTT at 24 to 28 Weeks of Gestation (KQ4)

Diagnostic Criteria | Threshold (HbA1c) | Author, Year | Country | Timing of Index & Timing of OGTT (Weeks’ Gestation) | Number Analyzed | Prevalence (%) | Sensitivity (%) | Specificity (%) | Accuracy (%)
NDDG | ≥4.5% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 99.3 | 2.4 | 15.1
NDDG | ≥4.6% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 98.7 | 4.2 | 16.6
NDDG | ≥4.7% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 98.0 | 6.7 | 18.7
NDDG | ≥4.8% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 96.7 | 10.1 | 21.5
NDDG | ≥4.9% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 92.8 | 17.9 | 27.7
NDDG | ≥5.0% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 84.9 | 27.1 | 34.7
NDDG | ≥5.1% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 78.9 | 39.7 | 44.8
NDDG | ≥5.2% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 73.0 | 53.7 | 56.2
NDDG | ≥5.3% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 64.5 | 64.2 | 64.2
NDDG | ≥5.4% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 53.9 | 74.6 | 71.8
NDDG | ≥5.5% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 44.1 | 82.9 | 77.8
NDDG | ≥5.6% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 32.9 | 89.3 | 81.9
NDDG | ≥5.7% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 25.7 | 92.5 | 83.8
NDDG | ≥5.8% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 19.7 | 94.9 | 85.1
NDDG | ≥5.9% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 14.5 | 97.5 | 86.6
NDDG | ≥6.0% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 10.5 | 98.6 | 87.0
NDDG | ≥6.1% | Benaiges, 2017^94^ | Spain | HbA1c: ≤12; OGTT: 24-28 | 1158 | 13.1 | 7.2 | 99.4 | 87.3
IADPSG | ≥4.0% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 100.0 | 0.7 | 16.1
IADPSG | ≥4.1% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 100.0 | 2.1 | 17.2
IADPSG | ≥4.2% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 99.1 | 3.6 | 18.4
IADPSG | ≥4.3% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 96.3 | 5.8 | 19.9
IADPSG | ≥4.4% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 89.7 | 11.0 | 23.2
IADPSG | ≥4.5% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 85.0 | 17.0 | 27.5
IADPSG | ≥4.6% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 76.6 | 27.6 | 35.2
IADPSG | ≥4.7% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 66.4 | 39.1 | 43.3
IADPSG | ≥4.8% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 54.2 | 53.0 | 53.2
IADPSG | ≥4.9% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 39.3 | 69.1 | 64.5
IADPSG | ≥5.0% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 28.0 | 82.8 | 74.3
IADPSG | ≥5.1% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 21.5 | 89.5 | 79.0
IADPSG | ≥5.2% | Poo, 2018^114^ | Singapore | HbA1c: <14; OGTT: 24-28 | 151 | 11.3 | 82.4 | 71.6 | 72.8
IADPSG | ≥5.2% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 15.0 | 95.2 | 82.8
IADPSG | ≥5.3% | Pezeshki, 2019^113^ | Iran | HbA1c: 1^st^ trimester; OGTT: 24-28 | 356 | 8.4 | 80.0 | 80.0 | 80.1
IADPSG | ≥5.3% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 8.4 | 98.1 | 84.2
IADPSG | ≥5.4% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 5.6 | 99.3 | 84.8
IADPSG | ≥5.6% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 4.7 | 99.8 | 85.1
IADPSG | ≥5.7% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 1.9 | 100.0 | 84.8
IADPSG | ≥5.8% | Wu, 2018^130^ | China | HbA1c: 12-16; OGTT: 24-28 | 690 | 15.5 | 0.9 | 100.0 | 84.6

Abbreviations: CC = Carpenter Coustan; HbA1c = hemoglobin A1c; IADPSG = International Association of Diabetes and Pregnancy Study Groups; NDDG = National Diabetes Data Group; OGTT = oral glucose tolerance test; wGA = weeks’ gestational age

Appendix D Table 6 Evidence for Accuracy of Hemoglobin A1C Screening, HbA1c vs. IADPSG Criteria at Various Timepoints (KQ4)

Threshold (HbA1c) | Author, Year | Country | Timing of Index & Timing of OGTT (Weeks’ Gestation) | N Analyzed | Prevalence (%) | Sensitivity (%) | Specificity (%) | Accuracy (%)
≥4.0% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 100.0 | 0.6 | 13.9
≥4.2% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 100.0 | 3.6 | 16.5
≥4.4% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 97.4 | 8.2 | 20.2
≥4.4% | Odsaeter 2016^109^ | Norway | HbA1c: 18-22; OGTT: 18-22 & 32-36 | 628 | 7.2 | 100.0 | 0.5 | 11.8
≥4.6% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 93.3 | 20.3 | 30.1
≥4.6% | Odsaeter 2016^109^ | Norway | HbA1c: 18-22; OGTT: 18-22 & 32-36 | 628 | 7.2 | 97.8 | 2.4 | 9.2
≥4.7% | Odsaeter 2016^109^ | Norway | HbA1c: 18-22; OGTT: 18-22 & 32-36 | 628 | 7.2 | 95.6 | 16.5 | 22.1
≥4.7% | Odsaeter 2016^109^ | Norway | HbA1c: 18-22; OGTT: 18-22 | 677 | 2.4 | 100.0 | 16.6 | 18.6
≥4.8% | Hughes 2014^103^ | New Zealand | <20 | 974 | 17.5 | 100.0 | 3.0 | 22.7
≥4.8% | Odsaeter 2016^109^ | Norway | HbA1c: 18-22; OGTT: 18-22 | 677 | 2.4 | 87.5 | 30.3 | 31.6
≥4.8% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 83.1 | 36.7 | 42.9
≥4.9% | Odsaeter 2016^109^ | Norway | HbA1c: 18-22; OGTT: 18-22 | 677 | 2.4 | 68.8 | 51.2 | 51.7
≥5.0% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 66.2 | 56.2 | 57.5
≥5.2% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 51.3 | 76.4 | 73.1
≥5.2% | Odsaeter 2016^109^ | Norway | HbA1c: 18-22; OGTT: 18-22 & 32-36 | 628 | 7.2 | 13.3 | 95.2 | 89.3
≥5.2% | Odsaeter 2016^109^ | Norway | HbA1c: 18-22; OGTT: 18-22 | 677 | 2.4 | 12.5 | 94.7 | 92.8
≥5.3% | Odsaeter 2016^109^ | Norway | HbA1c: 18-22; OGTT: 18-22 & 32-36 | 628 | 7.2 | 8.9 | 97.8 | 91.4
≥5.3% | Odsaeter 2016^109^ | Norway | HbA1c: 18-22; OGTT: 18-22 | 677 | 2.4 | 6.3 | 97.4 | 95.3
≥5.4% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 31.8 | 88.4 | 80.8
≥5.6% | Saadati 2016^117^ | Iran | <20 | 158 | 29.1 | 40.0 | 80.0 | 68.4
≥5.6% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 18.5 | 94.3 | 84.2
≥5.8% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 11.3 | 97.9 | 86.3
≥5.8% | Odsaeter 2016^109^ | Norway | HbA1c: 18-22; OGTT: 18-22 & 32-36 | 628 | 7.2 | 0.0 | 100.0 | 92.8
≥5.8% | Odsaeter 2016^109^ | Norway | HbA1c: 18-22; OGTT: 18-22 | 677 | 2.4 | 0.0 | 100.0 | 97.6
≥5.9% | Hughes 2014^103^ | New Zealand | <20 | 974 | 17.5 | 18.8 | 98.4 | 84.5
≥6.0% | Hughes 2014^103^ | New Zealand | <20 | 974 | 17.5 | 13.5 | 99.2 | 84.3
≥6.0% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 8.7 | 99.1 | 87.0
≥6.1% | Hughes 2014^103^ | New Zealand | <20 | 974 | 17.5 | 9.9 | 99.7 | 84.1
≥6.2% | Hughes 2014^103^ | New Zealand | <20 | 974 | 17.5 | 5.9 | 99.9 | 83.5
≥6.2% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 4.6 | 99.2 | 86.6
≥6.3% | Hughes 2014^103^ | New Zealand | <20 | 974 | 17.5 | 4.0 | 99.9 | 83.2
≥6.4% | Hughes 2014^103^ | New Zealand | <20 | 974 | 17.5 | 3.3 | 100.0 | 83.2
≥6.4% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 2.6 | 99.5 | 86.6
≥6.6% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 2.1 | 99.6 | 86.6
≥6.8% | Bhavadharini 2017^96^ | India | HbA1c:; 19.5 ± 7.6; Early FPG (dx): 1^st^ trimester; OGTT: 2^nd^/3^rd^ trimester | 1459 | 13.4; (n=33 1^st^ trimester; n=162 2^nd^/3^rd^ trimester) | 1.0 | 99.7 | 86.5

Abbreviations: CC = Carpenter Coustan; IADPSG = International Association of Diabetes and Pregnancy Study Groups; NDDG = National Diabetes Data Group; OGTT = oral glucose tolerance test

Appendix D Table 7 Supplemental Analysis for Association Between More Inclusive GDM and Pregnancy Outcomes (KQ5)

Outcome | Comparison | Number of Studies | Number of Events and Patients (n/N); Exposed | Number of Events and Patients (n/N); Control | Relative Risk [95% CI]; I^2^ | Absolute Risk Difference [95% CI]
Preeclampsia | OAV (CC) vs NGT | 1^201^ | 18/395 | 20/790 | 1.80 [0.96 to 3.36]; NA
Preeclampsia | OAV (NDDG) vs NGT | 3^195,205,217^ | 8/264 | 46/2335; (data and numbers per group were not provided by one study (n=3,637)^217^ | OR 1.65 [1.09 to 2.50]; 0%; (RR 1.62 [1.09 to 2.41]) | 0.015 [0.002 to 0.039]
Preeclampsia | - OAV (NDDG) vs NGT (only blinded studies) | 1^217^ | NR | NR | OR 1.80 [1.10 to 2.95]; NA; (RR, 1.77 [1.1 to 2.82]) (using CER 0.023 from 2 studies in above)
Preeclampsia | IADPSG (excluding CC) vs NGT | 7^193,203,206,210,212,218,221^ | 185/1961 | 829/22198 | 1.93 [1.34 to 2.77]; 69% | 0.0328 [−0.0044 to 0.0700]
Preeclampsia | - IADPSG (excluding CC) vs NGT (profile likelihood) | 7^193,203,206,210,212,218,221^ | 185/1961 | 829/22198 | 1.92 [1.28 to 3.05]; 63.5%
Preeclampsia | - IADPSG (excluding CC) vs NGT (only VHDI studies) | 4^193,206,210,221^ | 140/1135 | 624/14418 | 2.15 [1.30 to 3.58]; 71%
Preeclampsia | - IADPSG (excluding CC) vs NGT (only blinded studies) | 1^221^ | 109/732 | 285/4420 | 2.31 [1.88 to 2.84]; NA
Preeclampsia | IADPSG (excluding CC) vs NGT (adjusted) | 3^203,206,221^ | 1249 | 8410 | aOR 1.99 [1.10 to 3.58]; 56%
Preeclampsia | IADPSG (excluding CC) vs NGT (adjusted; profile likelihood) | 3^203,206,221^ | 1249 | 8410 | aOR 1.77 [1.30 to 3.49]; 0%
Gestational hypertension | OAV (CC) vs NGT | 1^201^ | 13/395 | 32/790 | 0.88 [0.47 to 1.62]; NA
Gestational hypertension | IADPSG (excluding CC) vs NGT | 3^193,210,212^ | 21/554 | 304/8442 | 1.01 [0.45 to 2.24]; 61%
Gestational hypertension | IADPSG (excluding CC) vs NGT (profile likelihood) | 3^193,210,212^ | 21/554 | 304/8442 | 1.05 [0.39 to 2.36]; 38.8%
Gestational hypertension | IADPSG (excluding NDDG) vs NGT | 1^222^ | 52/1175 | 749/21629 | 1.28 [0.97 to 1.68]; NA
Hypertensive disorders of pregnancy | OAV (CC) vs NGT | 5^197,204,208,219,220^ | 95/904 | 391/9458 | 2.09 [1.53 to 2.86]; 40% | 0.050 [0.030 to 0.070]
Hypertensive disorders of pregnancy | - OAV (CC) vs NGT (profile likelihood) | 5^197,204,208,219,220^ | 95/904 | 391/9458 | 2.08 [1.49 to 3.01]; 31%
Hypertensive disorders of pregnancy | - OAV (CC) vs NGT (only VHDI studies) | 4^197,204,208,219^ | 75/615 | 188/2688 | 1.98 [1.34 to 2.94]; 46%
Hypertensive disorders of pregnancy | - OAV (CC) vs NGT (only blinded studies) | 2^208,219^ | 43/383 | 90/1184 | 1.55 [1.07 to 2.25]; 0%
Hypertensive disorders of pregnancy | OAV (CC) vs NGT (adjusted) | 2^197,220^ | 441 | 6595 | aOR 2.14 [1.44 to 3.17]; 0%
Hypertensive disorders of pregnancy | OAV (NDDG) vs NGT | 1^220^ | 17/225 | 210/6992 | 2.52 [1.56 to 4.05]; NA | 0.046 [0.019 to 0.080]
Hypertensive disorders of pregnancy | OAV (NDDG) vs NGT (adjusted) | 1^220^ | 225 | 5971 | aOR 2.09 [1.21 to 3.61]; NA
Hypertensive disorders of pregnancy | IADPSG (excluding CC) vs NGT | 4^198,200,207,212^ | 101/1133 | 1200/16357 | 1.15 [0.93 to 1.41]; 0%
Hypertensive disorders of pregnancy | IADPSG (excluding CC) vs NGT (only VHDI studies) | 3^198,200,207^ | 70/851 | 1166/16075 | 1.22 [0.96 to 1.53]; 0%
Hypertensive disorders of pregnancy | IADPSG (excluding CC) vs NGT (adjusted) | 1^198^ | 181 | 5485 | aOR 1.41 [0.79 to 2.52]; NA
Total cesarean deliveries | OAV (CC) vs NGT | 10^192,196,197,201,209,213,214,216,219,220^ | 525/1312 | 5308/17343 | 1.29 [1.13, 1.47]; 52% | 0.078 [0.034 to 0.123]
Total cesarean deliveries | - OAV (CC) vs NGT (profile likelihood) | 10^192,196,197,201,209,213,214,216,219,220^ | 525/1312 | 5308/17343 | 1.29 [1.12 to 1.49]; 50%
Total cesarean deliveries | - OAV (CC) vs NGT (only VHDI studies) | 8^192,196,197,209,213,214,216,219^ | 217/628 | 2783/9783 | 1.32 [1.10, 1.60]; 48%
Total cesarean deliveries | - OAV (CC) vs NGT (only blinded studies) | 3^196,216,219^ | 56/268 | 1485/6080 | 1.32 [0.99, 1.75]; 0%
Total cesarean deliveries | - OAV (CC) vs NGT (removing Arbib [third trimester only]) | 9^196,197,201,209,213,214,216,219,220^ | 515/1280 | 5249/17066 | 1.28 [1.12, 1.47]; 57%
Total cesarean deliveries | OAV (CC) vs NGT (adjusted) | 1^197^; 1^220^ | 152; 289 | 624; 5971 | aOR 2.20 [1.55 to 3.12]; NA
Total cesarean deliveries | | | | | aOR 1.20 [0.94 to 1.53]; NA
Total cesarean deliveries | OAV (NDDG) vs NGT | 4^195,205,217,220^ | 217/489 | 3399/9327; (data and numbers per group were not provided by one study (n=3,637)^217^ | OR 1.48 [1.27 to 1.72]; 0%; (RR 1.28 [1.17 to 1.39) | 0.092 [0.056 to 0.129]
Total cesarean deliveries | - OAV (NDDG) vs NGT (only VHDI studies) | 3^195,205,217^ | 264 | 2335 | OR 1.42 [1.18 to 1.71]; 0%; (RR 1.24 [1.11 to 1.37]
Total cesarean deliveries | - OAV (NDDG) vs NGT (only blinded studies) | 1^217^ | NR | NR | OR 1.40 [1.10 to 1.78]; NA; (RR 1.27 [1.06 to 1.42]
Total cesarean deliveries | OAV (NDDG) vs NGT(adjusted) | 1^220^ | 225 | 5971 | aOR 1.18 [0.89 to 1.56]; NA
Total cesarean deliveries | IADPSG (excluding CC) vs NGT | 6^193,207,210–212,218^ | 532/1153 | 7004/19084 | 1.20 [1.05 to 1.38]; 77% | 0.0695 [0.0131 to 0.1258]
Total cesarean deliveries | IADPSG (excluding CC) vs NGT (profile likelihood) | 6^193,207,210–212,218^ | 532/1153 | 7004/19084 | 1.20 [1.04 to 1.39]; 68.3%
Total cesarean deliveries | - IADPSG (excluding CC) vs NGT (only VHDI studies) | 4^193,207,210,211^ | 196/713 | 3443/13456 | 1.27 [1.07 to 1.52]; 48%
Total cesarean deliveries | IADPSG (excluding CC) vs NGT (adjusted) | 2^207,211^ | 441 | 5169 | 1.02 [0.49 to 2.12]; NA
Total cesarean deliveries | IADPSG (excluding NDDG) vs NGT | 1^222^ | 732/1175 | 10689/21629 | 1.26 [1.20 to 1.32]; NA | 0.129 [0.100 to 0.157]
Primary cesarean deliveries | OAV (CC) vs NGT | 1^204^ | 30/80 | 218/880 | 1.51 [1.12, 2.05]; NA | 0.127 [0.017 to 0.237]
Primary cesarean deliveries | IADPSG (excluding CC) vs NGT | 5^198,200,203,206,221^ | 433/1707 | 4591/21687 | 1.10 [0.91, 1.34]; 77%
Primary cesarean deliveries | - IADPSG (excluding CC) vs NGT (profile likelihood) | 5^198,200,203,206,221^ | 433/1707 | 4591/21687 | 1.11 [0.90 to 1.34]; 68%
Primary cesarean deliveries | - IADPSG (excluding CC) vs NGT (only VHDI countries) | 4^198,200,206,221^ | 312/1321 | 3871/19535 | 1.16 [0.95, 1.42]; 69%
Primary cesarean deliveries | - IADPSG (excluding CC) vs NGT (only blinded studies) | 1^221^ | 174/728 | 764/4441 | 1.39 [1.20, 1.61]; NA
Primary cesarean deliveries | IADPSG (excluding CC) vs NGT (adjusted) | 4^198,203,206,221^ | 1426 | 13916 | aOR 0.94 [0.69 to 1.28; 73%
Primary cesarean deliveries | - IADPSG (excluding CC) vs NGT (adjusted; profile likihood) | 4^198,203,206,221^ | 1426 | 13916 | aOR 0.95 [0.68 to
Primary cesarean deliveries | - IADPSG (excluding CC) vs NGT (adjusted VHDI studies) | 3^198,206,221^ | 1040 | 11764 | 1.27]; 59%; aOR 1.00 [0.69 to 1.45]; 67%
Primary cesarean deliveries | - IADPSG (excluding CC) vs NGT (adjusted blinded studies) | 1^221^ | 728 | 4441 | aOR 1.31 [1.07 to 1.60; NA
Induction of Labor | OAV (CC) vs NGT | 1^192^ | 0/32 | 1/277 | 2.81 [0.12 to 67.54]; NA
Induction of Labor | IADPSG (excluding CC) vs NGT | 3^203,206,207^ | 93/906 | 648/6809 | 1.13 [0.93 to 1.39]; 0%
Induction of Labor | IADPSG (excluding CC) vs NGT (only VHDI studies) | 2^206,207^ | 79/520 | 590/4657 | 1.11 [0.89 to 1.37]; 0%
Induction of Labor | IADPSG (excluding CC) vs NGT (adjusted) | 3^203,206,207^ | 906 | 6682 | aOR 1.15 [0.91 to 1.46]; 0%
Preterm delivery | OAV (CC) not NGT | 6^201,204,213,214,219,220^ | 97/1023 | 760/10888 | 1.42 [1.14 to 1.77]; 0% | 0.018 [−0.032 to 0.068]
Preterm delivery | - OAV (CC) not NGT (only VHDI studies) | 4^204,213,214,219^ | 26/339 | 25/3328 | 1.27 [0.64 to 2.52]; 42%
Preterm delivery | - OAV (CC) not NGT (only blinded studies) | 1^219^ | 7/131 | 4/108 | 1.44 [0.43 to 4.80]; NA
Preterm delivery | OAV (CC) vs NGT (adjusted) | 1^220^ | 289 | 5971 | aOR 1.53 [1.03 to 2.27[; NA
Preterm delivery | OAV (NDDG) not NGT | 3^195,205,220^ | 32/489 | 534/9327 | 1.37 [0.97 to 1.94]; 0% | 0.012 [−0.0043 to 0.029]
Preterm delivery | - OAV (NDDG) not NGT (only VHDI studies) | 2^195,205^ | 10/264 | 43/2335 | 1.46 [0.57 to 3.75]; 32%
Preterm delivery | OAV (NDDG) not NGT (adjusted) | 1^220^ | 225 | 5971 | aOR 1.37 [0.86 to 2.18]; NA
Preterm delivery | IADPSG (excluding CC) vs NGT | 9^193,198,203,206,207,211,212,218,221^ | 220/2617 | 3322/31764 | 1.19 [0.97 to 1.46]; 45% | 0.0076 [−0.0084 to 0.0236]
Preterm delivery | - IADPSG (excluding CC) vs NGT (profile likelihood) | 9^193,198,203,206,207,211,212,218,221^ | 220/2617 | 3322/31764 | 1.20 [0.98 to 1.44]; 0%
Preterm delivery | - IADPSG (excluding CC) vs NGT (only VHDI studies) | 6^193,198,206,207,211,221^ | 152/1791 | 2682/23984 | 1.26 [1.03 to 1.53]; 23% | 0.0125 [−0.0036 to 0.0287]
Preterm delivery | - IADPSG (excluding CC) vs NGT (only blinded studies) | 1^221^ | 68/878 | 301/5020 | 1.29 [1.00 to 1.66]; NA
Preterm delivery | IADPSG (excluding CC) vs NGT (adjusted) | 5^198,203,206,211,221^ | 1628 | 16474 | aOR 1.43 [1.16 to 1.75]; 0%
Maternal birth trauma | OAV (CC) not NGT | 1^220^ | 289 | 5971 | aOR 1.01 [0.49 to 2.08]; NA
Maternal birth trauma | OAV (NDDG) vs NGT | 1^220^ | 225 | 5971 | aOR 1.61 [0.80 to 3.24]; NA
Maternal birth trauma | IADPSG (excluding CC) vs NGT | 4^198,200,203,211^ | 27/900 | 522/17885 | 1.19 [0.81 to 1.76]; 0%
Maternal birth trauma | - IADPSG (excluding CC) vs NGT (only VHDI) | 3^198,200,211^ | 17/514 | 470/15733 | 1.19 [0.67 to 2.10]; 16%
Maternal birth trauma | IADPSG (excluding CC) vs NGT (adjusted) | 2^198,203^ | 462 | 13256 | aOR [1.05; [0.59 to 1.86]; 0%
Excessive gestational weight gain | IADPSG (excluding CC) vs NGT | 1^198^ | 63/181 | 1748/5485 | 1.09 [0.89 to 1.34]; NA

Abbreviations: aOR = adjusted odds ratio; CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; NA = not applicable; NGT = normal glucose tolerance; NDDG = National Diabetes Data Group; OAV = one abnormal value; OGCT = oral glucose challenge test

Appendix D Table 8 Supplemental Analysis for Association Between More Inclusive GDM and Fetal/Neonatal Outcomes (KQ5)

Outcome | Comparisons | Number of Studies | Number of Events and Patients (n/N) (Only N for ORs and MDs):; GDM | Number of Events and Patients (n/N) (Only N for ORs and MDs):; Control | Relative Effects [95% CI]; I^2^; (RR unless otherwise stated) | Absolute Risk Difference [95% CI]
Mortality: All outcomes | All studies | 8^196,200,201,203–205,219,222^ | 13/2629 | 148/39674 | 1.66 [0.93 to 2.95]; 0%
Mortality: All outcomes | - All studies (only blinded studies) | 2^196,219^ | 1/190 | 29/5875 | 1.95 [0.24 to 15.91]; 0%
Mortality: All outcomes | - All studies (only VHDI studies) | 5^196,200,204,205,219^ | 3/673 | 50/15103 | 2.17 [0.74 to 6.37]; 0%
Mortality: Neonatal death | OAV (CC) vs NGT | 1^204^ | 2/80 | 6/880 | 3.67 [0.75 to 17.87]; NA
Mortality: Stillbirth | OAV (CC) vs NGT | 2^196,201^ | 1/454 | 29/6557 | 2.86 [0.35 to 23.32]; 0%
Mortality: Stillbirth | IADPSG (excluding CC) vs NGT | 1^200^ | 0/281 | 13/7771 | 1.02 [0.06 to 17.13]; NA
Mortality: Perinatal death | OAV (CC) vs GCT-ve | 1^219^ | 1/131 | 0/108 | 2.48 [0.10 to 60.20]; NA
Mortality: Perinatal death | OAV (NDDG) vs NGT | 1^205^ | 0/122 | 2/577 | 0.94 [0.05 to 19.45]; NA
Mortality: Perinatal death | - IADPSG (excluding CC) vs NGT | 1^203^ | 3/386 | 9/2152 | 1.86 [0.51 to 6.83]; NA
Mortality: Perinatal death | - IADPSG (excluding CC) vs NGT (adjusted) | 1^203^ | 386 | 2152 | aOR 1.68 [0.44 to 6.41]; NA
Mortality: Perinatal death | - IADPSG (excluding NDDG) vs NGT | 1^222^ | 6/1175 | 89/21629 | 1.24 [0.54 to 2.83]; NA
Birth injury | OAV (NDDG) vs NGT | 1^217^ | 3,637 | | OR 1.10 [0.60 to 2.02]; NA; (RR not estimable)
Shoulder dystocia or birth injury | IADPSG (excluding CC) vs NGT | 2^206,221^ | 28/1006 | 101/6858 | 1.70 [1.13 to 2.57]; 0% | 0.011 [0.001, 0.022]
Shoulder dystocia or birth injury | IADPSG (excluding CC) vs NGT (adjusted) | 2^206,221^ | 28/1006 | 101/6858 | aOR: 1.64 [0.80 to 3.38]; 24%
Shoulder dystocia | OAV (CC) vs NGT | 5^192,201,204,208,219^ | 10/890 | 26/3131 | 1.55 [0.60 to 3.98]; 28%
Shoulder dystocia | - OAV (CC) vs NGT (only blinded studies) | 1^208^; 1^219^ | 6/252; 1/131 | 14/1076; 4/108 | 1.83 [0.71 to 4.72]; 0.21 [0.02 to 1.82]
Shoulder dystocia | - OAV (CC) vs NGT (only VHDI studies) | 4^192,204,208,219^ | 9/495 | 24/2341 | 1.60 [0.50 to 5.17]; 44%
Shoulder dystocia | - OAV (CC) vs NGT (removing Arbib) | 4^201,204,208,219^ | 10/858 | 25/2854 | 1.41 [0.56 to 4.31]; 45%
Shoulder dystocia | OAV (CC) vs NGT (adjusted) | 1^220^ | 289 | 5971 | aOR 0.88 [0.12 to 6.45]; NA
Shoulder dystocia | OAV (NDDG) vs NGT | 1^220^ | 225 | 5971 | aOR 2.21 [0.51 to 9.58]; NA
Shoulder dystocia | IADPSG (excluding CC) vs NGT | 4^193,198,200,211^ | 14/674 | 269/22078 | 1.79 [1.02 to 3.15]; 9% | 0.0054 [−0.0083 to 0.0191]
Shoulder dystocia | IADPSG (excluding CC) vs NGT(adjusted) | 1^198^ | 181 | 5485 | aOR [1.29 [0.40 to 4.19]; NA
Macrosomia >4000g | OAV (CC) vs NGT | 10^192,196,197,201,202,204,209,213,219,220^ | 125/1564 | 1697/26522 | 1.47 [1.16 to 1.87]; 18% | 0.026 [−0.008 to 0.059]
Macrosomia >4000g | - OAV (CC) vs NGT (only blinded studies) | 2^196,219^ | 24/190 | 296/5975 | 1.65 [0.82 to 3.36]; 16%
Macrosomia >4000g | - OAV (CC) vs NGT (only VHDI studies) | 8^192,196,197,202,204,209,213,219^ | 107/880 | 1621/18962 | 1.36 [1.11 to 1.67]; 0%
Macrosomia >4000g | - OAV (CC) vs NGT (removing Arbib) | 9^196,197,201,202,204,209,213,219,220^ | 121/1532 | 1664/26245 | 1.51 [1.17 to 1.96]; 24%
Macrosomia >4000g | OAV (CC) vs NGT (adjusted) | 1^197^; 1^220^ | 152; 289 | 624; 5971 | aOR 2.00 [1.13 to 3.54]; NA; aOR 0.33 [0.05 to 2.18]; NA
Macrosomia >4000g | OAV (NDDG) vs NGT | 4^194,195,217,220^ | 454 | 9323; (data and numbers per group were not provided by one study (n=3,637)^217^ | OR 1.85 [1.44 to 2.38]; 3.2%; (RR 1.76 [1.40 to 2.19]) | 0.048 [0.025 to 0.074]
Macrosomia >4000g | - OAV (NDDG) vs NGT (only VHDI countries) | 3^194,195,217^ | 229 | 2331 | OR 1.80 [1.39 to 2.34]; 0%; (RR 1.71 [1.36 to 2.16]) | 0.044 [0.022 to 0.072]
Macrosomia >4000g | - OAV (NDDG) vs NGT (only blinded studies) | 1^217^ | NR | NR | OR 1.70 [1.20 to 2.41]; NA; (RR 1.63 [1.18 to 2.22]) | 0.039 [0.011 to 0.076]
Macrosomia >4000g | OAV (NDDG) vs NGT (adjusted) | 1^220^ | 225 | 5971 | aOR 2.06 [0.80 to 5.30]; NA
Macrosomia >4000g | IADPSG (excluding CC) vs NGT | 8^193,198,200,206,210–212,218^ | 127/1357 | 2156/31359 | 1.70 [1.35 to 2.14]; 37% | 0.0357 [0.0099 to 0.0614]
Macrosomia >4000g | - IADPSG (excluding CC) vs NGT (only VHDI studies) | 6^193,198,200,206,210,211^ | 101/917 | 1745/25731 | 1.76 [1.32 to 2.35]; 51%
Macrosomia >4000g | IADPSG (excluding CC) vs NGT (adjusted) | 3^198,206,211^ | 364 | 8758 | aOR 2.21 [1.49 to 3.29]; 0%
Macrosomia >4000g | IADPSG (not NDDG) vs NGT | 1^222^ | 170/1151 | 1428/21286 | 2.20 [1.90 to 2.55]; NA | 0.081 [0.060 to 0.101]; NA
Large for gestational age | OAV (CC) vs NGT | 8^192,196,201,204,208,209,216,219^ | 152/1075 | 506/9562 | 1.64 [1.25 to 2.15]; 49% | 0.047 [0.018 to 0.076]
Large for gestational age | - OAV (CC) vs NGT (profile likelihood) | 7^192,196,201,204,208,209,216,219^ | 152/1075 | 506/9562 | 1.62 [1.24 to 2.19]; 33%
Large for gestational age | - OAV (CC) vs NGT (only blinded studies) | 4^192,201,204,209^ | 67/520 | 218/7153 | 1.65 [0.96 to 2.82]; 61%
Large for gestational age | - OAV (CC) vs NGT (only VHDI countries) | 7^192,196,204,208,209,216,219^ | 105/680 | 453/8772 | 1.62 [1.16 to 2.26]; 56%
Large for gestational age | - OAV (CC) vs NGT (removing Arbib) | 7^196,201,204,208,209,216,219^ | 141/1043 | 418/9285 | 1.75 [1.31 to 2.33]; 47%
Large for gestational age | OAV (CC) vs NGT (adjusted) | 3^201,209,219^ | 574 | 1232 | aOR 1.91 [1.33 to 2.75]; 0%
Large for gestational age | OAV (NDDG) vs NGT | 3^194,195,205^ | 52/351 | 266/2908 | 1.68 [1.28 to 2.21]; 0% | 0.053 [−0.0013 to 0.106]
Large for gestational age | IADPSG (excluding CC) vs NGT | 10^193,198,200,203,206,207,210–212,221^ | 435/2851 | 3465/35987 | 1.69 [1.42 to 2.01]; 64% | 0.0595 [0.0337 to 0.0853]
Large for gestational age | - IADPSG (excluding CC) vs NGT (profile likelihood) | 10^193,198,200,203,206,207,210–212,221^ | 435/2851 | 3449/35860 | 1.69 [1.39 to 2.02]; 61.3%
Large for gestational age | - IADPSG (excluding CC) vs NGT (only blinded studies) | 1^221^ | 134/877 | 394/5003 | 1.94 [1.62 to 2.33]; NA
Large for gestational age | - IADPSG (excluding CC) vs NGT (only VHDI studies) | 8^193,198,200,206,207,210,211,221^ | 356/2183 | 3180/33426 | 1.79 [1.50 to 2.15]; 63%
Large for gestational age | IADPSG (excluding CC) vs NGT (adjusted) | 6^198,203,206,207,211,221^ | 2016 | 18605 | aOR 1.73 [1.41 to 2.11]; 42%
Large for gestational age | - IADPSG (excluding CC) vs NGT (adjusted; profile likelihood) | 4^198,203,206,221^ | 1574 | 13934 | aOR 1.70 [1.29 to 2.25]; 26%
Large for gestational age | - IADPSG (excluding CC) vs NGT (adjusted & only VHDI) | 5^198,206,207,211,221^ | 1630 | 16453 | aOR 1.85 [1.53 to 2.23]; 19%
NICU admissions | OAV (CC) vs NGT | 5^201,204,213,219,220^ | 47/958 | 634/10795 | 1.15 [0.84 to 1.57]; 0%
NICU admissions | OAV (CC) vs NGT (only VHDI studies) | 3^204,213,219^ | 17/301 | 157/3235 | 1.15 [0.65 to 2.02]; 0%
NICU admissions | OAV (CC) vs NGT (adjusted) | 1^220^ | 289 | 5971 | aOR 1.11 [0.70 to 1.76]; NA
NICU admissions | OAV (NDDG) vs NGT | 1^220^ | 19/225 | 477/6992 | 1.24 [0.80 to 1.92]; NA
NICU admissions | OAV (NDDG)) vs NGT (adjusted) | 1^220^ | 225 | 6992 | aOR 1.33 [0.82 to 2.16]; NA
NICU admissions | IADPSG (excluding CC) vs NGT | 6^193,200,203,206,211,221^ | 145/1885 | 2083/25589 | 1.17 [0.99 to 1.38]; 0% | 0.0091 [−0.0031 to 0.0214]
NICU admissions | - IADPSG (excluding CC) vs NGT (only VHDI studies) | 5^193,200,206,211,221^ | 128/1499 | 1997/23437 | 1.17 [0.98 to 1.40]; 1%
NICU admissions | - IADPSG (excluding CC) vs NGT (only blinded studies) | 1^221^ | 71/875 | 313/5006 | 1.30 [1.01 to 1.66]; NA
NICU admissions | IADPSG (excluding CC) vs NGT (adjusted) | 4^203,206,211,221^ | 1444 | 10975 | aOR 1.02 [0.81 to 1.28]; 0%
Respiratory distress syndrome | OAV (CC) vs NGT | 3^192,201,219^ | 4/558 | 10/1175 | 0.65 [0.18 to 2.35]; 0%
Respiratory distress syndrome | - OAV (CC) vs NGT (only VHDI studies) | 2^192,219^ | 2/163 | 1/385 | 1.65 [0.15 to 17.94]; NA (no events in 1 study)
Respiratory distress syndrome | OAV (NDDG) vs NGT | 1^205^ | 11/122 | 25/577 | 2.00 [1.02 to 3.94] | 0.045 [−0.0085 to 0.099]
Hypoglycemia | OAV (CC) vs NGT | 7^192,196,197,201,204,216,219^ | 76/927 | 331/8651 | 1.61 [1.20 to 2.15]; 0% | 0.019 [0.0022 to 0.040]
Hypoglycemia | - OAV (CC) vs NGT (only VHDI studies) | 6^192,196,197,204,216,219^ | 52/532 | 308/7861 | 1.46 [1.04 to 2.05]; 0%
Hypoglycemia | - OAV (CC) vs NGT (only blinded studies) | 3^196,216,219^ | 34/268 | 236/6080 | 1.25 [0.79 to 1.97]; 0%
Hypoglycemia | - OAV (CC) vs NGT (only unblinded studies) | 4^192,197,201,204^ | 42/659 | 95/2571 | 1.91 [1.31 to 2.77]; 0%; Subgroup effects for blinding p=0.16
Hypoglycemia | - OAV (CC) vs NGT (with defined outcome) | 3^196,197,219^ | 34/342 | 242/6499 | 1.34 [0.85 to 2.11]; 0%
Hypoglycemia | - OAV (CC) vs NGT (without defined outcome) | 4^192,201,204,216^ | 42/585 | 89/2152 | 1.82 [1.25 to 2.65]; 0%; Subgroup effects for defined outcome p=0.30
Hypoglycemia | - OAV (CC) vs NGT (removing Arbib) | 6^196,197,201,204,216,219^ | 75/895 | 330/8374 | 1.58 [1.18 to 2.11]; 0%
Hypoglycemia | OAV (CC) vs NGT (adjusted) | 1^201^ | 395 | 790 | aOR 1.79 [0.97 to 3.34]; NA
Hypoglycemia | OAV (NDDG) vs NGT | 2^195,205^ | 7/264 | 11/2335 | 6.64 [2.52 to 17.49]; 0% | 0.020 [0.002 to 0.038]
Hypoglycemia | | | | | Sermer 1995 (n=3637): no association found for IV for hypoglycemia (data NR)^217^
Hypoglycemia | - OAV (NDDG) vs NGT (with defined outcome) | 2^195,205^ | 7/264 | 11/2335 | 6.64 [2.52 to 17.49]; 0%; Sermer 1995 (n=3637): no association found for IV for hypoglycemia (data NR)^217^
Hypoglycemia | - OAV (NDDG) vs NGT (only blinded studies) | 1^217^ | 3637 | | Sermer 1995 (n=3637): no association found for IV for hypoglycemia (data NR)^217^
Hypoglycemia | IADPSG (excluding CC) vs NGT | 3^203,206,221^ | 37/1392 | 91/8996 | 2.51 [1.72 to 3.68]; 0% | 0.016 [0.0072 to 0.025]
Hypoglycemia | - IADPSG (excluding CC) vs NGT (with defined outcome) | 3^203,206,221^ | 37/1392 | 91/8996 | 2.51 [1.72 to 3.68]; 0%
Hypoglycemia | - IADPSG (excluding CC) vs NGT (only VHDI studies) | 2^206,221^ | 28/1006 | 76/6844 | 2.48 [1.35 to 4.65]; 21%
Hypoglycemia | - IADPSG (excluding CC) vs | 1^221^ | 25/875 | 67/5006 | 2.13 [1.36 to 3.34]; NA
Hypoglycemia | - NGT (only blinded studies)
Hypoglycemia | IADPSG (excluding CC) vs NGT (adjusted) | 3^203,206,221^ | 1392 | 8996 | aOR 2.48 [1.64 to 3.74]; 0%
Hypoglycemia | IADPSG (excluding NDDG) vs NGT | 1^222^ | 30/1175 | 254/21629 | 2.17 [1.50 to 3.15]; NA | 0.014 [0.005 to 0.023]
Hyperbilirubinem-ia | OAV (CC) vs NGT (removing Arbib) | 4^196,201,204,219^ | 137/665 | 388/7545 | 1.21 [1.02 to 1.45]; 0%
Hyperbilirubinem-ia | - OAV (CC) vs NGT (with Arbib) | 5^192,196,201,204,219^ | 138/697 | 388/7822 | 1.34 [0.84 to 2.13]; 15%
Hyperbilirubinem-ia | - OAV (CC) vs NGT (only VHDI studies) | 4^192,196,204,219^ | 8/302 | 172/7032 | 1.95 [0.64 to 5.97]; 24%
Hyperbilirubinem-ia | - OAV (CC) vs NGT (only blinded studies) | 2^196,219^ | 3/190 | 144/5875 | 1.15 [0.22 to 5.94]; 0%
Hyperbilirubinem-ia | OAV (CC) vs NGT (adjusted) | 1^201^ | 395 | 790 | aOR 1.16 [0.88 to 1.53]; NA
Hyperbilirubinem-ia | OAV (NDDG) vs NGT | 2^195,217^ | 142 | 1758; (data and numbers per group were not provided by one study (n=3,637)^217^ | OR 2.04 [1.47 to 2.84]; 0%; (RR 1.97 [1.45 to 2.68]) | 0.031 [0.014 to 0.054]
Hyperbilirubinem-ia | - OAV (NDDG) vs NGT (only blinded studies) | 1^217^ | 3637 (NR by group) | | OR 1.90 [1.30 to 2.87]; NA; (RR 1.85 [1.29 to 2.63]; NA)
Hyperbilirubinem-ia | IADPSG (excluding CC) vs NGT | 4^203,206,211,221^ | 140/1444 | 1513/11473 | 1.32 [1.13 to 1.54]; 0% | 0.0213 [−0.0040 to 0.0467]
Hyperbilirubinem-ia | - IADPSG (excluding CC) vs NGT (only VHDI studies) | 3^206,211,221^ | 124/1058 | 1448/9321 | 1.32 [1.12 to 1.55]; 0%
Hyperbilirubinem-ia | - IADPSG (excluding CC) vs NGT (only blinded studies) | 1^221^ | 57/875 | 249/5006 | 1.31 [0.99 to 1.73]; NA
Hyperbilirubinem-ia | IADPSG (excluding CC) vs NGT (adjusted) | 4^203,206,211,221^ | 1444 | 10975 | aOR 1.38 [1.11 to 1.70]; 0%
Hyperbilirubinem-ia | IADPSG (excluding CC) vs NGT (adjusted and only VHDI) | 3^206,211,221^ | 1058 | 8823 | aOR 1.37 [1.09 to 1.73]; 0%
APGAR score <7 at 1 minute | OAV (CC) vs NGT | 1^201^; 1^219^ | 12/395; 6/131 | 22/790; 0/108 | 1.09 [0.55 to 2.18]; NA; 10.73 [0.61 to 88.43]; NA
APGAR score <7 at 1 minute | OAV (NDDG) vs NGT | 1^205^ | 6/122 | 12/577 | 2.36 [0.91 to 6.18]; NA
APGAR score <7 at 1 minute | IADPSG (excluding CC) vs NGT | 2^200,211^ | 26/333 | 676/10248 | 1.11 [0.76 to 1.62]; 0%
APGAR score <7 at 5 minutes | OAV (CC) vs NGT | 3^201,204,219^ | 8/606 | 31/1778 | 1.63 [0.70 to 3.83]; 0%
APGAR score <7 at 5 minutes | - OAV (CC) vs NGT (only VHDI studies) | 2^204,219^ | 6/211 | 28/988 | 1.73 [0.66 to 4.57]; 0%
APGAR score <7 at 5 minutes | - OAV (CC) vs NGT (only blinded studies) | 1^219^ | 2/131 | 0/108 | 4.13 [0.20 to 85.09]; NA
APGAR score <7 at 5 minutes | OAV (NDDG) vs NGT | 1^205^ | 4/122 | 5/577 | 3.78 [1.03 to 13.89]; NA | 0.024 [−0.0084 to 0.057]
APGAR score <7 at 5 minutes | IADPSG (excluding CC) vs NGT | 3^193,200,211^ | 5/493 | 223/16593 | 0.97 [0.30 to 3.11]; 29%
APGAR score <7 at 5 minutes | IADPSG (excluding CC) vs NGT (adjusted) | 1^211^ | 0/52 | 9/1979 | aOR 0.79 [0.31 to 2.01]; NA

Abbreviations: aOR = adjusted odds ratio; CC = Carpenter Coustan; IADPSG = International Association of Diabetes and Pregnancy Study Groups; NA = not applicable; NGT = normal glucose tolerance; NDDG = National Diabetes Data Group; OAV = one abnormal value; OGCT = oral glucose challenge test; VHDI = very high development index

Appendix D Table 9 Supplemental Analysis Including Subgroup Analysis, From Trials of Treatment vs. No Treatment for GDM at 24 Weeks of Gestation or Later, Pregnancy Outcomes (KQ6)

Outcome | Comparisons | Number of Studies | #Events/ Treated | #Events/ Untreated | Relative Risk [95% CI]; I^2^ (unless stated otherwise) | Absolute Risk Difference [95% CI]
Preeclampsia | All studies | 6^42,224,229,230,232,236^ | 42/1032 | 48/1052 | 0.99 [0.46 to 2.16]; 59%
Preeclampsia | - Profile likelihood | 6^42,224,229,230,232,236^ | 42/1032 | 48/1052 | 0.96 [0.46 to 2.39]; 48%
Preeclampsia | - Removing OGTT-ve studies | 4^42,230,232,236^ | 38/947 | 47/954 | 0.81 [0.35 to 1.91]; 70%
Preeclampsia | - Removing studies with minimal intervention in UC | 4^42,229,230,232^ | 22/658 | 39/643 | 0.55 [0.33 to 0.92]; 0% | −0.017 [−0.052 to 0.017]
Preeclampsia | - Removing studies with some early treatment | 5^42,224,229,232,236^ | 39/999 | 43/1016 | 1.11 [0.44 to 2.84]; 67%
Preeclampsia | - Removing nonVHDI studies | 5^42,224,229,230,232^ | 24/693 | 40/691 | 0.60 [0.35 to 1.01]; 3%
Preeclampsia | - Only blinded studies | 2^42,230^ | 15/509 | 30/491 | 0.49 [0.27 to 0.90]; 0% | −0.030 [−0.055 to −0.005]
Preeclampsia | - Removing CCT | 5^42,224,230,232,236^ | 40/982 | 48/1002 | 0.90 [0.41 to, 2.01]; 64%
Preeclampsia | - Removing study with no outcome definition (Bevier) | 5^42,229,230,232,236^ | 40/997 | 47/1004 | 0.91 [0.40 to 2.09]; 65%
Gestational hypertension | All studies | 2^42,236^ | 38/815 | 45/816 | 0.82 [0.54 to 1.25]; 0%
Gestational hypertension | - Removing nonVHDI studies/with minimal intervention | 1^42^ | 29/476 | 37/455 | 0.75 [0.47 to 1.20]; NA
Gestational hypertension | - Only blinded studies | 1^42^ | 29/476 | 37/455 | 0.75 [0.47 to 1.20]; NA
Hypertensive disorders of pregnancy | All studies | 3^41,42,236^ | 126/1305 | 171/1326 | 0.85 [0.50 to 1.43]; 80%
Hypertensive disorders of pregnancy | - Only blinded and VHDI studies | 2^41,42^ | 99/966 | 155/965 | 0.64 [0.51 to 0.81]; 0%
Hypertensive disorders of pregnancy | Subgroup: gestational age at timing of treatment | 1^240^ | 24-26 wGA: 7/68; 27 wGA: 4/77; 28 wGA: 15/102; 29 wGA: 7/109; ≥30 wGA: 8/119 | 24-26 wGA: 6/43; 27 wGA: 19/88; 28 wGA: 8/87; 29 wGA: 10/106; ≥30 wGA: 19/130 | 24-26 wGA: 0.74 [0.27 to 2.05]; NA; 27 wGA: 0.24 [0.09 to 0.68]; NA; 28 wGA: 1.60 [0.71 to 3.59]; NA; 29 wGA: 0.68 [0.27 to 1.72]; NA; ≥30 wGA: 0.46 [0.21 to 1.01]; NA; Subgroup effect: p=0.06 | 27 wGA: −0.164 [−0.263 to −0.0647]
Hypertensive disorders of pregnancy | Subgroup: Hispanic vs Non-Hispanic white | 1^237^ | Hispanic: 23/274; Non-Hispanic white: 11/123 | Hispanic: 37/255; Non-Hispanic white: 13/116 | Hispanic: 0.58 [0.35 to 0.95];NA; Non-Hispanic white: 0.80 [0.37 to 1.71]; NA; Subgroup effect: p=0.49 | Hispanic: −0.061 [−0.115 to −0.0069]
Hypertensive disorders of pregnancy | Subgroup: Meeting NDDG 1979 vs meeting CC 1982 criteria | 1^239^ | NDDG: 25/280; CC: 16/196 | NDDG: 35/262; CC: 27/193 | NDDG: 0.67 [0.41 to, 1.09]; NA; CC: 0.58 [0.32 to 1.05]; NA; Subgroup effect: p=0,73
Cesarean delivery | All studies | 8^41,42,224–226,230,232,236^ | 638/1771 | 684/1812 | 0.95 [0.83 to 1.08]; 43%
Cesarean delivery | - Profile likelihood | 8^41,42,224–226,230,232,236^ | 638/1771 | 684/1812 | 0.96 [0.82 to 1.08]; 34%
Cesarean delivery | - Removing OGTT-ve studies | 6^41,42,226,230,232,236^ | 589/1586 | 630/1614 | 0.95 [0.82 to 1.10]; 54%
Cesarean delivery | - Removing studies with minimal intervention in UC | 5^41,42,225,230,232^ | 364/1248 | 411/1253 | 0.89 [0.79 to 1.00]; 0%
Cesarean delivery | - Removing studies with some early treatment | 6^41,42,224,226,232,236^ | 587/1588 | 634/1626 | 0.93 [0.79 to 1.09]; 60%
Cesarean delivery | - Removing nonVHDI studies | 7^41,42,224–226,230,232^ | 399/1432 | 451/1451 | 0.89 [0.80 to 1.00]; 0%
Cesarean delivery | - Only blinded studies | 3^41,42,230^ | 287/999 | 326/1001 | 0.88 [0.77 to 1.01]; 2%
Cesarean delivery | - Cesarean delivery, defined as total/all | 3^41,42,224^ | 285/1001 | 330/1013 | 0.87 [0.73 to 1.03]; 29%
Cesarean delivery | Subgroup: gestational age at timing of treatment | 1^240^ | 24-26 wGA: 23/68; 27 wGA: 22/77; 28 wGA: 29/102; 29 wGA: 26/109; ≥30 wGA: 28/120 | 24-26 wGA: 15/43; 27 wGA: 32/88; 28 wGA:; 28/87; 29 wGA: 33/107; ≥30 wGA: 46/130 | 24-26 wGA: 0.97 [0.57 to 1.64]; NA; 27 wGA: 0.79 [0.50 to 1.23]; NA; 28 wGA: 0.88 [0.57 to 1.36]; NA; 29 wGA: 0.77 [0.50 to 1.20]; NA; ≥30 wGA: 0.66 [0.44 to 0.98]; Subgroup effect: p=0.80 | ≥30 wGA: −0.121 [−0.232 to −0.008]
Cesarean delivery | Subgroup: meeting NDDG versus meeting CC criteria | 1^239^ | NDDG: 78/280; CC: 50/196 | NDDG: 79/262; CC: 75/193 | NDDG: 0.92 [0.71 to 1.20]; NA; CC: 0.66 [0.49 to 0.88]; NA; Subgroup effect: p=0.09 | CC: −0.134 [−0.225 to −0.041]
Primary cesarean delivery | All studies | 3^42,224,229^ | 81/561 | 113/553 | 0.70 [0.54 to 0.91]; 0% | −0.0525 [−0.103 to −0.0024]
Primary cesarean delivery | - Removing OGTT-ve studies/only blinded studies | 1^42^ | 62/476 | 90/455 | 0.66 [0.49 to 0.89]; NA | −0.058 [−0.115 to −0.020]
Primary cesarean delivery | - Removing studies with minimal intervention in UC | 2^42,229^ | 78/526 | 110/505 | 0.69 [0.53 to 0.89]; 0% | −0.068 [−0.114 to −0.223]
Primary cesarean delivery | - Removing Landon (broader definition) | 2^224,229^ | 19/85 | 23/98 | 0.85 [0.51 to 1.39]; 0%
Primary cesarean delivery | - Removing CCT | 2^42,224^ | 65/511 | 93/503 | 0.68 [0.51 to 0.90]; 0% | −0.038 [−0.123 to 0.048]
Emergency cesarean delivery | All studies | 1^41^ | 80/490 | 103/510 | 0.81 [0.62 to 1.05]; NA
Induction of Labor | All studies | 5^41,42,224,230,236^ | 338/1373 | 285/1410 | 1.18 [0.92 to 1.52]; 45%
Induction of Labor | - Profile likelihood | 5^41,42,224,230,236^ | 338/1373 | 285/1410 | 1.18 [0.93 to 1.51]; 13%
Induction of Labor | - Removing OGTT-ve studies | 4^41,42,230,236^ | 332/1338 | 285/1362 | 1.17 [0.98 to 1.39]; 21%
Induction of Labor | - Removing studies with minimal intervention in UC & no blinding | 3^41,42,230^ | 332/999 | 284/1001 | 1.17 [0.97 to 1.41]; 39%
Induction of Labor | - Removing studies with some early treatment | 4^41,42,224,236^ | 325/1340 | 273/1374 | 1.19 [0.87 to 1.62]; 59%
Induction of Labor | - Removing nonVHDI studies | 4^41,42,224,230^ | 338/1034 | 284/1049 | 1.19 [0.92 to 1.55]; 56%
Preterm delivery | All studies | 4^42,229,232,236^ | 69/965 | 92/968 | 0.75 [0.56 to 1.01]; 0%
Preterm delivery | - Removing OGTT-ve studies | 3^42,232,236^ | 68/915 | 88/918 | 0.77 [0.57 to 1.04]; 0%
Preterm delivery | - Removing studies with minimal intervention in UC/nonVHDI | 3^42,229,232^ | 51/626 | 64/607 | 0.78 [0.55 to 1.10]; 0%
Preterm delivery | - Only blinded studies | 1^42^ | 45/477 | 53/455 | 0.81 [0.56 to 1.18]; NA
Preterm delivery | Subgroup: Hispanic vs Non-Hispanic white (Berggren 2012, secondary analysis of Landon 2009) | 1^237^ | Hispanic: 24/274; Non-Hispanic white: 14/123 | Hispanic: 23/255; Non-Hispanic white: 14/116 | Hispanic: 0.97 [0.56 to 1.68]; NA; Non-Hispanic white: 0.94 [0.47 to 1.89]; NA; Subgroup effect: p=0.95
Maternal birth trauma | All studies | 2^41,229^ | 255/540 | 255/560 | 1.04 [0.92 to 1.18]; 0%
Maternal birth trauma | - Only blinded study/without OGTT-ve | 1^41^ | 255/490 | 254/510 | 1.04 [0.93 to 1.18]; NA
Long-term maternal development of metabolic impairment (Impaired fasting glucose) | All studies | 1^241^ | 66/243 | 54/214 | 1.08 [0.79 to 1.47]; NA
Long-term maternal development of T2DM (5-10 years) | All studies | 1^241^ | 21/243 | 17/214 | 1.09 [0.59 to 2.01]; NA
Long-term maternal development of metabolic syndrome (5-10 years) | All studies | 1^241^ | 73/243 | 69/214 | 0.93 [0.71 to 1.22]; NA; After adjustment for race-ethnicity and time since diagnosis: 0.95 [0.73 to 1.25]
Long-term maternal obesity (≥30kg/m^2^) | All studies | 1^241^ | 98/243 | 79/214 | 1.09 [0.87 to 1.38]; NA

Abbreviations: CC = Carpenter Coustan; CCT = controlled clinical trial; CI = confidence interval; GDM = gestational diabetes mellitus; NA = not applicable; NDDG = National Diabetes Data Group; OGTT = oral glucose tolerance test; UC = usual care; VHDI = very high development index; wGA = weeks’ gestational age; -ve = negative

Appendix D Table 10 Supplemental Analysis Including Subgroup Analysis, From Trials of Treatment vs. No Treatment for GDM at 24 Weeks of Gestation or Later, Fetal/Neonatal Outcomes (KQ6)

Outcome | Comparison | Number of studies | #Events/# Treated | # Events/#Untreated | Relative Risk [95% CI]; I^2^ (unless stated otherwise) | Absolute Risk Difference [95% CI]
Mortality | All studies | 6^41,42,226,229,230,236^ | 4/1562 | 9/1592 | Peto OR 0.49 [0.16 to 1.45]; 68%
Birth injury | All studies | 3^41,42,230^ | 3/1015 | 10/1013 | Peto OR 0.33 [0.11, 0.99] | −0.002 [−0.006 to −0.002]
Shoulder dystocia | All studies | 3^41,42,224^ | 15/1017 | 36/1027 | 0.42 [0.23 to 0.77]; 0% | −0.013 [−0.043 to 0.016]
Shoulder dystocia | - Removing OGTT-ve studies | 2^41,42^ | 14/982 | 34/979 | 0.41 [0.22 to 0.76]; 0% | −0.013 [−0.045 to 0.019]
Shoulder dystocia | - Removing studies with minimal intervention in UC/no blinding/nonVHDI | 2^41,42^ | 14/982 | 34/979 | 0.41 [0.22 to 0.76]; 0% | −0.020 [−0.034 to −0.007]
Shoulder dystocia | - Removing nonVHDI studies | 3^41,42,224^ | 15/1017 | 36/1027 | 0.42 [0.23 to 0.77]; 0% | −0.020 [−0.033 to −0.007]
Shoulder dystocia | Subgroup: Meeting NDDG vs meeting CC criteria (Harper 2016, secondary analysis of Landon, 2009) | 1^239^ | NDDG: 5/280; CC: 2/196 | NDDG: 15/262; CC: 3/193 | NDDG: 0.31 [0.11 to 0.85]; NA; CC: 0.66 [0.11 to 3.89]; NA; Subgroup effect: 0.47 | NDDG: −0.039 [−0.072 to −0.007]
Macrosomia >4000g | All studies | 8^41,42,224–226,229,232,236^ | 164/1805 | 330/1839 | 0.53 [0.41 to 0.68]; 42% | −0.089 [−0.120 to −0.059]
Macrosomia >4000g | - Profile likelihood | 8^41,42,224–226,229,232,236^ | 164/1805 | 330/1839 | 0.53 [0.40 to 0.67]; 15%
Macrosomia >4000g | - Removing OGTT-ve studies | 5^41,42,226,232,236^ | 154/1570 | 292/1591 | 0.56 [0.43 to 0.71]; 43% | −0.084 [−0.109 to −0.059]
Macrosomia >4000g | - Removing studies with minimal intervention in UC | 5^41,42,225,229,232^ | 101/1282 | 227/1280 | 0.46 [0.37 to 0.57]; 0% | −0.095 [−0.123 to −0.066]
Macrosomia >4000g | - Removing studies with some early treatment | 7^41,42,224,226,229,232,236^ | 156/1655 | 314/1689 | 0.53 [0.39 to 0.71]; 42% | −0.096 [−0.130 to −0.062]
Macrosomia >4000g | - Removing nonVHDI studies | 7^41,42,224–226,229,232^ | 126/1466 | 267/1478 | 0.50 [0.36 to 0.68]; 45% | −0.096 [−0.131 to −0.060]
Macrosomia >4000g | - Only blinded studies | 2^41,42^ | 77/983 | 175/978 | 0.44 [0.34 to 0.57]; 0% | −0.097 [−0.126 to −0.068]
Macrosomia >4000g | - Removed Bevier (macrosomia or LGA) | 7^41,42,225,226,229,232,236^ | 163/1770 | 318/1791 | 0.54 [0.42, 0.69]; 38% | −0.083 [−0.109 to −0.057]
Macrosomia >4000g | Subgroup: Hispanic vs non-Hispanic white (Berggren 2012-secondary analysis of Landon 2009) | 1^237^ | Hispanic: 20/274; Non-Hispanic white: 5/123 | Hispanic: 40/255; Non-Hispanic white: 17/116 | Hispanic: 0.47 [0.28 to 0.77]; Non-Hispanic White: 0.28 [0.11 to 0.73]; Subgroup effect: p=0.35 | Hispanic: −0.084 [−0.138 to −0.030]; Non-Hispanic White: −0.106 [−0.179 to −0.033]
Macrosomia >4000g | Subgroup: Meeting NDDG versus meeting CC criteria (Harper 2016, secondary analysis of Landon, 2009) | 1^239^ | NDDG: 16/281; CC: 12/196 | NDDG: 41/261; CC: 24/193 | NDDG: 0.36 [0.21 to 0.63]; NA; CC: 0.49 [0.25 to 0.96]; NA; Subgroup effect: 0.49 | NDDG: −0.10 [−0.152 to −0.048]; CC: −0.063 [−0.121 to −0.0057]
Macrosomia >4500g | All studies | 3^226,230,236^ | 16/521 | 23/545 | 0.72 [0.39 to 1.35]; 0%
Macrosomia >4500g | - Removing studies with minimal intervention in UC and no blinding | 1^230^ | 3/33 | 7/34 | 0.44 [0.12 to 1.56]; NA
Macrosomia >4500g | - Removing studies with some early treatment | 2^226,236^ | 13/488 | 16/511 | 0.85 [0.41 to 1.75]; 0%
Macrosomia >4500g | - Removing nonVHDI studies | 2^226,230^ | 9/182 | 13/184 | 0.70 [0.31 to 1.62]; 0%
Large for gestational age | All studies | 7^41,42,225,229,230,232,236^ | 174/1654 | 322/1675 | 0.56 [0.47 to 0.66]; 0% | −0.084 [−0.108 to −0.061]
Large for gestational age | - Removing OGTT-ve studies | 5^41,42,230,232,236^ | 163/1454 | 290/1475 | 0.58 [0.48 to 0.69]; 0% | −0.081 [−0.106 to −0.056]
Large for gestational age | - Removing studies with minimal intervention in UC and nonVHDI | 6^41,42,225,229,230,232^ | 130/1315 | 250/1314 | 0.53 [0.44 to 0.65]; 0% | −0.088 [−0.114 to −0.062]
Large for gestational age | - Removing studies with some early treatment | 5^41,42,229,232,236^ | 158/1471 | 285/1491 | 0.57 [0.48 to 0.69]; 0% | −0.083 [−0.108 to −0.058]
Large for gestational age | - Only blinded studies | 3^41,42,230^ | 109/1016 | 197/1012 | 0.56 [0.45 to 0.69]; 0% | −0.085 [−0.124 to −0.046]
Large for gestational age | Subgroup: gestational age at timing of treatment | 1^240^ | 24-26 wGA: 8/69; 27 wGA: 5/77; 28 wGA: 8/103; 29 wGA: 7/109; ≥30 wGA: 6/120 | 24-26 wGA: 6/43; 27 wGA: 12/88; 28 wGA: 14/86; 29 wGA: 14/107; ≥30 wGA: 20/130 | 24-26 wGA: 0.83 [0.31 to 2.23]; NA; 27 wGA: 0.48 [0.18 to 1.29]; NA; 28 wGA: 0.48 [0.21 to 1.08]; NA; 29 wGA: 0.49 [0.21 to 1.17]; NA; ≥30 wGA: 0.33 [0.14 to 0.78]; NA; Subgroup effect: p=0.75 | ≥30 wGA: −0.104 [−0.177 to −0.031]
Large for gestational age | Subgroup: BMI category | 1^238^ | <25kg/m^2^: 1/73; 25-29.9 kg/m^2^: 11/187; 30-34.9 kg/m^2^: 13/153; 35-39.9 kg/m^2^: 4/53; ≥40 kg/m^2^: 4/19 | <25kg/m^2^: 2/70; 25-29.9 kg/m^2^: 22/181; 30-34.9 kg/m^2^: 30/151; 35-39.9 kg/m^2^: 13/57; ≥40 kg/m^2^: 3/20 | <25kg/m^2^: 0.48 [0.04 to 5.17]; NA; 25-29.9 kg/m^2^: 0.48 [0.24 to 0.97]; NA; 30-34.9 kg/m^2^: 0.43 [0.23 to 0.79]; NA; 35-39.9 kg/m^2^: ≥40 kg/m^2^: 0.33 [0.12 to 0.95]; NA; ≥40 kg/m^2^: 1.40 [0.6 to 5.46]; Subgroup effect: p=0.56 | 25-29.9 kg/m^2^: −0.063 [−0.121 to −0.004]; 30-34.9 kg/m^2^: −0.114 [−0.191 to −0.036]; 35-39.9 kg/m^2^: −0.153 [−0.283 to −0.023]
Large for gestational age | Subgroup: Hispanic vs Non-Hispanic white | 1^237^ | Hispanic: 22/274; Non-Hispanic white: 6/123 | Hispanic: 38/255; Non-Hispanic white: 16/116 | Hispanic: 0.54 [0.33 to 0.89]; NA; Non-Hispanic white: 0.35 [0.14 to 0.87]; NA; Subgroup effect: p=0.42 | Hispanic: −0.069 [−0.123 to −0.015]; Non-Hispanic white: −0.089 [−0.163 to −0.016]
Large for gestational age | Subgroup: meeting NDDG versus meeting CC criteria | 1^239^ | NDDG: 17/281; CC: 17/196 | NDDG: 41/261; CC: 25/193 | NDDG: 0.39 [0.22 to 0.66]; NA; CC: 0.67 [0.37 to 1.20]; NA; Subgroup effect: p=0.17 | NDDG: −0.097 [−0.149 to −0.044]
NICU admissions | All studies | 5^42,225,229,230,232^ | 63/809 | 84/791 | 0.73 [0.53 to 0.99]; 0% | −0.020 [−0.045, 0.0051]
NICU admissions | - Removing OGTT-ve studies | 3^42,230,232^ | 50/609 | 61/591 | 0.79 [0.55 to 1.13]; 0% | −0.018 [−0.050 to 0.013]
NICU admissions | - Removing studies with some early treatment | 3^42,229,232^ | 57/626 | 76/607 | 0.72 [0.52 to 1.00]; 0%
NICU admissions | - Only blinded studies | 2^42,230^ | 44/510 | 54/489 | 0.78 [0.53 to 1.14]
NICU admissions | Subgroup: gestational age at timing of treatment | 1^240^ | 24-26 wGA: 10/69; 27 wGA: 9/77; 28 wGA: 7/101; 29 wGA: 9/108; ≥30 wGA: 8/119 | 24-26 wGA: 7/43; 27 wGA: 13/89; 28 wGA: 12/87; 29 wGA: 13/107; ≥30 wGA: 8/129 | 24-26 wGA: 0.89 [0.37 to 2.16]; NA; 27 wGA: 0.80 [0.36 to, 1.77]; NA; 28 wGA: 0.50 [0.21 to 1.22]; NA; 29 wGA: 0.69 [0.31 to 1.54]; NA; ≥30 wGA: 1.08 [0.42 to 2.80]; NA; Subgroup effect: p=0.81
NICU admissions | Subgroup: Hispanic vs Non-Hispanic white | 1^237^ | Hispanic: 20/274; Non-Hispanic white: 8/123 | Hispanic: 21/255; Non-Hispanic white: 13/116 | Hispanic: 0.89 [0.49 to 1.60]; NA; Non-Hispanic white: 0.58 [0.25 to 1.35]; NA; Subgroup effect: p=0.42
Respiratory distress syndrome | All studies (both VHDI, both with Tx initiation mid-pregnancy) | 2^41,42^ | 36/983 | 32/979 | 1.05 [0.48 to 2.28]; 58%
Respiratory distress syndrome | - Profile likelihood | ^41,42^ | 36/983 | 32/979 | 1.13 [0.39 to 2.56]; 5%
Any Hypoglycemia | All studies | 5^42,225,226,232,236^ | 91/1118 | 80/1120 | 1.10 [0.83 to 1.45]; 0%
Any Hypoglycemia | - Removing OGTT-ve studies and with early treatment | 4^42,226,232,236^ | 86/968 | 74/970 | 1.12 [0.83 to 1.49]; 0%
Any Hypoglycemia | - Removing studies with minimal intervention in UC | 3^42,225,232^ | 68/630 | 63/609 | 1.02 [0.75 to 1.41]; 0%
Any Hypoglycemia | - Removing nonVHDI studies | 4^42,225,226,232^ | 89/779 | 76/759 | 1.12 [0.84 to 1.49]; 0%
Any Hypoglycemia | - Only blinded studies | 1^42^ | 62/381 | 55/357 | 1.06 [0.76 to 1.47]; NA
Any Hypoglycemia | - Removing study without definition of outcome | 4^42,225,232,236^ | 70/969 | 67/970 | 1.00 [0.73 to 1.37]; 0%
Any Hypoglycemia | Subgroup: Hispanic vs Non-Hispanic white | 1^237^ | Hispanic: 34/274 | Hispanic: 30/255 | Hispanic: 1.05 [0.67 to 1.67]; NA
Any Hypoglycemia | | | Non-Hispanic white: 15/123 | Non-Hispanic white: 13/116 | Non-Hispanic white: 1.09 [0.54 to 2.19]; NA; Subgroup effect: p=0.94
Hyperbilirubinemia | All studies (all VHDI) | 5^41,42,225,226,230^ | 101/1288 | 119/1276 | 0.84 [0.65 to 1.08]; 0%
Hyperbilirubinemia | - Removing OGTT-ve studies | 4^41,42,226,230^ | 95/1138 | 115/1126 | 0.82 [0.63, 1.06]; 0%
Hyperbilirubinemia | - Removing studies with minimal intervention in UC | 4^41,42,225,230^ | 93/1139 | 109/1126 | 0.84 [0.65 to 1.10]; 0%
Hyperbilirubinemia | - Removing studies with some early treatment | 3^41,42,226^ | 95/1105 | 112/1092 | 0.83 [0.64, 1.08]; 05
Hyperbilirubinemia | - Only blinded studies | 2^41,42,230^ | 87/956 | 102/942 | 0.83 [0.64 to 1.09]; 0%
Hyperbilirubinemia | Subgroup: Hispanic vs Non-Hispanic white | 1^237^ | Hispanic: 27/274; Non-Hispanic white: 11/123 | Hispanic: 31/255; Non-Hispanic white: 12/116 | Hispanic: 0.81 [0.50 to 1.32]; NA; Non-Hispanic white: 0.86 [0.40 to 1.88]; NA; Subgroup effect: p=0.89
APGAR score <7 at 1 minute | All studies | 1^236^ | 0/339 | 7/361 | 0.07 [0.00 to 1.24]; NA
APGAR score <7 at 5 minutes | All studies | 2 | 9/605 | 15/626 | 0.62 [0.27 to 1.41]; 0%
APGAR score <7 at 5 minutes | - Only blinded studies | 1^41^ | 6/506 | 11/524 | 0.56 [0.21 to 1.52]; NA

Abbreviations: BMI = body mass index; CC = Carpenter Coustan; CI = confidence interval; g = grams; GDM = gestational diabetes mellitus; NA = not applicable; NDDG = National Diabetes Data Group; OGTT = oral glucose tolerance test; UC = usual care; -ve = negative

Appendix D Table 11 Supplemental Analysis Including Subgroup Analysis, From Trials of Treatment vs. No Treatment for GDM in Early Pregnancy, Pregnancy Outcomes (KQ6)

Outcome | Comparison | Number of studies | Number of events and patients (n/N); Early treated | Number of events and patients (n/N); Usual care | Relative Effects [95% CI]; I^2^ | Absolute risk difference [95% CI]
Preeclampsia | All studies | 3^231,233,235^ | 4/109 | 8/120 | 0.69 [0.21, 2.23]; 0%
Preeclampsia | Removing CCT | 2^231,233^ | 2/73 | 5/66 | 0.47 [0.07, 2.92]; 19%
Gestational hypertension | All studies | 2^233,235^ | 7/74 | 12/90 | 0.75 [0.31, 1.84]; 0%
Gestational hypertension | Removing CCT | 1^233^ | 3/38 | 3/36 | 0.95 [0.20, 4.39]; NA
Hypertensive disorders of pregnancy | All studies | 3^233–235^ | 14/85 | 17/99 | 0.92 [0.46, 1.81]; 0%
Hypertensive disorders of pregnancy | Removing CCT | 2^233,234^ | 8/49 | 5/45 | 1.49 [0.31, 7.19]; 30%
Cesarean delivery | All studies | 4^231,233–235^ | 34/107 | 41/121 | 0.91 [0.56, 1.48]; 35%
Cesarean delivery | Removing CCT | 3^231,233,234^ | 22/71 | 29/67 | 0.72 [0.46, 1.13]; 0%
Cesarean delivery | Subgroup: Obese vs non-obese | 1^233^ | ≥30kg/m^2^: 3/11; <30kg/m^2^: 8/26 | ≥30kg/m^2^: 10/16; <30kg/m^2^: 7/21 | ≥30kg/m^2^: 0.44 [0.15, 1.23]; NA; <30kg/m^2^: 0.92 [0.40, 2.13]; NA; Subgroup effect: p=0.27
Primary cesarean delivery | All studies | 1^233^ | 5/37 | 10/37 | 0.50 [0.19, 1.32]; NA
Primary cesarean delivery | Subgroup: Obese vs non-obese | 1^233^ | ≥30kg/m^2^: 0/11; <30kg/m^2^: 5/26 | ≥30kg/m^2^: 5/16; <30kg/m^2^: 5/21 | ≥30kg/m^2^: 0.13 [0.01, 2.12]; NA; <30kg/m^2^: 0.81 [0.27, 2.42]; NA; Subgroup effect: p=0.23
Emergency cesarean delivery | All studies | 3^231,234,235^ | 12/70 | 16/84 | 0.81 [0.37, 1.78]; 11%
Emergency cesarean delivery | Removing CCT | 2^231,234^ | 8/34 | 7/30 | 1.14 [0.23, 5.74]; 52%
Induction of Labor | All studies | 3^231,233,234^ | 33/71 | 27/67 | 1.12 [0.76, 1.67]; 3%
Induction of Labor | Subgroup: Obese vs non-obese | 1^233^ | ≥30kg/m^2^: 6/11; <30kg/m^2^: 10/26 | ≥30kg/m^2^: 5/16; <30kg/m^2^: 8/21 | ≥30kg/m^2^: 1.75 [0.71, 4.32]; NA; <30kg/m^2^: 1.01 [0.49, 2.10]; NA; Subgroup effect: p=0.36
Preterm delivery | All studies | 2^231,235^ | 3/59 | 3/75 | 1.27 [0.27, 6.07]; 0%
Preterm delivery | Removing CCT | 1^231^ | 1/23 | 1/21 | 0.91 [0.06, 13.69]; NA
Excessive gestational weight gain | All studies | 2^233,235^ | 15/70 | 31/89 | 0.65 [0.37, 1.15]; 6%
Excessive gestational weight gain | Removing CCT | 1^233^ | 6/35 | 6/36 | 1.03 [0.37, 2.89]; NA

Abbreviations: CCT = controlled clinical trial; GDM = gestational diabetes mellitus; kg/m^2^ = kilograms per meter squared; NA = not applicable

Appendix D Table 12 Supplemental Analysis Including Subgroup Analysis, From Trials of Treatment vs. No Treatment for GDM in Early Pregnancy, Fetal/Neonatal Outcomes (KQ6)

Outcome | Comparison | Number of Studies | Number of Events and Patients (n/N); Early treated | Number of Events and Patients (n/N); Usual care | Relative Effects [95% CI]; I^2^ (RR unless otherwise) | Absolute Risk Difference [95% CI]
Mortality | All studies | 3^231,233,234^ | 0/71 | 2/67 | Peto OR 0.12 [0.01 to 1.95]
Birth injury | All studies | 1^231^ | 0/23 | 0/21 | Not estimable
Shoulder dystocia | All studies | 3^231,234,235^ | 0/70 | 2/84 | Peto OR 0.11 [0.00 to 5.57
Macrosomia >4000g | All studies | 2^233,235^ | 15/73 | 21/91 | 0.89 [0.33, 2.42]; 42%
Macrosomia >4000g | - Profile likelihood | 2^233,235^ | 15/73 | 21/91 | 1.08 [0.27 to 2.23]; 0%
Macrosomia >4000g | - Removing CCT | 1^233^ | 2/37 | 5/37 | 0.40 [0.08, 1.93]; NA
Macrosomia >4000g | Subgroup: Obese vs non-obese | 1^233^ | ≥30kg/m^2^: 0/11; <30kg/m^2^: 2/26 | ≥30kg/m^2^: 2/16; <30kg/m^2^: 3/21 | ≥30kg/m^2^: 0.28 [0.01, 5.39]; NA; <30kg/m^2^: 0.54 [0.10, 2.93]; Subgroup effect: p=0.71
Macrosomia >4500g | All studies (CCT) | 1^235^ | 0/36 | 3/54 | 0.21 [0.01, 3.99]; NA
Large for gestational age | All studies | 3^231,234,235^ | 8/70 | 13/84 | 0.68 [0.18, 2.54]; 35%
Large for gestational age | - Removing CCT | 2^231,234^ | 1/34 | 5/30 | 0.27 [0.04, 1.61]; 0%
NICU admissions | All studies | 3^231,234,235^ | 10/70 | 12/84 | 0.98 [0.28, 3.43]; 29%
NICU admissions | - Removing CCT | 2^231,234^ | 5/34 | 2/30 | 1.66 [0.10, 27.18]; 58%
Any Hypoglycemia | All studies | 3^231,233,234^ | 10/63 | 6/60 | 1.77 [0.62, 5.03]; 0%
Hyperbilirubinemia | All studies | 2^231,233^ | 10/59 | 6/57 | 1.57 [0.65 to 3.82]; 0%

Abbreviations: CCT = controlled clinical trial; CI = confidence interval; g = grams; kg/m^2^ =kilograms per meter squared; NA = not applicable; NICU = neonatal intensive care unit; OGTT = oral glucose tolerance test; OR = odds ratio; RR = relative risk; VHDI = Very High Development Index country

Appendix D Table 13 Supplemental Analysis With Subgroup Analysis, From Trials of Treatment vs. No Treatment for GDM, Harms (KQ7)

Outcome | Comparison | Number of Studies | Number of Events and Patients (n/N); Intervention; Treated | Number of Events and Patients (n/N); Intervention; Untreated | Relative Effects (RR) [95% CI]; I^2^ | Absolute Risk Difference [95% CI]
Small for gestational age | All studies | 6^41,42,224,225,229,232^ | 92/1317 | 84/1329 | 1.10 [0.83 to 1.47]; 0%
Small for gestational age | - Removing OGTT-ve studies | 3^41,42,232^ | 71/1082 | 70/1081 | 1.01 [0.73, 1.39]; 0%
Small for gestational age | - Removing studies with minimal intervention in UC | 5^41,42,225,229,232^ | 89/1282 | 82/1281 | 1.08 [0.81, 1.45]; 0%
Small for gestational age | - Removing studies with some early treatment | 5^41,42,224,229,232^ | 79/1167 | 75/1179 | 1.06 [0.78, 1.44]; 0%
Small for gestational age | - Only blinded studies | 2^41,42^ | 69/983 | 67/979 | 1.03 [0.74 to 1.42]; 0%
Small for gestational age | Subgroup: Hispanic vs Non-Hispanic white | 1^237^ | Hispanic: 20/274; Non-Hispanic white: 10/123 | Hispanic: 13/255; Non-Hispanic white: 9/116 | Hispanic: 1.43 [0.73 to 2.82]; NA; Non-Hispanic white: 1.05 [0.44 to 2.49]; NA; Subgroup effect: p=0.58
Small for gestational age | Subgroup: meeting NDDG versus meeting CC criteria | 1^239^ | NDDG: 22/381; CC: 14/196 | NDDG: 17/261; CC: 12/193 | NDDG: 1.20 [0.65 to 2.21]; NA; CC: 1.15 [0.55 to 2.42]; NA; Subgroup effect: p=0.93
Low birthweight | All studies | 1^236^ | 14/339 | 14/361 | 1.06 [0.52 to 2.20]; NA
Severe Hypoglycemia | All studies | 3^41,42,230^ | 60/1014 | 58/1013 | 1.02 [0.60 to 1.76]; 58%

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; NA = not applicable; NDDG = National Diabetes Data Group; OGTT = oral glucose tolerance test; RR = relative risk; UC = usual care

Appendix D Table 14 Comparisons of Findings for Total and Primary Cesarean Deliveries and Macrosomia From GDM Treatment Trials (KQ7)

Timing of treatment | Author, Year; Sample Size | Total and Primary Cesarean Delivery Rates, % (events/N) and Relative Risk [95% CI]; Treated | Total and Primary Cesarean Delivery Rates, % (events/N) and Relative Risk [95% CI]; Untreated | Total and Primary Cesarean Delivery Rates, % (events/N) and Relative Risk [95% CI]; RR | Macrosomia (>4,000 g) Rate (unless otherwise noted), % (events/N) and Relative Risk [95% CI]; Treated | Macrosomia (>4,000 g) Rate (unless otherwise noted), % (events/N) and Relative Risk [95% CI]; Untreated | Macrosomia (>4,000 g) Rate (unless otherwise noted), % (events/N) and Relative Risk [95% CI]; RR
Treatment at >24 weeks’ gestation | Bevier 1999^224^; 83 | 14.3% (5/35); 8.6% (3/35) | 25.0% (12/48); 6.3% (3/48) | 0.57 [0.22 to 1.47]; 1.37 [0.29 to 6.40] | 2.9% (1/35) | 25.0% (12/48) | 0.11 [0.02 to 0.84]
Treatment at >24 weeks’ gestation | Bonomo 2005^225^; 300 | 29.0% (44/150) | 28.0% (42/150) | 1.05 [0.73 to 1.50] | 5.3% (8/150) | 10.7% (16/150) | 0.50 [0.22 to 1.13]
Treatment at >24 weeks’ gestation | Crowther 2005^41^; 1000 | 31.0% (152/490) | 32.0% (164/510) | 0.96 [0.80 to 1.16] | 10.0% (49/506) | 21.0% (110/524) | 0.46 [0.34 to 0.63]
Treatment at >24 weeks’ gestation | Garner 1997^226^; 299 | 20.1% (30/149) | 18.6% (28/150) | 1.08 [0.68 to 1.71] | 16.1% (24/149) | 18.7% (28/150) | 0.86 [0.53 to 1.42]
Treatment at >24 weeks’ gestation | Landon 2009^42^; 931 | 26.9% (128/476); 13.0% (62/476) | 33.8% (154/455); 19.8% (90/455) | 0.79 [0.65 to 0.97]; 0.66 [0.49 to 0.89] | 5.9% (28/477) | 14.3% (65/454) | 0.41 [0.27 to 0.63]
Treatment at >24 weeks’ gestation | Deveer 2013^229^; 100 | NR; 32% (16/50) | NR; 40% (20/50) | 0.80 [0.47 to 1.36] | 2.0% (1/50) | 20.0% (10/50) | 0.10 [0.01 to 0.75]
Treatment at >24 weeks’ gestation | Fadl 2015^230^; 69 | 21.2% (7/33) | 22.2% (8/36) | 0.95 [0.39 to 2.34] | >4,500g: 9.1% (3/33) | >4,500 g: 20.6% (7/34) | 0.44 [0.12 to 1.56]*
Treatment at >24 weeks’ gestation | Kokanali 2014^232^; 201 | 33.3% (33/99) | 42.2% (43/102) | 0.79 [0.55 to 1.13] | 15.1% (15/99) | 25.5% (26/102) | 0.59 [0.34 to 1.05]
Treatment at >24 weeks’ gestation | Yang 2014^236^; 700 | 70.5% (239/339) | 64.5% (233/361) | 1.09 [0.99 to 1.21] | 11.2% (38/339) | 17.5% (63/361) | 0.64 [0.44 to 0.93]
Treatment at >24 weeks’ gestation | Pooled estimate | | | Total cesarean: 0.95 [0.83, 1.08]; Primary: 0.70 [0.54 to 0.91] | | | 0.53 [0.41 to 0.68]
Early Treatment | Vinter 2018^235^; 90 | 33.3% (12/36) | 22.2% (12/54) | 1.50 [0.76 to 2.96] | 36% (13/36) | 30% (16/54) | 1.22 [0.67 to 2.22]
Early Treatment | Osmundson 2016^233^; 74 | 29.7% (11/37); 13.5% (5/37) | 46.0% (17/37); 27% (10/37) | 0.65 [0.35 to 1.19]; 0.50 [0.19 to 1.32] | 5.4% (2/37) | 13.5% (5/37) | 0.40 [0.08 to 1.93]
Early Treatment | Hughes 2016^231^; 44 | 26.1% (6/23) | 42.8% (9/21) | 0.61 [0.26 to 1.42] | LGA: 4.3% (1/23) | LGA: 9.5% (2/21) | 0.46 [0.04 to 4.68]
Early Treatment | Simmons 2018^234^; 20 | 5/11 | 3/9 | 1.36 [0.44 to 4.21] | LGA: 0% (0/11) | LGA: 33.3% (3/9) | 0.12 [0.01 to 2.04]
Early Treatment | Pooled estimate | | | Total cesarean: 0.91 [0.56 to 1.48]; Primary cesarean: NA | | | Macrosomia: 0.89 [0.33 to 2.42]; LGA: 0.27 [0.04 to 1.61]

Abbreviations: CI = confidence interval; g = grams; LGA =large for gestational age; NR=not reported; RR = relative risk

Appendix D Table 15 Relationship Between Predictive Values and Prevalence of GDM for 50-g OGCT Test Accuracy

Screening Test | Prevalence | Positive Predictive Value | Negative Predictive Value
50 g OGCT ≥140 mg/dL by CC 1982; Sensitivity=82%; Specificity=82% | 7% | 26% | 98%
50 g OGCT ≥140 mg/dL by CC 1982; Sensitivity=82%; Specificity=82% | 15% | 45% | 96%
50 g OGCT ≥140 mg/dL by CC 1982; Sensitivity=82%; Specificity=82% | 25% | 60% | 93%
50 g OGCT ≥135 mg/dL by CC 1982; Sensitivity=93%; Specificity=79% | 7% | 25% | 99%
50 g OGCT ≥135 mg/dL by CC 1982; Sensitivity=93%; Specificity=79% | 15% | 44% | 98%
50 g OGCT ≥135 mg/dL by CC 1982; Sensitivity=93%; Specificity=79% | 25% | 60% | 97%
50 g OGCT ≥130 mg/dL by CC 1982; Sensitivity=90%; Specificity=81% (median) | 7% | 26% | 99%
50 g OGCT ≥130 mg/dL by CC 1982; Sensitivity=90%; Specificity=81% (median) | 15% | 46% | 98%
50 g OGCT ≥130 mg/dL by CC 1982; Sensitivity=90%; Specificity=81% (median) | 25% | 61% | 96%
50 g OGCT ≥140 mg/dL by IADPSG 2010; Sensitivity=48%; Specificity=87% (median) | 7% | 22% | 96%
50 g OGCT ≥140 mg/dL by IADPSG 2010; Sensitivity=48%; Specificity=87% (median) | 15% | 39% | 90%
50 g OGCT ≥140 mg/dL by IADPSG 2010; Sensitivity=48%; Specificity=87% (median) | 25% | 55% | 83%
50 g OGCT ≥135 mg/dL by IADPSG 2010; Sensitivity=53%; Specificity=82% (median) | 7% | 18% | 96%
50 g OGCT ≥135 mg/dL by IADPSG 2010; Sensitivity=53%; Specificity=82% (median) | 15% | 34% | 91%
50 g OGCT ≥135 mg/dL by IADPSG 2010; Sensitivity=53%; Specificity=82% (median) | 25% | 50% | 84%
50 g OGCT ≥130 mg/dL by IADPSG 2010; Sensitivity=60%; Specificity=77% (median) | 7% | 16% | 96%
50 g OGCT ≥130 mg/dL by IADPSG 2010; Sensitivity=60%; Specificity=77% (median) | 15% | 32% | 92%
50 g OGCT ≥130 mg/dL by IADPSG 2010; Sensitivity=60%; Specificity=77% (median) | 25% | 47% | 85%
50 g OGCT ≥140 mg/dL by NDDG 1979; Sensitivity=85%; Specificity=81% | 7% | 25% | 99%
50 g OGCT ≥140 mg/dL by NDDG 1979; Sensitivity=85%; Specificity=81% | 15% | 44% | 97%
50 g OGCT ≥140 mg/dL by NDDG 1979; Sensitivity=85%; Specificity=81% | 25% | 60% | 94%
50 g OGCT ≥135 mg/dL by NDDG 1979; Sensitivity=84%; Specificity=65% (median) | 7% | 15% | 98%
50 g OGCT ≥135 mg/dL by NDDG 1979; Sensitivity=84%; Specificity=65% (median) | 15% | 30% | 96%
50 g OGCT ≥135 mg/dL by NDDG 1979; Sensitivity=84%; Specificity=65% (median) | 25% | 44% | 92%
50 g OGCT ≥130 mg/dL by NDDG 1979; Sensitivity=91%; Specificity=79% | 7% | 25% | 99%
50 g OGCT ≥130 mg/dL by NDDG 1979; Sensitivity=91%; Specificity=79% | 15% | 43% | 98%
50 g OGCT ≥130 mg/dL by NDDG 1979; Sensitivity=91%; Specificity=79% | 25% | 59% | 96%
50 g OGCT ≥140 mg/dL by Sacks 1989; Sensitivity=82%; Specificity=88% | 7% | 34% | 98%
50 g OGCT ≥140 mg/dL by Sacks 1989; Sensitivity=82%; Specificity=88% | 15% | 55% | 97%
50 g OGCT ≥140 mg/dL by Sacks 1989; Sensitivity=82%; Specificity=88% | 25% | 69% | 94%
50 g OGCT ≥135 mg/dL by Sacks 1989; Sensitivity=84%; Specificity=87% | 7% | 33% | 99%
50 g OGCT ≥135 mg/dL by Sacks 1989; Sensitivity=84%; Specificity=87% | 15% | 53% | 97%
50 g OGCT ≥135 mg/dL by Sacks 1989; Sensitivity=84%; Specificity=87% | 25% | 68% | 94%
50 g OGCT ≥130 mg/dL by Sacks 1989; Sensitivity=89%; Specificity=92% | 7% | 27% | 99%
50 g OGCT ≥130 mg/dL by Sacks 1989; Sensitivity=89%; Specificity=92% | 15% | 47% | 98%
50 g OGCT ≥130 mg/dL by Sacks 1989; Sensitivity=89%; Specificity=92% | 25% | 62% | 96%

Abbreviations: CC = Carpenter Coustan; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes and Pregnancy Study Group; NDDG = National Diabetes Data Group; OGCT = oral glucose challenge test

Appendix D Table 16 Relationship Between Predictive Values and Prevalence of GDM for Fasting Plasma Glucose Screening Tests

Screening Test | Prevalence | Positive Predictive Value | Negative Predictive Value
FPG ≥76 mg/dL by CC 1982; Sensitivity=median 98%; Specificity=median 17% | 7% | 8% | 99%
FPG ≥76 mg/dL by CC 1982; Sensitivity=median 98%; Specificity=median 17% | 15% | 17% | 98%
FPG ≥76 mg/dL by CC 1982; Sensitivity=median 98%; Specificity=median 17% | 25% | 28% | 97%
FPG ≥79 mg/dL by CC 1982; Sensitivity=96%; Specificity=35% | 7% | 10% | 99%
FPG ≥79 mg/dL by CC 1982; Sensitivity=96%; Specificity=35% | 15% | 21% | 98%
FPG ≥79 mg/dL by CC 1982; Sensitivity=96%; Specificity=35% | 25% | 33% | 96%
FPG ≥80 mg/dL by CC 1982; Sensitivity=median 90%; Specificity=median 72% | 7% | 20% | 99%
FPG ≥80 mg/dL by CC 1982; Sensitivity=median 90%; Specificity=median 72% | 15% | 36% | 98%
FPG ≥80 mg/dL by CC 1982; Sensitivity=median 90%; Specificity=median 72% | 25% | 52% | 96%
FPG ≥85 mg/dL by CC 1982; Sensitivity=88%; Specificity=73% | 7% | 20% | 99%
FPG ≥85 mg/dL by CC 1982; Sensitivity=88%; Specificity=73% | 15% | 37% | 97%
FPG ≥85 mg/dL by CC 1982; Sensitivity=88%; Specificity=73% | 25% | 52% | 95%
FPG ≥86 mg/dL by CC 1982; Sensitivity=median 80%; Specificity=median 76% | 7% | 20% | 98%
FPG ≥86 mg/dL by CC 1982; Sensitivity=median 80%; Specificity=median 76% | 15% | 37% | 96%
FPG ≥86 mg/dL by CC 1982; Sensitivity=median 80%; Specificity=median 76% | 25% | 53% | 92%
FPG ≥90 mg/dL by CC 1982; Sensitivity=81%; Specificity=82% | 7% | 25% | 98%
FPG ≥90 mg/dL by CC 1982; Sensitivity=81%; Specificity=82% | 15% | 44% | 96%
FPG ≥90 mg/dL by CC 1982; Sensitivity=81%; Specificity=82% | 25% | 60% | 93%
FPG ≥92 mg/dL by CC 1982; Sensitivity=median 67%; Specificity=median 90% | 7% | 33% | 97%
FPG ≥92 mg/dL by CC 1982; Sensitivity=median 67%; Specificity=median 90% | 15% | 54% | 94%
FPG ≥92 mg/dL by CC 1982; Sensitivity=median 67%; Specificity=median 90% | 25% | 69% | 89%
FPG ≥95.5 mg/dL by CC 1982; Sensitivity=58%; Specificity=98% | 7% | 69% | 97%
FPG ≥95.5 mg/dL by CC 1982; Sensitivity=58%; Specificity=98% | 15% | 84% | 93%
FPG ≥95.5 mg/dL by CC 1982; Sensitivity=58%; Specificity=98% | 25% | 91% | 88%
FPG ≥76 mg/dL by IADPSG 2010; Sensitivity=median 96%; Specificity=median 27% | 7% | 9% | 99%
FPG ≥76 mg/dL by IADPSG 2010; Sensitivity=median 96%; Specificity=median 27% | 15% | 19% | 97%
FPG ≥76 mg/dL by IADPSG 2010; Sensitivity=median 96%; Specificity=median 27% | 25% | 30% | 95%
FPG ≥77.5 mg/dL by IADPSG 2010; Sensitivity=median 93%; Specificity=median 40% | 7% | 10% | 99%
FPG ≥77.5 mg/dL by IADPSG 2010; Sensitivity=median 93%; Specificity=median 40% | 15% | 21% | 97%
FPG ≥77.5 mg/dL by IADPSG 2010; Sensitivity=median 93%; Specificity=median 40% | 25% | 34% | 95%
FPG ≥79 mg/dL by IADPSG 2010; Sensitivity=median 93%; Specificity=median 56% | 7% | 14% | 99%
FPG ≥79 mg/dL by IADPSG 2010; Sensitivity=median 93%; Specificity=median 56% | 15% | 27% | 98%
FPG ≥79 mg/dL by IADPSG 2010; Sensitivity=median 93%; Specificity=median 56% | 25% | 41% | 96%
FPG ≥83 mg/dL by IADPSG 2010; Sensitivity=median 87%; Specificity=median 67% | 7% | 17% | 99%
FPG ≥83 mg/dL by IADPSG 2010; Sensitivity=median 87%; Specificity=median 67% | 15% | 32% | 97%
FPG ≥83 mg/dL by IADPSG 2010; Sensitivity=median 87%; Specificity=median 67% | 25% | 47% | 94%
FPG ≥85 mg/dL by IADPSG 2010; Sensitivity=median 82%; Specificity=median 78% | 7% | 22% | 98%
FPG ≥85 mg/dL by IADPSG 2010; Sensitivity=median 82%; Specificity=median 78% | 15% | 40% | 96%
FPG ≥85 mg/dL by IADPSG 2010; Sensitivity=median 82%; Specificity=median 78% | 25% | 56% | 93%
FPG ≥86.5 mg/dL by IADPSG 2010; Sensitivity=median 80%; Specificity=median 85% | 7% | 28% | 98%
FPG ≥86.5 mg/dL by IADPSG 2010; Sensitivity=median 80%; Specificity=median 85% | 15% | 48% | 96%
FPG ≥86.5 mg/dL by IADPSG 2010; Sensitivity=median 80%; Specificity=median 85% | 25% | 63% | 93%
FPG ≥90 mg/dL by IADPSG 2010; Sensitivity=79%; Specificity=96% | 7% | 60% | 98%
FPG ≥90 mg/dL by IADPSG 2010; Sensitivity=79%; Specificity=96% | 15% | 78% | 96%
FPG ≥90 mg/dL by IADPSG 2010; Sensitivity=79%; Specificity=96% | 25% | 87% | 93%

Abbreviations: CC = Carpenter Coustan; FPG = fasting plasma glucose; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes in Pregnancy Study Groups