# Appendix C Supplementary Forest Plots

Appendix C Figure 1 Meta-Analysis of Trials: Preeclampsia, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 1 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies for preeclampsia. Our meta-analysis (3 trials, 1059 subjects) found the pooled relative risk was 0.66 with a 95% CI of 0.15 to 2.98; I2=76%.

Appendix C Figure 2 Meta-Analysis of Trials: Gestational Hypertension, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 2 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies for gestational hypertension. Our meta-analysis (2 trials, 833 subjects) found the pooled relative risk was 0.98 with a 95% CI of 0.70 to 1.38; I2=NA.

Appendix C Figure 3 Meta-Analysis of Trials: Hypertensive Disorders in Pregnancy, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 3 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies for hypertensive disorders in pregnancy. Our meta-analysis (2 trials, 22746 subjects) found the pooled relative risk was 1.01 with a 95% CI of 0.95 to 1.08; I2=0%.

Appendix C Figure 4 Meta-Analysis of Trials: Primary Cesarean Deliveries, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 4 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies for primary cesarean deliveries. Our meta-analysis (3 trials, 24302 subjects) found the pooled relative risk was 0.87 with a 95% CI of 0.67 to 1.13; I2=57%.

Appendix C Figure 5 Meta-Analysis of Trials: Total Cesarean Deliveries, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 5 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies for total cesarean deliveries. Our meta-analysis (3 trials, 1151 subjects) found the pooled relative risk was 1.04 with a 95% CI of 0.87 to 1.26; I2=0%.

Appendix C Figure 6 Meta-Analysis of Trials: Induction of Labor, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 6 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies for induction of labor. Our meta-analysis (3 trials, 23742 subjects) found the pooled relative risk was 1.00 with a 95% CI of 0.96 to 1.04; I2=0%.

Appendix C Figure 7 Meta-Analysis of Trials: Preterm Delivery, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 7 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies for preterm delivery. Our meta-analysis (4 trials, 23440 subjects) found the pooled peto odds ratio was 0.86 with a 95% CI of 0.53 to 1.39; I2=66%.

Appendix C Figure 8 Meta-Analysis of Trials: Maternal Birth Trauma, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 8 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies for maternal birth trauma. Our meta-analysis (3 trials, 1151 subjects) found the pooled relative risk was 0.65 with a 95% CI of 0.30 to 1.44; I2=0%.

Appendix C Figure 9 Meta-Analysis of Trials: Mortality, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question

Appendix C Figure 9 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies for mortality. Our meta-analysis (5 trials, 24381 subjects) found the pooled relative risk was 0.83 with a 95% CI of 0.60 to 1.14; I2=0%.

Appendix C Figure 10 Meta-Analysis of Trials: Shoulder Dystocia, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question

Appendix C Figure 10 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies for shoulder dystocia. Our meta-analysis (4 trials, 23583 subjects) found the pooled relative risk was 1.08 with a 95% CI of 0.90 to 1.30; I2=0%.

Appendix C Figure 11 Meta-Analysis of Trials: Neonatal Hyperbilirubinemia, IADPSG vs. CC Screening Strategies (KQ3)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 11 depicts the results of a meta-analysis of trials comparing the IADPSG versus CC screening strategies for neonatal hyperbilirubinemia. Our meta-analysis (4 trials, 24271 subjects) found the pooled relative risk was 1.02 with a 95% CI of 0.78 to 1.36; I2=32%.

Appendix C Figure 12 Forest Plot for Association Between More Inclusive GDM and Gestational Hypertension (KQ5)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value

Appendix C Figure 12 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and gestational hypertension. One abnormal value (OAV) on CC versus NGT study (1185 subjects) showed an estimated association with increased risk of 0.88 with a 95% CI of 0.47 to 1.62; I2=NA. The IADPSG excluding CC versus NGT meta-analysis (3 studies, 8996 subjects) showed an estimated association with increased risk of 1.01 with a 95% CI of 0.45 to 2.24; I2=61%. The IADPSG excluding NDDG versus NGT study (22804 subjects) showed an estimated association with increased risk of 1.28 with a 95% CI of 0.97 to 1.68; I2=NA.

Appendix C Figure 13 Forest Plot for Association Between More Inclusive GDM and Primary Cesarean Deliveries (KQ5)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value

Appendix C Figure 13 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and primary cesarean deliveries. One abnormal value (OAV) on CC versus NGT study (960 subjects) showed an estimated association with increased risk of 1.51 with a 95% CI of 1.12 to 2.05; I2=NA. The IADPSG excluding CC versus NGT meta-analysis (5 studies, 23394 subjects) showed an estimated association with increased risk of 1.10 with a 95% CI of 0.91 to 1.34; I2=77%.

Appendix C Figure 14 Forest Plot for Association Between More Inclusive GDM and Induction of Labor (KQ5)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value

Appendix C Figure 14 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and induction of labor. One abnormal value (OAV) on CC versus NGT study (309 subjects) showed an estimated association with increased risk of 2.81 with a 95% CI of 0.12 to 67.54; I2=NA. The IADPSG excluding CC versus NGT meta-analysis (3 studies, 7715 subjects) showed an estimated association with increased risk of 1.13 with a 95% CI of 0.93 to 1.39; I2=0%.

Appendix C Figure 15 Forest Plots for Association Between More Inclusive GDM and Maternal Birth Trauma (KQ5)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes and Pregnancy Study Groups; IV = inverse variance; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value; SE = standard error

Appendix C Figure 15 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and maternal birth trauma. One abnormal value (OAV) on CC versus NGT study (6260 subjects) showed an estimated association with increased odds of 1.01 with a 95% CI of 0.49 to 2.08; I2=NA. The OAV on NDDG versus NGT study (6196 subjects) showed an estimated association with increased odds of 1.61 with a 95% CI of 0.80 to 3.24; I2=NA. The IADPSG excluding CC meta-analysis (4 studies, 18785 subjects) showed an estimated association with increased risk of 1.19 with a 95% CI of 0.81 to 1.76; I2=0%.

Appendix C Figure 16 Forest Plots for Association Between More Inclusive GDM and Hyperbilirubinemia (KQ5)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value

Appendix C Figure 16 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and hyperbilirubinemia. One abnormal value (OAV) on CC versus NGT meta-analysis (4 studies, 8210 subjects) showed an estimated association with increased risk of 1.21 with a 95% CI of 1.02 to 1.45; I2=0%. The OAV on NDDG versus NGT study (1900 subjects) showed an estimated association with increased risk of 2.43 with a 95% CI of 1.30 to 4.54; I2=NA. The IADPSG excluding CC meta-analysis (4 studies, 12917 subjects) showed an estimated association with increased risk of 1.32 with a 95% CI of 1.13 to 1.54; I2=0%.

Appendix C Figure 17 Meta-Analysis for Association Between More Inclusive GDM and Mortality, All Comparisons (KQ5)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel; NGT = normal glucose tolerance

Appendix C Figure 17 depicts the results of a meta-analysis comparing observational studies on the association between more but not less inclusive criteria for GDM across all comparisons and mortality. Our meta-analysis (8 studies, 42303 subjects) showed an estimated association with increased risk of 1.66 with a 95% CI of 0.93 to 2.95; I2=0%.

Appendix C Figure 18 Forest Plots for Association Between More Inclusive GDM and Shoulder Dystocia (KQ5)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel; NGT = normal glucose tolerance; OAV = one abnormal value

Appendix C Figure 18 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and shoulder dystocia. One abnormal value (OAV) on CC versus NGT meta-analysis (5 studies, 4021 subjects) showed an estimated association with increased risk of 1.55 with a 95% CI of 0.60 to 3.98; I2=28%. The IADPSG excluding CC versus NGT meta-analysis (4 studies, 22752 subjects) showed an estimated association with increased risk of 1.79 with a 95% CI of 1.02 to 3.15; I2=9%.

Appendix C Figure 19 Forest Plots for Association Between More Inclusive GDM and NICU Admissions (KQ5)^*^ * Four studies^203,206,211,221^ examining IADPSG excluding CC performed adjusted analyses (N=12,419; aOR 1.02 [95% CI, 0.81 to 1.28]; I^2^=0%)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value

Appendix C Figure 19 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and NICU admissions. One abnormal value (OAV) on CC versus NGT meta-analysis (5 studies, 11780 subjects) showed an estimated association with increased risk of 1.15 with a 95% CI of 0.84 to 1.57; I2=0%. The OAV on NDDG versus NGT study (7217 subjects) showed an estimated association with increased risk of 1.24 with a 95% CI of 0.80 to 1.92; I2=NA. The IADPSG excluding CC versus NGT meta-analysis (5 studies, 27474 subjects) showed an estimated association with increased risk of 1.17 with a 95% CI of 0.99 to 1.38; I2=0%.

Appendix C Figure 20 Forest Plots for Association Between More Inclusive GDM and Respiratory Distress Syndrome (KQ5)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value

Appendix C Figure 20 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and respiratory distress syndrome. One abnormal value (OAV) on CC versus NGT meta-analysis (3 studies, 1733 subjects) showed an estimated association with increased risk of 0.65 with a 95% CI of 0.18 to 2.35; I2=0%. The OAV on NDDG versus NGT study (699 subjects) showed an estimated association with increased risk of 2.00 with a 95% CI of 1.02 to 3.94; I2=NA.

Appendix C Figure 21 Forest Plots for Association Between More Inclusive GDM and APGAR Scores Below 7 at 1 Minute (KQ5)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value

Appendix C Figure 21 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and APGAR scores below 7 at 1 minute. One abnormal value (OAV) on CC versus NGT meta-analysis (2 studies, 1424 subjects) showed an estimated association with increased risk of 2.28 with a 95% CI of 0.26 to 20.14; I2=60%. The OAV on NDDG versus NGT study (699 subjects) showed an estimated association with increased risk of 2.36 with a 95% CI of 0.91 to 6.18; I2=NA. The IADPSG excluding CC meta-analysis (2 studies, 10581 subjects) showed an estimated association with increased risk of 1.11 with a 8=95% CI of 0.76 to 1.62; I2=0%.

Appendix C Figure 22 Forest Plots for Association Between More Inclusive GDM and APGAR Scores Below 7 at 5 Minutes (KQ5)

Abbreviations: CC = Carpenter Coustan; CI = confidence interval; GDM = gestational diabetes mellitus; IADPSG = International Association of Diabetes and Pregnancy Study Groups; KQ = key question; M-H = Mantel-Haenszel; NDDG = National Diabetes Data Group; NGT = normal glucose tolerance; OAV = one abnormal value

Appendix C Figure 22 depicts the results of a forest plot comparing observational studies on the association between more but not less inclusive criteria for GDM and APGAR scores below 7 at 5 minutes. One abnormal value (OAV) on CC versus NGT meta-analysis (3 studies, 2384 subjects) showed an estimated association with increased risk of 1.63 with a 95% CI of 0.70 to 3.83; I2=0%. The OAV on NDDG versus NGT study (699 subjects) showed an estimated association with increased risk of 3.78 with a 95% CI of 1.03 to 13.89; I2=NA. The IADPSG excluding CC meta-analysis (3 studies, 17086 subjects) showed an estimated association with increased risk of 0.97 with a 8=95% CI of 0.30 to 3.11; I2=29%.

Appendix C Figure 23 Meta-Analysis of Trials: Gestational Hypertension, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 23 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for gestational hypertension. Our meta-analysis (2 trials, 1631 subjects) found the pooled relative risk was 0.82 with a 95% CI of 0.54 to 1.25; I2=0%.

Appendix C Figure 24 Meta-Analysis of Trials: Primary Cesarean Delivery, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 24 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for primary cesarean delivery. Our meta-analysis (3 trials, 1114 subjects) found the pooled relative risk was 0.70 with a 95% CI of 0.54 to 0.91; I2=0%.

Appendix C Figure 25 Meta-Analysis of Trials: Induction of Labor, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 25 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for induction of labor. Our meta-analysis (5 trials, 2783 subjects) found the pooled relative risk was 1.18 with a 95% CI of 0.92 to 1.52; I2=45%.

Appendix C Figure 26 Meta-Analysis of Trials: Maternal Birth Trauma, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 26 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for maternal birth trauma. Our meta-analysis (2 trials, 1100 subjects) found the pooled relative risk was 1.04 with a 95% CI of 0.92 to 1.18; I2=0%.

Appendix C Figure 27 Meta-Analysis of Trials: Mortality, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 27 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for mortality. Our meta-analysis (6 trials, 3154 subjects) found the pooled peto odds ratio was 0.49 with a 95% CI of 0.16 to 1.45; I2=68%.

Appendix C Figure 28 Meta-Analysis of Trials: Macrosomia (>4500g), Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 28 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for macrosomia (>4500g). Our meta-analysis (3 trials, 1066 subjects) found the pooled relative risk was 0.72 with a 95% CI of 0.39 to 1.35; I2=0%.

Appendix C Figure 29 Meta-Analysis of Trials: Respiratory Distress Syndrome, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 29 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for respiratory distress syndrome. Our meta-analysis (2 trials, 1962 subjects) found the pooled relative risk was 1.05 with a 95% CI of 0.48 to 2.28; I2=58%.

Appendix C Figure 30 Meta-Analysis of Trials: Any Hypoglycemia, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 30 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for any hypoglycemia. Our meta-analysis (5 trials, 2238 subjects) found the pooled relative risk was 1.10 with a 95% CI of 0.83 to 1.45; I2=0%.

Appendix C Figure 31 Meta-Analysis of Trials: Hyperbilirubinemia, Treated vs. Untreated GDM (KQ6)

Abbreviations: CI = confidence interval; GDM = gestational diabetes mellitus; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 31 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for hyperbilirubinemia. Our meta-analysis (5 trials, 2564 subjects) found the pooled relative risk was 0.84 with a 95% CI of 0.65 to 1.08; I2=0%.

Appendix C Figure 32 Meta-Analysis of Trials: 5 Minute Apgar Score Less Than 7, Treated vs. Untreated (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 32 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for a 5-minute APGAR score less than 7. Our meta-analysis (3 trials, 1331 subjects) found the pooled relative risk was 0.62 with a 95% CI of 0.27 to 1.41; I2=0%.

Appendix C Figure 33 Meta-Analysis of Trials: Childhood Overweight or Obesity (BMI ≥85th percentile), Treated vs. Untreated (KQ6)

Abbreviations: BMI = body mass index; CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 33 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for childhood overweight or obesity (BMI greater than or equal to 85th percentile). Our meta-analysis (2 trials, 699 subjects) found the pooled relative risk was 0.96 with a 95% CI of 0.69 to 1.33; I2=49%.

Appendix C Figure 34 Meta-Analysis of Trials: Childhood Obesity (BMI ≥95th percentile), Treated vs. Untreated (KQ6)

Abbreviations: BMI = body mass index; CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 34 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for childhood obesity (BMI greater than or equal to 95th percentile). Our meta-analysis (2 trials, 585 subjects) found the pooled relative risk was 1.02 with a 95% CI of 0.66 to 1.59; I2=24%.

Appendix C Figure 35 Meta-Analysis of Trials: Preeclampsia, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Data for Osmundson were reported at ClincialTrials.gov

Appendix C Figure 35 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for preeclampsia. Our meta-analysis (3 trials, 229 subjects) found the pooled relative risk was 0.69 with a 95% CI of 0.21 to 2.23; I2=0%.

Appendix C Figure 36 Meta-Analysis of Trials: Gestational Hypertension, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 36 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for gestational hypertension. Our meta-analysis (2 trials, 164 subjects) found the pooled relative risk was 0.75 with a 95% CI of 0.31 to 1.84; I2=0%.

Appendix C Figure 37 Meta-Analysis of Trials: Hypertensive Disorders of Pregnancy, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Data for Osmundson are adding data for pre-eclampsia from ClincialTrials.gov with data in primary publication on Gestational hypertension.

Appendix C Figure 37 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for hypertensive disorders of pregnancy. Our meta-analysis (3 trials, 184 subjects) found the pooled relative risk was 0.92 with a 95% CI of 0.46 to 1.81; I2=0%.

Appendix C Figure 38 Meta-Analysis of Trials: Cesarean Delivery, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 38 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for cesarean delivery. Our meta-analysis (4 trials, 228 subjects) found the pooled relative risk was 0.91 with a 95% CI of 0.56 to 1.48; I2=35%.

Appendix C Figure 39 Forest Plot of Trial: Primary Cesarean Delivery, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 39 depicts a forest plot of the results of a trial comparing early treatment for GDM versus usual care for primary cesarean delivery. The trial (74 subjects) found the relative risk was 0.50 with a 95% CI of 0.19 to 1.32; I2=NA.

Appendix C Figure 40 Meta-Analysis of Trials: Emergency Cesarean Delivery, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 40 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for emergency cesarean delivery. Our meta-analysis (3 trials, 154 subjects) found the pooled relative risk was 0.81 with a 95% CI of 0.37 to 1.78; I2=11%.

Appendix C Figure 41 Meta-Analysis of Trials: Induction of Labor, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 41 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for induction of labor. Our meta-analysis (3 trials, 138 subjects) found the pooled relative risk was 1.12 with a 95% CI of 0.76 to 1.67; I2=3%.

Appendix C Figure 42 Meta-Analysis of Trials: Preterm Delivery, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 42 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for preterm delivery. Our meta-analysis (2 trials, 134 subjects) found the pooled relative risk was 1.27 with a 95% CI of 0.27 to 6.07; I2=0%.

Appendix C Figure 43 Meta-Analysis of Trials: Excessive Gestational Weight Gain, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 43 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for excessive gestational weight gain. Our meta-analysis (2 trials, 159 subjects) found the pooled relative risk was 0.65 with a 95% CI of 0.37 to 1.15; I2=6%.

Appendix C Figure 44 Meta-Analysis of Trials: Mortality, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question

Data for Osmundson were reported at ClincialTrials.gov

Appendix C Figure 44 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for mortality. Our meta-analysis (3 trials, 138 subjects) found the pooled relative risk was 0.12 with a 95% CI of 0.01 to 1.95; I2=0%.

Appendix C Figure 45 Meta-Analysis of Trials: Shoulder Dystocia, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question

Appendix C Figure 45 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care and shoulder dystocia. Our meta-analysis (3 trials, 64 subjects) found the pooled peto odds ratio was 0.11 with a 95% CI of 0.00 to 5.57; I2=NA.

Appendix C Figure 46 Meta-Analysis of Trials: Macrosomia (>4000g), Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 46 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for macrosomia (>4000g). Our meta-analysis (2 trials, 164 subjects) found the pooled relative risk was 0.89 with a 95% CI of 0.33 to 2.42; I2=42%.

Appendix C Figure 47 Meta-Analysis of Trials: Large for Gestational Age, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 47 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for large for gestational age. Our meta-analysis (3 trials, 154 subjects) found the pooled relative risk was 0.68 with a 95% CI of 0.18 to 2.54; I2=35%.

Appendix C Figure 48 Meta-Analysis of Trials: NICU Admission, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel; NICU = neonatal intensive care unit

Appendix C Figure 48 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for NICU admission. Our meta-analysis (3 trials, 154 subjects) found the pooled relative risk was 0.98 with a 95% CI of 0.28 to 3.43; I2=29%.

Appendix C Figure 49 Meta-Analysis of Trials: Mild-to-Moderate Hypoglycemia, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Data for Osmundson are from ClincialTrials.gov.

Appendix C Figure 49 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for mild-to-moderate hypoglycemia. Our meta-analysis (3 trials, 123 subjects) found the pooled relative risk was 1.77 with a 95% CI of 0.62 to 5.03; I2=0%.

Appendix C Figure 50 Meta-Analysis of Trials: Hyperbilirubinemia, Early Treatment vs. Usual Care (KQ6)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Data for Osmundson are from ClincialTrials.gov

Appendix C Figure 50 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for hyperbilirubinemia. Our meta-analysis (2 trials, 116 subjects) found the pooled relative risk was 1.57 with a 95% CI of 0.65 to 3.82; I2=0%.

Appendix C Figure 51 Meta-Analysis of Trials: Small for Gestational Age, Treated vs. Untreated (KQ7)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 51 depicts the results of a meta-analysis of trials comparing treated versus untreated GDM for small for gestational age. Our meta-analysis (6 trials, 2646 subjects) found the pooled relative risk was 1.10 with a 95% CI of 0.83 to 1.47; I2=0%.

Appendix C Figure 52 Meta-Analysis of Trials: Small for Gestational Age, Early Treatment vs. Usual Care (KQ7)

Abbreviations: CI = confidence interval; KQ = key question; M-H = Mantel-Haenszel

Appendix C Figure 52 depicts the results of a meta-analysis of trials comparing early treatment for GDM versus usual care for small for gestational age. Our meta-analysis (2 trials, 64 subjects) found the pooled relative risk was 1.51 with a 95% CI of 0.28 to 8.00; I2=32%.