# Appendix B Study Characteristics and Quality Rating Tables

Appendix B Table 1 Studies on Effectiveness of Screening vs. No Screening (KQ1)

Appendix B Table 2 Quality Assessment of Studies on Effectiveness of Screening vs. No Screening (KQ1) Cohorts and Case-Controls

Appendix B Table 3 Studies on Harms Associated With the Screening Tests for, or With a Diagnosis of, GDM (KQ2)

Appendix B Table 4 Quality Assessment of Studies on Harms Associated With the Screening Tests for, or With a Diagnosis of, GDM (KQ2)

Appendix B Table 5 Studies Comparing Different Screening Strategies (KQ3)

Appendix B Table 6 Quality Assessment of Studies Comparing Different Screening Strategies (KQ3)

Appendix B Table 7 Studies on Accuracy of Screening Tests (KQ4)

Appendix B Table 8 Quality Assessment of Studies on Accuracy of Screening Tests (KQ4), QUADAS-2

Appendix B Table 9 Quality Assessment of Studies on Accuracy of Risk-based Scoring Systems (KQ4), PROBAST

Appendix B Table 10 Studies on Associations of Outcomes for More vs. Less Inclusive GDM Criteria (KQ5)

Appendix B Table 11 Quality Assessment of Studies on Associations of Outcomes for More vs. Less Inclusive GDM Criteria (KQ5)

Appendix B Table 12 Studies on Treatment of Gestational Diabetes (KQs 6 and 7)

Appendix B Table 13 Quality Ratings of Studies on Treatment of Gestational Diabetes (KQs 6 and 7)