# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Ovid MEDLINE(R) and Epub Ahead of Print, In-Process & Other Non-Indexed Citations and Daily 1946 to May 10, 2019 (Updated to May 22 2020)

1. Diabetes, Gestational/
2. (GDM or booking diabetes).tw.
3. (gestation$ adj2 (diabet$ or DM or glucose intoleran$ or insulin resistan$)).mp.
4. (pregnan$ adj3 (diabet$ or DM or glucose intoleran$ or insulin resistan$ or dysglycem$)).mp.
5. (maternal adj2 (diabet$ or DM or glyc?emia or hyperglyc?emia or glucose or dysglycem$)).tw.
6. (hyperglyc?emia adj2 pregnan$).tw.
7. or/1-6
8. mass screening/
9. prenatal diagnosis/
10. screen$.ti,ab.
11. diagnos$.ti,ab.
12. Glucose Tolerance Test/
13. Blood Glucose/
14. (serum or blood glucose or maternal glucose).tw.
15. (OGTT or tolerance test$).tw.
16. (GCT or challenge test$).tw.
17. ((fasting adj2 glucose) or FG or FBG).tw.
18. (Carpenter-Coustan or Carpenter Coustan or NDDG or IADPSG or HbA1c or A1c or glycated hemoglobin).tw.
19. Glycated Hemoglobin A/
20. or/8-19
21. intervention$.mp.
22. (treat$ or therap$).mp.
23. manage$.mp.
24. monitor$.mp.
25. exp sulfonylurea compounds/
26. Gliclazide/
27. Glyburide/
28. Tolbutamide/
29. sulfonylurea?.tw.
30. gliclazid$.tw.
31. glimepirid$.tw.
32. glipizid$.tw.
33. glyburid$.tw.
34. tolbutamid$.tw.
35. Metformin/
36. Metformin.tw.
37. (antidiabet$ or anti-diabet$).tw.
38. insulin$.mp.
39. glibenclamid$.mp.
40. acarbos$.mp.
41. exp Diet Therapy/
42. (diet adj2 (therap$ or restrict$ or advice)).tw.
43. medical nutrition$ therapy.tw.
44. MNT.tw.
45. exp Life Style/
46. (lifestyle$ or life-style$).mp.
47. Blood Glucose Self-Monitoring/
48. (blood glucose adj (self monitor$ or self-monitor$)).tw.
49. ((self monitor$ or self-monitor$) adj blood glucose).tw.
50. SMBG.tw.
51. Counseling/
52. counsel$.tw.
53. or/21-52
54. “Sensitivity and Specificity”/
55. “Predictive Value of Tests”/
56. ROC Curve/
57. specificit$.tw.
58. sensitivit$.tw.
59. predictive value.tw.
60. accurac$.tw.
61. diagnostic errors/
62. diagnostic error?.tw.
63. false negative reactions/
64. false positive reactions/
65. (false adj (negative or positive)).tw.
66. reference values/
67. reference standards/
68. or/54-67
69. (controlled clinical trial or randomized controlled trial or pragmatic clinical trial or equivalence trial).pt.
70. clinical trial.pt.
71. (randomi?ed or randomi?ation$ or randomly or RCT$).tw,kf.
72. Randomized Controlled Trials as Topic/
73. trial.ti.
74. Controlled Clinical Trial/ or Controlled Clinical Trials as Topic/
75. (control$ adj2 trial$).tw,kf.
76. Non-Randomized Controlled Trials as Topic/
77. (nonrandom$ or non-random$ or quasi-random$ or quasi-experiment$).tw,kf.
78. (nRCT or non-RCT).tw,kf.
79. Controlled Before-After Studies/
80. (control$ adj3 ((before and after) or before after)).tw,kf.
81. (pre- adj3 post-).tw,kf.
82. (pretest adj3 posttest).tw,kf.
83. Historically Controlled Study/
84. (control$ adj2 study).tw,kf.
85. Control Groups/
86. group$.tw,kf.
87. exp Cohort Studies/
88. cohort$.tw,kf.
89. Retrospective Studies/
90. (longitudinal or prospective or retrospective).tw,kf.
91. ((followup or follow-up or follow up) adj (study or studies)).tw,kf.
92. Observational study.pt.
93. (observation$ adj (study or studies)).tw,kf.
94. ((population or population-based) adj (study or studies or analys?s)).tw,kf.
95. Comparative Study.pt.
96. ((comparative or comparison) adj (study or studies)).tw,kf.
97. exp Case-Control Studies/
98. ((case-control$ or case-based or case-comparison) adj (study or studies)).tw,kf.
99. (case-series or case series).tw.
100. or/69-99
101. (animal$ or bovine$ or calf or calves or camel$ or canine$ or cat or cats or chimp$ or dog or dogs or equine$ or feline$ or goat$ or hamster$ or horse$ or llama$ or mice$ or monkey$ or mouse$ or pig or piglet$ or pigs or porcine$ or primate$ or rabbit$ or rat or rats or rodent$ or sheep$ or simian$ or swine$ or veterinar$).ti.
102. 7 and (20 or 53)
103. 68 or 100
104. 102 and 103
105. 104 not 101

### Embase 1974 to 2019 May 10, 2019 (Updated in May 22 2020)

1. pregnancy diabetes mellitus/
2. (GDM or booking diabetes).tw.
3. (gestation$ adj2 (diabet$ or DM or glucose intoleran$ or insulin resistan$)).mp.
4. (pregnan$ adj3 (diabet$ or DM or glucose intoleran$ or insulin resistan$ or dysglycem$)).mp.
5. (maternal adj2 (diabet$ or DM or glyc?emia or hyperglyc?emia or glucose or dysglycem$)).tw.
6. (hyperglyc?emia adj2 pregnan$).tw.
7. or/1-6
8. mass screening/
9. prenatal diagnosis/
10. prenatal screening/
11. screen$.ti,ab.
12. diagnos$.ti,ab.
13. exp Glucose Tolerance Test/
14. Blood Glucose level/
15. (glucose adj (tolerance or intolerance or challenge)).tw.
16. (serum or blood glucose or maternal glucose).tw.
17. (OGTT or tolerance test$).tw.
18. (GCT or challenge test$).tw.
19. ((fasting adj2 glucose) or FG or FBG).tw.
20. (Carpenter-Coustan or Carpenter Coustan or NDDG or IADPSG or HbA1c or A1c or glycated h?emoglobin).tw.
21. glycosylated hemoglobin/
22. or/8-21
23. intervention$.mp.
24. (treat$ or therap$).mp.
25. manage$.mp.
26. monitor$.mp.
27. exp sulfonylurea derivative/
28. metformin/
29. sulfonylurea?.tw.
30. gliclazid$.tw.
31. glimepirid$.tw.
32. glipizid$.tw.
33. glyburid$.tw.
34. tolbutamid$.tw.
35. Metformin.tw.
36. (antidiabet$ or anti-diabet$).tw.
37. insulin$.mp.
38. glibenclamid$.mp.
39. acarbos$.mp.
40. exp Diet Therapy/
41. (diet adj2 (therap$ or restrict$ or advice)).tw.
42. medical nutrition$ therapy.tw.
43. MNT.tw.
44. exp lifestyle/
45. (lifestyle$ or life-style$).mp.
46. Blood Glucose Monitoring/
47. (blood glucose adj (self monitor$ or self-monitor$)).tw.
48. ((self monitor$ or self-monitor$) adj blood glucose).tw.
49. SMBG.tw.
50. Counseling/
51. counsel$.tw.
52. or/23-51
53. “Sensitivity and Specificity”/
54. predictive value/
55. receiver operating characteristic/
56. specificit$.tw.
57. sensitivit$.tw.
58. predictive value.tw.
59. accurac$.tw.
60. diagnostic error/
61. diagnostic accuracy/
62. diagnostic error$.tw.
63. false negative result/
64. false positive result/
65. (false adj (negative or positive)).tw.
66. reference value/
67. reference standard/
68. or/53-67
69. clinical trial/
70. controlled clinical trial/
71. randomized controlled trial/
72. pragmatic trial/
73. equivalence trial/
74. cohort analysis/
75. exp case control study/
76. Control Groups/
77. retrospective study/
78. trial.ti.
79. (control$ adj2 (trial$ or study or studies or group$)).tw.
80. (nonrandom$ or non-random$ or quasi-random$ or quasi-experiment$).tw.
81. (nRCT or non-RCT).tw.
82. (control$ adj3 ((before and after) or before after)).tw.
83. (pre- adj3 post-).tw.
84. (pretest adj3 posttest).tw.
85. group$.tw.
86. cohort$.tw.
87. (longitudinal or prospective or retrospective).tw.
88. ((followup or follow-up or follow up) adj (study or studies)).tw.
89. (observation$ adj (study or studies)).tw.
90. ((population or population-based) adj (study or studies or analys?s)).tw.
91. ((comparative or comparison) adj (study or studies)).tw.
92. ((case-control$ or case-based or case-comparison) adj (study or studies)).tw.
93. or/69-92
94. (animal$ or bovine$ or calf or calves or camel$ or canine$ or cat or cats or chimp$ or dog or dogs or equine$ or feline$ or goat$ or hamster$ or horse$ or llama$ or mice$ or monkey$ or mouse$ or pig or piglet$ or pigs or porcine$ or primate$ or rabbit$ or rat or rats or rodent$ or sheep$ or simian$ or swine$ or veterinar$).ti.
95. 7 and (22 or 52)
96. 68 or 93
97. 95 and 96
98. 97 not 94
99. limit 98 to (conference abstract or conference paper or editorial)
100. 98 not 99

### CINAHL Plus with Full Text, May 10, 2019 (Updated May 22, 2020)

# | Query
S69 | S67 AND S68
S68 | S22 or S65
S67 | S4 and (S11 or S19)
S66 | TI (animal* or bovine* or calf or calves or camel* or canine* or cat or cats or chimp* or dog or dogs or equine* or feline* or goat* or hamster* or horse* or llama* or mice* or monkey* or mouse* or pig or piglet* or pigs or porcine* or primate* or rabbit* or rat or rats or rodent* or sheep* or simian* or swine* or veterinar*)
S65 | S55 OR S56 OR S57 OR S58 OR S59 OR S60 OR S61 OR S62 OR S63 OR S64
S64 | (followup or follow-up or “follow up” or observation* or population or population-based or comparative or comparison or case-control* or case-based or case-comparison) n2 (study or studies or analys#s)
S63 | pretest n3 posttest
S62 | (pre- n3 post-)
S61 | (nonrandom* or non-random* or quasi-random* or quasi-experiment* or nRCT or non-RCT or “time series” or cohort* or longitudinal or prospective or retrospective or case-series or case series)
S60 | (control* n3 (“before and after” or “before after”))
S59 | (control* n2 (trial* or study or studies or group*))
S58 | (MH “Clinical Trials+”) or (MH “Control Group”) or (MH “prospective studies”) or (MH “Case Control Studies+”)
S57 | TI trial* or group*
S56 | randomi#ed or randomi#ation or randomly or RCT*
S55 | PT “controlled clinical trial” or “randomized controlled trial” or “pragmatic clinical trial” or “equivalence trial” or “clinical trial” or “controlled before-after study” or “historically controlled study” or “retrospective study” or “observational study” or “comparative study” or “case-control study”
S54 | S52 OR S53
S53 | (specificit* or sensitivit* or (predictive w1 value*) or accurac* or (diagnostic w1 error*)) OR ((false w1 negative) or (false w1 positive))
S52 | (MH “Sensitivity and Specificity”) or (MH “Predictive Value of Tests”) or (MH “ROC Curve”) or (MH “Diagnostic Errors”) or (MH “False Negative Reactions”) or (MH “False Positive Reactions”) or (MH “Reference Values”) or (MH “Reference Standards”)
S51 | S44 OR S45 OR S46 OR S47 OR S48 OR S49 OR S50
S50 | (MH “Counseling”) OR counsel*
S49 | (MH “Blood Glucose Self-Monitoring”) OR (“blood glucose” w1 “self monitor*” or “blood glucose” w1 “self-monitor*”) OR SMBG
S48 | (MH “Life Style Changes”) OR (lifestyle* or life-style*)
S47 | (MH “Diet Therapy”) OR (diet w2 therap* or diet w2 restrict* or diet w2 advice) OR (“medical nutrition therapy” or MNT)
S46 | (sulfonyurea? or gliclazid* or glimepirid* or glipizid* or glyburid* or tolbutamid* ) OR (antidiabet* or anti-diabet*) OR (insulin* or glibenclamid* or acarbos* or metformin*)
S45 | (MH “Sulfonylurea Compounds+”)
S44 | intervention* or treating or treatment* or therapy or therapies or manage* or monitor*
S43 | S37 OR S38 OR S39 OR S40 OR S41 OR S42
S42 | MH Hemoglobin A, Glycosylated
S41 | (Carpenter-Coustan or “Carpenter Coustan” or NDDG or IADPSG or HbA1c or A1c or glycated h#emoglobin)
S40 | (fasting n2 glucose) or FG or FBG
S39 | (serum or “blood glucose” or “maternal glucose” or OGTT or “tolerance test” or GCT or “challenge test”
S38 | (TI (screen* or diagnos*)) or (AB (screen* or diagnos*))
S37 | (MH “mass screening”) or (MH “prenatal diagnosis”) or (MH “Glucose tolerance test”) or (MH “Blood Glucose”) or (MH “blood glucose monitoring”)
S36 | S33 OR S34 OR S35
S35 | hyperglyc#emia n2 pregnan*
S34 | ( (gestation* w2 diabet* or gestation* w2 DM or gestation* w2 glucose intoleran* or gestation* w2 insulin resistan*) ) OR ( (pregnan* w3 diabet* or pregnan* w3 DM or pregnan* w3 glucose intoleran* or pregnan* w3 insulin resistan* or pregnanc* w3 dysglycem*) ) OR ( (maternal w2 diabet* or maternal w2 DM or maternal w2 glyc#emia or maternal w2 hyperglyc#emia or maternal w2 dysglycem*) )
S33 | MM Diabetes Mellitus, Gestational OR GDM OR “Booking diabetes”
S32 | (followup or follow-up or “follow up” or observation* or population or population-based or comparative or comparison or case-control* or case-based or case-comparison) n2 (study or studies or analys#s)
S31 | pretest n3 posttest
S30 | (pre- n3 post-)
S29 | (nonrandom* or non-random* or quasi-random* or quasi-experiment* or nRCT or non-RCT or “time series” or cohort* or longitudinal or prospective or retrospective or case-series or case series)
S28 | (control* n3 (“before and after” or “before after”))
S27 | (control* n2 (trial* or study or studies or group*))
S26 | (MH “Clinical Trials+”)
S25 | TI trial* or group*
S24 | randomi#ed or randomi#ation or randomly or RCT*
S23 | PT “controlled clinical trial” or “randomized controlled trial” or “pragmatic clinical trial” or “equivalence trial” or “clinical trial” or “controlled before-after study” or “interrupted time series analysis” or “historically controlled study” or “retrospective study” or “observational study” or “comparative study” or “case-control study”
S22 | S20 OR S21
S21 | (specificit* or sensitivit* or (predictive w1 value*) or accurac* or (diagnostic w1 error*)) OR ((false w1 negative) or (false w1 positive))
S20 | (MH “Sensitivity and Specificity”) or (MH “Predictive Value of Tests”) or (MH “ROC Curve”) or (MH “Diagnostic Errors”) or (MH “False Negative Reactions”) or (MH “False Positive Reactions”) or (MH “Reference Values”) or (MH “Reference Standards”)
S19 | S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18
S18 | (MH “Counseling”) OR counsel*
S17 | (MH “Blood Glucose Self-Monitoring”) OR (“blood glucose” w1 “self monitor*” or “blood glucose” w1 “self-monitor*”) OR SMBG
S16 | (MH “Life Style Changes”) OR (lifestyle* or life-style*)
S15 | (MH “Diet Therapy”) OR (diet w2 therap* or diet w2 restrict* or diet w2 advice) OR (“medical nutrition therapy” or MNT)
S14 | (sulfonyurea? or gliclazid* or glimepirid* or glipizid* or glyburid* or tolbutamid* ) OR (antidiabet* or anti-diabet*) OR (insulin* or glibenclamid* or acarbos* or metformin*)
S13 | (MH “Sulfonylurea Compounds+”)
S12 | intervention* or treating or treatment* or therapy or therapies or manage* or monitor*
S11 | S5 OR S6 OR S7 OR S8 OR S9 OR S10
S10 | MH Hemoglobin A, Glycosylated
S9 | (Carpenter-Coustan or “Carpenter Coustan” or NDDG or IADPSG or HbA1c or A1c or glycated h#emoglobin)
S8 | (fasting n2 glucose) or FG or FBG
S7 | (serum or “blood glucose” or “maternal glucose” or OGTT or “tolerance test” or GCT or “challenge test”
S6 | (TI (screen* or diagnos*)) or (AB (screen* or diagnos*))
S5 | (MH “mass screening”) or (MH “prenatal diagnosis”) or (MH “Glucose tolerance test”) or (MH “Blood Glucose”) or (MH “blood glucose monitoring”)
S4 | S1 OR S2 OR S3
S3 | hyperglyc#emia n2 pregnan*
S2 | ( (gestation* w2 diabet* or gestation* w2 DM or gestation* w2 glucose intoleran* or gestation* w2 insulin resistan*) ) OR ( (pregnan* w3 diabet* or pregnan* w3 DM or pregnan* w3 glucose intoleran* or pregnan* w3 insulin resistan* or pregnanc* w3 dysglycem*) ) OR ( (maternal w2 diabet* or maternal w2 DM or maternal w2 glyc#emia or maternal w2 hyperglyc#emia or maternal w2 dysglycem*) )
S1 | MM Diabetes Mellitus, Gestational OR GDM OR “Booking diabetes”

## Appendix A2 Inclusion and Exclusion Criteria

| Include | Exclude
Population | KQs 1–5: Pregnant women with no known history of pre-existing diabetes mellitus; KQs 6, 7: Pregnant women with GDM or hyperglycemia; KQs 1c, 3c, 6c: Pre-pregnancy body mass index (i.e., <25 vs. ≥25 kg/m^2^, <30 vs. ≥30 kg/m^2^); age (e.g., <25 vs. ≥25 years, <35 vs. ≥35 years); timing during pregnancy (e.g., <24 vs ≥24 weeks); race/ethnicity (i.e., non-Hispanic white, American Indian or Alaskan Native, African American, Asian, Hispanic, or Pacific Islander); family history of type 2 diabetes mellitus, history of GDM, identified as “high-risk” by study authors (KQs 1 and 3 only), and severity of hyperglycemia (KQ 6 only)
Interventions/Exposure | KQs 1–3: Screening using one- or two-step strategies,^*^ followed by intention-to-treat patients with a diagnosis of GDM:; - In two-step screening, the screening test must be FPG, 50-g OGCT, risk factor–based method (clinical or historical using ≥1 factors), or hemoglobin A1c; in both one- and two-step screening, the diagnostic tool must be FPG or OGTT (using any GDM criteria); - Screening strategies may vary the timing of screening based on patient characteristics (e.g., early screening for patients with risk factors vs. later screening for those without); KQ 4: Screening tests (i.e., FPG, 50-g OGCT, risk factor–based method, or hemoglobin A1c); KQ 5: Diagnosis of GDM using one of the below criteria, but no treatment of GDM or meeting two-step Carpenter-Coustan or NDDG criteria:; - IADPSG (also known as HAPO 1.75 criteria, new World Health Organization GDM criteria, or the Diabetes Canada alternative strategy); - One-step Carpenter-Coustan, NDDG, or HAPO 2.0 criteria; - Two-step Carpenter-Coustan or NDDG criteria (both using only one abnormal glucose value) or HAPO 2.0 criteria (also known as the Diabetes Canada preferred criteria); KQs 6, 7: Any treatment of GDM offered during pregnancy, including but not limited to dietary advice, physical activity, blood glucose monitoring, insulin therapy (all preparations), or glucose-lowering medications | KQs 1–5: Alternative methods to deliver glucose (e.g., candy bars)
Comparators | KQs 1, 2: No screening; for KQ2, may be no intervention comparison if study authors measure outcomes before and after screening in each participant; KQ 3: Another screening strategy, such as one- vs. two-step screening, different diagnostic criteria or cut-offs, different timing in pregnancy (may be due to risk factors), or selective/risk-based vs. universal screening; KQ 4: Any FPG or OGTT used for diagnosis; KQ 5: No GDM by any criteria applied in the study (e.g., OCGT negative, OCGT positive but no GDM [false-positive result], both OGCT negative and false-positive results); KQs 6, 7: No treatment (i.e., no additional management or minimally active intervention, such as printed materials) | KQs 1–5: Alternative methods to deliver glucose (e.g., candy bars, glucose loads) with same diagnostic criteria; KQs 6, 7: All active interventions
Outcomes | KQs 1, 3, 5, 6:; Intermediate; - Pregnancy: Excessive gestational weight gain (as per guidance from the Institute of Medicine, or defined by study author); - Long-term: Maternal and childhood development of metabolic impairment (impaired glucose tolerance) or obesity; Health; - Pregnancy: Pre-eclampsia, gestational hypertension, cesarean delivery, and induction of labor; - Fetal/neonatal: Mortality (miscarriage, stillbirth, neonatal death), birth injury (fracture, permanent nerve injury), acute morbidity (e.g., hypoglycemia, hyperbilirubinemia, NICU admission, respiratory distress syndrome), fetal overgrowth (large for gestational age or macrosomia), and shoulder dystocia; - Long-term maternal: Development of type 2 diabetes mellitus; mortality or major morbidity from type 2 diabetes mellitus (e.g., retinopathy, neuropathy), cardiovascular disease, or both; and quality of life; - Long-term childhood: Development of type 2 diabetes mellitus, cardiovascular outcomes, and neurocognitive outcomes; KQ 2: Adverse effects from screening tests (e.g., vomiting, anxiety or depression for the mother), from a GDM diagnosis (i.e., consequences from the label of GDM to the woman, fetus or neonate, such as unnecessary delivery interventions, additional interventions with formula, separation of infant and mother, breastfeeding challenges/failure), or both; KQ 4: Sensitivity, specificity, positive or negative predictive values, accuracy, and yield (i.e., prevalence); KQ 7: Severe maternal or neonatal hypoglycemia, delivery of neonate who is small for gestational age, and long-term growth and development of the child | KQs 1, 3–6: Other outcomes
Outcome assessment timing | Any duration of followup
Setting | KQs 1–3, 5–7: Settings applicable to primary care; countries not categorized as “Very High” on the Human Development Index (as defined by the United Nations Development Programme) will be subject to sensitivity analysis; KQ 4: Any setting
Study designs | KQs 1, 2: RCTs, CCTs, and controlled observational studies; KQ 2: Studies in which all patients are screened but harms are assessed before (i.e., earlier in pregnancy) and after screening; KQ 3: RCTs and CCTs; KQ 4: Prospective cohort studies, single arms of trials; KQ 5: Observational studies and single-arm trials (i.e., trial arms not receiving treatment); KQs 6, 7: RCTs, CCTs; controlled observational studies, if no trials exist | Systematic reviews^†^, abstracts, and conference proceedings
Publication language | English

Abbreviations: CCT=controlled clinical trial; FPG=fasting plasma glucose; GDM=gestational diabetes mellitus; HAPO=Hyperglycemia and Adverse Pregnancy Outcome Study; IADPSG=International Association of Diabetes and Pregnancy Study Group; KQ=key question; NDDG=National Diabetes Data Group; NICU=neonatal intensive care unit; OGCT=oral glucose challenge test; OGTT=oral glucose tolerance test; RCT=randomized, controlled trial.

* Two-step screening involves a screening test (e.g., 50-g OGCT, risk factor–based method) followed by a diagnostic test (i.e., OGTT), whereas one-step screening involves one test used for diagnosis in everyone.

† Systematic reviews, identified from a preliminary search for reviews on GDM and from searches for primary studies, will be scanned for potentially relevant studies but will not be included as the unit of analysis.

## Appendix A3 Literature Flow Diagram

Appendix A3 is a flow chart that summarizes the search and selection of articles. It begins with the total number of citations retrieved from electronic literature searches and originally included studies, and ends with the number of unique studies that satisfied the inclusion criteria of the report. Electronic searches identified 12,304 abstracts of potentially relevant articles. 11,244 studies were excluded after screening titles and abstracts, leaving 1,060 potentially relevant articles to be retrieved and evaluated for inclusion. In total 118 full-text articles were included and 896 were excluded. There were 107 unique studies and 11 associated publications for the following key questions: KQ1 (2 original studies, 2 from update), KQ2 (0 original studies, 7 from update), KQ3 (0 original trials, 7 from update), KQ4 (16 original studies, 29 from update), KQ5 (13 original studies, 18 from update), KQ6/7 (5 original trials, 8 from update). Reasons for exclusion were: wrong population-development cohort for KQ4 (30), wrong population other (100), wrong index test for KQ4 (90), wrong intervention other (40), wrong comparison for KQ2 (40), wrong comparison other (121), wrong criteria for KQ5 (48), wrong outcome (125), wrong study design (211), protocol (8), not primary research (61), wrong language (4), duplicate (14), other (4).

## Appendix A4 Included Studies

1 Agarwal MM, Dhatt GS, Punnose J. Gestational diabetes: utility of fasting plasma glucose as a screening test depends on the diagnostic criteria. Diabet Med. 2006 Dec;23(12):1319–26. doi: 10.1111/j.1464-5491.2006.01987.x. PMID: 17116182.17116182
2 Agarwal MM, Hughes PF, Punnose J, . Fasting plasma glucose as a screening test for gestational diabetes in a multi-ethnic, high-risk population. Diabet Med. 2000 Oct;17(10):720–6. doi: 10.1046/j.1464-5491.2000.00371.x. PMID: 11110505.11110505
3 Agarwal MM, Hughes PF, Punnose J, . Gestational diabetes screening of a multiethnic, high-risk population using glycated proteins. Diabetes Res Clin Pract. 2001 Jan;51(1):67–73. doi: 10.1016/s0168-8227(00)00206-0. PMID: 11137184.11137184
4 Agarwal MM, Punnose J, Sukhija K, . Gestational diabetes mellitus: using the fasting plasma glucose level to simplify the international association of diabetes and pregnancy study groups diagnostic algorithm in an adult South Asian population. Can J Diabetes. 2018 Oct;42(5):500–4. doi: 10.1016/j.jcjd.2017.12.009. PMID: 29545111.29545111
5 Arbib N, Gabbay-Benziv R, Aviram A, . Third trimester abnormal oral glucose tolerance test and adverse perinatal outcome. J Matern Fetal Neonatal Med. 2017 Apr;30(8):917–21. doi: 10.1080/14767058.2016.1190825. PMID: 27186963.27186963
6 Ayach W, Costa RA, Calderon Ide M, . Comparison between 100-g glucose tolerance test and two other screening tests for gestational diabetes: combined fasting glucose with risk factors and 50-g glucose tolerance test. Sao Paulo Med J. 2006 Jan 5;124(1):4–9. doi: 10.1590/s1516-31802006000100002. PMID: 16612455.16612455
7 Basri NI, Mahdy ZA, Ahmad S, . The World Health Organization (WHO) versus the International Association of Diabetes and Pregnancy Study Group (IADPSG) diagnostic criteria of gestational diabetes mellitus (GDM) and their associated maternal and neonatal outcomes. Horm Mol Biol Clin Investig. 2018 Feb 17;34(1). doi: 10.1515/hmbci-2017-0077. PMID: 620980761.
8 Benaiges D, Flores-Le Roux JA, Marcelo I, . Is first-trimester HbA1c useful in the diagnosis of gestational diabetes? Diabetes Res Clin Pract. 2017 Nov;133:85–91. doi: 10.1016/j.diabres.2017.08.019. PMID: 28918341.28918341
9 Benhalima K, Hanssens M, Devlieger R, . Analysis of pregnancy outcomes using the new IADPSG recommendation compared with the carpenter and coustan criteria in an area with a low prevalence of gestational diabetes. Int J Endocrinol. 2013;2013:248121. doi: 10.1155/2013/248121. PMID: 23365571.23365571
10 Benhalima K, Van Crombrugge P, Moyson C, . A modified two-step screening strategy for gestational diabetes mellitus based on the 2013 WHO criteria by combining the glucose challenge test and clinical risk factors. J Clin Med. 2018 Oct;7(10):13. doi: 10.3390/jcm7100351. PMID: 30322138.30322138
11 Berkus MD, Langer O, Piper JM, . Efficiency of lower threshold criteria for the diagnosis of gestational diabetes. Obstet Gynecol. 1995 Dec;86(6):892–6. doi: 10.1016/0029-7844(95)00319-m. PMID: 7501334.7501334
12 Bevier WC, Fischer R, Jovanovic L. Treatment of women with an abnormal glucose challenge test (but a normal oral glucose tolerance test) decreases the prevalence of macrosomia. Am J Perinatol. 1999;16(6):269–75. doi: 10.1055/s-2007-993871. PMID: 10586979.10586979
13 Bhavadharini B, Mahalakshmi MM, Deepa M, . Elevated glycated hemoglobin predicts macrosomia among Asian Indian pregnant women (WINGS-9). Indian J Endocrinol Metab. 2017 Jan-Feb;21(1):184–9. doi: 10.4103/2230-8210.196003. PMID: 28217520.28217520
14 Biri A, Korucuoglu U, Ozcan P, . Effect of different degrees of glucose intolerance on maternal and perinatal outcomes. J Matern Fetal Neonatal Med. 2009 Jun;22(6):473–8. doi: 10.1080/14767050802610344. PMID: 19479645.19479645
15 Bonomo M, Corica D, Mion E, . Evaluating the therapeutic approach in pregnancies complicated by borderline glucose intolerance: a randomized clinical trial. Diabet Med. 2005 Nov;22(11):1536–41. doi: 10.1111/j.1464-5491.2005.01690.x. PMID: 16241919.16241919
16 Braga FO, Negrato CA, Matta M, . Relationship between inflammatory markers, glycated hemoglobin and placental weight on fetal outcomes in women with gestational diabetes. Arch Endocrinol Metab. 2019 Feb;63(1):22–9. doi: 10.20945/2359-3997000000099. PMID: 30864628.30864628
17 Cetin M, Cetin A. Time-dependent gestational diabetes screening values. Int J Gynaecol Obstet. 1997 Mar;56(3):257–61. doi: 10.1016/s0020-7292(96)02831-7. PMID: 9127158.9127158
18 Chanprapaph P, Sutjarit C. Prevalence of gestational diabetes mellitus (GDM) in women screened by glucose challenge test (GCT) at Maharaj Nakorn Chiang Mai Hospital. J Med Assoc Thai. 2004 Oct;87(10):1141–6. PMID: 15560687.15560687
19 Chevalier N, Fenichel P, Giaume V, . Universal two-step screening strategy for gestational diabetes has weak relevance in French Mediterranean women: should we simplify the screening strategy for gestational diabetes in France? Diabetes Metab. 2011 Nov;37(5):419–25. doi: 10.1016/j.diabet.2011.01.004. PMID: 21489844.21489844
20 Chico A, Lopez-Rodo V, Rodriguez-Vaca D, . Features and outcome of pregnancies complicated by impaired glucose tolerance and gestational diabetes diagnosed using different criteria in a Spanish population. Diabetes Res Clin Pract. 2005 May;68(2):141–6. doi: 10.1016/j.diabres.2004.09.009. PMID: 15860242.15860242
21 Corrado F, Benedetto AD, Cannata ML, . A single abnormal value of the glucose tolerance test is related to increased adverse perinatal outcome. J Matern Fetal Neonatal Med. 2009 Jul;22(7):597–601. doi: 10.1080/14767050902801801. PMID: 19488948.19488948
22 Crowther CA, Hiller JE, Moss JR, . Effect of treatment of gestational diabetes mellitus on pregnancy outcomes. N Engl J Med. 2005 Jun 16;352(24):2477–86. doi: 10.1056/NEJMoa042973. PMID: 15951574.15951574
23 Daniells S, Grenyer BF, Davis WS, . Gestational diabetes mellitus: is a diagnosis associated with an increase in maternal anxiety and stress in the short and intermediate term? Diabetes Care. 2003 Feb;26(2):385–9. doi: 10.2337/diacare.26.2.385. PMID: 12547867.12547867
24 Davis EM, Scifres CM, Abebe K, . Comparison of birth outcomes by gestational diabetes screening criteria. AJP Rep. 2018;8(4):e280–e8. PMID: 30450267.30450267
25 Davis EM, Abebe KZ, Simhan HN, . Perinatal outcomes of two screening strategies for gestational diabetes mellitus: a randomized controlled trial. 2021;138(online ahead of print). doi: 10.1097/AOG.0000000000004431
26 De los Monteros AE, Parra A, Hidalgo R, . The after breakfast 50-g, 1-hour glucose challenge test in urban Mexican pregnant women: its sensitivity and specificity evaluated by three diagnostic criteria for gestational diabetes mellitus. Acta Obstet Gynecol Scand. 1999 Apr;78(4):294–8. PMID: 10203295.10203295
27 Derks IPM, Hivert MF, Rifas-Shiman SL, . Associations of prenatal exposure to impaired glucose tolerance with eating in the absence of hunger in early adolescence. International Journal of Obesity. 2019;43(10):1903–13. PMID: 30622313.30622313
28 Deveer R, Deveer M, Akbaba E, . The effect of diet on pregnancy outcomes among pregnant with abnormal glucose challenge test. Eur Rev Med Pharmacol Sci. 2013 May;17(9):1258–61. PMID: 23690197.23690197
29 Dickson LM, Buchmann EJ, Janse van Rensburg C, . Fasting plasma glucose and risk factor assessment: comparing sensitivity and specificity in identifying gestational diabetes in urban black African women. South African Medical Journal. 2019;110(1):21–6. PMID: 31865938.31865938
30 Doughty KN, Ronnenberg AG, Reeves KW, . Barriers to exclusive breastfeeding among women with gestational diabetes mellitus in the United States. J Obstet Gynecol Neonatal Nurs. 2018 May;47(3):301–15. doi: doi: 10.1016/j.jogn.2018.02.005. PMID: 29510090.29510090
31 Ethridge JK, Jr., Catalano PM, Waters TP. Perinatal outcomes associated with the diagnosis of gestational diabetes made by the international association of the diabetes and pregnancy study groups criteria. Obstet Gynecol. 2014 Sep;124(3):571–8. doi: 10.1097/AOG.0000000000000412. PMID: 25162258.25162258
32 Fadl HE, Gardefors S, Hjertberg R, . Randomized controlled study in pregnancy on treatment of marked hyperglycemia that is short of overt diabetes. Acta Obstet Gynecol Scand. 2015 Nov;94(11):1181–7. doi: 10.1111/aogs.12717. PMID: 26222270.26222270
33 Garner P, Okun N, Keely E, . A randomized controlled trial of strict glycemic control and tertiary level obstetric care versus routine obstetric care in the management of gestational diabetes: a pilot study. Am J Obstet Gynecol. 1997 Jul;177(1):190–5. doi: 10.1016/s0002-9378(97)70461-7. PMID: 9240606.9240606
34 Gobl CS, Bozkurt L, Rivic P, . A two-step screening algorithm including fasting plasma glucose measurement and a risk estimation model is an accurate strategy for detecting gestational diabetes mellitus. Diabetologia. 2012 Dec;55(12):3173–81. doi: 10.1007/s00125-012-2726-7. PMID: 23001377.23001377
35 Harper LM, Jauk V, Longo S, . Early gestational diabetes screening in obese women: a randomized controlled trial. Am J Obstet Gynecol. 2020 May;222(5):495.e1–495.e8. doi: 10.1016/j.ajog.2019.12.021. PMID: 31926951.31926951
36 Heetchuay T, Punpuckdeekoon P. Adverse outcomes of pregnancy with single abnormal value of 100-gram oral glucose tolerance test in phramongkutklao hospital. Journal of the Medical Association of Thailand. 2017 May;100(5):479–87. PMID: 616837307.
37 Hillier TA, Pedula KL, Schmidt MM, . Childhood obesity and metabolic imprinting: the ongoing effects of maternal hyperglycemia. Diabetes Care. 2007 Sep;30(9):2287–92. doi: 10.2337/dc06-2361. PMID: 17519427.17519427
38 Hillier T, Pedula K, Ogasawara K, . A pragmatic, randomized clinical trial of gestational diabetes screening. NEJM. 2021;384(10):395–904.
39 Hirst JE, Tran TS, Do MA, . Consequences of gestational diabetes in an urban hospital in Viet Nam: a prospective cohort study. PLoS Med. 2012 Jul;9(7):e1001272. doi: 10.1371/journal.pmed.1001272. PMID: 22911157.22911157
40 Hivert MF, Allard C, Menard J, . Impact of the creation of a specialized clinic for prenatal blood sampling and follow-up care in pregnant women. J Obstet Gynaecol Can. 2012 Mar;34(3):311–242. doi: 10.1016/S1701-2163(16)35194-5. PMID: 610739173.22472326
41 Ho YR, Wang P, Lu MC, . Associations of mid-pregnancy HbA1c with gestational diabetes and risk of adverse pregnancy outcomes in high-risk Taiwanese women. PLoS ONE. 2017 May;12(5):e0177563. doi: 10.1371/journal.pone.0177563. PMID: 28505205.28505205
42 Hughes RC, Moore MP, Gullam JE, . An early pregnancy HbA1c >=5.9% (41 mmol/mol) is optimal for detecting diabetes and identifies women at increased risk of adverse pregnancy outcomes. Diabetes Care. 2014 Nov;37(11):2953–9. doi: 10.2337/dc14-1312. PMID: 25190675.25190675
43 Hughes RCE, Rowan J, Williman J. Prediabetes in pregnancy, can early intervention improve outcomes? A feasibility study for a parallel randomised clinical trial. BMJ Open. 2018 Mar;8(3):e018493. doi: 10.1136/bmjopen-2017-018493. PMID: 29502087.29502087
44 Kauffman RP, Castracane VD, Peghee D, . Detection of gestational diabetes mellitus by homeostatic indices of insulin sensitivity: a preliminary study. Am J Obstet Gynecol. 2006 Jun;194(6):1576–84. doi: 10.1016/j.ajog.2006.01.010. PMID: 16638603.16638603
45 Kaymak O, Iskender CT, Ustunyurt E, . Retrospective evaluation of perinatal outcome in women with mild gestational hyperglycemia. J Obstet Gynaecol Res. 2011 Aug;37(8):986–91. doi: 10.1111/j.1447-0756.2010.01469.x. PMID: 21463427.21463427
46 Kerbel D, Glazier R, Holzapfel S, . Adverse effects of screening for gestational diabetes: a prospective cohort study in Toronto, Canada. J Med Screen. 1997;4(3):128–32. doi: 10.1177/096914139700400303. PMID: 9368868.9368868
47 Khalafallah A, Phuah E, Al-Barazan AM, . Glycosylated haemoglobin for screening and diagnosis of gestational diabetes mellitus. BMJ Open. 2016 Apr;6(4):e011059. doi: 10.1136/bmjopen-2016-011059. PMID: 27044587.27044587
48 Khalifeh A, Eckler R, Felder L, . One-step versus two-step diagnostic testing for gestational diabetes: a randomized controlled trial. J Matern Fetal Neonatal Med. 2020 Feb: 33(4):612–617. doi: 10.1080/14767058.2018.1498480. PMID: 29985079.29985079
49 Kim HS, Chang KH, Yang JI, . Clinical outcomes of pregnancy with one elevated glucose tolerance test value. Int J Gynaecol Obstet. 2002 Aug;78(2):131–8. doi: 10.1016/s0020-7292(02)00129-7. PMID: 12175714.12175714
50 Kim MH, Kwak SH, Kim SH, . Pregnancy outcomes of women additionally diagnosed as gestational diabetes by the international association of the diabetes and pregnancy study groups criteria. Diabetes Metab J. 2019 Dec;43(6):766–75. doi: 10.4093/dmj.2018.0192 PMID: 30877713.30877713
51 Koivunen S, Viljakainen M, Mannisto T, . Pregnancy outcomes according to the definition of gestational diabetes. PLoS ONE. 2020;15(3):e0229496. PMID: 32134959.32134959
52 Kokanali MK, Tokmak A, Kaymak O, . The effect of treatment on pregnancy outcomes in women with one elevated oral glucose tolerance test value. Ginekol Pol. 2014 Oct;85(10):748–53. PMID: 25546925.25546925
53 Lamar ME, Kuehl TJ, Cooney AT, . Jelly beans as an alternative to a fifty-gram glucose beverage for gestational diabetes screening. Am J Obstet Gynecol. 1999 Nov;181(5 Pt 1):1154–7. doi: 10.1016/s0002-9378(99)70099-2. PMID: 10561636.10561636
54 Landon MB, Mele L, Spong CY, . The relationship between maternal glycemia and perinatal outcome. Obstet Gynecol. 2011 Feb;117(2 Pt 1):218–24. doi: 10.1097/aog.0b013e318203ebe0. PMID: 21309194.21309194
55 Landon MB, Spong CY, Thom E, . A multicenter, randomized trial of treatment for mild gestational diabetes. N Engl J Med. 2009 Oct 1;361(14):1339–48. doi: 10.1056/NEJMoa0902430. PMID: 19797280.19797280
56 Lapolla A, Dalfra MG, Bonomo M, . Can plasma glucose and HbA1c predict fetal growth in mothers with different glucose tolerance levels? Diabetes Res Clin Pract. 2007 Sep;77(3):465–70. doi: 10.1016/j.diabres.2007.01.022. PMID: 17350135.17350135
57 Lapolla A, Dalfra MG, Ragazzi E, . New International Association of the Diabetes and Pregnancy Study Groups (IADPSG) recommendations for diagnosing gestational diabetes compared with former criteria: a retrospective study on pregnancy outcome. Diabet Med. 2011 Sep;28(9):1074–7. doi: 10.1111/j.1464-5491.2011.03351.x. PMID: 21658125.21658125
58 Lee KH, Han YJ, Chung JH, . Treatment of gestational diabetes diagnosed by the IADPSG criteria decreases excessive fetal growth. Obstet Gynec Sci. 2020;63(1):19–26. PMID: 31970124.31970124
59 Lekva T, Godang K, Michelsen AE, . Prediction of gestational diabetes mellitus and pre-diabetes 5 years postpartum using 75 g oral glucose tolerance test at 14-16 weeks’ gestation. Sci Rep. 2018 Sep;8(1):13392. doi: 10.1038/s41598-018-31614-z. PMID: 30190548.30190548
60 Loewenberg WY, Rausch J, Kachoria R, . Hospital supplementation differentially impacts the association between breastfeeding intention and duration among women with and without gestational diabetes mellitus history. Breastfeed Med. 2017 Jul/Aug;12(6):338–44. doi: 10.1089/bfm.2017.0019. PMID: 28631935.28631935
61 Martinez-Cruz N, Rapisarda AMC, Soriano-Ortega KP, . Perinatal outcomes in Mexican women with untreated mild gestational diabetes mellitus diagnosed by the International Association of Diabetes and Pregnancy Study Groups Criteria. Diabetes Metab Syndr Obes. 2019;12:2667–74. PMID: 31908507.31908507
62 Murat SM, Cavkaytar S, Atak Z, . Should we interpret the results of ‘two-step’ glucose screening again according to the obstetric outcomes? J Obstet Gynaecol. 2016 Aug;36(6):705–9. doi: 10.3109/01443615.2015.1134459. PMID: 27012881.27012881
63 Navid S, Alam K, Tasneem S. Glucose challenge test- Is it an effective screening tool for gestational diabetes mellitus in low risk population? Rawal Medical Journal. 2014;39(4):428–31. PMID: 600582251.
64 Naylor CD, Sermer M, Chen E, . Cesarean delivery in relation to birth weight and gestational glucose tolerance: pathophysiology or practice style? Toronto Trihospital Gestational Diabetes Investigators. JAMA. 1996 Apr 17;275(15):1165–70. PMID: 8609683.8609683
65 Odsaeter IH, Asberg A, Vanky E, . Hemoglobin A1c as screening for gestational diabetes mellitus in Nordic Caucasian women. Diabetol Metab Syndr. 2016 Jul 22;8:43. doi: 10.1186/s13098-016-0168-y. PMID: 27453735.27453735
66 Olagbuji BN, Aderoba AK, Kayode OO, . Accuracy of 50-g glucose challenge test to detect International Association of Diabetes and Pregnancy Study Groups criteria-defined hyperglycemia. Int J Gynaecol Obstet. 2017 Dec;139(3):312–7. doi: 10.1002/ijgo.12304. PMID: 28833075.28833075
67 Osmundson SS, Norton ME, El-Sayed YY, . Early screening and treatment of women with prediabetes: a randomized controlled trial. Am J Perinatol. 2016 Jan;33(2):172–9. doi: 10.1055/s-0035-1563715. PMID: 26344009.26344009
68 Oza-Frank R, Gunderson EP. In-hospital breastfeeding experiences among women with gestational diabetes. Breastfeed Med. 2017 Jun;12:261–8. doi: 10.1089/bfm.2016.0197. PMID: 28632447.28632447
69 Park TC, Lee BH, Norwitz ER, . Maternal hyperglycemia and the 100-g oral glucose tolerance test. Taiwan J Obstet Gynecol. 2015 Apr;54(2):137–42. doi: 10.1016/j.tjog.2014.04.026. PMID: 25951717.25951717
70 Perea-Carrasco R, Perez-Coronel R, Albusac-Aguilar R, . A simple index for detection of gestational diabetes mellitus. J R Soc Med. 2002 Sep;95(9):435–9. doi: 10.1258/jrsm.95.9.435. PMID: 12205206.12205206
71 Perucchini D, Fischer U, Spinas GA, . Using fasting plasma glucose concentrations to screen for gestational diabetes mellitus: prospective population based study. BMJ. 1999 Sep 25;319(7213):812–5. doi: 10.1136/bmj.319.7213.812. PMID: 10496823.10496823
72 Pezeshki B, Chiti H, Arasteh P, . Early screening of gestational diabetes mellitus using hemoglobin A1C: Revising current screening guidelines. Caspian J Intern Med. 2019;10(1):16–24. doi: 10.22088/cjim.10.1.16. PMID: 30858937.30858937
73 Poo ZX, Wright A, Ruochen D, . Optimal first trimester HbA1c threshold to identify Singaporean women at risk of gestational diabetes mellitus and adverse pregnancy outcomes: A pilot study. Obstetric Medicine. 2018;12(2:79–84. doi: 10.1177/1753495X18795984. PMID: 625513130.31217812
74 Poomalar GK, Rangaswamy V. A comparison of fasting plasma glucose and glucose challenge test for screening of gestational diabetes mellitus. J Obstet Gynaecol. 2013 July;33(5):447–50. doi: 10.3109/01443615.2013.771156. PMID: 23815193.23815193
75 Rajput R, Yogesh Y, Rajput M, . Utility of HbA1c for diagnosis of gestational diabetes mellitus. Diabetes Res Clin Pract. 2012 Oct;98(1):104–7. doi: 10.1016/j.diabres.2012.02.018. PMID: 22456454.22456454
76 Retnakaran R, Qi Y, Sermer M, . Glucose intolerance in pregnancy and future risk of pre-diabetes or diabetes. Diabetes Care. 2008 Oct;31(10):2026–31. doi: 10.2337/dc08-0972. PMID: 18628572.18628572
77 Rumbold AR, Crowther CA. Women’s experiences of being screened for gestational diabetes mellitus. Aust N Z J Obstet Gynaecol. 2002 May;42(2):131–7. doi: 10.1111/j.0004-8666.2002.00131.x. PMID: 12069138.12069138
78 Rust OA, Bofill JA, Andrew ME, . Lowering the threshold for the diagnosis of gestational diabetes. Am J Obstet Gynecol. 1996 Oct;175(4 Pt 1):961–5. doi: 10.1016/s0002-9378(96)80032-9. PMID: 8885755.8885755
79 Saadati N, Majlesi M, Barati M, . Determination of relationship between Hba1c levels and early diagnosis of gestational diabetes. Int J Pharm. 2016;5(3):252–7. PMID: 610539753.
80 Sacks DA, Chen W, Wolde-Tsadik G, . Fasting plasma glucose test at the first prenatal visit as a screen for gestational diabetes. Obstet Gynecol. 2003 Jun;101(6):1197–203. doi: 10.1016/s0029-7844(03)00049-8. PMID: 12798525.12798525
81 Saeedi M, Hanson U, Simmons D, . Characteristics of different risk factors and fasting plasma glucose for identifying GDM when using IADPSG criteria: a cross-sectional study. BMC Pregnancy Childbirth. 2018 Jun;18(1):225. doi: 10.1186/s12884-018-1875-1. PMID: 29898685.29898685
82 Scifres CM, Abebe KZ, Jones KA, . Gestational diabetes diagnostic methods (GD2M) pilot randomized trial. Matern Child Health J. 2015 Jul;19(7):1472–80. doi: 10.1007/s10995-014-1651-4. PMID: 25424454.25424454
83 Sermer M, Naylor CD, Farine D, . The Toronto Tri-Hospital Gestational Diabetes Project. A preliminary review. Diabetes Care. 1998 Aug;21 Suppl 2:B33–42. PMID: 9704225.9704225
84 Sermer M, Naylor CD, Gare DJ, . Impact of increasing carbohydrate intolerance on maternal-fetal outcomes in 3637 women without gestational diabetes. The Toronto Tri-Hospital Gestational Diabetes Project. Am J Obstet Gynecol. 1995 Jul;173(1):146–56. doi: 10.1016/0002-9378(95)90183-3. PMID: 7631672.7631672
85 Sevket O, Ates S, Uysal O, . To evaluate the prevalence and clinical outcomes using a one-step method versus a two-step method to screen gestational diabetes mellitus. J Matern Fetal Neonatal Med. 2014 Jan;27(1):36–41. doi: 10.3109/14767058.2013.799656. PMID: 23617557.23617557
86 Sevket O, Sevket A, Ozel A, . The use of HbA1c as an aid in the diagnosis of gestational diabetes mellitus. J Obstet Gynaecol. 2014 Nov;34(8):690–2. doi: 10.3109/01443615.2014.925855. PMID: 25340849.25340849
87 Sham S, Bhat BPR, Kamath A. Comparative study of fasting plasma glucose concentration and glucose challenge test for screening gestational diabetes mellitus. Journal of SAFOG. 2014 Aug;6(2):75–8. doi: 10.5005/jp-journals-10006-1275. PMID: 611871078.
88 Shang M, Lin L, Ma L, . Investigation on the suitability of the International Association of Diabetes and Pregnancy Study Group diagnostic criteria for gestational diabetes mellitus in China. J Obstet Gynaecol. 2014 Feb;34(2):141–5. doi: 10.3109/01443615.2013.832177. PMID: 24456434.24456434
89 Sharma M, Nayanisri K, Jain R, . Predictive value of fasting plasma glucose on first antenatal visit before 20 weeks of gestation to diagnose gestational diabetes mellitus. J Clin Diagn. 2018 Feb;12(2):QC01–QC4. doi: 10.7860/JCDR/2018/31741.11177. PMID: 620884219.
90 Simmons D, Nema J, Parton C, . The treatment of booking gestational diabetes mellitus (TOBOGM) pilot randomised controlled trial. BMC Pregnancy Childbirth. 2018 May;18(1):151. doi: 10.1186/s12884-018-1809-y. PMID: 29747594.29747594
91 Siricharoenthai P, Phupong V. Diagnostic accuracy of HbA1c in detecting gestational diabetes mellitus. J Matern Fetal Neonatal Med. 2019 Feb:1–4. doi: 10.1080/14767058.2019.1576169. PMID: 30691324.30691324
92 Solomon CG, Willett WC, Rich-Edwards J, . Variability in diagnostic evaluation and criteria for gestational diabetes. Diabetes Care. 1996 Jan;19(1):12–6. doi: 10.2337/diacare.19.1.12. PMID: 8720526.8720526
93 Soumya S, Rohilla M, Chopra S, . HbA1c: A useful screening test for gestational diabetes mellitus. Diabetes Technol Ther. 2015 Dec;17(12):899–904. doi: 10.1089/dia.2015.0041. PMID: 26496534.26496534
94 Stacey T, Tennant P, McCowan L, . Gestational diabetes and the risk of late stillbirth: a case-control study from England, UK. BJOG. 2019 Jul;126(8):973–82. doi: 10.1111/1471-0528.15659. PMID: 30891907.30891907
95 Trujillo J, Vigo A, Reichelt A, . Fasting plasma glucose to avoid a full OGTT in the diagnosis of gestational diabetes. Diabetes Res Clin Pract. 2014 Sep;105(3):322–6. doi: 10.1016/j.diabres.2014.06.00. PMID: 25037441.25037441
96 Uncu G, Ozan H, Cengiz C. The comparison of 50 grams glucose challenge test, HbA1c and fructosamine levels in diagnosis of gestational diabetes mellitus. Clin Exp Obstet Gynecol. 1995;22(3):230–4. PMID: 7554262.7554262
97 Vambergue A, Nuttens MC, Verier-Mine O, . Is mild gestational hyperglycaemia associated with maternal and neonatal complications? The Diagest Study. Diabet Med. 2000 Mar;17(3):203–8. doi: 10.1046/j.1464-5491.2000.00237.x. PMID: 10784224.10784224
98 Veres M, Creiut DI, Trutz J, . The utility of glycated hemoglobin, determined in the second trimester of pregnancy, in diagnosing gestational diabetes. Rom J Diabetes Nutr Metab Dis. 2015 Sep;22(3):233–40. doi: 10.1515/rjdnmd-2015-0029. PMID: 608162856.
99 Vinter CA, Tanvig MH, Christensen MH, . Lifestyle intervention in Danish obese pregnant women with early gestational diabetes mellitus according to WHO 2013 criteria does not change pregnancy outcomes: results from the LiP (Lifestyle in Pregnancy) Study. Diabetes Care. 2018 Oct;41(10):2079–85. doi: 10.2337/dc18-0808. PMID: 30061318.30061318
100 Wang P, Lu MC, Yan YH. Abnormal glucose tolerance is associated with preterm labor and increased neonatal complications in Taiwanese women. Taiwan J Obstet Gynecol. 2013 Dec;52(4):479–84. doi: 10.1016/j.tjog.2013.10.005. PMID: 24411030.24411030
101 Waters TP, Dyer AR, Scholtens DM, . Maternal and neonatal morbidity for women who would be added to the diagnosis of gdm using IADPSG criteria: a secondary analysis of the hyperglycemia and adverse pregnancy outcome study. Diabetes Care. 2016 Dec;39(12):2204–10. doi: 10.2337/dc16-1194. PMID: 27634392.27634392
102 Weerakiet S, Lertnarkorn K, Panburana P, . Can adiponectin predict gestational diabetes? Gynecol Endocrinol. 2006 Jul;22(7):362–8. doi: 10.1080/09513590600818919. PMID: 16864145.16864145
103 Wei Y, Yang H, Zhu W, . International Association of Diabetes and Pregnancy Study Group criteria is suitable for gestational diabetes mellitus diagnosis: further evidence from China. Chin Med J (Engl). 2014;127(20):3553–6. PMID: 25316228.25316228
104 Wu K, Cheng Y, Li T, . The utility of HbA1c combined with haematocrit for early screening of gestational diabetes mellitus. Diabetol Metab Syndr. 2018 Mar;10:14. PMID: 29541163.29541163
105 Yang X, Tian H, Zhang F, . A randomised translational trial of lifestyle intervention using a 3-tier shared care approach on pregnancy outcomes in Chinese women with gestational diabetes mellitus but without diabetes. Journal of Translational Medicine. 2014;12:290. doi: 10.1186/s13098-018-0314-9. PMID: 25349017.25349017
106 Zhu WW, Fan L, Yang HX, . Fasting plasma glucose at 24-28 weeks to screen for gestational diabetes mellitus: new evidence from China. Diabetes Care. 2013 Jul;36(7):2038–40. doi: 10.2337/dc12-2465. PMID: 23536582.23536582
107 Zhu WW, Yang HX, Wei YM, . Evaluation of the value of fasting plasma glucose in the first prenatal visit to diagnose gestational diabetes mellitus in China. Diabetes Care. 2013 Mar;36(3):586–90. doi: 10.2337/dc12-1157. PMID: 368426090.23193214

## Appendix A5 Excluded Studies With Reasons for Exclusions

1 Abbas A, Nasir H, Zehra A, . Assessment of depression as comorbidity in diabetes mellitus patients using Beck Depression Inventory II (BDI II) scale. J Young Pharm. 2015 Jul 01;7(3):206–16. PMID: 606004028. Wrong population.
2 Abbas AJ, Ali HA, M.M AL-R, . Association of serum preptin levels with insulin resistance in Iraqi women with gestational diabetes mellitus. Int Res J Pharm. 2019 Jan 01;10(1):49–55. PMID: 626383891. Wrong study design.
3 Abdollahi F, Zarghami M, Azhar MZ, . Predictors and incidence of post-partum depression: a longitudinal cohort study. J Obstet Gynaecol Re. 2014;40(12):2191–200. PMID: 25132641. Wrong study design.25132641
4 Abdollahi F, Zarghami M, Azhar MZ, . Predictors and incidence of post-partum depression: a longitudinal cohort study. J Obstet Gynaecol Re. 2014;40(12):2191–200. PMID: 25132641. Wrong comparison KQ225132641
5 Abebe KZ, Scifres C, Simhan HN, . Comparison of two screening strategies for gestational diabetes (GDM2) trial: design and rationale. Contemp. Clin. Trials Commun. 2017;62:43–9. PMID: 28823926. Protocol.28823926
6 Abell SK, Boyle JA, Earnest A, . Impact of different glycaemic treatment targets on pregnancy outcomes in gestational diabetes. Diabet Med. 2019;36(2):177–83. PMID: 30102812. Wrong comparison.30102812
7 Abell SK, Shorakae S, Boyle JA, . Role of serum biomarkers to optimise a validated clinical risk prediction tool for gestational diabetes. Aust NZ J Obstet Gyn. 2019;59(2):251–7. PMID: 29900538. Wrong index test KQ4.29900538
8 Abell SK, Shorakae S, Boyle JA, . Role of serum biomarkers to optimise a validated clinical risk prediction tool for gestational diabetes. Aust NZ J Obstet Gyn. 2019;59(2):251–7. PMID: 29900538. Wrong population (KQ4 development cohort).29900538
9 Abell SK, Teede HJ. The IADPSG diagnostic criteria identify women with increased risk of adverse pregnancy outcomes in Victoria. Aust NZ J Obstet Gyn. 2017;57(5):564–8. PMID: 28741654. Wrong criteria KQ5.28741654
10 Aberg A, Rydhstroem H, Frid A. Impaired glucose tolerance associated with adverse pregnancy outcome: a population-based study in southern Sweden. Am J Obstet Gynecol. 2001 Jan;184(2):77–83. doi: 10.1067/mob.2001.108085. PMID: 11174484. Wrong population.11174484
11 Abirami P, Judie A. Integrated approach of yoga therapy on maternal and fetal outcome in gestational diabetes mellitus. Int J Pharm Clin Res. 2015 Nov;7(6):377–82. PMID: 608056128. Wrong comparison.
12 Abu-Heija A, Al-Bash M, Ishrat N, . 50 grams oral glucose challenge test: is it an effective screening test for gestational diabetes mellitus? J Obstet Gynaecol India. 2016;66(Suppl 1):7–11. PMID: 27651570. Wrong outcome.27651570
13 Adam S, Rheeder P. Evaluating the utility of a point-of-care glucometer for the diagnosis of gestational diabetes. Int J Gynae Obstet. 2018;141(1):91–6. PMID: 29164614. Wrong index test KQ4.29164614
14 Adam S, Rheeder P. Screening for gestational diabetes mellitus in a South African population: prevalence, comparison of diagnostic criteria and the role of risk factors. SAMJ S Afr Med J. Suid-Afrikaanse Tydskrif Vir Geneeskunde. 2017;107(6):523–7. PMID: 28604326. Wrong population (KQ4 development cohort).28604326
15 Adam S, Rheeder P. Selective screening strategies for gestational diabetes: a prospective cohort observational study. J Diabetes Res. 2017;2017:2849346. PMID: 29201921. Wrong outcome.29201921
16 Adams KM, Li H, Nelson RL, . Sequelae of unrecognized gestational diabetes. Am J Obstet Gynecol. 1998 Jun;178(6):1321–32. doi: 10.1016/s0002-9378(98)70339-4. PMID: 9662318. Wrong study design.9662318
17 Afandi B, Hassanein M, Roubi S, . The value of continuous glucose monitoring and self-monitoring of blood glucose in patients with gestational diabetes mellitus during Ramadan fasting. Diabetes Res Clin. 2019;26:26. PMID: 30822494. Wrong population.30822494
18 Afandi BO, Hassanein MM, Majd LM, . Impact of Ramadan fasting on glucose levels in women with gestational diabetes mellitus treated with diet alone or diet plus metformin: a continuous glucose monitoring study. BMJ Open Diabetes Res Care. 2017;5(1):e000470. PMID: 29299329. Wrong comparison.29299329
19 Agarwal MM, Dhatt GS, Othman Y, . Gestational diabetes: an evaluation of serum fructosamine as a screening test in a high-risk population. Gynecol Obstet Inves. 2011;71(3):207–12. PMID: 21160150. Wrong outcome.21160150
20 Agarwal MM, Dhatt GS, Othman Y. Gestational diabetes in a tertiary care hospital: implications of applying the IADPSG criteria. Arch Gynecol Obstet. 2012;286(2):373–8. PMID: 22484479. Wrong outcome.22484479
21 Agarwal MM, Dhatt GS, Othman Y. Gestational diabetes: differences between the current international diagnostic criteria and implications of switching to IADPSG. J Diabetes Complicat. 2015;29(4):544–9. PMID: 25837380. Wrong study design.25837380
22 Agarwal MM, Dhatt GS, Punnose J, . Gestational diabetes in a high-risk population: using the fasting plasma glucose to simplify the diagnostic algorithm. Eur J Obstet Gynecol Reprod Biol. 2005 May 01;120(1):39–44. doi: 10.1016/j.ejogrb.2004.07.034. PMID: 15866084. Wrong outcome.15866084
23 Agarwal MM, Dhatt GS, Punnose J, . Gestational diabetes: a reappraisal of HBA1c as a screening test. Acta Obstet Gynecol Scand. 2005 Dec;84(12):1159–63. doi: 10.1111/j.0001-6349.2005.00650.x. PMID: 16305701. Wrong outcome.16305701
24 Agarwal MM, Dhatt GS, Safraou MF. Gestational diabetes: using a portable glucometer to simplify the approach to screening. Gynecol Obstet Invest. 2008;66(3):178–83. doi: 10.1159/000140602. PMID: 18562798. Wrong index test KQ4.18562798
25 Agarwal MM, Dhatt GS. Fasting plasma glucose at 24-28 weeks to screen for gestational diabetes mellitus: new evidence from China. Diabetes Care. 2013;36:2038–2040. PMID: 372220368. Not primary research.23536582
26 Agarwal MM, Weigl B, Hod M. Gestational diabetes screening: the low-cost algorithm. Int J Gynecol Obstet. 2011;115 Suppl 1:S30–3. PMID: 22099438. Not primary research.22099438
27 Agbozo F, Abubakari A, Narh C, . Accuracy of glycosuria, random blood glucose and risk factors as selective screening tools for gestational diabetes mellitus in comparison with universal diagnosing. BMJ Open Diabetes Res Care. 2018;6(1):e000493. PMID: 29942522. Wrong comparison.29942522
28 Ahern. Screening for gestational diabetes: a randomised clinical trial of two universal methods. http://www.who.int/trialsearch/Trial2.aspx?TrialID=ISRCTN15700608. 2019 PMID: CN-02070089. Protocol.
29 Ajala O, Chik C. Ethnic differences in antepartum glucose values that predict postpartum dysglycemia and neonatal macrosomia. Diabetes Res Clin. 2018;140:81–7. PMID: 29608977. Wrong population.29608977
30 Aksoy H, Aksoy U, Acmaz G, . The effect of impaired 50-gram oral glucose challenge test on fetal abdominal wall thickness. Diabetes Metab Res. 2014;30(7):570–4. PMID: 24353250. Wrong criteria KQ5.24353250
31 Aktun HL, Uyan D, Yorgunlar B, . Gestational diabetes mellitus screening and outcomes. J Turk Ger Gynecol Assoc. 2015;16(1):25–9. PMID: 25788845. Wrong population.25788845
32 Aktun LH, Yorgunlar B, Karaca N, . Predictive risk factors in the treatment of gestational diabetes mellitus. Clin Med Insights Womens Health. 2015;8:25–8. PMID: 26508897. Wrong comparison.26508897
33 Al-Ajlan A, Al-Musharaf S, Fouda MA, . Lower vitamin D levels in Saudi pregnant women are associated with higher risk of developing GDM. BMC Pregnancy Childb. 2018;18(1):86. PMID: 29631547. Wrong index test KQ4.29631547
34 Alanbay I, Coksuer H, Ercan M, . Can serum gamma-glutamyltransferase levels be useful at diagnosing gestational diabetes mellitus? Gynecol Endocrinol. 2012;28(3):208–11. PMID: 22320195. Wrong index test KQ4.22320195
35 Al-Daghri NM, Al-Hazmi HA, Al-Ajlan A, . Associations of Spexin and cardiometabolic parameters among women with and without gestational diabetes mellitus. Saudi J Biol Sci. 2018;25(4):710–4. PMID: 29740234. Wrong study design.29740234
36 Alfadhli E. Gestational diabetes in Saudi women identified by the International Association of Diabetes and Pregnancy Study Group versus the former American Diabetes Association criteria: a prospective cohort study. Ann Saudi Med. 2015;35(6):428–34. PMID: 26657225. Wrong population.26657225
37 Alfadhli EM, Osman EN, Basri TH, . Gestational diabetes among Saudi women: prevalence, risk factors and pregnancy outcomes. Ann Saudi Med. 2015;35(3):222–30. PMID: 26409797. Wrong comparison.26409797
38 Al-Ghazali MJ, Ali HA, Al-Rufaie MM, . The correlation of irisin levels and some trace element as a potential mark for diagnosis of gestational diabetes mellitus. Pharmacologyonline. 2018 Dec 30;3:235–46. PMID: 625753935. Wrong study design.
39 Al-Ghazali MJ, Ali HA, Al-Rufaie MM, . The correlation of irisin levels and some trace element as a potential mark diagnosis of gestational diabetes mellitus. Acta Med Iran. 2019 Jan 18;57(1):42–50. PMID: 2001743893. Wrong study design.
40 Al-Hakmani FM, Al-Fadhil FA, Al-Balushi LH, . The effect of obesity on pregnancy and its outcome in the population of Oman, Seeb province. Oman Med J. 2016;31(1):12–7. PMID: 26816564. Wrong outcome.26816564
41 Ali HA, Al-Rufaie MM, Al-Ghazali MJ, . The correlation of irisin levels and some trace element as a potential mark for diagnosis of gestational diabetes mellitous. Pharmacologyonline. 2018 Dec 30;3:124–35. PMID: 625753842. Wrong index test KQ4.
42 Alizzi FJ, Showman HAK. Serum irisin, level and validity in gestational diabetes mellitus in Iraqi women: a pilot study. Res J Obstet Gynecol. 2018;11(1):36–40. PMID: 2001528818. Wrong index test KQ4.
43 Allard C, Sahyouni E, Menard J, . Gestational diabetes mellitus identification based on self-monitoring of blood glucose. Can J Diabetes. 2015;39(2):162–8. PMID: 25492558. Wrong outcome.25492558
44 Al-Ofi EA, Mosli HH, Ghamri KA, . Management of postprandial hyperglycaemia and weight gain in women with gestational diabetes mellitus using a novel telemonitoring system. J Int Med Res. 2019;47(2):754–64. PMID: 30442052. Wrong comparison.30442052
45 Alptekin H, Cizmecioglu A, Isik H, . Predicting gestational diabetes mellitus during the first trimester using anthropometric measurements and HOMA-IR. J Endocrinol Invest. 2016;39(5):577–83. PMID: 26754418. Wrong population (KQ4 development cohort).26754418
46 Al-Rubeaan K, Al-Manaa HA, Khoja TA, . A community-based survey for different abnormal glucose metabolism among pregnant women in a random household study (SAUDI-DM). BMJ Open. 2014;4(8):e005906. PMID: 25138813. Wrong index test KQ4.25138813
47 Alunni ML, Roeder HA, Moore TR, . First trimester gestational diabetes screening - change in incidence and pharmacotherapy need. Diabetes Res Clin. 2015 Jul 01;109(1):135–40. PMID: 604283997. Wrong study design.
48 Alvarez-Bulnes O, Mones-Llivina A, Cavero-Roig L, . Ophthalmic Pathology in the Offspring of Pregnant Women with Gestational Diabetes Mellitus. Matern Child Health J. 2020;24(4):524–9. PMID: 31997119. Wrong population other.31997119
49 Amaefule CE, Bolou A, Drymoussi Z, . Effectiveness and acceptability of metformin in preventing the onset of type 2 diabetes after gestational diabetes in postnatal women: a protocol for a randomised, placebo-controlled, double-blind feasibility trialOptimising health outcomes with Metformin to prevent diAbetes After pregnancy (OMAhA). BMJ Open. 2020;10(5):e036198. PMID: 32423937. Wrong study design.32423937
50 Amaefule CE, Drymoussi Z, Dodds J, . Effectiveness and acceptability of myo-inositol nutritional supplement in the prevention of gestational diabetes (EMmY): a protocol for a randomised, placebo-controlled, double-blind pilot trial. BMJ Open. 2018;8(9):e022831. PMID: 30249632. Wrong intervention.30249632
51 Amason JS, Lee SY, Aduddell K, . Pilot feasibility study of an educational intervention in women with gestational diabetes. JOGNN-J Obst Gyn Neo. 2016 Jul 01;45(4):515–27. PMID: 620108549. Wrong comparison.
52 Amylidi S, Mosimann B, Stettler C, . First-trimester glycosylated hemoglobin in women at high risk for gestational diabetes. Acta Obstet Gyn Scan. 2016;95(1):93–7. PMID: 26400192. Wrong study design.26400192
53 Anderson V, Ye C, Sermer M, . Fasting capillary glucose as a screening test for ruling out gestational diabetes mellitus. J Obstet Gynaecol Can. 2013;35(6):515–22. PMID: 23870775. Wrong index test KQ4.23870775
54 Anjana RM, Sudha V, Lakshmipriya N, . Physical activity patterns and gestational diabetes outcomes - the wings project. Diabetes Res Clin. 2016;116:253–62. PMID: 27321343. Wrong intervention.27321343
55 Anjum F, Zaini R, Shami A, . Glycated hemoglobin and lipid profile association among pregnant women in Saudi Arabian population. Int J Women Heal Rep Sci. 2019 Apr;7(2):216–22. PMID: 2001743221. Wrong study design.
56 Ankumah NA, Tita AT, Biggio JR, . Pregnancy outcomes in women with 1-hour glucose challenge test >= 200 mg/dL. Am J Perinatol. 2016;33(5):490–4. PMID: 26529473. Wrong study design.26529473
57 Anonymous. No advantage to one-step gestational diabetes screening method. Clinical Laboratory News. 2016;42(2):7. PMID: 114705211. Not primary research.
58 Arafa A, Dong JY. Gestational diabetes and risk of postpartum depressive symptoms: A meta-analysis of cohort studies. J Affect Disord. 2019;253:312–6. PMID: 31078830. Not primary research.31078830
59 Arbib N, Shmueli A, Salman L, . First trimester glycosylated hemoglobin as a predictor of gestational diabetes mellitus. Int J Gynecol Obstet. 2019;145(2):158–63. PMID: 30791100. Wrong study design.30791100
60 Ardawi MS, Nasrat HA, Jamal HS, . Screening for gestational diabetes mellitus in pregnant females. Saudi Med J. 2000 Feb;21(2):155–60. PMID: 11533772. Wrong population.11533772
61 Aris IM, Rifas-Shiman SL, Li LJ, . Early-Life Predictors of Systolic Blood Pressure Trajectories From Infancy to Adolescence: Findings From Project Viva. Am J Epidemiol. 2019 01 Nov;188(11):1913–22. PMID: 629877404. Wrong population other.31497850
62 Arora D, Arora R, Sangthong S, . Universal screening of gestational diabetes mellitus: prevalence and diagnostic value of clinical risk factors. J Med Assoc Thai. 2013;96(3):266–71. PMID: 23539927. Wrong index test KQ4.23539927
63 Arora GP, Almgren P, Brons C, . Association between genetic risk variants and glucose intolerance during pregnancy in north Indian women. BMC Med Genomics. 2018 Aug 08;11(1). PMID: 623387260. Wrong study design.
64 Arora GP, Thaman RG, Prasad RB, . Prevalence and risk factors of gestational diabetes in Punjab, North India: results from a population screening program. Eur J Endocrinol. 2015;173(2):257–67. PMID: 26012589. Wrong outcome.26012589
65 Arshad R, Khanam S, Shaikh F, . Feto-maternal outcomes and glycemic control in Metformin versus insulin treated gestational diabetics. Pak J Med Sci. 2017;33(5):1182–7. PMID: 29142561. Wrong comparison.29142561
66 Artzi NS, Shilo S, Hadar E, . Prediction of gestational diabetes based on nationwide electronic health records. Nat Med. 2020;26(1):71–6. PMID: 31932807. Wrong study design.31932807
67 Asemi Z, Samimi M, Tabassi Z, . The effect of DASH diet on pregnancy outcomes in gestational diabetes: a randomized controlled clinical trial. Eur J Clin Nutr. 2014;68(4):490–5. PMID: 24424076. Wrong comparison.24424076
68 Assaf-Balut C, Bordiu E, Del Valle L, . The impact of switching to the one-step method for GDM diagnosis on the rates of postpartum screening attendance and glucose disorder in women with prior GDM: the San Carlos gestational study. J Diabetes Complicat. 2016;30(7):1360–4. PMID: 27210051. Wrong study design.27210051
69 Assaf-Balut C, Garcia De La Torre N, Duran A, . Medical nutrition therapy for gestational diabetes mellitus based on Mediterranean diet principles: A subanalysis of the St Carlos GDM prevention study. BMJ Open Diabetes Res Care. 2018 Oct 01;6(1):e000550. PMID: 624327468. Wrong comparison.
70 Atia HC, Koren Y, Weintraub AY, . Is a value of over 200mg/dL in the oral glucose tolerance test, a marker of severity in patients with gestational diabetes mellitus? J Matern-Fetal Neo M. 2013 Sep;26(13):1259–62. PMID: 369504023. Wrong study design.
71 Avalos G, Dunne FP, Atlantic DIPc. Atlantic DIP: subject recruitment, data collection, missing data management and analysis procedures. Ir Med J. 2012;105(5 Suppl):4–6. PMID: 22838097. Not primary research.22838097
72 Avalos GE, Owens LA, Dunne F, . Applying current screening tools for gestational diabetes mellitus to a European population: is it time for change? Diabetes Care. 2013;36(10):3040–4. PMID: 23757431. Wrong study design.23757431
73 Aviram A, Shtaif B, Gat-Yablonski G, . The association between adipocytokines and glycemic control in women with gestational diabetes mellitus. J Matern-Fetal Neo M. 2018 PMID: 623239294. Wrong comparison.
74 Aydin H, Celik O, Yazici D, . Prevalence and predictors of gestational diabetes mellitus: a nationwide multicentre prospective study. Diabet Med. 2019;36(2):221–7. PMID: 30402933. Wrong population (KQ4 development cohort).30402933
75 Babadi M, Khorshidi A, Aghadavood E, . The effects of probiotic supplementation on genetic and metabolic profiles in patients with gestational diabetes mellitus: a randomized, double-blind, placebo-controlled trial. Probiotics Antimicrob. 2018;08:08. PMID: 30535534. Wrong outcome.30535534
76 Baci Y, Ustuner I, Keskin HL, . Effect of maternal obesity and weight gain on gestational diabetes mellitus. Gynecol Endocrinol. 2013;29(2):133–6. PMID: 23110595. Wrong outcome.23110595
77 Badon SE, Zhu Y, Sridhar SB, . A pre-pregnancy biomarker risk score improves prediction of future gestational diabetes. J Clin Endocrinol Metab. 2018;2(10):1158–69. PMID: 30302420. Wrong study design.30302420
78 Bahado-Singh RO, Mele L, Landon MB, . Fetal male gender and the benefits of treatment of mild gestational diabetes mellitus. Am J Obstet Gynecol. 2012;206(5):422.e1–5. PMID: 22542118. Wrong outcome.22542118
79 Balaji V, Balaji M, Anjalakshi C, . Diagnosis of gestational diabetes mellitus in Asian-Indian women. Indian J Endocr Metab. 2011;15(3):187–90. PMID: 21897895. Wrong study design.21897895
80 Balaji V, Balaji M, Anjalakshi C, . Inadequacy of fasting plasma glucose to diagnose gestational diabetes mellitus in Asian Indian women. Diabetes Res Clin Pract. 2011 Oct;94(1):e21–3. doi: 10.1016/j.diabres.2011.07.008. PMID: 21831468. Wrong outcome.21831468
81 Balaji V, Balaji MS, Alexander C, . Premixed insulin aspart 30 (Biasp 30) vs. premixed human insulin 30 (BHI 30) in gestational diabetes mellitus-a pilot study. J Assoc Physicians India. 2010;58:99–101. PMID: 20653150. Wrong comparison.20653150
82 Balaji V, Balaji MS, Alexander C, . Premixed insulin aspart 30 (BIAsp 30) versus premixed human insulin 30 (BHI 30) in gestational diabetes mellitus: a randomized open-label controlled study. Gynecol Endocrinol. 2012;28(7):529–32. PMID: 22468861. Wrong comparison.22468861
83 Balaji V, Balaji MS, Paneerselvam A, . Point of care for gestational diabetes mellitus - a community-based study. J Indian Med Assoc. 2012 May;110(5):314–6. PMID: 365231490. Wrong index test KQ4.23360023
84 Balaji V, Madhuri BS, Paneerselvam A, . Comparison of venous plasma glucose and capillary whole blood glucose in the diagnosis of gestational diabetes mellitus: a community-based study. Diabetes Technol Ther. 2012;14(2):131–4. PMID: 21992269. Wrong index test KQ4.21992269
85 Balani J, Hyer S, Johnson A, . Pregnancy outcomes after metformin treatment for gestational diabetes: a case-control study. Obstet Med. 2012;5(2):78–82. PMID: 27579140. Wrong comparison.27579140
86 Balani J, Hyer S, Syngelaki A, . Association between insulin resistance and preeclampsia in obese non-diabetic women receiving metformin. Obstet Med. 2017;10(4):170–3. PMID: 29225676. Wrong population.29225676
87 Balani J, Hyer SL, Shehata H, . Visceral fat mass as a novel risk factor for predicting gestational diabetes in obese pregnant women. Obstet Med. 2018 Sep 01;11(3):121–5. PMID: 621308687. Wrong index test KQ4.30214477
88 Barat S, Ghanbarpour A, Bouzari Z, . Triglyceride to HDL cholesterol ratio and risk for gestational diabetes and birth of a large-for-gestational-age newborn. Caspian J Intern Med. 2018;9(4):368–75. PMID: 30510652. Wrong population (KQ4 development cohort).30510652
89 Barchilon-Tiosano L, Sheiner E, Wainstock T, . Long-term risk for maternal cardiovascular morbidities in twin pregnancies complicated with gestational diabetes mellitus - a retrospective cohort study. J Matern. 2019:1–5. PMID: 31581869. Wrong population other.31581869
90 Barrett PM, McCarthy FP, Kublickiene K, . Adverse Pregnancy Outcomes and Long-term Maternal Kidney Disease: A Systematic Review and Meta-analysis. JAMA Network Open. 2020;3(2):e1920964. PMID: 32049292. Wrong population other.32049292
91 Barton K, Donovan L, Giroux I, . Glycated hemoglobin measurements at three, 12 and 24 months postpartum after gestational diabetes. Clin Invest Med. 2019;42(4):E37–E41. PMID: 31922707. Wrong outcome.31922707
92 Bassaw B, Mohammed N, Ramsewak S, . Pregnancy outcome among women universally screened for gestational diabetes mellitus with a lime-flavoured drink. J Obstet Gynaecol. 2012;32(5):422–5. PMID: 22663310. Wrong index test KQ4.22663310
93 Bastani F. Effect of acupressure on maternal anxiety in women with gestational diabetes mellitus: a randomized clinical trial. Clin Nurs Res. 2016;25(3):325–41. PMID: 25848127. Wrong study design.25848127
94 Behboudi Gandevani S, Garshasbi A, Shahpari Niri S, . New criteria for gestational diabetes in Tehran, Iran. Iranian J Reprod Med. 2012;10(3):237–42. PMID: 25242999. Wrong outcome.25242999
95 Behboudi-Gandevani S, Safary K, Moghaddam-Banaem L, . The relationship between maternal serum iron and zinc levels and their nutritional intakes in early pregnancy with gestational diabetes. Biol Trace Elem Res. 2013;154(1):7–13. PMID: 23743666. Wrong index test KQ4.23743666
96 Behrashi M, Samimi M, Ghasemi T, . Comparison of glibenclamide and insulin on neonatal outcomes in pregnant women with gestational diabetes. Int J Prev Med. 2016;7:88. PMID: 27413519. Wrong comparison.27413519
97 Beka Q, Bowker S, Savu A, . Development of perinatal mental illness in women with gestational diabetes mellitus: a population-based cohort study. Can J Diabetes. 2018;42(4):350–5.e1. PMID: 28943221. Wrong comparison KQ228943221
98 Benhalima K, Lens K, Bosteels J, . The Risk for Glucose Intolerance after Gestational Diabetes Mellitus since the Introduction of the IADPSG Criteria: A Systematic Review and Meta-Analysis. J Clin Med. 2019;8(9):10. PMID: 31510081. Not primary research.31510081
99 Benhalima K, Van Crombrugge P, Moyson C, . Estimating the risk of gestational diabetes mellitus based on the 2013 WHO criteria: a prediction model based on clinical and biochemical variables in early pregnancy. Acta Diabetol. 2020;57(6):661–71. PMID: 31915927. Wrong population (KQ4 development cohort).31915927
100 Benhalima K, Van Crombrugge P, Moyson C, . Risk factor screening for gestational diabetes mellitus based on the 2013 WHO criteria. Eur J Endocrinol. 2019;180(6):353–63. PMID: 31120231. Wrong population (KQ4 development cohort).31120231
101 Benhalima K, Van Crombrugge P, Verhaeghe J, . The Belgian diabetes in pregnancy study (BEDIP-N), a multi-centric prospective cohort study on screening for diabetes in pregnancy and gestational diabetes: methodology and design. BMC Pregnancy Childb. 2014;14:226. PMID: 25015413. Not primary research.25015413
102 Berggren EK, Boggess KA, Funk MJ, . Racial disparities in perinatal outcomes among women with gestational diabetes. J Womens Health. 2012;21(5):521–7. PMID: 22216896. Wrong study design.22216896
103 Berggren EK, Boggess KA, Mathew L, . First trimester maternal glycated hemoglobin and sex hormone-binding globulin do not predict third trimester glucose intolerance of pregnancy. Reprod Sci. 2017;24(4):613–8. PMID: 27613817. Wrong study design.27613817
104 Berggren EK, Boggess KA, Stuebe AM, . National diabetes data group vs Carpenter-Coustan criteria to diagnose gestational diabetes. Am J Obstet Gynecol. 2011 Sep;205(3):253.e1–7. doi: 10.1016/j.ajog.2011.06.026. PMID: 22071053. Wrong population.22071053
105 Berggren EK, Roeder HA, Boggess KA, . First-trimester maternal serum C-reactive protein as a predictor of third-trimester impaired glucose tolerance. Reprod Sci. 2015;22(1):90–3. PMID: 24784714. Wrong study design.24784714
106 Berghella V, Caissutti C, Saccone G, . The one step approach for diagnosing gestational diabetes is associated with better perinatal outcomes than the two step approach: evidence of randomized clinical trials. Am J Obstet Gynecol. 2019;31:31. PMID: 30711511. Not primary research.30711511
107 Berghella V, Caissutti C, Saccone G, . The One Step approach for diagnosing gestational diabetes is associated with better perinatal outcomes than the Two Step approach: evidence of randomized clinical trials. Am J Obstet. 2019;220(6):562–4. PMID: 30711511. Not primary research.30711511
108 Berkus MD, Langer O. Glucose tolerance test periodicity: the effect of glucose loading. Obstet Gynecol. 1995 Mar;85(3):423–7. doi: 10.1016/0029-7844(94)00410-f. PMID: 7862384. Wrong index test KQ4.7862384
109 Bernasko J. Gestational diabetes screening: the international association of the diabetes and pregnancy study groups compared with Carpenter-Coustan screening. Obstet Gynecol. 2016;127(5):964–5. PMID: 27101111. Not primary research.27101111
110 Bhargava A, Siddiqui S, Waghdhare S, . Comment on Rudland et al.: Identifying glucokinase monogenic diabetes in a multiethnic gestational diabetes mellitus cohort: new pregnancy screening criteria and utility of HbA1c. Diabetes Care. 2016;39:50–52. PMID: 26696667. Not primary research.26109503
111 Bhavadharini B, Mahalakshmi MM, Maheswari K, . Use of capillary blood glucose for screening for gestational diabetes mellitus in resource-constrained settings. Acta Diabetol. 2016;53(1):91–7. PMID: 25916215. Wrong index test KQ4.25916215
112 Bianchi C, de Gennaro G, Romano M, . Italian national guidelines for the screening of gestational diabetes: time for a critical appraisal? Nutr Metab Cardiovas. 2017;27(8):717–22. PMID: 28755805. Wrong study design.28755805
113 Bianchi C, e Gennaro G, Romano M, . Early vs. standard screening and treatment of gestational diabetes in high-risk women - An attempt to determine relative advantages and disadvantages. Nutr Metab Cardiovasc Dis. 2019;29(6):598–603. PMID: 30954416. Wrong comparison other.30954416
114 Bianco ME, Josefson JL. Hyperglycemia During Pregnancy and Long-Term Offspring Outcomes. Curr Diab Rep. 2019;19(12):143. PMID: 31754898. Wrong population other.31754898
115 Bildaci TB, Cevik H, Aksan Desteli G, . Placental elasticity on patients with gestational diabetes: single institution experience. J Chin Med Assoc. 2017;80(11):717–20. PMID: 28539240. Wrong study design.28539240
116 Bisson M, Series F, Giguere Y, . Gestational diabetes mellitus and sleep-disordered breathing. Obstet Gynecol. 2014;123(3):634–41. PMID: 24499765. Wrong study design.24499765
117 Black MH, Sacks DA, Xiang AH, . Clinical outcomes of pregnancies complicated by mild gestational diabetes mellitus differ by combinations of abnormal oral glucose tolerance test values. Diabetes Care. 2010 Dec;33(12):2524–30. doi: 10.2337/dc10-1445. PMID: 20843973. Wrong population.20843973
118 Black MH, Sacks DA, Xiang AH, . The relative contribution of prepregnancy overweight and obesity, gestational weight gain, and IADPSG-defined gestational diabetes mellitus to fetal overgrowth. Diabetes Care. 2013;36(1):56–62. PMID: 22891256. Wrong study design.22891256
119 Blatt AJ, Nakamoto JM, Kaufman HW. Gaps in diabetes screening during pregnancy and postpartum. Obstet Gynecol. 2011 Jan;117(1):61–8. PMID: 361023780. Wrong outcome.21173645
120 Bloomgarden Z. Troubling ethical questions from gestational diabetes trial. J Diabetes. 2010;2(1):1–4. PMID: 20923469. Not primary research.20923469
121 Blotsky AL, Rahme E, Dahhou M, . Gestational diabetes associated with incident diabetes in childhood and youth: A retrospective cohort study. Cmaj. 2019;191(15):E410–E7. PMID: 2001846728. Wrong population other.30988041
122 Bo S, Menato G, Gallo ML, . Mild gestational hyperglycemia, the metabolic syndrome and adverse neonatal outcomes. Acta Obstet Gynecol Scand. 2004 Apr;83(4):335–40. doi: 10.1111/j.0001-6349.2004.00314.x. PMID: 15005779. Wrong population.15005779
123 Bo S, Rosato R, Ciccone G, . Simple lifestyle recommendations and the outcomes of gestational diabetes. A 2 x 2 factorial randomized trial. Diabetes Obes Metab. 2014;16(10):1032–5. PMID: 24646172. Wrong comparison.24646172
124 Bobrowski RA, Bottoms SF, Micallef JA, . Is the 50-gram glucose screening test ever diagnostic? J Matern Fetal Med. 1996 Nov;5(6):317–20. doi: 10.1002/(sici)1520-6661(199611/12)5:6<317::aid-mfm5>3.0.co;2-s. PMID: 8972407. Wrong outcome.8972407
125 Bodmer-Roy S, Morin L, Cousineau J, . Pregnancy outcomes in women with and without gestational diabetes mellitus according to the international association of the diabetes and pregnancy study groups criteria. Obstet Gynecol. 2012 Oct;120(4):746–52. PMID: 365749794. Wrong criteria KQ5.22996090
126 Boe B, Barbour LA, Allshouse AA, . Universal early pregnancy glycosylated hemoglobin A1c as an adjunct to Carpenter-Coustan screening: an observational cohort study. Am J Obstet MFM. 2019 March;1(1):24–32. PMID: 2001778650. Wrong comparison other.
127 Bolognani CV, de Sousa Moreira Reis LB, de Souza SS, . Waist circumference in predicting gestational diabetes mellitus. J Matern-Fetal Neo M. 2014;27(9):943–8. PMID: 24053462. Wrong population (KQ4 development cohort).24053462
128 Bonakdaran S, Azami G, Tara F, . Soluble (pro) renin receptor is a predictor of gestational diabetes mellitus. Curr Diabetes Rev. 2017;13(6):555–9. PMID: 27654965. Wrong index test KQ4.27654965
129 Bonomo M, Gandini ML, Farina A, . Should we treat minor degrees of glucose intolerance in pregnancy? Ann Ist Super Sanita. 1997;33(3):393–7. PMID: 9542269. Wrong study design.9542269
130 Bonongwe P, Lindow SW, Coetzee EJ. Reproducibility of a 75G oral glucose tolerance test in pregnant women. J Perinat Med. 2015;43(3):333–8. PMID: 25405716. Wrong study design.25405716
131 Bouchghoul H, Alvarez JC, Verstuyft C, . Transplacental transfer of glyburide in women with gestational diabetes and neonatal hypoglycemia risk. PLoS ONE [Electronic Resource]. 2020;15(5):e0232002. PMID: 32379777. Wrong population other.32379777
132 Bourdages M, Demers ME, Dube S, . First-trimester abdominal adipose tissue thickness to predict gestational diabetes. J Obstet Gynaecol Can. 2018;40(7):883–7. PMID: 29724492. Wrong outcome.29724492
133 Bowker SL, Savu A, Yeung RO, . Patterns of glucose-lowering therapies and neonatal outcomes in the treatment of gestational diabetes in Canada, 2009-2014. Diabet Med. 2017;34(9):1296–302. PMID: 28586507. Wrong study design.28586507
134 Boyadzhieva M, Atanasova I, Zacharieva S, . Adipocytokines during pregnancy and postpartum in women with gestational diabetes and healthy controls. J Endocrinol Invest. 2013;36(11):944–9. PMID: 23685996. Wrong index test KQ4.23685996
135 Boyadzhieva MV, Atanasova I, Zacharieva S, . Comparative analysis of current diagnostic criteria for gestational diabetes mellitus. Obstet Med. 2012;5(2):71–7. PMID: 27579139. Wrong criteria KQ5.27579139
136 Braga FO, Negrato CA, Matta M, . Relationship between inflammatory markers, glycated hemoglobin and placental weight on fetal outcomes in women with gestational diabetes. Arch Endocrinol Metab. 2019;63(1):22–9. PMID: 30864628. Duplicates.30864628
137 Brankica K, Valentina VN, Slagjana SK, . Maternal 75-g OGTT glucose levels as predictive factors for large-for-gestational age newborns in women with gestational diabetes mellitus. Arch Endocrin Metab. 2016;60(1):36–41. PMID: 26909480. Wrong comparison.26909480
138 Brink HS, Alkemade M, van der Lely AJ, . Metformin in women at high risk of gestational diabetes mellitus. Diabetes Metab. 2018;44(3):300–2. PMID: 29422358. Wrong intervention.29422358
139 Broekhuizen K, Simmons D, Devlieger R, . Cost-effectiveness of healthy eating and/or physical activity promotion in pregnant women at increased risk of gestational diabetes mellitus: economic evaluation alongside the DALI study, a European multicenter randomized controlled trial. Int J Behav Nutr Phy. 2018;15(1):23. PMID: 29540227. Wrong intervention.29540227
140 Brown AM, Rajeswari D, Bowles A. Choice of planned place of birth for women with diet-controlled gestational diabetes mellitus. Br J Midwifery. 2016;24(10):702–10. doi: 10.12968/bjom.2016.24.10.702. PMID: 118651563. Wrong comparison.
141 Brown FM, Isganaitis E, James-Todd T. Much to HAPO FUS About: Increasing Maternal Glycemia in Pregnancy Is Associated With Worsening Childhood Glucose Metabolism. Diabetes Care. 2019;42(3):393–5. PMID: 30787060. Wrong study design.30787060
142 Brown FM, Wyckoff J. Application of one-step IADPSG versus two-step diagnostic criteria for gestational diabetes in the real world: impact on health services, clinical care, and outcomes. Curr Diabetes Rep. 2017;17(10):85. PMID: 28799123. Not primary research.28799123
143 Brustman L, Langer O, Scarpelli S, . Hypoglycemia in glyburide-treated gestational diabetes: is it dose-dependent? Obstet Gynecol. 2011;117(2 Pt 1):349–53. PMID: 21252749. Wrong comparison.21252749
144 Brustman LE, Gela BD, Moore M, . Variations in oral glucose tolerance tests: the 100- versus 75-g controversy. J Assoc Acad Minor Phys. 1995;6(2):70–2. PMID: 7772935. Wrong index test KQ4.7772935
145 Brustman LE, Langer O, Bimson B, . Weight gain in gestational diabetes: the effect of treatment modality. J Matern-Fetal Neo M. 2016;29(7):1025–9. PMID: 25902398. Wrong comparison.25902398
146 Buelo AK, Kirk A, Lindsay RS, . Exploring the effectiveness of physical activity interventions in women with previous gestational diabetes: A systematic review of quantitative and qualitative studies. Prev Med Rep. 2019;14:100877. PMID: 31110933. Not primary research.31110933
147 Bugallo FM, Alvarez CR, Aguirre-Jaime A, . Effectiveness of a screening protocol for gestational diabetes in pregnant Spanish women. J Matern-Fetal Neo M. 2011;24(7):917–22. PMID: 21142770. Wrong study design.21142770
148 Buhling KJ, Elze L, Henrich W, . The usefulness of glycosuria and the influence of maternal blood pressure in screening for gestational diabetes. Eur J Obstet Gynecol Reprod Biol. 2004 Apr 15;113(2):145–8. doi: 10.1016/j.ejogrb.2003.06.013. PMID: 15063950. Wrong outcome.15063950
149 Bullard KM, Ali MK, Imperatore G, . Receipt of glucose testing and performance of two us diabetes screening guidelines, 2007-2012. PLoS ONE. 2015 01 Apr;10(4):e0125249. PMID: 608141902. Wrong population.25928306
150 Burris HH, Rifas-Shiman SL, Kleinman K, . Vitamin D deficiency in pregnancy and gestational diabetes mellitus. Am J Obstet Gynecol. 2012;207(3):182.e1–8. PMID: 22717271. Wrong study design.22717271
151 Byrn M, Penckofer S. The relationship between gestational diabetes and antenatal depression. JOGNN-J Obst Gyn Neo. 2015 Mar 01;44(2):246–55. PMID: 607607534. Wrong comparison KQ2
152 Cade TJ, Polyakov A, Brennecke SP. Implications of the introduction of new criteria for the diagnosis of gestational diabetes: a health outcome and cost of care analysis. BMJ Open. 2019;9(1):e023293. PMID: 30612109. Wrong study design.30612109
153 Cade TJ, Polyakov A, Brennecke SP. Implications of the introduction of new criteria for the diagnosis of gestational diabetes: a health outcome and cost of care analysis. BMJ Open. 2019;9(1):e023293. PMID: 30612109. Duplicates.30612109
154 Caglar GS, Ozdemir ED, Cengiz SD, . Sex-hormone-binding globulin early in pregnancy for the prediction of severe gestational diabetes mellitus and related complications. J Obstet Gynaecol Res. 2012;38(11):1286–93. PMID: 22612716. Wrong index test KQ4.22612716
155 Caissutti C, Khalifeh A, Saccone G, . Are women positive for the One Step but negative for the Two Step screening tests for gestational diabetes at higher risk for adverse outcomes? Acta Obstet Gyn Scan. 2018;97(2):122–34. PMID: 29091257. Not primary research.29091257
156 Calle-Pascual AL, Perez-Ferre N, Galindo M, . The outcomes of gestational diabetes mellitus after a telecare approach are not inferior to traditional outpatient clinic visits. Int J Endocrinol. 2010;2010:386941. PMID: 361363779. Wrong comparison.20628517
157 Cambos S, Rigalleau V, Blanco L. A Medically Supervised Pregnancy Exercise Intervention in Obese Women: A Randomized Controlled Trial. Obstet Gynecol. 2018;131(3):599-. doi: 10.1097/AOG.0000000000002505. PMID: 128347338. Language: English. Entry Date: In Process. Revision Date: 20190104. Publication Type: journal article. Journal Subset: Biomedical. Not primary research.
158 Capula C, Chiefari E, Borelli M, . A new predictive tool for the early risk assessment of gestational diabetes mellitus. Prim care diabetes. 2016;10(5):315–23. PMID: 27268754. Wrong study design.27268754
159 Capula C, Chiefari E, Vero A, . Gestational diabetes mellitus: screening and outcomes in southern italian pregnant women. Isrn Endocrinol. 2013;2013:387495. PMID: 24093064. Wrong study design.24093064
160 Capula C, Mazza T, Vero R, . HbA1c levels in patients with gestational diabetes mellitus: relationship with pre-pregnancy BMI and pregnancy outcome. J Endocrinol Invest. 2013 Dec;36(11):1038–45. PMID: 372050013. Wrong intervention.23873403
161 Carolan M, Steele C, Margetts H. Attitudes towards gestational diabetes among a multiethnic cohort in Australia. J Clin Nurs. 2010;19(17-18):2446–53. PMID: 20920072. Wrong study design.20920072
162 Carter EB, Martin S, Temming LA, . Early versus 6-12 week postpartum glucose tolerance testing for women with gestational diabetes. Obstet Gynecol Surv. 2018 01 Jul;73(7):389–91. PMID: 623325569. Wrong population.
163 Casey BM, Duryea EL, Abbassi-Ghanavati M, . Glyburide in women with mild gestational diabetes: a randomized controlled trial. Obstet Gynecol. 2015;126(2):303–9. PMID: 26241419. Wrong comparison.26241419
164 Casey BM, Rice MM, Landon MB, . Effect of Treatment of Mild Gestational Diabetes on Long-Term Maternal Outcomes. Am J Perinatol. 2020;37(5):475–82. PMID: 30866027. Duplicates.30866027
165 Celentano C, Matarrelli B, Pavone G, . The influence of different inositol stereoisomers supplementation in pregnancy on maternal gestational diabetes mellitus and fetal outcomes in high-risk patients: a randomized controlled trial. J Matern-Fetal Neo M. 2018. PMID: 625545467. Wrong intervention.
166 Celtik A, Akinci B, Demir T. Mean platelet volume in women with gestational diabetes. Turk J Endocrinol Metab. 2016 Jun;20(2):48–53. PMID: 610994618. Wrong intervention.
167 Cha HH, Kim JY, Choi SJ, . How high is too high in cutoff levels from 50-g glucose challenge test. Obstet Gynecol Sci. 2016;59(3):178–83. PMID: 27200307. Wrong study design.27200307
168 Champion ML, Jauk VC, Biggio JR, . 440: early gestational diabetes screening in class III obesity (BMIâ‰¥40). Am J Obstet. 2020;222(1):S289‐. doi: 10.1016/j.ajog.2019.11.456. PMID: CN-02077332. Protocol.
169 Chandrasekaran N, Storm S, De souza LR, . 790: The impact of video based activity platform on management of gestational diabetes, a randomized controlled trial. Am J Obstet Gynecol. 2018;218:S471–S2. doi: 10.1016/j.ajog.2017.11.322. PMID: 127385887. Wrong comparison.
170 Chastang N, Hartemann-Heurtier A, Sachon C, . Comparison of two diagnostic tests for gestational diabetes in predicting macrosomia. Diabetes Metab. 2003 Apr;29(2 Pt 1):139–44. doi: 10.1016/s1262-3636(07)70020-4. PMID: 12746634. Wrong index test KQ4.12746634
171 Chen L, Pocobelli G, Yu O, . Early Pregnancy Hemoglobin A1C and Pregnancy Outcomes: A Population-Based Study. Am J Perinatol. 2019;36(10):1045–53. PMID: 30500961. Wrong study design.30500961
172 Cheng J, Eskenazi B, Widjaja F, . Improving autism perinatal risk factors: A systematic review. Med Hypotheses. 2019 June;127:26–33. PMID: 2001757641. Not primary research.31088644
173 Cheng YW, Block-Kurbisch I, Caughey AB. Carpenter-Coustan criteria compared with the national diabetes data group thresholds for gestational diabetes mellitus. Obstet Gynecol. 2009 Aug;114(2 Pt 1):326–32. doi: 10.1097/AOG.0b013e3181ae8d85. PMID: 19622994. Wrong population.19622994
174 Cheung NW, Jiang S, Athayde N. Impact of the IADPSG criteria for gestational diabetes, and of obesity, on pregnancy outcomes. Aust NZ J Obstet Gynaecol. 2018;58(5):553–9. PMID: 29359312. Wrong criteria KQ5.29359312
175 Chitme HR, Al Shibli SA, Al-Shamiry RM. Risk factors and plasma glucose profile of gestational diabetes in Omani women. Oman Med J. 2016;31(5):370–7. PMID: 27602192. Wrong study design.27602192
176 Chiu YH, Minguez-Alarcon L, Ford JB, . Trimester-specific urinary bisphenol a concentrations and blood glucose levels among pregnant women from a fertility clinic. J Clin Endocrinol Metab. 2017 Apr 01;102(4):1350–7. PMID: 615320488. Wrong index test KQ4.28323984
177 Chong YS, Cai S, Lin H, . Ethnic differences translate to inadequacy of high-risk screening for gestational diabetes mellitus in an Asian population: a cohort study. BMC Pregnancy Childb. 2014;14:345. PMID: 25273851. Wrong study design.25273851
178 Chou CY, Lin CL, Yang CK, . Pregnancy outcomes of Taiwanese women with gestational diabetes mellitus: a comparison of Carpenter-Coustan and national diabetes data group criteria. J Womens Health. 2010 May;19(5):935–9. doi: 10.1089/jwh.2009.1620. PMID: 20370431. Wrong population.20370431
179 Church D, Halsall D, Meek C, . Random blood glucose measurement at antenatal booking to screen for overt diabetes in pregnancy: a retrospective study. Diabetes Care. 2011;34(10):2217–9. PMID: 21844290. Wrong comparison.21844290
180 Claesson R, Ekelund M, Berntorp K. The potential impact of new diagnostic criteria on the frequency of gestational diabetes mellitus in Sweden. Acta Obstet Gyn Scan. 2013;92(10):1223–6. PMID: 23931629. Wrong criteria KQ5.23931629
181 Clark CE, Rasgon NL, Reed DE, 2nd, . Depression precedes, but does not follow, gestational diabetes. Acta Psychiat Scand. 2019;139(4):311–21. PMID: 30561785. Wrong comparison KQ230561785
182 Clark CE, Rasgon NL, Reed DE, . Depression precedes, but does not follow, gestational diabetes. Acta Psychiat Scand. 2019;139(4):311–21. PMID: 30561785. Wrong outcome.30561785
183 Clarke E, Cade TJ, Brennecke S. Early Pregnancy Screening for Women at High-Risk of GDM Results in Reduced Neonatal Morbidity and Similar Maternal Outcomes to Routine Screening. J Pregnancy. 2020;2020:9083264. PMID: 32411467. Wrong comparison other.32411467
184 Coetzee A, Vyver M, Hoffmann M, . A comparison between point‐of‐care testing and venous glucose determination for the diagnosis of diabetes mellitus 6–12 weeks after gestational diabetes. Diabet Med. 2019;36(5):591–9. doi: 10.1111/dme.13903. PMID: 135876858. Wrong population.30663133
185 Cok T, Tarim E, Bagis T. Isolated abnormal value during the 3-hour glucose tolerance test: which value is associated with macrosomia? J Matern Fetal Neonatal Med. 2011 Aug;24(8):1039–41. doi: 10.3109/14767058.2010.545910. PMID: 21247232. Wrong population.21247232
186 Colak E, Ozcimen EE, Ceran MU, . Role of mean platelet volume in pregnancy to predict gestational diabetes mellitus in the first trimester. J Matern-Fetal Neo M. 2019 PMID: 627092456. Wrong index test KQ4.
187 Coolen JC, Verhaeghe J. Physiology and clinical value of glycosuria after a glucose challenge during pregnancy. Eur J Obstet Gynecol Reprod Biol. 2010;150(2):132–6. PMID: 20207065. Wrong index test KQ4.20207065
188 Cooper DL, Petherick ES, Wright J. Lifestyle related risk factors in a multi-ethnic cohort of pregnant women: preliminary results from the Born in Bradford study. Public Health. 2013 Nov;127(11):1034–7. PMID: 52773410. Wrong intervention.24035564
189 Corrado F, D’Anna R, Cannata ML, . Correspondence between first-trimester fasting glycaemia, and oral glucose tolerance test in gestational diabetes diagnosis. Diabetes Metab. 2012;38(5):458–61. PMID: 22595470. Wrong study design.22595470
190 Corrado F, Pintaudi B, Di Vieste G, . Italian risk factor-based screening for gestational diabetes. J Matern-Fetal Neo M. 2014;27(14):1445–8. PMID: 24175881. Wrong study design.24175881
191 Correa PJ, Venegas P, Palmeiro Y, . First trimester prediction of gestational diabetes mellitus using plasma biomarkers: a case-control study. J Perinat Med. 2019;47(2):161–8. PMID: 30205647. Wrong index test KQ4.30205647
192 Cosson E, Benbara A, Pharisien I, . Diagnostic and prognostic performances over 9 years of a selective screening strategy for gestational diabetes mellitus in a cohort of 18,775 subjects. Diabetes Care. 2013;36(3):598–603. PMID: 23150287. Wrong outcome.23150287
193 Cosson E, Cussac-Pillegand C, Benbara A, . The diagnostic and prognostic performance of a selective screening strategy for gestational diabetes mellitus according to ethnicity in Europe. J Clin Endocrinal Metab. 2014;99(3):996–1005. PMID: 24423342. Wrong outcome.24423342
194 Cosson E, Vicaut E, Sandre-Banon D, . Early screening for gestational diabetes mellitus is not associated with improved pregnancy outcomes: an observational study including 9795 women. Diabetes Metab. 2019;45(5):465–72. PMID: 30502406. Wrong outcome.30502406
195 Cosson E, Vicaut E, Sandre-Banon D, . Initially untreated fasting hyperglycaemia in early pregnancy: prognosis according to occurrence of gestational diabetes mellitus after 22 weeks’ gestation: a case-control study. Diabet Med. 2020;37(1):123–30. PMID: 31536661. Wrong study design.31536661
196 Cosson E, Vicaut E, Sandre-Banon D, . Performance of a selective screening strategy for diagnosis of hyperglycaemia in pregnancy as defined by IADPSG/WHO criteria. Diabetes Metab. 2019;30:30. PMID: 31672576. Wrong population (KQ4 development cohort).31672576
197 Costa E, Kirckpartick C, Gerday C, . Change in prevalence of gestational diabetes and obstetric complications when applying IADPSG screening criteria in a Belgian French speaking University Hospital. A retrospective cohort study. BMC Pregnancy Childbirth. 2019;19(1):249. PMID: 31311547. Wrong study design.31311547
198 Coustan DR. The American Diabetes Association and the International Association of Diabetes and Pregnancy Study Groups recommendations for diagnosing gestational diabetes should be used worldwide. Clin Chem. 2012 Jul;58(7):1094–7. PMID: 365192696. Not primary research.22529107
199 Craig L, Sims R, Glasziou P, . Women’s experiences of a diagnosis of gestational diabetes mellitus: a systematic review. BMC Pregnancy Childbirth. 2020;20(1):76. PMID: 32028931. Not primary research.32028931
200 Crete JE, Anasti JN. Diagnosis of gestational diabetes mellitus: can we avoid the glucose challenge test? J am Assoc Nurs Pract. 2013;25(6):329–33. PMID: 24170598. Wrong study design.24170598
201 Crowther CA, Hague WM, Middleton PF, . The IDEAL study: investigation of dietary advice and lifestyle for women with borderline gestational diabetes: a randomised controlled trial - study protocol. BMC Pregnancy Childb. 2012;12:106. PMID: 23046499. Protocol.23046499
202 Culliney K, McCowan LME, Okesene-Gafa K, . Accuracy of point-of-care HbA1c testing in pregnant women. Aust NZ J Obstet Gynaecol. 2018;58(6):643–7. PMID: 29468638. Wrong comparison.29468638
203 Cuschieri S, Craus J, Savona-Ventura C. The role of untimed blood glucose in screening for gestational diabetes mellitus in a high prevalent diabetic population. Scientifica. 2016;2016:3984024. PMID: 26998382. Wrong study design.26998382
204 Daglar K, Kara O, Turkmen GG, . Clinical significance of fasting plasma glucose in patients with normal 50-g glucose challenge test in pregnancy: Is 100 bigger than 92? J Obstet Gynaecol. 2016;36(7):957–61. PMID: 27565573. Wrong criteria KQ5.27565573
205 Dahanayaka NJ, Agampodi SB, Ranasinghe OR, . Inadequacy of the risk factor based approach to detect gestational diabetes mellitus. Ceylon Med J. 2012;57(1):5–9. PMID: 22453704. Wrong outcome.22453704
206 Dalfra MG, Nicolucci A, Bisson T, . Quality of life in pregnancy and post-partum: a study in diabetic patients. Qual Life Res. 2012 Mar;21(2):291–8. PMID: 366392981. Wrong comparison KQ221633879
207 Daly B, Toulis KA, Thomas N, . Correction: Increased risk of ischemic heart disease, hypertension, and type 2 diabetes in women with previous gestational diabetes mellitus, a target group in general practice for preventive interventions: A population-based cohort study. PLoS Med / Public Library of Science. 2019;16(7):e1002881. PMID: 31318867. Wrong study design.31318867
208 Daly B, Toulis KA, Thomas N, . Correction: Increased risk of ischemic heart disease, hypertension, and type 2 diabetes in women with previous gestational diabetes mellitus, a target group in general practice for preventive interventions: A population-based cohort study. 2019;16:1-. doi: 10.1371/journal.pmed.1002881. PMID: 137566383. Language: English. Entry Date: In Process. Revision Date: 20190820. Publication Type: corrected article. Journal Subset: Biomedical. Wrong study design.
209 Daly N, Carroll C, Flynn I, . Evaluation of point-of-care maternal glucose measurements for the diagnosis of gestational diabetes mellitus. Int J Obstet Gynaecol. 2017;124(11):1746–52. PMID: 27532888. Wrong comparison.27532888
210 Daly N, Turner MJ. Changing the diagnostic criteria for gestational diabetes mellitus?: gestational diabetes screening: the International Association of the Diabetes and Pregnancy study groups compared with Carpenter-Coustan screening. Obstet Gynecol. 2016;127(4):800. PMID: 27008221. Not primary research.27008221
211 D’Anna R, Scilipoti A, Giordano D, . Myo-Inositol supplementation and onset of gestational diabetes mellitus in pregnant women with a family history of type 2 diabetes: a prospective, randomized, placebo-controlled study. Diabetes Care. 2013;36(4):854–7. PMID: 23340885. Wrong intervention.23340885
212 Danyliv A, Gillespie P, O’Neill C, . Health related quality of life two to five years after gestational diabetes mellitus: Cross-sectional comparative study in the ATLANTIC DIP cohort. BMC Pregnancy and Childb. 2015 Oct 24;15 (1). PMID: 606569277. Wrong comparison KQ2
213 D’Arcy E, Rayner J, Hodge A, . The Role of Diet in the Prevention of Diabetes among Women with Prior Gestational Diabetes: A Systematic Review of Intervention and Observational Studies. J Acad Nutr Diet. 2020;120(1):69–85.e7. PMID: 31636052. Not primary research.31636052
214 Davis B, McLean A, Sinha AK, . A threefold increase in gestational diabetes over two years: review of screening practices and pregnancy outcomes in Indigenous women of Cape York, Australia. Aust NZ J Obstet Gynaecol. 2013;53(4):363–8. PMID: 23472663. Wrong study design.23472663
215 De Silva SR, Riaz Y, Watson SL. Monitoring diabetic retinopathy in pregnancy: Meeting the NICE guidelines. Acta Ophthalmol. 2012 May;90(3):e243–e4. PMID: 51384447. Not primary research.21518305
216 Deerochanawong C, Putiyanun C, Wongsuryrat M, . Comparison of national diabetes data group and World Health Organization criteria for detecting gestational diabetes mellitus. Diabetologia. 1996 Sep;39(9):1070–3. doi: 10.1007/bf00400656. PMID: 8877291. Wrong outcome.8877291
217 Dehaene I, Roelens K. Gestational diabetes screening: The International Association of the Diabetes and Pregnancy study groups compared With Carpenter-Coustan screening and: changing the diagnostic criteria for gestational diabetes mellitus? Obstet Gynecol. 2016;127(5):963. PMID: 27101108. Not primary research.27101108
218 Delibas IB, Tanriverdi S, Cakmak B. Does reactive hypoglycemia during the 100 g oral glucose tolerance test adversely affect perinatal outcomes? Ginekol Pol. 2018;89(1):25–9. PMID: 29411343. Wrong study design.29411343
219 Dell’Edera D, Sarlo F, Allegretti A, . The influence of D-chiro-inositol and D-myo-inositol in pregnant women with glucose intolerance. Biomed Rep. 2017;7(2):169–72. PMID: 28804631. Wrong intervention.28804631
220 d’Emden M. Do the new threshold levels for the diagnosis of gestational diabetes mellitus correctly identify women at risk? Diabetes Care. 2014;37(2):e30. PMID: 24459160. Not primary research.24459160
221 Demirpence M, Demirpence N, Tutuncuoglu P, . Does glucagon-like peptide-1 have a role in the etiopathogenesis of gestational diabetes? Turk J Endocrinol Metab 2016 Jun;20(2):26–30. PMID: 610994614. Wrong intervention.
222 Dhatt GS, Agarwal MM, Othman Y, . Performance of the roche accu-chek active glucose meter to screen for gestational diabetes mellitus using fasting capillary blood. Diabetes Technol Ther. 2011 01 Dec;13(12):1229–33. PMID: 363014625. Wrong index test KQ4.21864017
223 Di Cianni G, Gualdani E, Berni C, . Screening for gestational diabetes in Tuscany, Italy. A population study. Diabetes Res Clin. 2017;132:149–56. PMID: 28863332. Wrong study design.28863332
224 Diabetes Prevention Program Research G. Long-term Effects of Metformin on Diabetes Prevention: Identification of Subgroups That Benefited Most in the Diabetes Prevention Program and Diabetes Prevention Program Outcomes Study. Diabetes Care. 2019;42(4):601–8. PMID: 30877090. Wrong intervention other.30877090
225 Dickson LM, Buchmann EJ, Janse van Rensburg C, . Accuracy of five plasma calibrated glucometers to screen for and diagnose gestational diabetes mellitus in a low resource clinic setting. J Clin Transl Endocrinol. 2019 Jun;16:100174. PMID: 2001688661. Wrong index test KQ4.30923676
226 Dinglas C, Muscat J, Heo H, . Immediate postpartum glucose tolerance testing in women with gestational diabetes: a pilot study. Am J Perinatol. 2017 Oct 01;34(12):1264–70. PMID: 618457473. Wrong population.28910846
227 Dinham GK, Henry A, Lowe SA, . Twin pregnancies complicated by gestational diabetes mellitus: a single centre cohort study. Diabet Med. 2016;33(12):1659–67. PMID: 26802478. Wrong study design.26802478
228 Disse E, Graeppi-Dulac J, Joncour-Mills G, . Heterogeneity of pregnancy outcomes and risk of LGA neonates in caucasian females according to IADPSG criteria for gestational diabetes mellitus. Diabetes Metab. 2013 Apr;39(2):132–8. PMID: 52314871. Wrong criteria KQ5.23182459
229 Djakovic I, Sabolovic Rudman S, Gall V, . Do changing diagnostic criteria for gestational diabetes influence pregnancy outcome? Acta Clin Croat. 2016;55(3):422–7. PMID: 29045107. Wrong study design.29045107
230 Donovan BM, Breheny PJ, Robinson JG, . Development and validation of a clinical model for preconception and early pregnancy risk prediction of gestational diabetes mellitus in nulliparous women. PLoS ONE. 2019;14(4):e0215173. PMID: 30978258. Wrong outcome.30978258
231 Donovan BM, Breheny PJ, Robinson JG, . Development and validation of a clinical model for preconception and early pregnancy risk prediction of gestational diabetes mellitus in nulliparous women. PLoS ONE [Electronic Resource]. 2019;14(4):e0215173. PMID: 30978258. Wrong population (KQ4 development cohort).30978258
232 Donovan LE, Edwards AL, Savu A, . Population-level outcomes with a 2-step approach for gestational diabetes screening and diagnosis. Can J Diabetes. 2017;41(6):596–602. PMID: 28454899. Wrong criteria KQ5.28454899
233 Draffin CR, Alderdice FA, McCance DR, . Impact of an educational DVD on anxiety and glycaemic control in women diagnosed with gestational diabetes mellitus (GDM): A randomised controlled trial. Diabetes Res Clin. 2017;126:164–71. PMID: 28258027. Wrong study design.28258027
234 Du C, Kong F. A prospective study of maternal plasma concentrations of retinol-binding protein 4 and risk of gestational diabetes mellitus. Ann Nutr Metab. 2019;74(1):1–8. PMID: 30428456. Wrong outcome.30428456
235 Dubey D, Kunwar S, Gupta U. Mid-trimester glycosylated hemoglobin levels (HbA1c) and its correlation with oral glucose tolerance test. J Obstet Gynaecol Res. 2019;45(4):817–23. PMID: 30618078. Wrong outcome.30618078
236 Duenas-Garcia OF, Ramirez-Torres A, Diaz-Sotomayor M, . Perinatal outcomes of patients with gestational diabetes diagnosed by three different methods. Ginecol Obstet Mex. 2011 Jul;79(7):411–8. PMID: 362136302. Wrong language.21966835
237 Dunlevy F, Tadesse W, Daly S, . SUN-P008: dietary structured group education is effective and efficient in treating gestational diabetes mellitus. Clin Nutr. 2016;35:S47–S8. doi: 10.1016/S0261-5614(16)30351-X. PMID: 118102119. Wrong comparison.
238 Duran A, Runkle I, Rubio MA, . Response to comment on Duran et al. Introduction of IADPSG criteria for the screening and diagnosis of gestational diabetes mellitus results in improved pregnancy outcomes at a lower cost in a large cohort of pregnant women: the St. Carlos gestational diabetes study. Diabetes Care 2014;37:2442-2450. Diabetes Care. 2015;38(4):e69–70. PMID: 25805880. Not primary research.25805880
239 Duran A, Saenz S, Torrejon MJ, . Introduction of IADPSG criteria for the screening and diagnosis of gestational diabetes mellitus results in improved pregnancy outcomes at a lower cost in a large cohort of pregnant women: the St. Carlos gestational diabetes study. Diabetes Care. 2014;37(9):2442–50. PMID: 24947793. Wrong study design.24947793
240 Egan AM, Heerey AM, Carmody L, . The changing diagnosis of gestational diabetes mellitus: does anyone miss out? Diabetes Res Clin. 2014;106(3):e53–5. PMID: 25467618. Wrong criteria KQ5.25467618
241 Ehmann DMT, Hickman PE, Potter JM. Are the changes in diagnostic criteria for gestational diabetes mellitus reflected in perinatal outcomes? A retrospective assessment. Aust NZ J Obstet Gynaecol. 2019 PMID: 626609406. Wrong criteria KQ5.
242 Ehrlich SF, Crites YM, Hedderson MM, . The risk of large for gestational age across increasing categories of pregnancy glycemia. Am J Obstet Gynecol. 2011;204(3):240.e1–6. PMID: 21247550. Wrong outcome.21247550
243 Ehrlich SF, Hedderson MM, Xu F, . Diagnostic thresholds for pregnancy hyperglycemia, maternal weight status and the risk of childhood obesity in a diverse Northern California cohort using health care delivery system data. PLoS ONE [Electronic Resource]. 2019;14(5):e0216897. PMID: 31075132. Wrong comparison other.31075132
244 Ekeroma AJ, Chandran GS, McCowan L, . Impact of using the International Association of Diabetes and Pregnancy study groups criteria in South Auckland: prevalence, interventions and outcomes. Aust NZ J Obstet Gynaecol. 2015;55(1):34–41. PMID: 25307052. Wrong criteria KQ5.25307052
245 Ellenberg A, Sarvilinna N, Gissler M, . New guidelines for screening, diagnosing, and treating gestational diabetes - evaluation of maternal and neonatal outcomes in Finland from 2006 to 2012. Acta Obstet Gyn Scan. 2017;96(3):372–81. PMID: 27925166. Wrong study design.27925166
246 El-Shamy FF, El-Kholy SS, Labib M, . Ameliorative potential of acupressure on gestational diabetes mellitus: A randomized controlled trial. J Complement Integrat Med. 2018;16(1):21. PMID: 29927746. Wrong comparison.29927746
247 El-Shamy FF, El-Kholy SS, Labib M, . Ameliorative potential of acupressure on gestational diabetes mellitus: A randomized controlled trial. J Complement Integrat Med. 2019;16(1):0011. PMID: 622842095. Wrong comparison.
248 Erdem Celikel E, Kurt S, Toz E, . Mean platelet volume in diagnosis of gestational diabetes. J Exp Clin Med. 2013 Dec;30(4):291–4. PMID: 373160153. Wrong index test KQ4.
249 Erem C, Kuzu UB, Deger O, . Prevalence of gestational diabetes mellitus and associated risk factors in Turkish women: the Trabzon GDM study. Arch Med Sci. 2015;11(4):724–35. PMID: 26322083. Wrong study design.26322083
250 Erkamp JS, Geurtsen ML, Duijts L, . Associations of maternal early-pregnancy glucose concentrations with placental hemodynamics, blood pressure and gestational hypertensive disorders. Am J Hypertens. 2020;23:23. PMID: 32322887. Wrong intervention other.32322887
251 Eslamian L, Ramezani Z. Evaluation of a breakfast as screening test for the detection of gestational diabetes. Acta Med Iran. 2008;46(1):43–6. Wrong outcome.
252 Fadl H, Saeedi M, Montgomery S, . Changing diagnostic criteria for gestational diabetes in Sweden - a stepped wedge national cluster randomised controlled trial - the CDC4G study protocol. BMC Pregnancy Childbirth. 2019;19(1):398. PMID: 31675922. Protocol.31675922
253 Fahami F, Torabi S, Abdoli S. Prediction of glucose intolerance at 24-28 weeks of gestation by glucose and insulin level measurements in the first trimester. Iran J Nurs Midwifery Res. 2015;20(1):81–6. PMID: 25709695. Wrong comparison.25709695
254 Fairbrother N, Young AH, Zhang A, . The prevalence and incidence of perinatal anxiety disorders among women experiencing a medically complicated pregnancy. Arch Womens Ment Health. 2017 Apr 01;20(2):311–9. PMID: 613923493. Wrong population.28032213
255 Falcone V, Kotzaeridi G, Breil MH, . Early assessment of the risk for gestational diabetes mellitus: can fasting parameters of glucose metabolism contribute to risk prediction? Diabetes Metab. 2019;12:12. PMID: 30877716. Wrong index test KQ4.30877716
256 Falcone V, Kotzaeridi G, Breil MH, . Early Assessment of the Risk for Gestational Diabetes Mellitus: Can Fasting Parameters of Glucose Metabolism Contribute to Risk Prediction? Diabetes Metab. 2019;43(6):785–93. PMID: 30877716. Wrong outcome.30877716
257 Fan Y, Wang L, Zhang S, . Effects of obesity and a history of gestational diabetes on the risk of postpartum diabetes and hyperglycemia in Chinese women: Obesity, GDM and diabetes risk. Diabetes Res Clin Pract. 2019 October;156 (no pagination) PMID: 2002817628. Wrong population other.
258 Fang JH, Zhang SH, Yu XM, . Effects of quercetin and melatonin in pregnant and gestational diabetic women. Lat Am J Pharm. 2016;35(6):1420–5. PMID: 611205251. Wrong comparison.
259 Faroughi F, Charandabi SMA, Javadzadeh Y, . Effects of garlic pill on blood glucose level in borderline gestational diabetes mellitus: A randomized controlled trial. Iranian Red Crescent Med J. 2018 May;20(5):e60675. PMID: 623417938. Wrong intervention.
260 Farrar D, Fairley L, Wright J, . Evaluation of the impact of universal testing for gestational diabetes mellitus on maternal and neonatal health outcomes: a retrospective analysis. BMC Pregnancy Childb. 2014;14:317. PMID: 25199524. Wrong study design.25199524
261 Farrar D, Simmonds M, Bryant M, . Risk factor screening to identify women requiring oral glucose tolerance testing to diagnose gestational diabetes: A systematic review and meta-analysis and analysis of two pregnancy cohorts. PLoS ONE. 2017;12(4):e0175288. PMID: 28384264. Not primary research.28384264
262 Fassett MJ, Dhillon SH, Williams TR. Effects on perinatal outcome of treating women with 1 elevated glucose tolerance test value. Am J Obstet Gynecol. 2007 Jun;196(6):e1–4. doi: 10.1016/j.ajog.2007.03.017. PMID: 17547912. Wrong study design.17547912
263 Fatema N, Deeba F, Akter S, . CRP (C-reactive protein) in early pregnancy predictor for development of GDM. Mymensingh Med J. 2016;25(2):271–6. PMID: 27277359. Wrong index test KQ4.27277359
264 Fatima SS, Rehman R, Butt Z, . Screening of subclinical hypothyroidism during gestational diabetes in Pakistani population. J Matern-Fetal Neo M. 2016 02 Jul;29(13):2166–70. PMID: 605987087. Wrong intervention.
265 Fawole AO, Ezeasor C, Bello FA, . Effectiveness of a structured checklist of risk factors in identifying pregnant women at risk of gestational diabetes mellitus: a cross-sectional study. Niger J Clin Pract. 2014;17(4):495–501. PMID: 24909476. Wrong outcome.24909476
266 Feig D. Treatment of mild gestational diabetes did not prevent neonatal complications but reduced fetal overgrowth. ACP J Club. 2010;152(1):4p-p. PMID: 105121587. Not primary research.
267 Feldman RK. Gestational diabetes screening: The International Association of the Diabetes and Pregnancy Study Groups compared with Carpenter-Coustan screening. Baltimore, Maryland: Lippincott Williams & Wilkins; 2016. p. 965-. Wrong study design
268 Feng R, Liu L, Zhang YY, . Unsatisfactory glucose management and adverse pregnancy outcomes of gestational diabetes mellitus in the real world of clinical practice: a retrospective study. Chin Med J. 2018;131(9):1079–85. PMID: 29692380. Wrong study design.29692380
269 Ferreira AF, Rezende JC, Vaikousi E, . Maternal serum visfatin at 11-13 weeks of gestation in gestational diabetes mellitus. Clin Chem. 2011;57(4):609–13. PMID: 21325104. Wrong index test KQ4.21325104
270 Fiskin G, Sahin NH. Effect of diaphragmatic breathing exercise on psychological parameters in gestational diabetes: A randomised controlled trial. Eur J Integr Med. 2018 Oct;23:50–6. PMID: 2001145546. Wrong intervention.
271 Fong A, Serra AE, Gabby L, . Use of hemoglobin A1c as an early predictor of gestational diabetes mellitus. Am J Obstet Gynecol. 2014;211(6):641.e1–7. PMID: 24912095. Wrong study design.24912095
272 Fonseca A, Lopes J, Clode N. Glucose intolerance in the third trimester is not predictive of adverse outcomes. Int J Gynaecol. 2019;147(1):108–14. PMID: 31304595. Wrong population other.31304595
273 Froslie KF, Roislien J, Qvigstad E, . Shape information from glucose curves: functional data analysis compared with traditional summary measures. BMC Med Res Methodol. 2013;13:6. PMID: 23327294. Wrong study design.23327294
274 Fukatsu M, Takai Y, Matsunaga S, . Diagnosis and potential management of gestational diabetes mellitus using the international association of diabetes and pregnancy study groups criteria. J Obstet Gynaecol Res. 2017;43(2):272–80. PMID: 27987346. Wrong criteria KQ5.27987346
275 Gabbay-Benziv R, Doyle LE, Blitzer M, . First trimester prediction of maternal glycemic status. J Perinat Med. 2015;43(3):283–9. PMID: 25153547. Wrong population (KQ4 development cohort).25153547
276 Gandevani SB, Garshasbi A, Dibaj S. Cut-off value of 1-h, 50-g glucose challenge test for screening of gestational diabetes mellitus in an Iranian population. J Obstet Gynaecol Res. 2011 Jun;37(6):534–7. doi: 10.1111/j.1447-0756.2010.01400.x. PMID: 21375670. Wrong outcome.21375670
277 Gandhi P, Farrell T. Gestational diabetes mellitus (GDM) screening in morbidly obese pregnant women. Eur J Obstet Gynecol Reprod Biol. 2011;159(2):329–32. PMID: 21968030. Wrong study design.21968030
278 Gao S, Leng J, Liu H, . Development and validation of an early pregnancy risk score for the prediction of gestational diabetes mellitus in Chinese pregnant women. BMJ Open Diab Res Ca. 2020;8(1) PMID: 32327440. Wrong outcome.32327440
279 Gao XL, Wei YM, Yang HX, . Difference between 2 h and 3 h 75 g glucose tolerance test in the diagnosis of gestational diabetes mellitus (GDM): results from a national survey on prevalence of GDM. Front Med China. 2010;4(3):303–7. PMID: 21191836. Wrong criteria KQ5.21191836
280 Gariani K, Egloff M, Prati S, . Consequences of the adoption of the IADPSG versus Carpenter and Coustan Criteria to diagnose gestational diabetes: a before-after comparison. Exp Clin Endocr Diab. 2018;26:26. PMID: 30257263. Wrong study design.30257263
281 Gariani K, Egloff M, Prati S, . Consequences of the Adoption of the IADPSG versus Carpenter and Coustan Criteria to Diagnose Gestational Diabetes: A Before-After Comparison. Experimental & Clinical Endocrinology & Diabetes. 2019;127(7):473–6. PMID: 30257263. Wrong study design.30257263
282 Garshasbi A, Zamiry, A., Faghihzadeh, S., Naghizadeh, MM. Comparative evaluation of fasting plasma glucose and one hour 50-g glucose challenge test in screening gestational diabetes mellitus. J Zanjan Univ Med Sci Health Serv. 2010 Summer;18(71):1p–p. PMID: 104975474. Wrong language.
283 Gelaleti RB, Damasceno DC, Salvadori DMF, . Gene expression profile of whole blood cells differs in pregnant women with positive screening and negative diagnosis for gestational diabetes. BMJ Open Diabetes Res Care. 2016 Jan 01;4 (1):e000273. PMID: 614970942. Wrong study design.
284 Gelaye B, Clish CB, Denis M, . Metabolomics signatures associated with an oral glucose challenge in pregnant women. Diabetes Metab. 2019 Jan;45(1):39–46. PMID: 620367814. Wrong study design.29395809
285 Gentili P, Tambelli R, Abbruzzese S, . Proposed multidisciplinary psycho-educational protocol for women outpatients with previous gestational diabetes mellitus. G Ital di Diabetol e Metab. 2012 Jun;32(2):55–62. PMID: 364995038. Wrong language.
286 Gerome JM, Bucher LKM, Dogbey G. Effects of implementing International Association of Diabetes and Pregnancy study groups gestational diabetes screening on pregnancy outcomes at a small community teaching hospital. Clin Diabetes. 2017;35(2):84–9. PMID: 28442822. Wrong study design.28442822
287 Geurtsen ML, van Soest EEL, Voerman E, . High maternal early-pregnancy blood glucose levels are associated with altered fetal growth and increased risk of adverse birth outcomes. Diabetologia. 2019;62(10):1880–90. PMID: 31392381. Wrong intervention other.31392381
288 Ghio A, Seghieri G, Lencioni C, . 1-hour OGTT plasma glucose as a marker of progressive deterioration of insulin secretion and action in pregnant women. Int J Endocrinol. 2012;2012:460509. PMID: 364814974. Wrong intervention.22567007
289 Giannakou K, Evangelou E, Yiallouros P, . Risk factors for gestational diabetes: An umbrella review of meta-analyses of observational studies. PLoS ONE [Electronic Resource]. 2019;14(4):e0215372. PMID: 31002708. Not primary research.31002708
290 Glaharn P, Chumworathayi B, Kongwattanakul K, . Proportion of abnormal second 50-g glucose challenge test in gestational diabetes mellitus screening using the two-step method in high-risk pregnant women. Journal of Obstet Gynaecol. 2020;46(2):229–36. PMID: 31814200. Wrong population other.31814200
291 Goedegebure EAR, Koning SH, Hoogenberg K, . Pregnancy outcomes in women with gestational diabetes mellitus diagnosed according to the WHO-2013 and WHO-1999 diagnostic criteria: a multicentre retrospective cohort study. BMC Pregnancy Childb. 2018;18(1):152. PMID: 29747601. Wrong study design.29747601
292 Gojnic M, Stefanovic T, Perovic M, . Prediction of fetal macrosomia with ultrasound parameters and maternal glycemic controls in gestational diabetes mellitus. Clin Exp Obstet Gyn. 2012;39(4):512–5. PMID: 23444756. Wrong index test KQ4.23444756
293 Goldberg RJ, Ye C, Sermer M, . Predictors and clinical implications of a false negative glucose challenge test in pregnancy. J Obstet Gynaecol Can. 2013;35(10):889–98. PMID: 24165056. Wrong index test KQ4.24165056
294 Gopalakrishnan V, Singh R, Pradeep Y, . Evaluation of the prevalence of gestational diabetes mellitus in North Indians using the International Association of Diabetes and Pregnancy Study groups (IADPSG) criteria. J Postgrad Med. 2015;61(3):155–8. PMID: 26119433. Wrong comparison.26119433
295 Gopinath S, Ganesh BA, Manoj K, . Comparision between body mass index and abdominal obesity for the screening for diabetes in healthy individuals. Indian J Endocr Metab. 2012;16(Suppl 2):S441–2. PMID: 23565459. Wrong population.23565459
296 Gorgal R, Goncalves E, Barros M, . Gestational diabetes mellitus: a risk factor for non-elective cesarean section. J Obstet Gynaecol Res. 2012;38(1):154–9. PMID: 21995455. Other reason.21995455
297 Gorkem U, Togrul C, Arslan E. Relationship between elevated serum level of placental growth factor and status of gestational diabetes mellitus. J Matern-Fetal Neo M. 2019. PMID: 627009222. Wrong study design.
298 Grandi SM, Filion KB, Yoon S, . Cardiovascular Disease-Related Morbidity and Mortality in Women With a History of Pregnancy Complications. Circulation. 2019;139(8):1069–79. PMID: 30779636. Not primary research.30779636
299 Graves E, Hill DJ, Evers S, . The impact of abnormal glucose tolerance and obesity on fetal growth. J Diabetes Res. 2015;2015:847674. PMID: 25977929. Wrong population.25977929
300 Grewal E, Kansara S, Kachhawa G, . Prediction of gestational diabetes mellitus at 24 to 28 weeks of gestation by using first-trimester insulin sensitivity indices in Asian Indian subjects. Metab Clin Exp. 2012;61(5):715–20. PMID: 22146095. Wrong index test KQ4.22146095
301 Griffin ME, Coffey M, Johnson H, . Universal vs. risk factor-based screening for gestational diabetes mellitus: detection rates, gestation at diagnosis and outcome. Diabet Med. 2000 Jan;17(1):26–32. PMID: 10691156. Wrong population.10691156
302 Griffith RJ, Harding JE, McKinlay CJD, . Maternal glycemic control in diabetic pregnancies and neurodevelopmental outcomes in preschool aged children. A prospective cohort study. Early Hum Dev. 2019;130:101–8. PMID: 30716594. Wrong population other.30716594
303 Grotenfelt NE, Rono K, Eriksson JG, . Neonatal outcomes among offspring of obese women diagnosed with gestational diabetes mellitus in early versus late pregnancy. J Public Health. 2019;41(3):535–42. PMID: 30260419. Wrong comparison other.30260419
304 Gu Y, Lu J, Li W, . Joint Associations of Maternal Gestational Diabetes and Hypertensive Disorders of Pregnancy With Overweight in Offspring. Front Endocrinol. 2019;10:645. PMID: 31616376. Wrong population other.31616376
305 Gunderson EP, Quesenberry CP, Jr., Jacobs DR, Jr., . Longitudinal study of prepregnancy cardiometabolic risk factors and subsequent risk of gestational diabetes mellitus: The CARDIA study. Am J Epidemiol. 2010;172(10):1131–43. PMID: 20929958. Wrong outcome.20929958
306 Guo F, Yang S, Zhang Y, . Nomogram for prediction of gestational diabetes mellitus in urban, Chinese, pregnant women. BMC Pregnancy Childbirth. 2020;20(1):43. PMID: 31959134. Wrong outcome.31959134
307 Guo L, Ma J, Tang J, . Comparative Efficacy and Safety of Metformin, Glyburide, and Insulin in Treating Gestational Diabetes Mellitus: A Meta-Analysis. J Diabetes Res. 2019;2019:9804708. PMID: 31781670. Not primary research.31781670
308 Gupta Y, Kapoor D, Josyula LK, . A lifestyle intervention programme for the prevention of Type 2 diabetes mellitus among South Asian women with gestational diabetes mellitus [LIVING study]: protocol for a randomized trial. Diabet Med. 2019;36(2):243–51. PMID: 30368898. Wrong population other.30368898
309 Halbritter S, Fedrigo M, Hollriegl V, . Human breath gas analysis in the screening of gestational diabetes mellitus. Diabetes Technol Ther. 2012 Oct 01;14(10):917–25. PMID: 365771886. Wrong index test KQ4.22775148
310 Halkoaho A, Kavilo M, Pietila AM, . Does gestational diabetes affect women’s health-related quality of life after delivery? Eur J Obstet Gynecol Reprod Biol. 2010;148(1):40–3. PMID: 19883969. Wrong comparison KQ219883969
311 Hammoud NM, de Valk HW, Biesma DH, . Gestational diabetes mellitus diagnosed by screening or symptoms: does it matter? J Matern-Fetal Neo M. 2013;26(1):103–5. PMID: 22937897. Wrong population.22937897
312 Han S, Middleton PF, Bubner TK, . Women’s views on their diagnosis and management for borderline gestational diabetes mellitus. J Diabetes Res. 2015;2015:209215. PMID: 25785278. Wrong study design.25785278
313 Han Y, Zheng YL, Wu AM, . Effects of management in gestational diabetes mellitus with normal prepregnancy body mass index on pregnancy outcomes and placental ultrastructures: a prospective cohort study. Endocrine. 2016;54(3):691–9. PMID: 27481362. Wrong comparison.27481362
314 Hancerliogullari N, Celik HK, Karakaya BK, . Effect of prolonged fasting duration on 50 gram oral glucose challenge test in the diagnosis of gestational diabetes mellitus. Horm Metab Res. 2018;50(9):671–4. PMID: 30001567. Wrong comparison.30001567
315 Hancerliogullari N, Kansu-Celik H, Asli Oskovi-Kaplan Z, . Optimal maternal neck and waist circumference cutoff values for prediction of gestational diabetes mellitus at the first trimester in Turkish population; a prospective cohort study. Gynecol Endocrinol. 2020:1–4. PMID: 32274939. Wrong outcome.32274939
316 Hanna FW, Duff CJ, Shelley-Hitchen A, . Diagnosing gestational diabetes mellitus: implications of recent changes in diagnostic criteria and role of glycated haemoglobin (HbA1c). Clin Med. 2017;17(2):108–13. PMID: 28365618. Wrong criteria KQ5.28365618
317 Hansarikit J, Manotaya S. Sensitivity and specificity of modified 100-g oral glucose tolerance tests for diagnosis of gestational diabetes mellitus. J Med Assoc Thai. 2011;94(5):540–4. PMID: 21675441. Wrong index test KQ4.21675441
318 Hantoushzadeh S, Sheikh M, Bosaghzadeh Z, . The impact of gestational weight gain in different trimesters of pregnancy on glucose challenge test and gestational diabetes. Postgrad Med J. 2016;92(1091):520–4. PMID: 26929392. Wrong outcome.26929392
319 Hao M, Lin L. Fasting plasma glucose and body mass index during the first trimester of pregnancy as predictors of gestational diabetes mellitus in a Chinese population. Endocr J. 2017;64(5):561–9. PMID: 28420856. Wrong study design.28420856
320 Harper LM, Jauk V, Longo S, . Early gestational diabetes screening in obese women: a randomized controlled trial. American J Obstet. 2020;222(5):495.e1–.e8. PMID: 31926951. Duplicates.31926951
321 Harper LM, Jauk VC, Longo S, . 400: early Screening for Gestational Diabetes: what cutoffs should we use? American J Obstet. 2019;220(1):S272‐S3. doi: 10.1016/j.ajog.2018.11.421. PMID: CN-01726140. Duplicates.
322 Harper LM, Jauk VC, Longo S, . 6: early gestational diabetes screening in obese women: a randomized controlled trial. American J Obstet. 2019;220(1):S5‐S6. doi: 10.1016/j.ajog.2018.11.007. PMID: CN-01710595. Duplicates.
323 Harper LM, Mele L, Landon MB, . Carpenter-Coustan compared with national diabetes data group criteria for diagnosing gestational diabetes. Obstet Gynecol. 2016;127(5):893–8. PMID: 27054932. Wrong criteria KQ5.27054932
324 Harper LM, Xue Y, Szychowski JM, . 427: when should early screening for gestational diabetes occur? American journal of obstetrics and gynecology. 2020;222(1):S280‐S1. doi: 10.1016/j.ajog.2019.11.443. PMID: CN-02075421. Protocol.
325 Harrison CL, Lombard CB, East C, . Risk stratification in early pregnancy for women at increased risk of gestational diabetes. Diabetes Res Clin. 2015;107(1):61–8. PMID: 25444356. Wrong population (KQ4 development cohort).25444356
326 Harrison CL, Lombard CB, Teede HJ. Limiting postpartum weight retention through early antenatal intervention: the HeLP-her randomised controlled trial. Int J Behav Nutr Phy. 2014;11:134. PMID: 25358909. Wrong intervention.25358909
327 Hassan SM, Ejerish MA, Harba U. Effect of depression and anxiety on gestational diabetes in Babylon government. Int J Pharm Sci Res. 2017 Oct 01;8(10):4371–5. PMID: 618537200. Wrong comparison KQ2
328 Hassiakos D, Eleftheriades M, Papastefanou I, . Increased maternal serum interleukin-6 concentrations at 11 to 14 weeks of gestation in low risk pregnancies complicated with gestational diabetes mellitus: development of a prediction model. Horm Metab Res. 2016;48(1):35–41. PMID: 25565094. Wrong outcome.25565094
329 Hautala L, Englund E, Turkmen S. Performance of Variables in Screening for Gestational Diabetes. Eur J Endocrinol. 2019;15(2):101–5. PMID: 31616501. Wrong study design.31616501
330 Hayase M, Shimada M, Seki H. Sleep quality and stress in women with pregnancy-induced hypertension and gestational diabetes mellitus. J Aust Coll Midwives. 2014;27(3):190–5. PMID: 24881523. Wrong comparison KQ224881523
331 He F, He H, Liu W, . Neck circumference might predict gestational diabetes mellitus in Han Chinese women: A nested case-control study. J Diabetes Invest. 2017;8(2):168–73. PMID: 27589681. Wrong study design.27589681
332 He XJ, Dai RX, Tian CQ, . Neurodevelopmental outcome at 1 year in offspring of women with gestational diabetes mellitus. Gynecol Endocrinol. 2020:1–5. PMID: 32314619. Wrong population other.32314619
333 Herath M, Weerarathna TP, Umesha D. Is non fasting glucose challenge test sensitive enough to diagnose gestational diabetes mellitus? Int Arch Med. 2015;8(1):A71. PMID: 604426266. Wrong intervention.
334 Hernandez TL. 9. A higher complex carbohydrate diet in gestational diabetes improves maternal metabolic outcomes and infant adiposity: a randomized study. Nurs Outlook. 2015;63(1):104. doi: 10.1016/j.outlook.2014.12.011. PMID: 103749787. Wrong comparison.
335 Herrera K, Brustman L, Foroutan J, . The importance of fasting blood glucose in screening for gestational diabetes. J Matern-Fetal Neo M. 2015 May 01;28(7):825–8. PMID: 604846071. Wrong comparison.
336 Hewage SS, Wu S, Neelakantan N, . Systematic review of effectiveness and cost-effectiveness of lifestyle interventions to improve clinical diabetes outcome measures in women with a history of GDM. Clin Nutr ESPEN. 2020;35:20–9. PMID: 31987117. Wrong outcome.31987117
337 Hidayat K, Zou SY, Shi BM. The influence of maternal body mass index, maternal diabetes mellitus, and maternal smoking during pregnancy on the risk of childhood-onset type 1 diabetes mellitus in the offspring: Systematic review and meta-analysis of observational studies. Obes Rev 019 August;20(8):1106–20. PMID: 627793401. Wrong outcome.
338 Hill JC, Krishnaveni GV, Annamma I, . Glucose tolerance in pregnancy in South India: relationships to neonatal anthropometry. Acta Obstet Gynecol Scand. 2005 Feb;84(2):159–65. doi: 10.1111/j.0001-6349.2005.00670.x. PMID: 15683377. Wrong population (KQ4 development cohort).15683377
339 Hillier TA, Ogasawara KK, Pedula KL, . Markedly different rates of incident insulin treatment based on universal gestational diabetes mellitus screening in a diverse HMO population. Am J Obstet Gynecol. 2013;209(5):440.e1–9. PMID: 23816844. Wrong comparison.23816844
340 Hinkle SN, Buck Louis GM, Rawal S, . A longitudinal study of depression and gestational diabetes in pregnancy and the postpartum period. Diabetologia. 2016 01 Dec;59(12):2594–602. PMID: 612270292. Wrong comparison KQ227640810
341 Hinkle SN, Tsai MY, Rawal S, . HbA measured in the first trimester of pregnancy and the association with gestational diabetes. Sci Rep. 2018;8(1):12249. PMID: 30116010. Wrong study design.30116010
342 Holt RI, Coleman MA, McCance DR. The implications of the new International Association of Diabetes and Pregnancy Study Groups (IADPSG) diagnostic criteria for gestational diabetes. Diabet Med. 2011;28(4):382–5. PMID: 21244472. Not primary research.21244472
343 Homko CJ, Deeb LC, Rohrbacher K, . Impact of a telemedicine system with automated reminders on outcomes in women with gestational diabetes mellitus. Diabetes Technol Ther. 2012 01 Jul;14(7):624–9. PMID: 365237883. Wrong comparison.22512287
344 Hong S, Lee SM, Kwak SH, . A Comparison of Predictive Performances between Old versus New Criteria in a Risk-Based Screening Strategy for Gestational Diabetes Mellitus. Diabetes Metab. 2020;13:13. PMID: 32431101. Wrong outcome.32431101
345 Horie I, Kawasaki E, Sakanaka A, . Efficacy of nutrition therapy for glucose intolerance in Japanese women diagnosed with gestational diabetes based on IADPSG criteria during early gestation. Diabetes Res Clin. 2015 Mar 01;107(3):400–6. PMID: 601681393. Wrong comparison.
346 Hossain N, Shah T, Rajar S, . Comparison of venous plasma glucose and capillary whole blood glucose in diagnosis of gestational diabetes: study from Karachi, Pakistan. Clin Epidemiol Glob Health. 2017 Dec;5(4):185–9. PMID: 614722584. Wrong index test KQ4.
347 Hosseini E, Janghorbani M, Aminorroaya A. Incidence, risk factors, and pregnancy outcomes of gestational diabetes mellitus using one-step versus two-step diagnostic approaches: A population-based cohort study in Isfahan, Iran. Diabetes Res Clin. 2018;140:288–94. PMID: 29649540. Wrong study design.29649540
348 Hou W, Meng X, Zhao A, . Development of multimarker diagnostic models from metabolomics analysis for gestational diabetes mellitus (GDM). Mol Cell Proteomics. 2018;17(3):431–41. PMID: 29282297. Wrong index test KQ4.29282297
349 Hromadnikova I, Kotlabova K, Dvorakova L, . Diabetes Mellitus and Cardiovascular Risk Assessment in Mothers with a History of Gestational Diabetes Mellitus Based on Postpartal Expression Profile of MicroRNAs Associated with Diabetes Mellitus and Cardiovascular and Cerebrovascular Diseases. J Mol Sci. 2020;21(7):31. PMID: 32244558. Wrong population other.32244558
350 Hu Z, Tylavsky FA, Han JC, . Maternal metabolic factors during pregnancy predict early childhood growth trajectories and obesity risk: the CANDLE Study. Int J Obes. 2019;43(10):1914–22. PMID: 30705389. Wrong population other.30705389
351 Huang T, Rifas-Shiman SL, Ertel KA, . Pregnancy hyperglycaemia and risk of prenatal and postpartum depressive symptoms. Paediatr Perinat Epidemiol. 2015 Jul;29(4):281–9. doi: 10.1111/ppe.12199. PMID: 26058318. Wrong comparison KQ226058318
352 Hughes RC, Williman J, Gullam JE. Universal HbA1c measurement in early pregnancy to detect type 2 diabetes reduces ethnic disparities in antenatal diabetes screening: a population-based observational study. PLoS ONE. 2016;11(6):e0156926. PMID: 27272760. Wrong index test KQ4.27272760
353 Huhn EA, Fischer T, Gobl CS, . Screening of gestational diabetes mellitus in early pregnancy by oral glucose tolerance test and glycosylated fibronectin: study protocol for an international, prospective, multicentre cohort trial. BMJ Open. 2016;6(10):e012115. PMID: 27733413. Wrong study design.27733413
354 Huhn EA, Massaro N, Streckeisen S, . Fourfold increase in prevalence of gestational diabetes mellitus after adoption of the new International Association of Diabetes and Pregnancy Study Groups (IADPSG) criteria. J Perinat Med. 2017;45(3):359–66. PMID: 27508951. Wrong study design.27508951
355 Hui AL, Sevenhuysen G, Harvey D, . Stress and anxiety in women with gestational diabetes during dietary management. Diabetes Educ. 2014;40(5):668–77. PMID: 24874692. Wrong comparison KQ224874692
356 Hulman A. Comment on Scholtens et al. Hyperglycemia and Adverse Pregnancy Outcome Follow-up Study (HAPO FUS): Maternal Glycemia and Childhood Glucose Metabolism. Diabetes Care 2019;42:381-392. Diabetes Care. 2019;42(7):e127. PMID: 31221712. Wrong study design.31221712
357 Hulman A. Comment on Scholtens et al. Hyperglycemia and Adverse Pregnancy Outcome Follow-up Study (HAPO FUS): Maternal Glycemia and Childhood Glucose Metabolism. Diabetes Care 2019;42:381-392. 2019;42:e127–e. doi: 10.2337/dc19-0650. PMID: 137101845. Language: English. Entry Date: 20191223. Revision Date: 20191226. Publication Type: letter. Wrong study design.
358 Hung CH, Yu CY, Huang MC. The perinatal biopsychosocial consequences of various levels of gestational hyperglycemia. Clin Nurs Res. 2018:1054773818769210. PMID: 29631415. Wrong comparison KQ229631415
359 Hung TH, Hsieh TT. The effects of implementing the International Association of Diabetes and Pregnancy Study Groups criteria for diagnosing gestational diabetes on maternal and neonatal outcomes. PLoS ONE. 2015;10(3):e0122261. PMID: 25756838. Wrong study design.25756838
360 Huvinen E, Eriksson JG, Stach-Lempinen B, . Heterogeneity of gestational diabetes (GDM) and challenges in developing a GDM risk score. Acta Diabetol. 2018;55(12):1251–9. PMID: 30221319. Wrong comparison.30221319
361 Huynh J, Ratnaike S, Bartalotta C, . Challenging the glucose challenge test. Aust NZ J Obstet Gynaecol. 2011;51(1):22–5. PMID: 21299504. Wrong study design.21299504
362 Ignell C, Berntorp K. Evaluation of the relationship between capillary and venous plasma glucose concentrations obtained by the HemoCue Glucose 201+ system during an oral glucose tolerance test. Scand J Clin Lab Inv. 2011;71(8):670–5. PMID: 21961814. Wrong index test KQ4.21961814
363 Iimura Y, Matsuura M, Yao Z, . Lack of predictive power of plasma lipids or lipoproteins for gestational diabetes mellitus in Japanese women. J Diabetes Invest. 2015;6(6):640–6. PMID: 26543537. Wrong index test KQ4.26543537
364 Ikenoue S, Miyakoshi K, Saisho Y, . Clinical impact of women with gestational diabetes mellitus by the new consensus criteria: two year experience in a single institution in Japan. Endocr J. 2014;61(4):353–8. PMID: 24430729. Wrong comparison.24430729
365 Inan C, Agir MC, Sagir FG. Efficacy of 50-G glucose challenge test in the diagnosis of gestational diabetes mellitus. Haseki Tip Bulteni. 2014;52(3):181–6. PMID: 600062547. Wrong outcome.
366 International Association of D, Pregnancy Study Groups Consensus P, Metzger BE, . International association of diabetes and pregnancy study groups recommendations on the diagnosis and classification of hyperglycemia in pregnancy. Diabetes Care. 2010;33(3):676–82. PMID: 20190296. Not primary research.20190296
367 Iwama N, Sugiyama T, Metoki H, . Difference in the prevalence of gestational diabetes mellitus according to gestational age at 75-g oral glucose tolerance test in Japan: the Japan assessment of gestational diabetes mellitus screening trial. J Diabetes Invest. 2019;21:21. PMID: 30897272. Wrong study design.30897272
368 Iwama N, Sugiyama T, Metoki H, . Difference in the prevalence of gestational diabetes mellitus according to gestational age at 75-g oral glucose tolerance test in Japan: The Japan Assessment of Gestational Diabetes Mellitus Screening trial. J Diabetes Investig. 2019;10(6):1576–85. PMID: 30897272. Wrong outcome.30897272
369 Jagiello KP, Azulay Chertok IR. Women’s experiences with early breastfeeding after gestational diabetes. J Obst Gyn Neo. 2015 Jul 01;44(4):500–9. PMID: 611472646. Wrong study design.
370 Jakobi P, Weissman A, Egozi J, . Perinatal significance of diagnosing glucose intolerance during pregnancy with portable glucose meter. J Perinat Med. 2003;31(2):140–5. doi: 10.1515/jpm.2003.019. PMID: 12747230. Wrong index test KQ4.12747230
371 Jamilian M, Samimi M, Kolahdooz F, . Omega-3 fatty acid supplementation affects pregnancy outcomes in gestational diabetes: A randomized, double-blind, placebo-controlled trial. J Matern-Fetal Neo M. 2016 Feb 16;29(4):669–75. PMID: 607347368. Wrong intervention.
372 Jawa A, Raza F, Qamar K, . Gestational diabetes mellitus is rare in primigravida Pakistani women. Indian J Endocr Metab. 2011;15(3):191–3. PMID: 21897896. Wrong outcome.21897896
373 Jensen DM, Molsted-Pedersen L, Beck-Nielsen H, . Screening for gestational diabetes mellitus by a model based on risk indicators: a prospective study. Am J Obstet Gynecol. 2003 Nov;189(5):1383–8. doi: 10.1067/s0002-9378(03)00601-x. PMID: 14634573. Wrong outcome.14634573
374 Jensen M, Lozeau A-M. Screening for gestational diabetes: are there differences in outcomes using a cutoff of 130 or 140 mg/dL for the 1-hour glucose challenge test? Evid Based Pract. 2011;14(10):7-. PMID: 104697154. Not primary research.
375 Jenum AK, Morkrid K, Sletner L, . Impact of ethnicity on gestational diabetes identified with the WHO and the modified International Association of Diabetes and Pregnancy Study Groups criteria: a population-based cohort study. Eur J Endocrinol. 2012;166(2):317–24. PMID: 22108914. Wrong outcome.22108914
376 Jenum AK, Sletner L, Voldner N, . The STORK Groruddalen research programme: A population-based cohort study of gestational diabetes, physical activity, and obesity in pregnancy in a multiethnic population. Rationale, methods, study population, and participation rates. Scand J Public Health. 2010;38(5 Suppl):60–70. PMID: 21062840. Wrong outcome.21062840
377 Jesmin S, Akter S, Akashi H, . Screening for gestational diabetes mellitus and its prevalence in Bangladesh. Diabetes Res Clin. 2014;103(1):57–62. doi: 10.1016/j.diabres.2013.11.024. PMID: 104016887. Language: English. Entry Date: 20141114. Revision Date: 20150710. Publication Type: Journal Article. Wrong study design.
378 Jiang S, Chipps D, Cheung WN, . Comparison of adverse pregnancy outcomes based on the new IADPSG 2010 gestational diabetes criteria and maternal body mass index. Aust NZ J Obstet Gynaecol. 2017;57(5):533–9. PMID: 28421604. Wrong criteria KQ5.28421604
379 Jo H, Eckel SP, Chen JC, . Associations of gestational diabetes mellitus with residential air pollution exposure in a large Southern California pregnancy cohort. Environ Int. 2019;130:104933. PMID: 31234004. Wrong outcome.31234004
380 Jo H, Eckel SP, Chen JC, . Gestational diabetes mellitus, prenatal air pollution exposure, and autism spectrum disorder. Environ Int. 2019;133(Pt A):105110. PMID: 31610366. Wrong intervention other.31610366
381 Jovanovic L, Liang Y, Weng W, . Trends in the incidence of diabetes, its clinical sequelae, and associated costs in pregnancy. Diabetes Metab Res. 2015;31(7):707–16. PMID: 25899622. Wrong comparison.25899622
382 Jovanovic L. Comment on Pareek et al. Enhanced Predictive Capability of a 1-Hour Oral Glucose Tolerance Test: A Prospective Population-Based Cohort Study. Diabetes Care 2018;41:171-177. Diabetes Care. 2018;41(5):e81. PMID: 29678871. Not primary research.29678871
383 Joy S, Roman A, Istwan N, . The effect of maternal obesity on pregnancy outcomes of women with gestational diabetes controlled with diet only, glyburide, or insulin. Am J Perinatol. 2012;29(8):643–8. PMID: 22644829. Wrong comparison.22644829
384 Jung YJ, Kwon JY, Cho HY, . Comparison of the performance of screening test for gestational diabetes in singleton versus twin pregnancies. Obstet Gynecol Sci. 2015;58(6):439–45. PMID: 26623406. Wrong study design.26623406
385 Kalamegham R, Nuwayhid BS, Mulla ZD. Prevalence of gestational fasting and postload single dysglycemia in Mexican-American women and their relative significance in identifying carbohydrate intolerance. Am J Perinatol. 2010;27(9):697–704. PMID: 20387187. Wrong study design.20387187
386 Kalter-Leibovici O, Freedman LS, Olmer L, . Screening and diagnosis of gestational diabetes mellitus: critical appraisal of the new International Association of Diabetes in Pregnancy Study Group recommendations on a national level. Diabetes Care. 2012;35(9):1894–6. PMID: 22787173. Wrong outcome.22787173
387 Kanai Y, Kamoda T, Saito M, . Cord blood insulin-like growth factor (IGF)-1, IGF-binding proteins and adiponectin, and birth size in offspring of women with mild gestational diabetes. Early Hum Dev. 2016;93:39–42. PMID: 26765797. Wrong criteria KQ5.26765797
388 Kang S, Kim MH, Kim MY, . Progression to Gestational Diabetes Mellitus in Pregnant Women with One Abnormal Value in Repeated Oral Glucose Tolerance Tests. Diabetes Metab. 2019;28:28. PMID: 30877710. Wrong index test KQ4.30877710
389 Kang S, Kim MH, Kim MY, . Progression to Gestational Diabetes Mellitus in Pregnant Women with One Abnormal Value in Repeated Oral Glucose Tolerance Tests. Diabetes Metab. 2019;43(5):607–14. PMID: 30877710. Wrong population other.30877710
390 Kang X, Liang Y, Wang S, . Prediction model comparison for gestational diabetes mellitus with macrosomia based on risk factor investigation. J Matern Fetal Neonatal Med. 2019:1–10. PMID: 31575301. Wrong population (KQ4 development cohort).31575301
391 Kansu-Celik H, Ozgu-Erdinc AS, Kisa B, . Maternal serum glycosylated hemoglobin and fasting plasma glucose predicts gestational diabetes at the first trimester in Turkish women with a low-risk pregnancy and its relationship with fetal birth weight; a retrospective cohort study. J Matern Fetal Neonatal Med. 2019:1–8. PMID: 31370710. Wrong study design.31370710
392 Kansu-Celik H, Ozgu-Erdinc AS, Kisa B, . Prediction of gestational diabetes mellitus in the first trimester: comparison of maternal fetuin-A, N-terminal proatrial natriuretic peptide, high-sensitivity C-reactive protein, and fasting glucose levels. Arch Endocrinol Metab. 2019;25:25. PMID: 31038593. Wrong outcome.31038593
393 Kansu-Celik H, Ozgu-Erdinc AS, Kisa B, . Prediction of gestational diabetes mellitus in the first trimester: comparison of maternal fetuin-A, N-terminal proatrial natriuretic peptide, high-sensitivity C-reactive protein, and fasting glucose levels. Arch Endocrinol Metab. 2019;63(2):121–7. PMID: 31038593. Wrong outcome.31038593
394 Kansu-Celik H, Ozgu-Erdinc AS, Kisa-Karakaya B, . Fasting and post-prandial plasma glucose screening for gestational diabetes mellitus. East Mediterr Health J. 2019;25(4):282–9. PMID: 31210349. Wrong comparison other.31210349
395 Karamali M, Dadkhah F, Sadrkhanlou M, . Effects of probiotic supplementation on glycaemic control and lipid profiles in gestational diabetes: A randomized, double-blind, placebo-controlled trial. Diabetes Metab. 2016 01 Sep;42(4):234–41. PMID: 610439521. Wrong intervention.27209439
396 Karcaaltincaba D, Altinbas S, Akyol M, . The relationship between markedly elevated glucose challenge test results and the rate of gestational diabetes mellitus and gestational impaired glucose tolerance. Ann Saudi Med. 2012;32(4):391–6. PMID: 22705610. Wrong study design.22705610
397 Karcaaltincaba D, Buyukkaragoz B, Kandemir O, . Gestational diabetes and gestational impaired glucose tolerance in 1653 teenage pregnancies: prevalence, risk factors and pregnancy outcomes. J Pediatr Adolesc Gynecol. 2011;24(2):62–5. PMID: 20709580. Wrong outcome.20709580
398 Kashi Z, Bourzouei SA, O, Moslemizadeh N, . Diagnostic value of fasting plasma glucose in screening of gestational diabetes mellitus. Int J Endrocrinol Metab. 2007;1:1–4. Wrong outcome.
399 Kattini R, Hummelen R, Kelly L. Early Gestational Diabetes Mellitus Screening With Glycated Hemoglobin: A Systematic Review. J Obstet Gynaecol Can: JOGC. 2020;05:05. PMID: 32268994. Not primary research.32268994
400 Kattini R, Poirier JN, Kelly LF, . Outcomes of Pregnancies Affected by Gestational Diabetes and Type 2 Diabetes in a Rural First Nations Obstetrical Program in Northwest Ontario. Can J Diabetes. 2020 PMID: 2005224945. Wrong comparison other.
401 Kaul P, Bowker SL, Savu A, . Association between maternal diabetes, being large for gestational age and breast-feeding on being overweight or obese in childhood. Diabetologia. 2019 01 Feb;62(2):249–58. Wrong population other.30421138
402 Kayemba-Kay’s S, Peters C, Geary MP, . Maternal hyperinsulinism and glycaemic status in the first trimester of pregnancy are associated with the development of pregnancy-induced hypertension and gestational diabetes. Eur J Endocrinol. 2013;168(3):413–8. PMID: 23243013. Wrong outcome.23243013
403 Kazandi M, Hasdemir PS, Zeybek B, . Placental growth factor: A putative screening test for gestational diabetes mellitus in first trimester. CEOG. 2010;37(4):322–3. PMID: 360177376. Wrong index test KQ4.
404 Kebapcilar L, Kebapcilar AG, Ilhan TT, . Is the Mean Platelet Volume a Predictive Marker of a Low Apgar Score and Insulin Resistance in Gestational Diabetes Mellitus? A Retrospective Case-Control Study. JCDR. 2016;10(10):OC06–OC10. PMID: 27891368. Wrong index test KQ4.27891368
405 Keskin FE, Ozyazar M, Pala AS, . Evaluation of cognitive functions in gestational diabetes mellitus. Exp Clin Endocr Diab. 2015;123(4):246–51. PMID: 25868060. Wrong comparison KQ225868060
406 Khalifeh A, Eckler R, Felder L, . One-step versus two-step diagnostic testing for gestational diabetes: a randomized controlled trial. J Matern Fetal Neonatal Med. 2020;33(4):612–7. PMID: 29985079. Duplicates.29985079
407 Khan S, Bal H, Khan ID, . Evaluation of the diabetes in pregnancy study group of India criteria and Carpenter-Coustan criteria in the diagnosis of gestational diabetes mellitus. Turkish Journal of Obstet Gynecol. 2018;15(2):75–9. PMID: 29971182. Wrong index test KQ4.29971182
408 Khan SH, Manzoor R, Baig AH, . Glucose Tolerance versus HbA1c Results as Depictive of Gestational Diabetes Mellitus. Jcpsp, J Coll Physicians Surg Pak. 2019;29(4):333–6. PMID: 30925955. Wrong outcome.30925955
409 Khan SH, Manzoor R, Baig AH, . Glucose Tolerance versus HbA1c Results as Depictive of Gestational Diabetes Mellitus. Jcpsp, J Coll Physicians Surg Pak. 2019;29(4):333–6. PMID: 30925955. Wrong outcome.30925955
410 KhushBakht D, Mazhar S, Bhalli A, . Correlation Between Neck Circumference and Gestational Diabetes Mellitus and Associated Risk Factors During Pregnancy. Cureus. 2018;10(5):e2699. PMID: 30062073. Wrong population (KQ4 development cohort).30062073
411 Kim C, Brawarsky P, Jackson RA, . Changes in Health Status Experienced by Women with Gestational Diabetes and Pregnancy-Induced Hypertensive Disorders. 2005;14(8):729–36. doi: 10.1089/jwh.2005.14.729. PMID: 16232105. Wrong comparison KQ216232105
412 Kim C, Herman WH, Cheung NW, . Comparison of hemoglobin A<inf>1c</inf> with fasting plasma glucose and 2-h postchallenge glucose for risk stratification among women with recent gestational diabetes mellitus. Diabetes Care. 2011 Sep;34(9):1949–51. PMID: 365152204. Wrong population.21750276
413 Kim MH, Kwak SH, Kim SH, . Pregnancy Outcomes of Women Additionally Diagnosed as Gestational Diabetes by the International Association of the Diabetes and Pregnancy Study Groups Criteria. Diabetes Metab. 2019;43(6):766–75. PMID: 30877713. Duplicates.30877713
414 King NMA, Chambers J, O’Donnell K, . Anxiety, depression and saliva cortisol in women with a medical disorder during pregnancy. Arch Womens Ment Health. 2010 Aug;13(4):339–45. PMID: 50776389. Wrong comparison KQ220101421
415 Kirbas A, Daglar K, Danisman N. Evaluation of inflammatory related markers in gestational diabetes mellitus. J Clin Anal Med. 2016 Jul;7(4):501–4. PMID: 620991079. Wrong study design.
416 Kirbas A, Daglar K, Timur H, . Maternal circulating levels of irisin in intrahepatic cholestasis of pregnancy. J Matern-Fetal Neo M. 2016 01 Nov;29(21):3483–7. PMID: 607882470. Wrong intervention.
417 Klara Feldman R, Tieu RS, Yasumura L. Gestational diabetes screening the international association of the diabetes and pregnancy study groups compared with carpenter-coustan screening. Obstet Gynecol. 2016;127(1):10–7. PMID: 607208933. Wrong study design.26646142
418 Kodama Y, Sameshima H, Ohashi M, . Impact of new gestational diabetes mellitus criteria on stillbirth: a regional population-based study in Japan. J Obstet Gynaecol Res. 2013;39(7):1242–5. PMID: 23803007. Wrong criteria KQ5.23803007
419 Koivunen S, Torkki A, Bloigu A, . Towards national comprehensive gestational diabetes screening - consequences for neonatal outcome and care. Acta Obstet Gyn Scan. 2017;96(1):106–13. PMID: 27682191. Wrong study design.27682191
420 Kong JM, Lim K, Thompson DM. Evaluation of the International Association of the Diabetes In Pregnancy Study Group new criteria: gestational diabetes project. Can J Diabetes. 2015;39(2):128–32. PMID: 25523181. Wrong study design.25523181
421 Kong L, Nilsson IAK, Brismar K, . Associations of Different Types of Maternal Diabetes and Body Mass Index With Offspring Psychiatric Disorders. JAMA Network Open. 2020;3(2):e1920787. PMID: 32031649. Wrong population other.32031649
422 Koning SH, van Zanden JJ, Hoogenberg K, . New diagnostic criteria for gestational diabetes mellitus and their impact on the number of diagnoses and pregnancy outcomes. Diabetologia. 2018;61(4):800–9. PMID: 29167927. Wrong criteria KQ5.29167927
423 Koninger A, Mathan A, Mach P, . Is Afamin a novel biomarker for gestational diabetes mellitus? A pilot study. Reprod Biol Endocrinol. 2018 27 Mar;16 (1) (no pagination)(30) PMID: 621399496. Wrong index test KQ4.29587878
424 Kopec JA, Ogonowski J, Rahman MM, . Patient-reported outcomes in women with gestational diabetes: a longitudinal study. Int JBehav Med. 2015;22(2):206–13. PMID: 25106672. Wrong comparison KQ225106672
425 Korpi-Hyovalti EA, Laaksonen DE, Schwab US, . Feasibility of a lifestyle intervention in early pregnancy to prevent deterioration of glucose tolerance. BMC Public Health. 2011;11:179. PMID: 21429234. Wrong population.21429234
426 Kosus A, Kosus N, Turhan N. What is the best cut-offpoint for screening gestational diabetes in Turkish women? Turk J Med Sci. 2012;42(3):523–31. PMID: 364626270. Wrong study design.
427 Kosus A, Kosus N, Turhan NO. Gestational diabetes: comparision of the carpenter and the coustan thresholds with the new thresholds of Turkish women and implications of variations in diagnostic criteria. J Matern-Fetal Neo M. 2012;25(6):616–22. PMID: 21801122. Wrong index test KQ4.21801122
428 Kouhkan A, Khamseh ME, Moini A, . Diagnostic Accuracy of Body Mass Index and Fasting Glucose for The Prediction of Gestational Diabetes Mellitus after Assisted Reproductive Technology Int J Fertil Steril. 2019;13(1):32–7. PMID: 30644242. Wrong study design.30644242
429 Kozuma Y, Inoue S, Horinouchi T, . Prognosis of Pregnant Women with One Abnormal Value on 75g OGTT. Kurume Med J. 2015;61(3-4):59–64. PMID: 25810420. Wrong comparison.25810420
430 Kragelund Nielsen K, Damm P, Kapur A, . Risk Factors for Hyperglycaemia in Pregnancy in Tamil Nadu, India. PLoS ONE [Electronic Resource]. 2016;11(3):e0151311. PMID: 26991305. Wrong population (KQ4 development cohort).26991305
431 Krejci H, Simjak P, Anderlova K, . The incidence of gestational diabetes mellitus before and after the introduction of HAPO diagnostic criteria. Ceska Gynekologie. 2019;84(6):404–11. PMID: 31948247. Wrong study design.31948247
432 Krendl E, Mustafa ME. Oral glucose tolerance test within the scope of prenatal care: Evaluation 2010-2012. LaboratoriumsMedizin. 2015;38(2) PMID: 612381405. Wrong study design.
433 Krzeczkowski JE, Lau A, Fitzpatrick J, . Maternal Metabolic Complications in Pregnancy and Offspring Behavior Problems at 2 Years of Age. Matern Child Health J. 2019;23(6):746–55. PMID: 30600520. Wrong population other.30600520
434 Kubo A, Ferrara A, Brown SD, . Perceived psychosocial stress and gestational weight gain among women with gestational diabetes. PLoS ONE [Electronic Resource]. 2017;12(3):e0174290. PMID: 28350836. Wrong comparison KQ228350836
435 Kumpulainen SM, Girchenko P, Lahti-Pulkkinen M, . Maternal early pregnancy obesity and depressive symptoms during and after pregnancy. Psychol Med. 2018;48(14):2353–63. PMID: 29338797. Wrong comparison KQ229338797
436 Kumru P, Arisoy R, Erdogdu E, . Prediction of gestational diabetes mellitus at first trimester in low-risk pregnancies. Taiwan J Obstet Gynecol. 2016;55(6):815–20. PMID: 28040126. Wrong population (KQ4 development cohort).28040126
437 Kuo CH, Chen SC, Fang CT, . Screening gestational diabetes mellitus: The role of maternal age. PLoS ONE [Electronic Resource]. 2017;12(3):e0173049. PMID: 28296923. Wrong index test KQ4.28296923
438 Kurbasic A, Fraser A, Mogren I, . Maternal Hypertensive Disorders of Pregnancy and Offspring Risk of Hypertension: A Population-Based Cohort and Sibling Study. Am J Hypertens. 2019;32(4):331–4. PMID: 30475953. Wrong population other.30475953
439 Kwik M, Seeho SK, Smith C, . Outcomes of pregnancies affected by impaired glucose tolerance. Diabetes Res Clin Pract. 2007 Aug;77(2):263–8. doi: 10.1016/j.diabres.2006.12.004. PMID: 17275121. Wrong population.17275121
440 Kwon SS, Kwon JY, Park YW, . HbA1c for diagnosis and prognosis of gestational diabetes mellitus. Diabetes Res Clin. 2015;110(1):38–43. PMID: 26344325. Wrong study design.26344325
441 Laafira A, White SW, Griffin CJ, . Impact of the new IADPSG gestational diabetes diagnostic criteria on pregnancy outcomes in Western Australia. Aust NZ J Obstet Gynaecol. 2016;56(1):36–41. PMID: 26293845. Wrong criteria KQ5.26293845
442 Lacaria E, Lencioni C, Russo L, . Selective screening for GDM in Italy: application and effectiveness of National Guidelines. J Matern-Fetal Neo M. 2015;28(15):1842–4. PMID: 25260129. Wrong comparison.25260129
443 Lachmann EH, Fox RA, Dennison RA, . Barriers to completing oral glucose tolerance testing in women at risk of gestational diabetes. Diabet Med. 2020;06:06. PMID: 32144795. Wrong outcome.32144795
444 Lahti-Pulkkinen M, Girchenko P, Tuovinen S, . Maternal Hypertensive Pregnancy Disorders and Mental Disorders in Children. Hypertension (0194911X). 2020;75(6):1429–38. doi: 10.1161/HYPERTENSIONAHA.119.14140. PMID: 143219612. Language: English. Entry Date: In Process. Revision Date: 20200519. Publication Type: Journal Article. Journal Subset: Biomedical. Wrong population other.
445 Landon MB, Mele L, Varner MW, . The relationship of maternal glycemia to childhood obesity and metabolic dysfunction‡. J Matern Fetal Neonatal Med. 2020;33(1):33–41. doi: 10.1080/14767058.2018.1484094. PMID: 139504992. Corporate Author: Eunice Kennedy Shriver National Institute of Child Health and Human Development Maternal-Fetal Medicine Units (MFMU) Network. Language: English. Entry Date: 20191122. Revision Date: 20200412. Publication Type: journal article. Journal Subset: Biomedical. Wrong comparison other.30021494
446 Landon MB, Spong CY, Thom E, . A multicenter, randomized trial of treatment for mild gestational diabetes. Obstet Gynecol Surv. 2010 Feb;65(2):69–70. PMID: 358199121. Wrong outcome.
447 Langer O, Yogev Y, Most O, . Gestational diabetes: the consequences of not treating. Am J Obstet Gynecol. 2005 Apr;192(4):989–97. doi: 10.1016/j.ajog.2004.11.039. PMID: 15846171. Wrong study design.15846171
448 Langer O. Obesity or diabetes: which is more hazardous to the health of the offspring? J Matern-Fetal Neo M. 2016;29(2):186–90. PMID: 25471171. Wrong criteria KQ5.25471171
449 Lao TT, Ho LF. Does maternal glucose intolerance affect the length of gestation in singleton pregnancies? J Soc Gynecol Investig. 2003 Sep;10(6):366–71. doi: 10.1016/s1071-5576(03)00115-1. PMID: 12969780. Wrong population.12969780
450 Lao TT, Tam KF. Gestational diabetes diagnosed in third trimester pregnancy and pregnancy outcome. Acta Obstet Gynecol Scand. 2001 Nov;80(11):1003–8. doi: 10.1034/j.1600-0412.2001.801106.x. PMID: 11703196. Wrong population.11703196
451 Lara-Cinisomo S, Swinford C, Massey D, . Diabetes, prenatal depression, and self-rated health in latina mothers. Diabetes Spectrum. 2018 01 May;31(2):159–65. PMID: 622618130. Wrong comparison KQ229773936
452 Lauring JR, Kunselman AR, Pauli JM, . Comparison of healthcare utilization and outcomes by gestational diabetes diagnostic criteria. J Perinat Med. 2018;46(4):401–9. PMID: 28753546. Wrong study design.28753546
453 Lavrentaki A, Thomas T, Subramanian A, . Increased risk of non-alcoholic fatty liver disease in women with gestational diabetes mellitus: A population-based cohort study, systematic review and meta-analysis. J Diabetes. 2019;33(10):107401. PMID: 31326267. Not primary research.31326267
454 Lee GT, Satyan MT, Grothusen JD, . A retrospective study comparing outcomes in a midwestern US population after introduction of IADPSG guidelines for gestational diabetes. J Matern-Fetal Neo M. 2019;32(1):67–72. PMID: 28835142. Wrong study design.28835142
455 Lee GT, Satyan MT, Grothusen JD, . A retrospective study comparing outcomes in a midwestern US population after introduction of IADPSG guidelines for gestational diabetes. J Matern Neonatal Med. 2019;32(1):67–72. PMID: 28835142. Wrong study design.28835142
456 Lee HJ, Norwitz E, Lee B. Relationship between threatened miscarriage and gestational diabetes mellitus. BMC Pregnancy Childb. 2018;18(1):318. PMID: 30081861. Wrong criteria KQ5.30081861
457 Lee IL, Purbrick B, Barzi F, . Cohort Profile: The Pregnancy and Neonatal Diabetes Outcomes in Remote Australia (PANDORA) Study. Int J Epidemiol. 2018;47(4):1045–6h. PMID: 29618003. Wrong population.29618003
458 Lee YQ, Collins CE, Gordon A, . The relationship between maternal obesity and diabetes during pregnancy on offspring kidney structure and function in humans: a systematic review. J Dev Orig Health Dis. 2019;10(4):406–19. PMID: 30411699. Not primary research.30411699
459 Lehmann R, Friedrich T, Krebiehl G, . Metabolic Profiles during an Oral Glucose Tolerance Test in Pregnant Women with and without Gestational Diabetes. Exp Clin Endocrinol Diabetes. 2015 01 Jul;123(7):433–8. PMID: 606666177. Wrong intervention.
460 Leng J, Wang P, Shao P, . Passive smoking increased risk of gestational diabetes mellitus independently and synergistically with prepregnancy obesity in Tianjin, China. Diabetes Metab. Res. Rev. 2017 01 Mar;33 (3) (no pagination)(e2861) PMID: 613777313. Wrong study design.
461 Lewandowski KC, Stojanovic N, Press M, . Raised concentrations of lipid peroxidation products (LPO) in pregnant women with impaired glucose tolerance. Ann Agric Environ Med. 2014;21(2):429–34. PMID: 373302846. Wrong index test KQ4.24959804
462 Li HY, Wei JN, Chuang LM, . Screening and diagnosis of diabetes in children and pregnant women. Diabetes Res Clin. 2014;106 Suppl 2:S288–90. PMID: 25550055. Not primary research.25550055
463 Li P, Lin S, Cui J, . First Trimester Neck Circumference as a Predictor for the Development of Gestational Diabetes Mellitus. Am J Med Sci. 2018;355(2):149–52. PMID: 29406042. Wrong study design.29406042
464 Li P, Lin S, Li L, . First-trimester fasting plasma glucose as a predictor of gestational diabetes mellitus and the association with adverse pregnancy outcomes. Pak J Med Sci. 2019;35(1):95–100. PMID: 30881404. Wrong study design.30881404
465 Li P, Lin S, Li L, . First-trimester fasting plasma glucose as a predictor of gestational diabetes mellitus and the association with adverse pregnancy outcomes. Pak J Med Sci. 2019;35(1):95–100. PMID: 30881404. Wrong study design.30881404
466 Li P, Yin Y, Lin S, . Utility of Pregestational Body Mass Index and Initial Fasting Plasma Glucose in Predicting Gestational Diabetes Mellitus. Am J Med Sci. 2016;351(4):420–5. PMID: 27079350. Wrong study design.27079350
467 Li S, Hou Y, Yan X, . Joint effects of folate and vitamin B<inf>12</inf> imbalance with maternal characteristics on gestational diabetes mellitus. J Diabetes. 2019 PMID: 626399358. Wrong study design.
468 Li Y, Zhao W, Shi R, . The diagnosis value of blood glucose combined glycosylated hemoglobin in gestational diabetes Int J Clin Exp Med. 2017 30 Mar;10(3):5344–8. PMID: 615036533. Wrong study design.
469 Li Z, Cheng Y, Wang D, . Incidence Rate of Type 2 Diabetes Mellitus after Gestational Diabetes Mellitus: A Systematic Review and Meta-Analysis of 170,139 Women. J Diabetes Res. 2020;2020:3076463. PMID: 32405502. Not primary research.32405502
470 Liao S, Mei J, Song W, . The impact of the International Association of Diabetes and Pregnancy Study Groups (IADPSG) fasting glucose diagnostic criterion on the prevalence and outcomes of gestational diabetes mellitus in Han Chinese women. Diabet Med. 2014;31(3):341–51. PMID: 24152069. Wrong criteria KQ5.24152069
471 LifeCycle Project-Maternal O, Childhood Outcomes Study G, Voerman E, . Association of Gestational Weight Gain With Adverse Maternal and Infant Outcomes. JAMA. 2019;321(17):1702–15. PMID: 31063572. Not primary research.31063572
472 Limruangrong P, Sinsuksai N, Ratinthorn A, . Effectiveness of a self-regulation program on diet control, exercise, and two-hour postprandial blood glucose levels in Thais with gestational diabetes mellitus. Pac Rim Int J Nurs Res. 2011;15(3):173–86. PMID: 104686041. Language: English. Entry Date: 20111104. Revision Date: 20150819. Publication Type: Journal Article. Wrong comparison.
473 Lindqvist M, Persson M, Lindkvist M, . No consensus on gestational diabetes mellitus screening regimes in Sweden: pregnancy outcomes in relation to different screening regimes 2011 to 2012, a cross-sectional study. BMC Pregnancy Childb. 2014;14:185. PMID: 24884711. Wrong study design.24884711
474 Lipscombe L. In high-risk pregnant women, an individualized lifestyle intervention reduced gestational diabetes mellitus. ACP J Club. 2015;163(12):1-. PMID: 111722808. Language: English. Entry Date: 20160114. Revision Date: 20160114. Publication Type: Article. Not primary research.
475 Lipscombe LL, Delos-Reyes F, Glenn AJ, . The Avoiding Diabetes After Pregnancy Trial in Moms Program: Feasibility of a Diabetes Prevention Program for Women With Recent Gestational Diabetes Mellitus. Can J Diabetes. 2019;43(8):613–20. PMID: 31669188. Wrong outcome.31669188
476 Liu CH, Tronick E. Rates and predictors of postpartum depression by race and ethnicity: results from the 2004 to 2007 New York City PRAMS survey (Pregnancy Risk Assessment Monitoring System). Matern Child Health J. 2013;17(9):1599–610. PMID: 23095945. Wrong comparison KQ223095945
477 Liu LY, Zhang YL, Li L. Risk factor of gestational diabetes among healthy chinese women: An observational study. Biomed Res (India). 2017;28(5):2126–30. PMID: 614854625. Wrong outcome.
478 Liu X, Chen Y, Zhou Q, . Utilization of International Association of Diabetes and Pregnancy Study Groups criteria vs. a two-step approach to screening for gestational diabetes mellitus in Chinese women with twin pregnancies. Diabet Med. 2015;32(3):367–73. PMID: 25407306. Wrong study design.25407306
479 Lopez Caudana AE, Lopez Ridaura R, Gonzalez Villalpando C, . Prediction of alterations in glucose metabolism by glucose and insulin measurements in early pregnancy. Arch Med Res. 2011;42(1):70–6. PMID: 21376266. Wrong study design.21376266
480 Lopez Del Val T, Alcazar Lazaro V, Garcia Lacalle C, . Fasting glucose in the first trimester: An initial approach to diagnosis of gestational diabetes. Endocrinol Diabetes Nutr. 2019;66(1):11–8. PMID: 30190244. Wrong outcome.30190244
481 Low CF, Mohd Tohit ER, Chong PP, . Adiponectin SNP45TG is associated with gestational diabetes mellitus. Arch Gynecol Obstet. 2011;283(6):1255–60. PMID: 20552210. Wrong index test KQ4.20552210
482 Lowe WL, Jr L, L. P K, . Maternal glucose levels during pregnancy and childhood adiposity in the Hyperglycemia and Adverse Pregnancy Outcome Follow-up Study. Diabetologia. 2019;62(4):598–610. PMID: 30648193. Wrong outcome.30648193
483 Lowe WL, Jr S, D. M K, . Hyperglycemia and Adverse Pregnancy Outcome Follow-up Study (HAPO FUS): Maternal Gestational Diabetes Mellitus and Childhood Glucose Metabolism. Diabetes Care. 2019;42(3):372–80. PMID: 30655380. Wrong comparison other.30655380
484 Lu J, Zhang S, Li W, . Maternal Gestational Diabetes Is Associated With Offspring’s Hypertension. Am J Hypertens. 2019;32(4):335–42. PMID: 30624576. Wrong outcome.30624576
485 Lu L, Koulman A, Petry CJ, . An Unbiased Lipidomics Approach Identifies Early Second Trimester Lipids Predictive of Maternal Glycemic Traits and Gestational Diabetes Mellitus. Diabetes Care. 2016;39(12):2232–9. PMID: 27703025. Wrong outcome.27703025
486 Lu MC, Huang SS, Yan YH, . Use of the National Diabetes Data Group and the Carpenter-Coustan criteria for assessing gestational diabetes mellitus and risk of adverse pregnancy outcome. BMC Pregnancy Childb. 2016;16:231. PMID: 27535366. Wrong criteria KQ5.27535366
487 Lucovnik M, Steblovnik L, Verdenik I, . Changes in perinatal outcomes after implementation of IADPSG criteria for screening and diagnosis of gestational diabetes mellitus: A national survey. Int J Gynaecol. 2020;149(1):88–92. PMID: 31925788. Wrong study design.31925788
488 Luengmettakul J, Sunsaneevithayakul P, Talungchit P. Pregnancy outcome in women with gestational diabetes mellitus according to the Carpenter-Coustan criteria in Thailand. J Obstet Gynaecol Res. 2015;41(9):1345–51. PMID: 26111427. Wrong criteria KQ5.26111427
489 Luewan S, Bootchaingam P, Tongsong T. Comparison of the Screening Tests for Gestational Diabetes Mellitus between “One-Step" and “Two-Step" Methods among Thai Pregnant Women. Obstet Gynecol Int. 2018;2018:1521794. PMID: 29581725. Wrong study design.29581725
490 Lydon K, Dunne FP, Owens L, . Psychological stress associated with diabetes during pregnancy: a pilot study. Ir Med J. 2012;105(5 Suppl):26–8. PMID: 22838106. Wrong comparison KQ222838106
491 Ma KK, Mele L, Landon MB, . The obstetric and neonatal implications of a low value on the 50-g glucose screening test. Am J Perinatol. 2013;30(9):715–22. PMID: 23271384. Wrong comparison.23271384
492 Ma S, Hu S, Liang H, . Metabolic effects of breastfeed in women with prior gestational diabetes mellitus: A systematic review and meta-analysis. Diabetes Metab Res Rev. 2019;35(3):e3108. PMID: 30513131. Not primary research.30513131
493 Macaulay S, Ngobeni M, Dunger DB, . The prevalence of gestational diabetes mellitus amongst black South African women is a public health concern. Diabetes Res Clin. 2018;139:278–87. PMID: 29526682. Wrong index test KQ4.29526682
494 Mackillop L, Hirst JE, Bartlett KJ, . Comparing the Efficacy of a Mobile Phone-Based Blood Glucose Management System With Standard Clinic Care in Women With Gestational Diabetes: Randomized Controlled Trial. JMIR MHealth and UHealth. 2018;6(3):e71. PMID: 29559428. Wrong comparison.29559428
495 Maegawa Y, Sugiyama T, Kusaka H, . Screening tests for gestational diabetes in Japan in the 1st and 2nd trimester of pregnancy. Diabetes Res Clin Pract. 2003 Oct;62(1):47–53. doi: 10.1016/s0168-8227(03)00146-3. PMID: 14581157. Wrong outcome.14581157
496 Maesa JM, Fernandez-Riejos P, Gonzalez-Rodriguez C, . Screening for Gestational Diabetes Mellitus by Measuring Glycated Hemoglobin Can Reduce the Use of the Glucose Challenge Test. Ann Lab Med. 2019;39(6):524–9. PMID: 31240879. Wrong study design.31240879
497 Maesa JM, Fernandez-Riejos P, Sanchez-Margalet V, . Fasting Glycemia as Screening Tool to Rule-Out Gestational Diabetes in Low-Risk Population. Clinical Laboratory. 2018;64(4):461–5. PMID: 29739067. Wrong study design.29739067
498 Maged AM, Moety GA, Mostafa WA, . Comparative study between different biomarkers for early prediction of gestational diabetes mellitus. J Matern-Fetal Neo M. 2014;27(11):1108–12. PMID: 24090161. Wrong index test KQ4.24090161
499 Maged AM, Torky H, Fouad MA, . Role of antioxidants in gestational diabetes mellitus and relation to fetal outcome: a randomized controlled trial. J Matern-Fetal Neo M. 2016;29(24):4049–54. PMID: 26999688. Wrong comparison.26999688
500 Maitland RA, Seed PT, Briley AL, . Prediction of gestational diabetes in obese pregnant women from the UK Pregnancies Better Eating and Activity (UPBEAT) pilot trial. Diabet Med. 2014;31(8):963–70. PMID: 24798080. Wrong outcome.24798080
501 Mak JKL, Lee AH, Pham NM, . Gestational diabetes and postnatal depressive symptoms: A prospective cohort study in Western China. ACM. 2018;06:06. PMID: 30196993. Wrong comparison KQ230196993
502 Mane L, Flores-Le Roux JA, Gomez N, . Association of first-trimester HbA1c levels with adverse pregnancy outcomes in different ethnic groups. Diabetes Res Clin Pract. 2019;150:202–10. PMID: 30880095. Wrong study design.30880095
503 Mane L, Flores-Le Roux JA, Pedro-Botet J, . Is fasting plasma glucose in early pregnancy a better predictor of adverse obstetric outcomes than glycated haemoglobin Eur. J. Obstet. Gynecol. Reprod. Biol. 2019;234:79–84. PMID: 30665080. Wrong study design.30665080
504 Marais C, Hall DR, van Wyk L, . Randomized cross-over trial comparing the diagnosis of gestational diabetes by oral glucose tolerance test and a designed breakfast glucose profile. Int J Gynecol Obstet. 2018;141(1):85–90. PMID: 29243247. Wrong study design.29243247
505 Marais C, Van Wyk L, Conradie M, . Screening for gestational diabetes: Examining a breakfast meal test. S Afr J Clin Nutr. 2016;29(3):118–21. PMID: 612155697. Wrong study design.
506 March MI, Modest AM, Ralston SJ, . The effect of adopting the IADPSG screening guidelines on the risk profile and outcomes of the gestational diabetes population. J Matern-Fetal Neo M. 2016;29(7):1141–5. PMID: 25958989. Wrong study design.25958989
507 Marquesim NA, Cavassini AC, Morceli G, . Depression and anxiety in pregnant women with diabetes or mild hyperglycemia. Arch Gynecol Obstet. 2016;293(4):833–7. PMID: 26408004. Wrong comparison KQ226408004
508 Martinez MP, Lin J, Chow T, . Maternal Gestational Diabetes and Type 2 Diabetes During Pregnancy and Risk of Childhood Asthma in Offspring. J Pediatr. 2020;219:173–9.e1. PMID: 31987655. Wrong outcome.31987655
509 Maryns AS, Dehaene I, Page G. Maternal and neonatal outcomes in a treated versus non- treated cohort of women with Gestational Diabetes Mellitus according to the HAPO 5 and 4 criteria. Facts Views & Vision in Obgyn. 2017;9(3):133–40. PMID: 29479398. Wrong study design.29479398
510 Matarrelli B, Vitacolonna E, D’Angelo M, . Effect of dietary myo-inositol supplementation in pregnancy on the incidence of maternal gestational diabetes mellitus and fetal outcomes: A randomized controlled trial. J Matern-Fetal Neo M. 2013 Jul;26(10):967–72. PMID: 369099532. Wrong intervention.
511 Matta-Coelho C, Monteiro AM, Fernandes V, . Universal vs. risk-factor-based screening for gestational diabetes-an analysis from a 5-Year Portuguese Cohort. Endocrine. 2019;63(3):507–12. PMID: 30255292. Wrong comparison.30255292
512 Mattioli AV, Sciomer S, Moscucci F, . Cardiovascular prevention in women: a narrative review from the Italian Society of Cardiology working groups on ‘Cardiovascular Prevention, Hypertension and peripheral circulation’ and on ‘Women Disease’. J Cardiovasc Med. 2019;20(9):575–83. PMID: 31246698. Not primary research.31246698
513 Mayo K, Melamed N, Vandenberghe H, . The impact of adoption of the international association of diabetes in pregnancy study group criteria for the screening and diagnosis of gestational diabetes. Am J Obstet Gynecol. 2015;212(2):224.e1–9. PMID: 25173183. Wrong criteria KQ5.25173183
514 Mazzoni S, Hill P, Briggs A, . The effect of group prenatal care for women with diabetes on social support and depressive symptoms: a pilot randomized trial. J Matern-Fetal Neo M. 2018 PMID: 624037022. Wrong comparison KQ2
515 McClean S, Farrar D, Kelly CA, . The importance of postpartum glucose tolerance testing after pregnancies complicated by gestational diabetes. Diabet Med. 2010;27(6):650–4. PMID: 20546282. Wrong population.20546282
516 McGrath NM, Baldwin A. Further post-partum follow-up of women with gestational diabetes mellitus from Northland, New Zealand. Diabet Med. 2012;29(3):415. PMID: 21988474. Wrong population.21988474
517 McIntyre HD, Gibbons KS, Lowe J, . Reprint of “Development of a risk engine relating maternal glycemia and body mass index to pregnancy outcomes”. Diabetes Res Clin. 2018;145:31–8. PMID: 30471322. Wrong outcome.30471322
518 Meek CL, Lewis HB, Patient C, . Diagnosis of gestational diabetes mellitus: falling through the net. Diabetologia. 2015;58(9):2003–12. PMID: 26071759. Wrong criteria KQ5.26071759
519 Meek CL, Murphy HR, Simmons D. Random plasma glucose in early pregnancy is a better predictor of gestational diabetes diagnosis than maternal obesity. Diabetologia. 2016;59(3):445–52. PMID: 26589686. Wrong study design.26589686
520 Meertens LJE, Scheepers HCJ, van Kuijk SMJ, . External validation and clinical utility of prognostic prediction models for gestational diabetes mellitus: A prospective cohort study. Acta Obstet Gynecol Scand. 2020;18:18. PMID: 31955406. Wrong comparison other.31955406
521 Megia A, Naf S, Herranz L, . The usefulness of HbA1c in postpartum reclassification of gestational diabetes. BJOG. 2012 Jun;119(7):891–4. PMID: 51982094. Wrong population.22530667
522 Melchior H, Kurch-Bek D, Mund M. The Prevalence of Gestational Diabetes. Dtsch Arztebl Intl. 2017;114(24):412–8. PMID: 28669379. Wrong comparison.28669379
523 Mello G, Elena P, Ognibene A, . Lack of concordance between the 75-g and 100-g glucose load tests for the diagnosis of gestational diabetes mellitus. Clin Chem. 2006 Sep;52(9):1679–84. doi: 10.1373/clinchem.2005.058040. PMID: 16873295. Wrong index test KQ4.16873295
524 Meloncelli NJL, Barnett AG, D’Emden M, . Effects of Changing Diagnostic Criteria for Gestational Diabetes Mellitus in Queensland, Australia. Obstet Gynecol. 2020;135(5):1215–21. PMID: 32282588. Wrong study design.32282588
525 Meltzer SJ, Snyder J, Penrod JR, . Gestational diabetes mellitus screening and diagnosis: a prospective randomised controlled trial comparing costs of one-step and two-step methods. BJOG. 2010;117(4):407–15. PMID: 20105163. Wrong outcome.20105163
526 Meltzer-Brody S, Maegbaek ML, Medland SE, . Obstetrical, pregnancy and socio-economic predictors for new-onset severe postpartum psychiatric disorders in primiparous women. Psychol Med. 2017;47(8):1427–41. PMID: 28112056. Wrong comparison KQ228112056
527 Memish ZA, Chang JL, Saeedi MY, . Screening for Type 2 Diabetes and Dysglycemia in Saudi Arabia: Development and Validation of Risk Scores. Diabetes Technol Ther. 2015;17(10):693–700. PMID: 26154413. Wrong population.26154413
528 Mendez-Figueroa H, Schuster M, Maggio L, . 483: Gestational diabetes and frequency of blood glucose monitoring: a multi-center randomized, non-inferiority trial. Am J Obstet Gynecol. 2017;216:S285–S. doi: 10.1016/j.ajog.2016.11.218. PMID: 120444452. Language: English. Entry Date: In Process. Revision Date: 20170104. Publication Type: Article. Supplement Title: Jan2017 Supplement. Journal Subset: Biomedical. Wrong comparison.
529 Menezes HT, Sherifali D, Brennan B, . Erratum to “Examining the Prevalence of Diabetes-Related Distress in Women With Diabetes in Pregnancy”: Can J Diabetes 2017;41:S78(S1499267117306457)(10.1016/j.jcjd.2017.08.225)). Can J Diabetes. 2018 Feb;42(1):112. PMID: 2000585778. Wrong population.
530 Mert M, Purcu S, Soyluk O, . The relationship between glycated hemoglobin and blood glucose levels of 75 and 100 gram oral glucose tolerance test during gestational diabetes diagnosis. Int J Clin Exp Med. 2015 30 Aug;8(8):13335–40. PMID: 606285432. Wrong study design.26550262
531 Meththananda Herath HM, Weerarathna TP, Weerasinghe NP. Is Risk Factor-based Screening Good Enough to Detect Gestational Diabetes Mellitus in High-Risk Pregnant Women? A Sri Lankan Experience. Int J Prev Med. 2016;7:99. PMID: 27625764. Wrong outcome.27625764
532 Metzger BE, Dyer AR. Do the new threshold levels for the diagnosis of gestational diabetes mellitus correctly identify women at risk? Diabetes care 2014;37:e30. Diabetes Care. 2014 Feb;37(2):e43–e4. PMID: 372220376. Other reason.24459170
533 Metzger BE, Lowe LP, Dyer AR, . Hyperglycemia and adverse pregnancy outcomes. N Engl J Med. 2008 May 8;358(19):1991–2002. doi: 10.1056/NEJMoa0707943. PMID: 18463375. Wrong population.18463375
534 Miailhe G, Kayem G, Girard G, . Selective rather than universal screening for gestational diabetes mellitus? Eur J Obstet Gynecol Reprod Biol. 2015;191:95–100. PMID: 26112365. Wrong outcome.26112365
535 Miao ZR, Wu HH, Zhang YZ, . Evaluation of the gestational diabetes mellitus diagnostic criteria recommended by the international association of diabetes and pregnancy study group for long-term maternal postpartum outcomes in mainland China. Medicine. 2020;99(8):e19242. PMID: 32080127. Wrong population other.32080127
536 Miller ES, Peri MR, Gossett DR. The association between diabetes and postpartum depression. Arch Womens Ment Health. 2016;19(1):183–6. PMID: 26184833. Wrong comparison KQ226184833
537 Miller NE, Curry E, Laabs SB, . Impact of gestational diabetes diagnosis on concurrent depression in pregnancy. J Psychosom Obstet Gynecol. 2020:1–4. PMID: 31909691. Wrong comparison other.31909691
538 Minsart AF, N’Guyen T S, Dimtsu H, . Are the new IADPSG criteria for gestational diabetes useful in a country with a very high prevalence? Gynecol Endocrinol. 2014;30(9):632–5. PMID: 24805833. Wrong study design.24805833
539 Miremberg H, Ben-Ari T, Betzer T, . The impact of a daily smartphone-based feedback system among women with gestational diabetes on compliance, glycemic control, satisfaction, and pregnancy outcome: a randomized controlled trial. Am J Obstet Gynecol. 2018;218(4):453.e1–.e7. PMID: 29425836. Wrong comparison.29425836
540 Mirfeizi M, Toorzani ZM, Jafarabadi MA, . Examining diagnostic value of the fasting plasma glucose in screening gestational diabetes. IJDLD. 2011;10:1–5. PMID: 362966954. Wrong outcome.
541 Mirghafourvand M, Zandinava H, Shafaei FS, . Effectiveness of self-care training on pregnancy consequences in gestational diabetes: A randomized controlled clinical trial. Shiraz E Medical J. 2019;20(6) PMID: 2002155732. Wrong outcome.
542 Mirzamoradi M, Bakhtiyari M, Kimiaee P, . Investigating the effects of treatment based on single high blood glucose in gestational diabetes screening on maternal and neonatal complications. Arch Gynecol Obstet. 2015;292(3):687–95. PMID: 25753159. Wrong comparison.25753159
543 Mission JF, Catov J, Comer D, . Perinatal Outcomes Associated with Early Diabetes Testing in Pregnancies Complicated by Obesity. Am J Perinatol. 2020;37(6):589–97. PMID: 30895578. Wrong comparison other.30895578
544 Mission JF, Ohno MS, Cheng YW, . Gestational diabetes screening with the new IADPSG guidelines: A cost-effectiveness analysis. Am J Obstet Gynecol. 2012 Oct;207(4):326.e1–.e9. PMID: 52130165. Not primary research.22840972
545 Miyakoshi K, Tanaka M, Saisho Y, . Pancreatic beta-cell function and fetal growth in gestational impaired glucose tolerance. Acta Obstet Gyn Scan. 2010;89(6):769–75. PMID: 20504080. Wrong index test KQ4.20504080
546 Mizuno S, Nishigori H, Sugiyama T, . Association between social capital and the prevalence of gestational diabetes mellitus: An interim report of the Japan Environment and Children’s Study. Diabetes Res Clin. 2016 01 Oct;120:132–41. PMID: 611909478. Wrong population.
547 Mohan V, Mahalakshmi MM, Bhavadharini B, . Comparison of screening for gestational diabetes mellitus by oral glucose tolerance tests done in the non-fasting (random) and fasting states. Acta Diabetol. 2014;51(6):1007–13. PMID: 25315629. Wrong index test KQ4.25315629
548 Morikawa M, Yamada T, Akaishi R, . Prevalence of hyperglycaemia in singleton versus twin pregnancy. Diabetes Metab Res. 2015;31(2):198–203. PMID: 25066690. Wrong study design.25066690
549 Morikawa M, Yamada T, Yamada T, . Change in the number of patients after the adoption of IADPSG criteria for hyperglycemia during pregnancy in Japanese women. Diabetes Res Clin Pract. 2010 Dec;90(3):339–42. doi: 10.1016/j.diabres.2010.08.023. PMID: 20870307. Wrong population.20870307
550 Morisset AS, Cote JA, Michaud A, . Dietary intakes in the nutritional management of gestational diabetes mellitus. Canadian Journal of Dietetic Practice & Research. 2014;75(2):64–71. PMID: 24897011. Wrong comparison.24897011
551 Morrison MK, Collins CE, Lowe JM, . Factors associated with early cessation of breastfeeding in women with gestational diabetes mellitus. Women and Birth. 2015 01 Jun;28(2):143–7. PMID: 601600919. Wrong outcome.25618836
552 Moses RG, Morris GJ, Petocz P, . The impact of potential new diagnostic criteria on the prevalence of gestational diabetes mellitus in Australia. Med J Aust. 2011 Apr 4;194(7):338–40. PMID: 21470082. Wrong index test KQ4.21470082
553 Mosimann B, Amylidi S, Risch L, . First-Trimester Placental Growth Factor in Screening for Gestational Diabetes. Fetal Diagn Ther. 2016;39(4):287–91. PMID: 26421599. Wrong study design.26421599
554 Mousavi SN, Kamali K, Mirbazel M, . The Best Cut-Off Value for HbA1c as a Screening Tool in Iranian Women With Gestational Diabetes Mellitus. J Family Reprod Health. 2017;11(1):37–42. PMID: 29114267. Wrong study design.29114267
555 Moussa M, Ali H, Churchill D, . An in situ comparison of the diagnosis of gestational diabetes mellitus (GDM) using the international association of diabetes in pregnancy study group (IADPSG) criteria between 13 october to 15 march epoch 1 (E1) and the national institute of health & social care excellence (NICE) criteria 15 april and 16 november epoch (E2). BJOG. 2019;126:177‐. doi: 10.1111/1471-0528.12_15703. PMID: CN-01960477. Wrong study design.
556 Muniswaran G, Soelar SA, Karalasingam SD, . Effectiveness of selective risk based screening for Gestational Diabetes (GDM) in Malaysia: A retrospective cohort study based on the National Obstetric Registry (NOR) of Malaysia. Medical J Malaysia. 2017;72(1):46–9. PMID: 28255139. Wrong study design.28255139
557 Murphy NM, McCarthy FP, Khashan AS, . Compliance with National Institute of Health and Care Excellence risk-based screening for Gestational Diabetes Mellitus in nulliparous women. Eur J Obstet Gynecol. 2016 Apr 01;199:60–5. PMID: 608967083. Wrong study design.
558 Nachankar A, Kotwal N, Upreti V, . Association of Vitamin D and Parathyroid Hormone with Insulin Sensitivity, Beta Cell Function and Gestational Diabetes in Pregnancy: A Cross-Sectional, Observational Study. Diabetes Therapy. 2018;9(5):2081–90. PMID: 30206904. Wrong index test KQ4.30206904
559 Nagalakshmi CS, Santhosh NU, Krishnamurthy N, . Role of Altered Venous Blood Lactate and HbA1c in Women with Gestational Diabetes Mellitus. JCDR. 2016;10(12):BC18–BC20. PMID: 28208845. Wrong study design.28208845
560 Nakanishi S, Aoki S, Kasai J, . Have pregnancy outcomes improved with the introduction of the International Association of Diabetes and Pregnancy Study Groups criteria in Japan? J Diabetes Investig. 2020;03:03. PMID: 32012487. Wrong study design.32012487
561 Nanda S, Savvidou M, Syngelaki A, . Prediction of gestational diabetes mellitus by maternal factors and biomarkers at 11 to 13 weeks. Prenatal Diagnosis. 2011;31(2):135–41. PMID: 21268030. Wrong population (KQ4 development cohort).21268030
562 Nassr AA, Shazly SA, Trinidad MC, . Body fat index: A novel alternative to body mass index for prediction of gestational diabetes and hypertensive disorders in pregnancy. Eur J Obstet Gynecol Reprod Biol. 2018;228:243–8. PMID: 30014931. Wrong study design.30014931
563 Nayak PK, Mitra S, Sahoo J, . Comparison of the world health organization and the international association of diabetes and pregnancy study groups criteria in diagnosing gestational diabetes mellitus in South Indians. Indian J Endocr Metab. 2014;18(3):433–4. PMID: 24944950. Not primary research.24944950
564 Nayak PK, Mitra S, Sahoo JP, . Feto-maternal outcomes in women with and without gestational diabetes mellitus according to the International Association of Diabetes and Pregnancy Study Groups (IADPSG) diagnostic criteria. Diabetes Metab Syndr. 2013;7(4):206–9. PMID: 24290085. Wrong index test KQ4.24290085
565 Naylor CD, Sermer M, Chen E, . Cesarean delivery in relation to birth weight and gestational glucose tolerance: pathophysiology or practice style? Toronto Trihospital Gestational Diabetes Investigators. Jama. 1996 Apr 17;275(15):1165–70. PMID: 8609683. Wrong study design.8609683
566 Neelakandan R, Sethu PS. Early universal screening for gestational diabetes mellitus. Journal of Clinical and Diagnostic Research JCDR. 2014;8(4):OC12–4. PMID: 24959483. Wrong index test KQ4.24959483
567 Newham JJ, Glinianaia SV, Tennant PWG, . Improved antenatal detection of congenital anomalies in women with pre-gestational diabetes: Population-based cohort study. Diabet Med. 2013 Dec;30(12):1442–8. PMID: 52750884. Wrong population.23909859
568 Ngala RA, Fondjo LA, Gmagna P, . Placental peptides metabolism and maternal factors as predictors of risk of gestational diabetes in pregnant women. A case-control study. PLoS ONE. 2017 Jul;12 (7) (no pagination)(e0181613) PMID: 617414351. Wrong index test KQ4.28732072
569 Nguyen CL, Lee AH, Minh Pham N, . Prevalence and pregnancy outcomes of gestational diabetes mellitus by different international diagnostic criteria: a prospective cohort study in Vietnam. J Matern-Fetal Neo M. 2019:1–7. PMID: 30843751. Wrong comparison.30843751
570 Nguyen CL, Lee AH, Minh Pham N, . Prevalence and pregnancy outcomes of gestational diabetes mellitus by different international diagnostic criteria: a prospective cohort study in Vietnam. J Matern-Fetal Neo M. 2019:1–7. PMID: 30843751. Wrong population other.30843751
571 Nguyen PTH, Binns CW, Nguyen CL, . Gestational Diabetes Mellitus Reduces Breastfeeding Duration: A Prospective Cohort Study. Breastfee Med. 2019;14(1):39–45. PMID: 30383402. Wrong outcome.30383402
572 Nguyen TH, Yang JW, Mahone M, . Are There Benefits for Gestational Diabetes Mellitus in Treating Lower Levels of Hyperglycemia Than Standard Recommendations? Can J Diabetes. 2016;40(6):548–54. PMID: 27423765. Wrong comparison.27423765
573 Nicklas JM, Miller LJ, Zera CA, . Factors associated with depressive symptoms in the early postpartum period among women with recent gestational diabetes mellitus. Matern child health j. 2013 Nov;17(9):1665–72. PMID: 563068954. Wrong comparison KQ223124798
574 Nicklas JM, Rosner BA, Zera CA, . Association Between Changes in Postpartum Weight and Waist Circumference and Changes in Cardiometabolic Risk Factors Among Women With Recent Gestational Diabetes. Prev Chronic Dis. 2019;16:E47. PMID: 31002638. Wrong population other.31002638
575 Nijs H, Benhalima K. Gestational Diabetes Mellitus and the Long-Term Risk for Glucose Intolerance and Overweight in the Offspring: A Narrative Review. J ClinMed. 2020;9(2):22. PMID: 32098435. Not primary research.32098435
576 Nilofer AR, Raju VS, Dakshayini BR, . Screening in high-risk group of gestational diabetes mellitus with its maternal and fetal outcomes. Indian J Endocr Metab. 2012;16 Suppl 1:S74–8. PMID: 22701851. Wrong population (KQ4 development cohort).22701851
577 Niroomand M, Afsar J, Hosseinpanah F, . Comparison of the International Association of Diabetes in Pregnancy Study Group Criteria with the Old American Diabetes Association Criteria for Diagnosis of Gestational Diabetes Mellitus. International Journal of Endocrinology and Metabolism. 2019;17(4):e88343. PMID: 31903093. Wrong population other.31903093
578 Nishikawa E, Oakley L, Seed PT, . Maternal BMI and diabetes in pregnancy: Investigating variations between ethnic groups using routine maternity data from London, UK. PLoS ONE [Electronic Resource]. 2017;12(6):e0179332. PMID: 28640854. Wrong study design.28640854
579 Njete HI, John B, Mlay P, . Prevalence, predictors and challenges of gestational diabetes mellitus screening among pregnant women in northern Tanzania. Trop Med Int Health. 2018;23(2):236–42. doi: 10.1111/tmi.13018. PMID: 127745048. Language: English. Entry Date: 20181108. Revision Date: 20190201. Publication Type: journal article. Journal Subset: Biomedical. Wrong outcome.29178236
580 Nobumoto E, Masuyama H, Hiramatsu Y, . Effect of the new diagnostic criteria for gestational diabetes mellitus among Japanese women. Diabetol Internat. 2015 04 Sep;6(3):226–31. PMID: 605848551. Wrong study design.
581 Nollino L, Marcon ML, Kiwanuka E, . Can Nurse-Based Management Screening Ensure Adequate Outcomes in Patients With Gestational Diabetes? A Comparison of 2 Organizational Models. Qual Manag Health Care. 2019;28(1):51–62. PMID: 30586123. Wrong comparison.30586123
582 Nombo AP, Mwanri AW, Brouwer-Brolsma EM, . Gestational diabetes mellitus risk score: A practical tool to predict gestational diabetes mellitus risk in Tanzania. Diabetes Res Clin. 2018;145:130–7. PMID: 29852237. Wrong population (KQ4 development cohort).29852237
583 Nord E, Hanson U, Persson B. Blood glucose limits in the diagnosis of impaired glucose tolerance during pregnancy. Relation to morbidity. Acta Obstet Gynecol Scand. 1995 Sep;74(8):589–93. doi: 10.3109/00016349509013467. PMID: 7660761. Wrong population.7660761
584 Nwose EU, Richards RS, Bwititi PT, . New guidelines for diagnosis of gestational diabetes: pathology-based impact assessment. N Am J Med Sci. 2013;5(3):191–4. PMID: 23626954. Wrong criteria KQ5.23626954
585 O’Dea A, Infanti JJ, Gillespie P, . Screening uptake rates and the clinical and cost effectiveness of screening for gestational diabetes mellitus in primary versus secondary care: Study protocol for a randomised controlled trial. Trials. 2014 17 Jan;15 (1) (no pagination)(27) PMID: 52967223. Wrong comparison.24438478
586 O’Dea A, Tierney M, Danyliv A, . Screening for gestational diabetes mellitus in primary versus secondary care: The clinical outcomes of a randomised controlled trial. Diabetes Res Clin. 2016;117:55–63. PMID: 27329023. Wrong comparison.27329023
587 Odsaeter IH, Asberg A, Vanky E, . HbA1c as screening for gestational diabetes mellitus in women with polycystic ovary syndrome. BMC Endocrine Disorders. 2015;15:38. PMID: 26245653. Wrong outcome.26245653
588 Ogunleye OK, Davidson KD, Gregg AR, . Perinatal outcomes after adopting 1- versus 2-step approach to diagnosing gestational diabetes. J Matern-Fetal Neo M. 2017;30(2):186–90. PMID: 27022779. Wrong study design.27022779
589 Ohara R, Obata-Yasuoka M, Abe K, . Effect of hyperemesis gravidarum on gestational diabetes mellitus screening. Int J Gynecol Obstet. 2016;132(2):156–8. PMID: 26582348. Wrong study design.26582348
590 Okada T, Iwashina M, Kasatani T, . Clinical outcomes of pregnancies complicated with and treated for gestational diabetes mellitus: Consequences of screening under the IADPSG criteria. Diabetol Int. 2013;4(3):186–9. PMID: 369937712. Wrong study design.
591 Olagbuji BN, Atiba AS, Olofinbiyi BA, . Prevalence of and risk factors for gestational diabetes using 1999, 2013 WHO and IADPSG criteria upon implementation of a universal one-step screening and diagnostic strategy in a sub-Saharan African population. Eur J Obstet Gynecol Reprod Biol. 2015;189:27–32. PMID: 25855324. Wrong study design.25855324
592 Olaiya MT, Wedekind LE, Hanson RL, . Birthweight and early-onset type 2 diabetes in American Indians: differential effects in adolescents and young adults and additive effects of genotype, BMI and maternal diabetes. Diabetologia. 2019 01 Sep;62(9):1628–37. PMID: 627826331. Wrong intervention other.31111170
593 Olarinoye JK, Ohwovoriole AE, Ajayi GO. Diagnosis of gestational diabetes mellitus in Nigerian pregnant women-comparison between 75G and 100G oral glucose tolerance tests. West Afr J Med. 2004 Jul-Sep;23(3):198–201. PMID: 15587828. Wrong population.15587828
594 Olsen SF, Houshmand-Oeregaard A, Granstrom C, . Diagnosing gestational diabetes mellitus in the Danish National Birth Cohort. Acta Obstet Gyn Scan. 2017;96(5):563–9. PMID: 28027410. Wrong study design.28027410
595 Orecchio A, Periard D, Kashef A, . Incidence of gestational diabetes and birth complications in Switzerland: screening in 1042 pregnancies. Gynecol Endocrinol. 2014;30(8):561–4. PMID: 24871384. Wrong study design.24871384
596 Oriot P, Radikov J, Gilleman U, . Gestational diabetes mellitus screening according to Carpenter-Coustan and IADPSG criteria: A 7-year follow-up of prevalence, treatment and neonatal complications at a Belgian general hospital. Diabetes Metab. 2018;44(3):309–12. PMID: 29066156. Wrong study design.29066156
597 Oriot P, Selvais P, Radikov J, . Assessing the incidence of gestational diabetes and neonatal outcomes using the IADPSG guidelines in comparison with the Carpenter and Coustan criteria in a Belgian general hospital. Acta Clinica Belgica. 2014;69(1):8–11. PMID: 24635392. Wrong study design.24635392
598 O’Shea P, O’Connor C, Owens L, . Trimester-specific reference intervals for IFCC standardised haemoglobin A(1c): new criterion to diagnose gestational diabetes mellitus (GDM)? Ir Med J. 2012;105(5 Suppl):29–31. PMID: 22838107. Wrong population.22838107
599 Osmundson SS, Zhao BS, Kunz L, . First Trimester Hemoglobin A1c Prediction of Gestational Diabetes. Am J Perinatol. 2016;33(10):977–82. PMID: 27120479. Wrong study design.27120479
600 Ostlund I, Hanson U. Occurrence of gestational diabetes mellitus and the value of different screening indicators for the oral glucose tolerance test. Acta Obstet Gynecol Scand. 2003 Feb;82(2):103–8. doi: 10.1034/j.1600-0412.2003.00001.x. PMID: 12648169. Wrong outcome.12648169
601 O’Sullivan EP, Avalos G, O’Reilly M, . Atlantic Diabetes in Pregnancy (DIP): the prevalence and outcomes of gestational diabetes mellitus using new diagnostic criteria. Diabetologia. 2011;54(7):1670–5. PMID: 21494772. Wrong criteria KQ5.21494772
602 Oza-Frank R, Chertok I, Bartley A. Differences in breast-feeding initiation and continuation by maternal diabetes status. Public Health Nutr. 2015;18(4):727–35. doi: 10.1017/S1368980014000792. PMID: 109700399. Language: English. Entry Date: 20150923. Revision Date: 20151022. Publication Type: journal article. Journal Subset: Allied Health. Wrong outcome.24809929
603 Ozgu-Erdinc AS, Iskender C, Uygur D, . One-hour versus two-hour postprandial blood glucose measurement in women with gestational diabetes mellitus: which is more predictive? Endocrine. 2016;52(3):561–70. PMID: 26645814. Wrong study design.26645814
604 Ozgu-Erdinc AS, Sert UY, Buyuk GN, . Prevalence of gestational diabetes mellitus and results of the screening tests at a tertiary referral center: A cross-sectional study. Diabetes Metab Syndr. 2019;13(1):74–7. PMID: 30641799. Wrong study design.30641799
605 Ozgu-Erdinc AS, Sert UY, Buyuk GN, . Prevalence of gestational diabetes mellitus and results of the screening tests at a tertiary referral center: A cross-sectional study. Diabetes Metab Syndr. 2019;13(1):74–7. PMID: 30641799. Wrong outcome.30641799
606 Ozgu-Erdinc AS, Sert UY, Kansu-Celik H, . Prediction of gestational diabetes mellitus in the first trimester by fasting plasma glucose which cutoff is better? Arch Physiol Biochem. 2019:1–5. PMID: 31573373. Wrong study design.31573373
607 Ozgu-Erdinc AS, Yilmaz S, Yeral MI, . Prediction of gestational diabetes mellitus in the first trimester: Comparison of C-reactive protein, fasting plasma glucose, insulin and insulin sensitivity indices. J Matern-Fetal Neo M. 2015 02 Nov;28(16):1957–62. PMID: 606232938. Wrong outcome.
608 Ozturk O, Serdar MA, Ozturk M, . Calculation of uncertainty for glucose: May it affect the diagnosis of gestational diabetes? Turkish J Biochem. 2012;37(1):68–72. PMID: 364585595. Wrong language.
609 Pace R, Rahme E, Da Costa D, . Association between gestational diabetes mellitus and depression in parents: a retrospective cohort study. Clin Epidemiol. 2018;10:1827–38. PMID: 30584375. Wrong comparison KQ230584375
610 Page AS, Visschers B, Page G. Importance of screening for gestational diabetes in late pregnancy. J Obstet Gynaecol Res. 2012 Mar;38(3):610. PMID: 364791893. Not primary research.22353488
611 Palatnik A, Swanson K, Churchill T, . Association Between Type of Screening for Gestational Diabetes Mellitus and Cesarean Delivery. Obstet Gynecol. 2017;130(3):539–44. PMID: 28796680. Wrong comparison KQ228796680
612 Paleti M, Krishna LG, Shailaja N, . Diagnosis of GDM by oral glucose challenge test. Biomedicine (India). 2014 Jan;34(1):115–9. PMID: 372656111. Wrong outcome.
613 Pan L, Leng J, Liu G, . Pregnancy outcomes of Chinese women with gestational diabetes mellitus defined by the IADPSG’s but not by the 1999 WHO’s criteria. Clin Endocrinol. 2015;83(5):684–93. PMID: 25903847. Wrong criteria KQ5.25903847
614 Panaviene J, Zakharchenko L, Olteanu D, . Factors Contributing to Non-Exclusive Breastfeeding in Primigravid Mothers. Ir Med J. 2019;112(9):1003. PMID: 31651134. Wrong outcome.31651134
615 Pancer J, Wu N, Mahmoud I, . Pharmacological intervention for diabetes after pregnancy prevention in women with prior gestational diabetes: A scoping review. Diabetes Res Clin. 2020;160:107998. PMID: 31911249. Not primary research.31911249
616 Pantzartzis KA, Manolopoulos PP, Paschou SA, . Gestational diabetes mellitus and quality of life during the third trimester of pregnancy. Qual Life Res. 2019;28(5):1349–54. PMID: 30600493. Wrong comparison KQ230600493
617 Park JS, Kim DW, Kwon JY, . Development of a Screening Tool for Predicting Adverse Outcomes of Gestational Diabetes Mellitus: A Retrospective Cohort Study. Medicine. 2016;95(1):e2204. PMID: 26735528. Wrong study design.26735528
618 Passarella G, Trifiro G, Gasparetto M, . Disorders in glucidic metabolism and congenital heart diseases: detection and prevention. Pediatr Cardiol. 2013;34(4):931–7. PMID: 23229289. Wrong outcome.23229289
619 Pastakia SD, Njuguna B, Onyango BA, . Prevalence of gestational diabetes mellitus based on various screening strategies in western Kenya: a prospective comparison of point of care diagnostic methods. BMC Pregnancy Childb. 2017;17(1):226. PMID: 28705184. Wrong index test KQ4.28705184
620 Pathirana MM, Lassi ZS, Roberts CT, . Cardiovascular risk factors in offspring exposed to gestational diabetes mellitus in utero: systematic review and meta-analysis. J Dev Orig Health Dis. 2020:1–18. PMID: 31902382. Wrong population other.31902382
621 Pazhohan A, Rezaee Moradali M, Pazhohan N. Association of first-trimester maternal lipid profiles and triglyceride-glucose index with the risk of gestational diabetes mellitus and large for gestational age newborn. J Matern Fetal Neonatal Med. 2019;32(7):1167–75. PMID: 29157043. Wrong outcome.29157043
622 Pedersen ML, Lind O, Abelsen T, . Gestational diabetes and macrosomia among Greenlanders. Time to change diagnostic strategy? Int J Circumpolar Health. 2018;77(1):1528126. PMID: 30300118. Wrong criteria KQ5.30300118
623 Pedula KL, Hillier TA, Ogasawara KK, . A randomized pragmatic clinical trial of gestational diabetes screening (ScreenR2GDM): Study design, baseline characteristics, and protocol adherence. Contemp Clin Trials. 2019;85:105829. PMID: 31425751. Protocol.31425751
624 Pellonpera O, Mokkala K, Houttu N, . Efficacy of Fish Oil and/or Probiotic Intervention on the Incidence of Gestational Diabetes Mellitus in an At-Risk Group of Overweight and Obese Women: A Randomized, Placebo-Controlled, Double-Blind Clinical Trial. Diabetes Care. 2019;09:09. PMID: 30967436. Wrong population.30967436
625 Pennison EH, Egerman RS. Perinatal outcomes in gestational diabetes: a comparison of criteria for diagnosis. Am J Obstet Gynecol. 2001 May;184(6):1118–21. doi: 10.1067/mob.2001.114918. PMID: 11349174. Wrong population.11349174
626 Perez-Ferre N, Galindo M, Fernandez MD, . The outcomes of gestational diabetes mellitus after a telecare approach are not inferior to traditional outpatient clinic visits. Int J Endocrinol Print. 2010;2010:386941. PMID: 20628517. Wrong comparison.20628517
627 Perichart-Perera O, Balas-Nakash M, Rodriguez-Cano A, . Low Glycemic Index Carbohydrates versus All Types of Carbohydrates for Treating Diabetes in Pregnancy: A Randomized Clinical Trial to Evaluate the Effect of Glycemic Control. Int J Endocrinol Print. 2012;2012:296017. PMID: 23251152. Wrong comparison.23251152
628 Perovic M, Garalejic E, Gojnic M, . Sensitivity and specificity of ultrasonography as a screening tool for gestational diabetes mellitus. J Matern-Fetal Neo M. 2012 Aug;25(8):1348–53. PMID: 365249662. Wrong index test KQ4.
629 Perovic M, Gojnic M, Arsic B, . Relationship between mid-trimester ultrasound fetal liver length measurements and gestational diabetes mellitus. J Diabetes. 2015;7(4):497–505. PMID: 25124095. Wrong index test KQ4.25124095
630 Peter R, Bright D, Cheung WY, . Proinsulin in the identification and risk stratification of gestational diabetes mellitus: study protocol for a prospective, longitudinal cohort study. BMJ Open. 2018;8(8):e022571. PMID: 30158232. Wrong index test KQ4.30158232
631 Petkova V, Dimitrov M, Geourgiev S. Pilot project for education of gestational diabetes mellitus (GDM) patients - can it be beneficial? Afr J Pharm Pharmacol. 2011 15 Sep;5(10):1282–6. PMID: 362601590. Wrong intervention.
632 Pezeshki B, Chiti H, Arasteh P, . Early screening of gestational diabetes mellitus using hemoglobin A1C: Revising current screening guidelines. Caspian J Intern Med. 2019;10(1):16–24. PMID: 30858937. Duplicates.30858937
633 Picon MJ, Murri M, Munoz A, . Hemoglobin A1c versus oral glucose tolerance test in postpartum diabetes screening. Diabetes Care. 2012;35(8):1648–53. PMID: 22688550. Wrong population.22688550
634 Pintaudi B, Di Vieste G, Corrado F, . Improvement of selective screening strategy for gestational diabetes through a more accurate definition of high-risk groups. Eur J Endocrinol. 2014;170(1):87–93. PMID: 24114434. Wrong study design.24114434
635 Plasencia W, Garcia R, Pereira S, . Criteria for screening and diagnosis of gestational diabetes mellitus in the first trimester of pregnancy. Fetal Diagn Ther. 2011;30(2):108–15. PMID: 21454960. Wrong study design.21454960
636 Pocobelli G, Yu O, Fuller S, . One-Step Approach to Identifying Gestational Diabetes Mellitus: Association With Perinatal Outcomes. Obstet Gynecol. 2018;132(4):859–67. PMID: 30130344. Wrong study design.30130344
637 Poirier J, Kattini R, Kelly L, . Screening for gestational diabetes in pregnancy in Northwestern Ontario. Can J Rural Med. 2020;25(2):61–6. PMID: 32235107. Wrong study design.32235107
638 Poo ZX, Wright A, Ruochen D, . Optimal first trimester HbA1c threshold to identify Singaporean women at risk of gestational diabetes mellitus and adverse pregnancy outcomes: A pilot study. Obstet Med. 2019;12(2):79–84. PMID: 31217812. Duplicates.31217812
639 Popova PV, Grineva EN, Gerasimov AS, . The new combination of risk factors determining a high risk of gestational diabetes mellitus. Minerva Endocrinologica. 2015;40(4):239–47. PMID: 25288096. Wrong population (KQ4 development cohort).25288096
640 Pouliot A, Elmahboubi R, Adam C. Incidence and Outcomes of Gestational Diabetes Mellitus Using the New International Association of Diabetes in Pregnancy Study Group Criteria in Hopital Maisonneuve-Rosemont. Can J Diabetes. 2019;43(8):594–9. PMID: 31787245. Wrong study design.31787245
641 Poyhonen-Alho MK, Teramo KA, Kaaja RJ, . 50gram oral glucose challenge test combined with risk factor-based screening for gestational diabetes. Eur J Obstet Gynecol Reprod Biol. 2005 Jul 1;121(1):34–7. doi: 10.1016/j.ejogrb.2004.10.008. PMID: 15989983. Wrong outcome.15989983
642 Pramodkumar TA, Jayashri R, Gokulakrishnan K, . 1,5 Anhydroglucitol in gestational diabetes mellitus. J Diabetes Complicat. 2019;33(3):231–5. PMID: 30594413. Wrong index test KQ4.30594413
643 Pratama R, Cristobal RJ. Association of inflammatory and hemogram parameters to gestational diabetes mellitus: Predictive value for early diagnosis during pregnancy. Eur J Obstet Gynecol Reprod Biol. 2019;234:e61–e. doi: 10.1016/j.ejogrb.2018.08.288. PMID: 134775575. Language: English. Entry Date: In Process. Revision Date: 20190221. Publication Type: Article. Journal Subset: Biomedical. Wrong index test KQ4.
644 Pugh SK, Poole AT, Hill JB, . Abnormal 1 hour glucose challenge test followed by a normal 3 hour glucose tolerance test: does it identify adverse pregnancy outcome? J Miss State Med Assoc. 2010;51(1):3–6. PMID: 20827864. Wrong criteria KQ5.20827864
645 Punnose J, Malhotra RK, Sukhija K, . Bimodal glucose distribution in Asian Indian pregnant women: Relevance in gestational diabetes mellitus diagnosis J. Clin. Transl. Endocrinol. 2018;13:20–5. PMID: 30013937. Wrong study design.30013937
646 Punnose J, Malhotra RK, Sukhija K, . Glycated haemoglobin in the first trimester: A predictor of gestational diabetes mellitus in pregnant Asian Indian women. Diabetes Res Clin Pract. 2020;159:107953. PMID: 31794807. Wrong study design.31794807
647 Qiu H, Yu HY, Wang LY, . Electronic Health Record Driven Prediction for Gestational Diabetes Mellitus in Early Pregnancy. Sci Rep. 2017;7(1):16417. PMID: 29180800. Wrong index test KQ4.29180800
648 Racusin DA, Antony K, Showalter L, . Candy twists as an alternative to the glucola beverage in gestational diabetes mellitus screening. Am J Obstet Gynecol. 2015;212(4):522.e1–5. PMID: 25446695. Wrong outcome.25446695
649 Ragland D, Payakachat N, Hays EB, . Depression and diabetes: Establishing the pharmacist’s role in detecting comorbidity in pregnant women. JAPhA. 2010 2010 Mar-Apr;50(2):195–9. PMID: 358848826. Wrong comparison KQ220199962
650 Rajab KE, Issa AA, Hasan ZA, . Incidence of gestational diabetes mellitus in Bahrain from 2002 to 2010. Int J Gynaecol Obstet. 2012 Apr;117(1):74–7. PMID: 51820400. Wrong study design.22265190
651 Rajput R, Yadav Y, Rajput M, . Comparative evaluation of IADPSG criteria with ADA and WHO criteria for diagnosis of gestational diabetes mellitus J Indian Acad Clin Med. 2015;16(1):27–32. PMID: 603215009. Wrong criteria KQ5.
652 Rakibul-Hasan M, Sultana N, Jahan S, . Diagnostic efficiency of diabetes in pregnancy study group of India versus World Health Organization 2013 criteria. Int J Diabetes Dev. 2020 PMID: 2004380125. Wrong comparison other.
653 Ramezani Tehrani F, Gulf Study Cooperative Research G. Cost effectiveness of different screening strategies for gestational diabetes mellitus screening: study protocol of a randomized community non-inferiority trial. Diabetol metab syndr. 2019;11:106. PMID: 31890040. Protocol.31890040
654 Ramos JG, Bgeginski R, Opperman ML, . [209-POS]: Effect of aerobic training in pregnant women diagnosed with gestational diabetes: A preliminary report. Pregnancy Hypertens. 2015;5(1):105-. doi: 10.1016/j.preghy.2014.10.215. PMID: 109712633. Language: English. Entry Date: 20150923. Revision Date: 20150923. Publication Type: Journal Article. Journal Subset: Biomedical. Wrong comparison.
655 Rasanen JP, Snyder CK, Rao PV, . Glycosylated fibronectin as a first-trimester biomarker for prediction of gestational diabetes. Diabetes Technol Ther. 2015 01 Feb;17(Supplement 1):S68. PMID: 602425216. Wrong index test KQ4.
656 Rasheed FA, Mshattat RH, Alnakkash UM, . Hypertriglyceridemia and waist phenotype as markers in the prediction of gestational diabetes in Iraqi women. Res J Obstet Gynecol. 2018;11(1):25–30. PMID: 2001528816. Wrong study design.
657 Rasmussen KV, Nielsen KK, Pedersen ML. No association between early maternal HbA1c and offspring birthweight among women without pre-existing diabetes in Greenland. Int J Circumpolar Health. 2020;79(1):1702798. PMID: 31825748. Wrong outcome.31825748
658 Ratnayake C, Weerasekara ND, Suranimala DH, . Validity of over the counter finger stick glucose measurement devices in comparison with laboratory venous plasma glucose measurements on pregnant women with diabetes. Ceylon Med J. 2018;63(4):180–5. PMID: 30669213. Wrong index test KQ4.30669213
659 Rauf M, Sevil E, Ebru C, . Early diagnosis of gestational diabetes mellitus during the first trimester of pregnancy based on the one-step approach of the International Association of Diabetes and Pregnancy Study Groups. Int J Diabetes Dev.2018 01 Jan;38(1):20–5. PMID: 620906250. Wrong intervention.
660 Rebarber A, Dolin C, Fields JC, . Screening approach for gestational diabetes in twin pregnancies. Am J Obstet Gynecol. 2014;211(6):639.e1–5. PMID: 25439813. Wrong study design.25439813
661 Refuerzo JS, Viteri OA, Hutchinson M, . The effects of metformin on weight loss in women with gestational diabetes: A pilot randomized, placebo-controlled trial. Am. J. Obstet. Gynecol. 2015 01 Mar;212(3):389.e1-.e9. PMID: 601454595. Wrong population.25526875
662 Regnault N, Gillman MW, Rifas-Shiman SL, . Sex-specific associations of gestational glucose tolerance with childhood body composition. Diabetes Care. 2013;36(10):3045–53. PMID: 23877978. Wrong population.23877978
663 Rehder PM, Pereira BG, JL ES. The prognostic value of a normal oral glucose tolerance test in pregnant women who tested positive at screening: a validation study. Diabetol metab syndr. 2012;4(1):10. PMID: 22472182. Wrong study design.22472182
664 Reichelt AJ, Spichler ER, Branchtein L, . Fasting plasma glucose is a useful test for the detection of gestational diabetes. Brazilian Study of Gestational Diabetes (EBDG) Working Group. Diabetes Care. 1998 Aug;21(8):1246–9. doi: 10.2337/diacare.21.8.1246. PMID: 9702428. Wrong outcome.9702428
665 Reichelt AJ, Weinert LS, Mastella LS, . Clinical characteristics of women with gestational diabetes - comparison of two cohorts enrolled 20 years apart in southern Brazil. Sao Paulo Medical Journal = Revista Paulista de Medicina. 2017;135(4):376–82. PMID: 28793129. Wrong criteria KQ5.28793129
666 Renz PB, Cavagnolli G, Weinert LS, . HbA1c Test as a Tool in the Diagnosis of Gestational Diabetes Mellitus. PLoS ONE [Electronic Resource]. 2015;10(8):e0135989. PMID: 26292213. Wrong outcome.26292213
667 Renz PB, Chume FC, Timm JRT, . Diagnostic accuracy of glycated hemoglobin for gestational diabetes mellitus: a systematic review and meta-analysis. Clin Chem Lab Med. 2019;57(10):1435–49. PMID: 30893053. Not primary research.30893053
668 Retnakaran R, Luo J, Shah BR. Gestational diabetes in young women predicts future risk of serious liver disease. Diabetologia. 2019 01 Feb;62(2):306–10. PMID: 624892383. Wrong outcome.30426169
669 Retnakaran R, Qi Y, Connelly PW, . The graded relationship between glucose tolerance status in pregnancy and postpartum levels of low-density-lipoprotein cholesterol and apolipoprotein B in young women: implications for future cardiovascular risk. J Clin Endocrinal Metab. 2010;95(9):4345–53. PMID: 20631030. Wrong outcome.20631030
670 Retnakaran R, Qi Y, Sermer M, . The postpartum cardiovascular risk factor profile of women with isolated hyperglycemia at 1-hour on the oral glucose tolerance test in pregnancy. Nutr Metab Cardiovas. 2011;21(9):706–12. PMID: 21703831. Other reason.21703831
671 Retnakaran R, Shah BR. Glucose screening in pregnancy and future risk of cardiovascular disease in women: a retrospective, population-based cohort study. Lancet Diabetes Endocrinol. 2019;7(5):378–84. PMID: 30928459. Wrong population other.30928459
672 Rey E, Hudon L, Michon N, . Fasting plasma glucose versus glucose challenge test: screening for gestational diabetes and cost effectiveness. Clin Biochem. 2004 Sep;37(9):780–4. doi: 10.1016/j.clinbiochem.2004.05.018. PMID: 15329316. Wrong outcome.15329316
673 Reyes-Munoz E, Parra A, Castillo-Mora A, . Effect of the diagnostic criteria of the International Association of Diabetes and Pregnancy Study Groups on the prevalence of gestational diabetes mellitus in urban Mexican women: a cross-sectional study. Endocr Pract. 2012;18(2):146–51. PMID: 21856596. Wrong index test KQ4.21856596
674 Reyes-Munoz E, Sandoval-Osuna NL, Reyes-Mayoral C, . Sensitivity of fasting glucose for gestational diabetes mellitus screening in Mexican adolescents based on International Association of Diabetes and Pregnancy Study Groups criteria: a diagnostic accuracy study based on retrospective data analysis. BMJ Open. 2018;8(4):e021617. PMID: 29654051. Wrong study design.29654051
675 Ribeiro MC, Nakamura MU, Scanavino Mde T, . Female sexual function and gestational diabetes. J Sex Med. 2012;9(3):786–92. PMID: 22189099. Wrong comparison KQ222189099
676 Ricart W, Lopez J, Mozas J, . Potential impact of American Diabetes Association (2000) criteria for diagnosis of gestational diabetes mellitus in Spain. Diabetologia. 2005 Jun;48(6):1135–41. doi: 10.1007/s00125-005-1756-9. PMID: 15889233. Wrong population.15889233
677 Rice MM, Landon MB, Varner MW, . Pregnancy-Associated Hypertension in Glucose-Intolerant Pregnancy and Subsequent Metabolic Syndrome. Obstet Gynecol. 2016;127(4):771–9. PMID: 26959208. Wrong outcome.26959208
678 Riddle SW, Nommsen-Rivers LA. A Case Control Study of Diabetes During Pregnancy and Low Milk Supply. Breastfeed Med. 2016;11(2):80–5. PMID: 26859784. Wrong outcome.26859784
679 Riskin-Mashiah S, Damti A, Younes G, . First trimester fasting hyperglycemia as a predictor for the development of gestational diabetes mellitus. Eur J Obstet Gynecol Reprod Biol. 2010;152(2):163–7. PMID: 20579799. Wrong study design.20579799
680 Riskin-Mashiah S, Damti A, Younes G, . Normal fasting plasma glucose levels during pregnancy: a hospital-based study. J Perinat Med. 2011;39(2):209–11. PMID: 21241203. Wrong study design.21241203
681 Robledo C, Peck JD, Stoner JA, . Is bisphenol-A exposure during pregnancy associated with blood glucose levels or diagnosis of gestational diabetes. J Toxicol Environ Health Part A. 2013 18 Jul;76(14):865–73. PMID: 369969799. Wrong index test KQ4.
682 Roeckner JT, Bennett S, Mitta M, . Pregnancy outcomes associated with an abnormal 50-g glucose screen during pregnancy: a systematic review and Meta-analysis. J Matern Fetal Neonatal Med. 2020:1–9. PMID: 31893960. Not primary research.31893960
683 Roeder HA, Moore TR, Wolfson MT, . Treating hyperglycemia in early pregnancy: a randomized controlled trial. American j obstet gynecol MFM. 2019;1(1):33‐41. doi: 10.1016/j.ajogmf.2019.03.003. PMID: CN-02086643. Duplicates.
684 Roshanravan N, Alizadeh M, Hedayati M, . Effect of zinc supplementation on insulin resistance, energy and macronutrients intakes in pregnant women with impaired glucose tolerance. Iran J Public Health. 2015;44(2):211–7. PMID: 25905055. Wrong intervention.25905055
685 Rowan JA, Budden A, Sadler LC. Women with a nondiagnostic 75 g glucose tolerance test but elevated HbA1c in pregnancy: an additional group of women with gestational diabetes. Aust NZ J Obstet Gynaecol. 2014;54(2):177–80. PMID: 24359339. Wrong study design.24359339
686 Rudge MVC, Barbosa AMP, Sobrevia L, . Altered maternal metabolism during mild gestational hyperglycemia as a predictor of adverse perinatal outcomes: A comprehensive analysis. Biochim Biophys Acta Mol Basis Dis. 2020;1866(2) PMID: 2002074024. Not primary research.
687 Rudland VL, Hinchcliffe M, Pinner J, . Identifying Glucokinase Monogenic Diabetes in a Multiethnic Gestational Diabetes Mellitus Cohort: New Pregnancy Screening Criteria and Utility of HbA1c. Diabetes Care. 2016;39(1):50–2. PMID: 26109503. Wrong study design.26109503
688 Ruiz-Gracia T, Duran A, Fuentes M, . Lifestyle patterns in early pregnancy linked to gestational diabetes mellitus diagnoses when using IADPSG criteria. The St Carlos gestational study. Clin Nutr. 2016;35(3):699–705. PMID: 25998584. Wrong population (KQ4 development cohort).25998584
689 Ruohomaki A, Toffol E, Upadhyaya S, . The association between gestational diabetes mellitus and postpartum depressive symptomatology: A prospective cohort study. J Affec Disord. 2018;241:263–8. PMID: 30138811. Wrong comparison KQ230138811
690 Rust O, Bofill JA, Carroll SC, . Two-hour postprandial test versus one-hour, fifty-gram glucola test as screening tools for gestational diabetes: a critical analysis. J Perinatol. 1998 Jan-Feb;18(1):49–54. PMID: 9527945. Wrong outcome.9527945
691 Ryan DK, Haddow L, Ramaesh A, . Early screening and treatment of gestational diabetes in high-risk women improves maternal and neonatal outcomes: A retrospective clinical audit. Diabetes Res Clin. 2018;144:294–301. PMID: 30244050. Wrong study design.30244050
692 Ryan EA, Savu A, Yeung RO, . Elevated fasting vs post-load glucose levels and pregnancy outcomes in gestational diabetes: a population-based study. Diabet Med. 2020 01 Jan;37(1):114–22. Wrong comparison other.31705695
693 Ryser Ruetschi J, Jornayvaz FR, Rivest R, . Fasting glycaemia to simplify screening for gestational diabetes. Int J Obstet Gynaecol. 2016;123(13):2219–22. PMID: 26810795. Wrong study design.26810795
694 Ryu AJ, Moon HJ, Na JO, . The usefulness of the glycosylated hemoglobin level for the diagnosis of gestational diabetes mellitus in the Korean population. Diabetes Metab. 2015;39(6):507–11. PMID: 607449145. Wrong study design.
695 Saccone G, Caissutti C, Khalifeh A, . One step versus two step approach for gestational diabetes screening: systematic review and meta-analysis of the randomized trials. J Matern Fetal Neonatal Med. 2019;32(9):1547–55. PMID: 29157030. Not primary research.29157030
696 Saccone G, Khalifeh A, Al-Kouatly HB, . Screening for gestational diabetes mellitus: one step versus two step approach. A meta-analysis of randomized trials. J Matern Fetal Neonatal Med. 2020;33(9):1616–24. PMID: 30173594. Not primary research.30173594
697 Sacks DA, Black MH, Li X, . Adverse Pregnancy Outcomes Using The International Association of the Diabetes and Pregnancy Study Groups Criteria: Glycemic Thresholds and Associated Risks. Obstet Gynecol. 2015;126(1):67–73. PMID: 26241258. Wrong criteria KQ5.26241258
698 Sacks DA, Grant DL, Macias M, . The virtual office visit for women with gestational diabetes mellitus. Diabetes Care. 2017 01 Mar;40(3):e34–e5. PMID: 616524018. Wrong comparison.28077459
699 Sacks DA, Greenspoon JS, Abu-Fadil S, . Toward universal criteria for gestational diabetes: the 75-gram glucose tolerance test in pregnancy. Am J Obstet Gynecol. 1995 Feb;172(2 Pt 1):607–14. doi: 10.1016/0002-9378(95)90580-4. PMID: 7856693. Wrong population.7856693
700 Sacks DA, Hadden DR, Maresh M, . Frequency of gestational diabetes mellitus at collaborating centers based on IADPSG consensus panel-recommended criteria: the Hyperglycemia and Adverse Pregnancy Outcome (HAPO) Study. Diabetes Care. 2012;35(3):526–8. PMID: 22355019. Wrong outcome.22355019
701 Sagili H, Kamalanathan S, Sahoo J, . Comparison of different criteria for diagnosis of gestational diabetes mellitus. Indian J Endocr Metab. 2015;19(6):824–8. PMID: 26693435. Wrong criteria KQ5.26693435
702 Sahin Aker S, Yuce T, Kalafat E, . Association of first trimester serum uric acid levels gestational diabetes mellitus development. Turk J Obstet Gynecol. 2016;13(2):71–4. PMID: 28913095. Wrong index test KQ4.28913095
703 Sahrakorpi N, Rono K, Koivusalo SB, . Effect of lifestyle counselling on health-related quality of life in women at high risk for gestational diabetes. Eur J Public Health. 2018;29:29. PMID: 30500903. Wrong comparison KQ230500903
704 Salib MM, Hickman PE, Oakman C, . Retrospective reassessment of gestational diabetes mellitus diagnosis by using the new classification. Pathology. 2015;47(4):391–2. PMID: 25938356. Wrong criteria KQ5.25938356
705 Salman L, Pardo A, Krispin E, . Perinatal outcome in gestational diabetes according to different diagnostic criteria. J Perinat Med. 2019;15:15. PMID: 30982004. Wrong study design.30982004
706 Salman L, Pardo A, Krispin E, . Perinatal outcome in gestational diabetes according to different diagnostic criteria. J Perinat Med. 2019;47(5):553–7. PMID: 30982004. Wrong population other.30982004
707 Sanchez-Gonzalez CM, Castillo-Mora A, Alvarado-Maldonado IN, . Reference intervals for hemoglobin A1c (HbA1c) in healthy Mexican pregnant women: a cross-sectional study. BMC Pregnancy Childb. 2018;18(1):424. PMID: 30373541. Wrong population.30373541
708 Sanchez-Lechuga B, Lara-Barea A, Cordoba-Dona JA, . Usefulness of blood pressure monitoring in patients with gestational diabetes mellitus. Endocrinologia Diabetes y Nutricion. 2018;65(7):394–401. PMID: 29680782. Wrong comparison.29680782
709 Santos MJ, Fernandes V, Portuguese P, . Gestational diabetes mellitus: different management strategies should be adopted for different subsets of patients diagnosed by oral glucose tolerance test. Endocrine. 2018;62(3):602–10. PMID: 30088142. Wrong comparison.30088142
710 Saraswathi K, Nirupa S. Gestational diabetes mellitus in primigravida: An observational study. Res J Pharm Biol Chem Sci. 2015;6(2):1614–21. PMID: 603178967. Wrong comparison.
711 Satodiya M, Takkar N, Goel P, . Comparison of One-Step Versus Two-Step Screening for Diagnosis of GDM in Indian Population: A Randomized Controlled Trial. J Obstet Gynaecol India. 2017;67(3):190–5. PMID: 28546666. Wrong population.28546666
712 Sattler MC, Jelsma JGM, Bogaerts A, . Correlates of poor mental health in early pregnancy in obese European women. BMC Pregnancy Childb. 2017;17(1):404. PMID: 29202779. Wrong population.29202779
713 Sauder KA, Starling AP, Shapiro AL, . Diet, physical activity and mental health status are associated with dysglycaemia in pregnancy: the Healthy Start Study. Diabet Med. 2016;33(5):663–7. PMID: 26872289. Wrong population.26872289
714 Savona-Ventura C, Vassallo J, Marre M, . A composite risk assessment model to screen for gestational diabetes mellitus among Mediterranean women. Int J Gynecol Obstet. 2013;120(3):240–4. PMID: 23279935. Wrong population (KQ4 development cohort).23279935
715 Savona-Ventura C, Vassallo J, Marre M, . Comment on: Zhu et al. Fasting plasma glucose at 24-28 weeks to screen for gestational diabetes mellitus: New evidence from China. Diabetes Care 2013;36:2038-2040. Diabetes Care. 2013 Sep;36(9):e165. PMID: 372062832. Wrong outcome.23970736
716 Savona-Ventura C, Vassallo J, Marre M, . Hyperglycaemia in pregnancy in Mediterranean women. Acta Diabetol. 2012;49(6):473–80. PMID: 22941281. Wrong population (KQ4 development cohort).22941281
717 Savvidou M, Nelson SM, Makgoba M, . First-trimester prediction of gestational diabetes mellitus: examining the potential of combining maternal characteristics and laboratory measures. Diabetes. 2010;59(12):3017–22. PMID: 20876721. Wrong outcome.20876721
718 Sawant AP, Naik SS, Nagarkar VD, . Screening for gestational diabetes mellitus (GDM) with oral glucose tolerance test (OGTT) in sai shirdi rural area of Maharashtra state. Biomed Res. 2011;22(2):203–6. PMID: 362313890. Wrong index test KQ4.
719 Saxena P, Verma P, Goswami B. Comparison of Diagnostic Accuracy of Non-fasting DIPSI and HbA1c with Fasting WHO Criteria for Diagnosis of Gestational Diabetes Mellitus. J Obstet Gynaecol India. 2017;67(5):337–42. PMID: 28867884. Wrong outcome.28867884
720 Schaefer KK, Xiao W, Chen Q, . Prediction of gestational diabetes mellitus in the Born in Guangzhou Cohort Study, China. Int J Gynecol Obstet. 2018;143(2):164–71. PMID: 30030928. Wrong outcome.30030928
721 Schellinger M, Abernathy M, May C, . Improved Outcomes for Hispanic Women with Gestational Diabetes Using the Centering Pregnancy Group Prenatal Care Model. Matern Child Health J. 2017;21(2):297–305. doi: 10.1007/s10995-016-2114-x. PMID: 121083445. Language: English. Entry Date: 20171021. Revision Date: 20180201. Publication Type: Article. Wrong comparison.27423239
722 Scherneck S, Schlinke N, Beck E, . Pregnancy outcome after first-trimester exposure to metformin: A prospective cohort study. Reprod Toxicol. 2018 Oct;81:79–83. PMID: 2000972652. Wrong population.30017588
723 Schmidt CB, Voorhorst I, van de Gaar VHW, . Diabetes distress is associated with adverse pregnancy outcomes in women with gestational diabetes: a prospective cohort study. BMC Pregnancy Childbirth. 2019;19(1):223. PMID: 31269913. Wrong comparison other.31269913
724 Schoenaker D, Vergouwe Y, Soedamah-Muthu SS, . Preconception risk of gestational diabetes: Development of a prediction model in nulliparous Australian women. Diabetes Res Clin. 2018;146:48–57. PMID: 30296462. Wrong population (KQ4 development cohort).30296462
725 Scholtens DM, Kuang A, Lowe LP, . Hyperglycemia and Adverse Pregnancy Outcome Follow-up Study (HAPO FUS): Maternal Glycemia and Childhood Glucose Metabolism. Diabetes Care. 2019;42(3):381–92. PMID: 30617141. Duplicates.30617141
726 Scholtens DM, Metzger BE. Response to Comment on Scholtens et al. Hyperglycemia and Adverse Pregnancy Outcome Follow-up Study (HAPO FUS): Maternal Glycemia and Childhood Glucose Metabolism. Diabetes Care 2019;42:381-392. Diabetes Care. 2019;42(7):e128–e9. PMID: 31221713. Wrong study design.31221713
727 Schwartz ML, Ray WN, Lubarsky SL. The diagnosis and classification of gestational diabetes mellitus: is it time to change our tune? Am J Obstet Gynecol. 1999 Jun;180(6 Pt 1):1560–71. doi: 10.1016/s0002-9378(99)70052-9. PMID: 10368504. Wrong population.10368504
728 Sederstrom J. Treating two: Effective management of gestational diabetes. Drug Topics. 2013;15 PMID: 370262038. Not primary research.
729 Sella T, Shalev V, Elchalal U, . Screening for gestational diabetes in the 21st century: a population-based cohort study in Israel. J Matern-Fetal Neo M. 2013;26(4):412–6. PMID: 23035769. Wrong study design.23035769
730 Şen E, Şirin A. The Effect of Gestational Diabetes Mellitus Training upon Metabolic Control, Maternal and Neonatal Outcomes. Int JCaring Sci. 2014;7(1):313–23. PMID: 104049305. Language: English. Entry Date: 20140324. Revision Date: 20180305. Publication Type: Journal Article. Wrong comparison.
731 Seshiah V, Balaji V, Shah SN, . Diagnosis of gestational diabetes mellitus in the community. J Assoc Physicians India. 2012;60:15–7. PMID: 23405515. Wrong outcome.23405515
732 Sesmilo G, Prats P, Garcia S, . First-trimester fasting glycemia as a predictor of gestational diabetes (GDM) and adverse pregnancy outcomes. Acta Diabetologica. 2020;57(6):697–703. PMID: 31984438. Wrong outcome.31984438
733 Sexton H, Heal C, Banks J, . Impact of new diagnostic criteria for gestational diabetes. J Obstet Gynaecol Res. 2018;44(3):425–31. PMID: 29323444. Wrong study design.29323444
734 Shah BR, Sharifi F. Perinatal outcomes for untreated women with gestational diabetes by IADPSG criteria: a population-based study. BJOG. 2020;127(1):116–22. PMID: 31553136. Wrong criteria KQ5.31553136
735 Shang M, Lin L, Ma L, . Investigation on the suitability of the International Association of Diabetes and Pregnancy Study Group diagnostic criteria for gestational diabetes mellitus in China. J Obstet Gynaecol. 2014;34(2):141–5. PMID: 24456434. Wrong criteria KQ5.24456434
736 Shang M, Lin L. IADPSG criteria for diagnosing gestational diabetes mellitus and predicting adverse pregnancy outcomes. Am J Perinatol. 2014;34(2):100–4. PMID: 24232664. Wrong study design.24232664
737 Shannon MH, Wintfeld N, Liang M, . Pregnancy snapshot: a retrospective, observational case-control study to evaluate the potential effects of maternal diabetes treatment during pregnancy on macrosomia. Curr Med Res Opin. 2016;32(7):1183–92. PMID: 26958899. Wrong comparison.26958899
738 Sharma K, Wahi P, Gupta A, . Single glucose challenge test procedure for diagnosis of gestational diabetes mellitus: a Jammu cohort study. J Assoc Physicians India. 2013;61(8):558–9. PMID: 24818340. Wrong index test KQ4.24818340
739 Shen S, Lu J, Zhang L, . Single Fasting Plasma Glucose Versus 75-g Oral Glucose-Tolerance Test in Prediction of Adverse Perinatal Outcomes: A Cohort Study. EBioMedicine. 2017;16:284–91. PMID: 28122694. Wrong index test KQ4.28122694
740 Shen Y, Hou L, Liu H, . Racial differences of incident diabetes postpartum in women with a history of gestational diabetes. JDC. 2019;33(12) PMID: 2003433828. Wrong population other.
741 Shen Y, Leng J, Li W, . Lactation intensity and duration to postpartum diabetes and prediabetes risk in women with gestational diabetes. Diabetes Metab Res Rev. 2019;35(3):e3115. PMID: 30548991. Wrong population other.30548991
742 Shen Y, Li W, Leng J, . High risk of metabolic syndrome after delivery in pregnancies complicated by gestational diabetes. Diabetes Res Clin Pract. 2019;150:219–26. PMID: 30905596. Wrong population other.30905596
743 Shi M, Liu ZL, Steinmann P, . Medical nutrition therapy for pregnant women with gestational diabetes mellitus-A retrospective cohort study. Taiwanese J Obstet Gynecol. 2016;55(5):666–71. PMID: 27751413. Wrong comparison.27751413
744 Shi X, Huang P, Wang L, . Maternal postload 1-hour glucose level during pregnancy and offspring’s overweight/obesity status in preschool age. BMJ Open Diab Res Ca. 2020;8(1):02. PMID: 32049640. Wrong population other.32049640
745 Shi X, Wang D, Lin M, . Maternal Gestational Diabetes Mellitus and Offspring’s Body Mass Index from 1 to 4 Years. Endocr Pract. 2020;11:11. PMID: 32045287. Wrong population other.32045287
746 Shimodaira M, Yamasaki T, Nakayama T. The association of maternal ABO blood group with gestational diabetes mellitus in Japanese pregnant women. Diabetes Metab Syndr. 2016 Apr;10(2):S102–S5. PMID: 609610204. Wrong index test KQ4.27025793
747 Shindo R, Aoki S, Kasai J, . Impact of introducing the International Association of Diabetes and Pregnancy Study Groups (IADPSG) criteria on pregnancy outcomes in Japan. Endocrine Journal. 2020;67(1):15–20. PMID: 31511438. Wrong criteria KQ5.31511438
748 Shirazian N, Mahboubi M, Emdadi R, . Comparison of different diagnostic criteria for gestational diabetes mellitus based on the 75-g oral glucose tolerance test: a cohort study. Endocr Pract. 2008 Apr;14(3):312–7. doi: 10.4158/ep.14.3.312. PMID: 18463038. Wrong population.18463038
749 Shorer DT, Wainstock T, Sheiner E, . Long-term endocrine outcome of small for gestational age infants born to mothers with and without gestational diabetes mellitus. Gynecol Endocrinol. 2019;35(11):1003–9. PMID: 31117838. Wrong intervention other.31117838
750 Shrestha A, Chawla CD. The glucose challenge test for screening of gestational diabetes. Kathmandu Univ Med J. 2011;9(34):22–5. PMID: 22610863. Wrong outcome.22610863
751 Shub A, Chee T, Templeton A, . Timing of diagnosis of gestational diabetes and pregnancy outcomes: A retrospective cohort. Aust N Z J Obstet Gynaecol. 2019;59(1):96–101. PMID: 29672829. Wrong comparison other.29672829
752 Siad FM, Fang XY, Santana MJ, . Understanding the Experiences of East African Immigrant Women With Gestational Diabetes Mellitus. Can J Diabetes. 2018;42(6):632–8. PMID: 29914780. Wrong study design.29914780
753 Sibartie P, Quinlivan J. Implementation of the International Association of Diabetes and Pregnancy Study Groups Criteria: Not Always a Cause for Concern. J Pregnancy. 2015;2015:754085. PMID: 26788370. Wrong study design.26788370
754 Siegel AM, Coxwell CA, Biggio JR, . Impact of Interval between Screening and Diagnosis of Gestational Diabetes on Pregnancy Outcomes. Am J Perinatol. 2017;34(6):557–62. PMID: 27855464. Wrong comparison.27855464
755 Silveira ML, Whitcomb BW, Pekow P, . Perceived psychosocial stress and glucose intolerance among pregnant Hispanic women. Diabetes Metab. 2014;40(6):466–75. PMID: 24948416. Wrong population.24948416
756 Silverman ME, Reichenberg A, Savitz DA, . The risk factors for postpartum depression: A population-based study. Depress Anxiety. 2017;34(2):178–87. PMID: 28098957. Wrong comparison KQ228098957
757 Simmons D, Hague WM, Teede HJ, . Hyperglycaemia in early pregnancy: the Treatment of Booking Gestational diabetes Mellitus (TOBOGM) study. A randomised controlled trial. Med J Aust. 2018;209(9):405–6. PMID: 29793404. Wrong comparison.29793404
758 Simmons D, Nema J, Parton C, . The treatment of booking gestational diabetes mellitus (TOBOGM) pilot randomised controlled trial. BMC Pregnancy Childb. 2018;18(1):151. PMID: 29747594. Wrong comparison.29747594
759 Singh H, Soyoltulga K, Fong T, . Delivery Outcomes, Emergency Room Visits, and Psychological Aspects of Gestational Diabetes: Results From a Community Hospital Multiethnic Cohort. Diabetes Educ. 2018;44(5):465–74. PMID: 30117353. Wrong study design.30117353
760 Siribaddana SH, Deshabandu R, Rajapakse D, . The prevalence of gestational diabetes in a Sri Lankan antenatal clinic. Ceylon Med J. 1998 Jun;43(2):88–91. PMID: 9704548. Wrong outcome.9704548
761 Siricharoenthai P, Phupong V. Diagnostic accuracy of HbA1c in detecting gestational diabetes mellitus. J Matern Fetal Neonatal Med. 2019:1–4. PMID: 30691324. Duplicates.30691324
762 Sirimarco MP, Guerra HM, Lisboa EG, . Diagnostic protocol for gestational diabetes mellitus (GDM) (IADPSG/ADA, 2011): influence on the occurrence of GDM and mild gestational hyperglycemia (MGH) and on the perinatal outcomes. Diabeto metab syndr. 2017;9:2. PMID: 28053673. Wrong study design.28053673
763 Sklempe Kokic I, Ivanisevic M, Biolo G, . Combination of a structured aerobic and resistance exercise improves glycaemic control in pregnant women diagnosed with gestational diabetes mellitus. A randomised controlled trial. ACM. 2018;31(4):e232–e8. PMID: 29055674. Wrong comparison.29055674
764 Smithers LG, Mittinty MN, Dekker G, . Diabetes during pregnancy modifies the association between birth weight and education: A whole-of-population study. Diabetes Care. 2019 01 Sep;42(9):E143–E5. PMID: 2002705463. Wrong intervention other.31296644
765 Snyder BM, Baer RJ, Oltman SP, . Early pregnancy prediction of gestational diabetes mellitus risk using prenatal screening biomarkers in nulliparous women. Diabetes Res Clinin Pract. 2020;163:108139. PMID: 32272192. Wrong index test KQ4.32272192
766 Soheilykhah S, Rashidi M, Mojibian M, . An appropriate test for diagnosis of gestational diabetes mellitus. Gynecol Endocrinol. 2011 Oct;27(10):785–8. doi: 10.3109/09513590.2010.540598. PMID: 21250875. Wrong outcome.21250875
767 Sokup A, Ruszkowska-Ciastek B, Goralczyk K, . Insulin resistance as estimated by the homeostatic method at diagnosis of gestational diabetes: estimation of disease severity and therapeutic needs in a population-based study. BMC Endocrine Disorders. 2013;13:21. PMID: 23819910. Wrong comparison.23819910
768 Somani B, Arora M, Bhatia K, . A comparative study of the different diagnostic criteria of gestational diabetes mellitus and its incidence. Med Jl Armed Forces India. 2012;68(1):6–11. PMID: 24623912. Wrong study design.24623912
769 Somohano-Mendiola N, Champion JD, Vatcheva K. Assessment of Gestational Diabetes Mellitus Outcomes for Hispanic Women Living in the Rio Grande Valley. HHCI. 2019:1540415319833996. PMID: 30922188. Wrong comparison.30922188
770 Somohano-Mendiola N, Champion JD, Vatcheva K. Assessment of Gestational Diabetes Mellitus Outcomes for Hispanic Women Living in the Rio Grande Valley. HHCI. 2019;17(3):111–7. PMID: 30922188. Wrong comparison other.30922188
771 Soonthornpun S, Soonthornpun K, Aksonteing J, . A comparison between a 75-g and 100-g oral glucose tolerance test in pregnant women. Int J Gynaecol Obstet. 2003 May;81(2):169–73. doi: 10.1016/s0020-7292(03)00031-6. PMID: 12706274. Wrong index test KQ4.12706274
772 Srichumchit S, Luewan S, Tongsong T. Outcomes of pregnancy with gestational diabetes mellitus. Int J Gynaecol Obstet. 2015;131(3):251–4. PMID: 606012838. Wrong comparison.26372349
773 Stacey T, Tennant P, McCowan L, . Gestational diabetes and the risk of late stillbirth: a case-control study from England, UK. BJOG. 2019;126(8):973–82. PMID: 30891907. Duplicates.30891907
774 Stacey T, Tennant P. Authors’ reply re: Gestational diabetes and the risk of late stillbirth: a case-control study from England, UK. 2019;126:1184-. doi: 10.1111/1471-0528.15810. PMID: 137772538. Language: English. Entry Date: 20190820. Revision Date: 20190926. Publication Type: Letter to the Editor. Wrong study design.
775 Stamilio DM, Olsen T, Ratcliffe S, . False-positive 1-hour glucose challenge test and adverse perinatal outcomes. Obstet Gynecol. 2004 Jan;103(1):148–56. doi: 10.1097/01.aog.0000109220.24211.bd. PMID: 14704259. Wrong population.14704259
776 Stevens DR, Taylor SN, Roberts JR, . Breastfeeding Initiation as Related to the Interaction of Race/Ethnicity and Maternal Diabetes. Breastfeed Med. 2019;14(9):630–9. doi: 10.1089/bfm.2019.0065. PMID: 139873246. Language: English. Entry Date: In Process. Revision Date: 20200330. Publication Type: journal article. Journal Subset: Biomedical. Wrong outcome.31364862
777 Sugiyama T, Metoki H, Hamada H, . A retrospective multi-institutional study of treatment for mild gestational diabetes in Japan. Diabetes Res Clin. 2014;103(3):412–8. PMID: 24485857. Wrong study design.24485857
778 Sukur YE, Seval MM, Ozmen B, . Is omitting the 3rd hour measurement in the 100 g oral glucose tolerance test feasible? J Perinat Med. 2016;44(4):363–7. PMID: 26124045. Wrong study design.26124045
779 Surapaneni T, Nikhat I, Nirmalan PK. Diagnostic effectiveness of 75 g oral glucose tolerance test for gestational diabetes in India based on the International Association of the Diabetes and Pregnancy Study Groups guidelines. Obstet Med. 2013;6(3):125–8. PMID: 27708704. Wrong study design.27708704
780 Syngelaki A, Kotecha R, Pastides A, . First-trimester biochemical markers of placentation in screening for gestational diabetes mellitus. Metab Clin Exp. 2015 Nov;64(11):1485–9. PMID: 605984616. Wrong population (KQ4 development cohort).26362726
781 Syngelaki A, Pastides A, Kotecha R, . First-Trimester Screening for Gestational Diabetes Mellitus Based on Maternal Characteristics and History. Fetal Diagn Ther. 2015;38(1):14–21. PMID: 25531073. Wrong outcome.25531073
782 Syngelaki A, Visser GHA, Krithinakis K, . First trimester screening for gestational diabetes mellitus by maternal factors and markers of inflammation. Metab Clin Exp. 2016 01 Mar;65(3):131–7. PMID: 608438343. Wrong index test KQ4.26892524
783 Tadesse WG, Dunlevy F, Nazir SF, . 139: Multidisciplinary group education for the treatment of gestational diabetes mellitus. Am J Obstet Gynecol. 2016;214:S92–S3. doi: 10.1016/j.ajog.2015.10.175. PMID: 111975817. Language: English. Entry Date: In Process. Revision Date: 20160106. Publication Type: Article. Supplement Title: Jan2016 Supplement. Journal Subset: Biomedical. Wrong intervention.
784 Taghiof H, Rezai S, Henderson CE. Effect of an Exercise Intervention on Gestational Diabetes Mellitus: A Randomized Controlled Trial. Baltimore, Maryland: Lippincott Williams & Wilkins; 2015. p. 676-.
785 Tahmina S, Daniel M. A comparison of pregnancy outcomes using two diagnostic criteria for gestational diabetes mellitus-carpenter coustan criteria and international association of the diabetes and pregnancy study groups (IADPSG) criteria. J. ASEAN Fed. Endocr. Soc. 2017;32(1):27–31. PMID: 616525854. Wrong study design.33442081
786 Takmaz T, Yalvac ES, Ozcan P, . The predictive value of weight gain and waist circumference for gestational diabetes mellitus. Turk J Obstet Gynecol. 2019;16(3):199–204. PMID: 31673474. Wrong population (KQ4 development cohort).31673474
787 Tan HLE, Luu J, Caswell A, . Impact of new International Association of Diabetes and Pregnancy Study Groups (IADPSG) diagnostic criteria on perinatal outcomes in a regional tertiary hospital in New South Wales, Australia. Diabetes Res Clin. 2017;134:191–8. PMID: 28988808. Wrong study design.28988808
788 Tan PC, Aziz AZ, Ismail IS, . Gamma-glutamyltransferase, alanine transaminase and aspartate transaminase levels and the diagnosis of gestational diabetes mellitus. Clin Biochem. 2012;45(15):1192–6. PMID: 22659058. Wrong index test KQ4.22659058
789 Tan PC, Ling LP, Omar SZ. Screening for gestational diabetes at antenatal booking in a Malaysian university hospital: the role of risk factors and threshold value for the 50-g glucose challenge test. Aust N Z J Obstet Gynaecol. 2007 Jun;47(3):191–7. doi: 10.1111/j.1479-828X.2007.00717.x. PMID: 17550485. Wrong outcome.17550485
790 Tan PC, Ling LP, Omar SZ. The 50-g glucose challenge test and pregnancy outcome in a multiethnic Asian population at high risk for gestational diabetes. Int J Gynaecol Obstet. 2009 Apr;105(1):50–5. doi: 10.1016/j.ijgo.2008.11.038. PMID: 19154997. Wrong population.19154997
791 Tang JW, Pumarino J, Cameron KA, . Perceptions of misdiagnosis among women diagnosed with gestational diabetes. Diabet Med. 2016;33(10):1451–2. PMID: 26535796. Wrong outcome.26535796
792 Tantanasis T, Daniilidis A, Giannoulis C, . Sonographic assessment of fetal subcutaneous fat tissue thickness as an indicator of gestational diabetes. Eur J Obstet Gynecol Reprod Biol. 2010 Oct;152(2):157–62. PMID: 50980553. Wrong index test KQ4.20609509
793 Tarim E, Cok T, Iskender C. Can the 50-g glucose challenge test be important for subsequent pregnancies? J Matern-Fetal Neo M. 2012;25(7):901–3. PMID: 22530876. Wrong study design.22530876
794 Tawfik MY. The Impact of Health Education Intervention for Prevention and Early Detection of Type 2 Diabetes in Women with Gestational Diabetes. J Community Health. 2017;42(3):500–10. PMID: 27743337. Wrong comparison.27743337
795 Teede HJ, Harrison CL, Teh WT, . Gestational diabetes: development of an early risk prediction tool to facilitate opportunities for prevention. Aust NZ J Obstet Gynaecol. 2011;51(6):499–504. PMID: 21951203. Wrong study design.21951203
796 Teh WT, Teede HJ, Paul E, . Risk factors for gestational diabetes mellitus: implications for the application of screening guidelines. Aust NZ J Obstet Gynaecol. 2011;51(1):26–30. PMID: 21299505. Wrong study design.21299505
797 Telejko B, Kuzmicki M, Kretowska MZ, . A comparison of the International Association of Diabetes and Pregnancy Study Groups Recommendations with Former Criteria for Diagnosing Gestational Diabetes Mellitus: A Retrospective Cohort Study. Exp. Clin. Endocrinol. Diabetes”. 2018;11 PMID: 622558170. Wrong criteria KQ5.
798 Temming LA, Tuuli MG, Stout MJ, . Diagnostic ability of elevated 1-h glucose challenge test. Journal of Perinatology. 2016;36(5):342–6. PMID: 26796129. Wrong index test KQ4.26796129
799 Thaware PK, Patterson CC, Young IS, . Clinical utility of ultrasonography-measured visceral adipose tissue depth as a tool in early pregnancy screening for gestational diabetes: a proof-of-concept study. Diabet Med. 2019;22:22. PMID: 30672019. Wrong index test KQ4.30672019
800 Theriault S, Forest JC, Masse J, . Validation of early risk-prediction models for gestational diabetes based on clinical characteristics. Diabetes Res Clin. 2014;103(3):419–25. PMID: 24447804. Wrong comparison.24447804
801 Theriault S, Giguere Y, Masse J, . Early prediction of gestational diabetes: a practical model combining clinical and biochemical markers. Clin Chem Lab Med. 2016;54(3):509–18. PMID: 26351946. Wrong outcome.26351946
802 Tierney M, O’Dea A, Danyliv A, . Feasibility, acceptability and uptake rates of gestational diabetes mellitus screening in primary care vs secondary care: findings from a randomised controlled mixed methods trial. Diabetologia. 2015;58(11):2486–93. PMID: 26242644. Wrong intervention.26242644
803 Tierney M, O’Dea A, Danyliv A, . Perspectives on the provision of GDM screening in general practice versus the hospital setting: a qualitative study of providers and patients. BMJ Open. 2016;6(2):e007949. PMID: 26888724. Wrong study design.26888724
804 Tita ATN, Lai Y, Landon MB, . Predictive Characteristics of Elevated 1-Hour Glucose Challenge Test Results for Gestational Diabetes. Am J Perinatol. 2017 01 Dec;34(14):1464–9. PMID: 617480445. Wrong outcome.28724164
805 Todi S, Sagili H, Kamalanathan SK. Comparison of criteria of International Association of Diabetes and Pregnancy Study Groups (IADPSG) with National Institute for Health and Care Excellence (NICE) for diagnosis of gestational diabetes mellitus. Arch Gynecol Obstet. 2020;09:09. PMID: 32388777. Wrong comparison other.32388777
806 Tonguc M, Tayyar AT, Muderris I, . An evaluation of two different screening criteria in gestational diabetes mellitus. J Matern-Fetal Neo M. 2018;31(9):1188–93. PMID: 28337930. Wrong study design.28337930
807 Toraman AR, Gurel A, Ulusal Z, . Evaluation of glucose challenge and oral glucose tolerance test results in pregnancy and estimation of prevalence of gestational diabetes mellitus at Sema Hospital in Istanbul. Turk J Med Sci. 2012;42(SUPPL.1):1235–40. PMID: 366277965. Wrong study design.
808 Toth EL, Keith KL, Littlechild R, . High Frequency of Pre-Existing Type 2 Diabetes in a Series of Pregnant Women Referred for “Gestational Diabetes” in a Large Canadian Indigenous Community. Can J Diabetes. 2016;40(6):487–9. PMID: 27427413. Wrong study design.27427413
809 Tozier PK. Colostrum versus formula supplementation for glucose stabilization in newborns of diabetic mothers. JOGNN. 2013;42(6):619–28. PMID: 25803211. Wrong population.25803211
810 Tran TS, Hirst JE, Do MA, . Early prediction of gestational diabetes mellitus in Vietnam: clinical impact of currently recommended diagnostic criteria. Diabetes Care. 2013;36(3):618–24. PMID: 23160727. Wrong population (KQ4 development cohort).23160727
811 Tripathi R, Tolia N, Gupta VK, . Screening for gestational diabetes mellitus: a prospective study in a tertiary care institution of North India. J Obstet Gynaecol Res. 2012;38(2):351–7. PMID: 22176476. Wrong comparison.22176476
812 Tripathi R, Verma D, Gupta VK, . Evaluation of 75 g glucose load in non-fasting state [Diabetes in Pregnancy Study group of India (DIPSI) criteria] as a diagnostic test for gestational diabetes mellitus. Indian J Med Res. 2017;145(2):209–14. PMID: 28639597. Wrong intervention.28639597
813 Trout KK, Homko CJ, Wetzel-Effinger L, . Macronutrient Composition or Social Determinants? Impact on Infant Outcomes With Gestational Diabetes Mellitus. Diabetes Spectr. 2016;29(2):71–8. PMID: 27182173. Wrong comparison.27182173
814 Trujillo J, Vigo A, Duncan BB, . Impact of the International Association of Diabetes and Pregnancy Study Groups criteria for gestational diabetes. Diabetes Res Clin. 2015;108(2):288–95. PMID: 25765668. Wrong comparison.25765668
815 Trutnovsky G, Panzitt T, Magnet E, . Gestational diabetes: women’s concerns, mood state, quality of life and treatment satisfaction. J Matern-Fetal Neo M. 2012;25(11):2464–6. PMID: 22525002. Wrong comparison KQ222525002
816 Tward C, Barrett J, Berger H, . Does gestational diabetes affect fetal growth and pregnancy outcome in twin pregnancies? Am J Obstet Gynecol. 2016;214(5):653.e1–8. PMID: 26596233. Wrong criteria KQ5.26596233
817 Usami T, Yokoyama M, Ueno M, . Comparison of pregnancy outcomes between women with early-onset and late-onset gestational diabetes in a retrospective multi-institutional study in Japan. J Diabetes Investig. 2020;11(1):216–22. PMID: 31199576. Wrong intervention other.31199576
818 Utz B, Assarag B, Essolbi A, . Diagnosis a posteriori? Assessing gestational diabetes screening and management in Morocco. Glob Health Action. 2016;9:32511. PMID: 27863534. Wrong comparison.27863534
819 Utz B, Assarag B, Essolbi A, . Improving detection and initial management of gestational diabetes through the primary level of care in Morocco: protocol for a cluster randomized controlled trial. Reproductive Health. 2017;14(1):75. PMID: 28629468. Wrong comparison.28629468
820 Utz B, Assarag B, Essolbi A, . Knowledge and practice related to gestational diabetes among primary health care providers in Morocco: Potential for a defragmentation of care? Prim care diabetes. 2017;11(4):389–96. PMID: 28576661. Wrong study design.28576661
821 Utz B, Assarag B, Smekens T, . Detection and initial management of gestational diabetes through primary health care services in Morocco: An effectiveness-implementation trial. PLoS ONE. 2018;13(12):e0209322. PMID: 30592751. Wrong comparison.30592751
822 van den Berg SA, de Groot MJ, Salden LP, . Pregnancy diabetes: A comparison of diagnostic protocols based on point-of-care, routine and optimized laboratory conditions. Sci Rep. 2015;5:16302. PMID: 26542612. Wrong comparison.26542612
823 van Leeuwen M, Opmeer BC, Zweers EJ, . External validation of a clinical scoring system for the risk of gestational diabetes mellitus. Diabetes Res Clin Pract. 2009 Jul;85(1):96–101. doi: 10.1016/j.diabres.2009.04.025. PMID: 19477547. Wrong outcome.19477547
824 van Leeuwen M, Zweers EJ, Opmeer BC, . Comparison of accuracy measures of two screening tests for gestational diabetes mellitus. Diabetes Care. 2007 Nov;30(11):2779–84. doi: 10.2337/dc07-0571. PMID: 17698616. Wrong outcome.17698616
825 Vanlalhruaii, Ranabir S, Prasad L, . Prevalence of gestational diabetes mellitus and its correlation with blood pressure in Manipuri women. Indian J Endocr Metab. 2013;17(6):957–61. PMID: 24381867. Wrong study design.24381867
826 Varela P, Spyropoulou AC, Kalogerakis Z, . Association between gestational diabetes and perinatal depressive symptoms: evidence from a Greek cohort study. Prim Health Care Res Dev. 2017;18(5):441–7. PMID: 28578724. Wrong comparison KQ228578724
827 Vellamkondu A, Vasudeva A, Bhat RG, . Risk Assessment at 11-14-Week Antenatal Visit: A Tertiary Referral Center Experience from South India. J Obstet Gynaecol India. 2017;67(6):421–7. PMID: 29162956. Wrong index test KQ4.29162956
828 Verd S, de Sotto D, Fernandez C, . The Effects of Mild Gestational Hyperglycemia on Exclusive Breastfeeding Cessation. Nutrients. 2016;8(11):19. PMID: 27869777. Wrong outcome.27869777
829 Veres M, Lacziko S, Babes A. The influence of first trimester maternal glucose on fetal growth and possible implications in pregnancy evolution Rom J Diabetes Nutr Metab Dis. 2013;20(2):141–8. PMID: 369169986. Wrong comparison.
830 Verhaeghe J, Van Herck E, Benhalima K, . Glycated hemoglobin in pregnancies at increased risk for gestational diabetes mellitus. Eur J Obstet Gynecol Reprod Biol. 2012;161(2):157–62. PMID: 22342592. Wrong study design.22342592
831 Vesco KK, Sharma AJ, Bulkley J, . Association of Glucose Levels in Pregnancy with Use of Health Care Services. Diabetes Res Clin. 2019;04:04. PMID: 31063853. Wrong comparison.31063853
832 Vigo PD, Silvares EA. Gestational diabetes: Maternal programming. Prog. en Obstet. y Ginecol. 2019 March-April;62(2):168–80. Not primary research.
833 Voormolen DN, de Wit L, van Rijn BB, . Neonatal Hypoglycemia Following Diet-Controlled and Insulin-Treated Gestational Diabetes Mellitus. Diabetes Care. 2018;41(7):1385–90. PMID: 29654142. Wrong comparison.29654142
834 Vounzoulaki E, Khunti K, Abner SC, . Progression to type 2 diabetes in women with a known history of gestational diabetes: systematic review and meta-analysis. BMJ. 2020;369:m1361. PMID: 32404325. Wrong study design.32404325
835 Wahab RJ, Voerman E, Jansen PW, . Maternal Glucose Concentrations in Early Pregnancy and Cardiometabolic Risk Factors in Childhood. Obesity. 2020;28(5):985–93. PMID: 32320145. Wrong outcome.32320145
836 Walker AR, Caughey AB. Positivity thresholds of HbA1c assay as a screening test for diabetes mellitus in the first trimester in high-risk populations. J Matern Fetal Neonatal Med. 2020:1–5. PMID: 32146861. Wrong index test KQ4.32146861
837 Walmer R, Huynh J, Wenger J, . Mental Health Disorders Subsequent to Gestational Diabetes Mellitus Differ By Race/Ethnicity. Depress Anxiety. 2015 Oct;32(10):774–82. doi: 10.1002/da.22388. PMID: 26130074. Wrong comparison KQ226130074
838 Walter E, Tsumi E, Wainstock T, . Maternal gestational diabetes mellitus: is it associated with long-term pediatric ophthalmic morbidity of the offspring J Matern Fetal Neonatal Med. 2019;32(15):2529–38. PMID: 29429374. Wrong population other.29429374
839 Wang C, Zhu W, Wei Y, . Exercise intervention during pregnancy can be used to manage weight gain and improve pregnancy outcomes in women with gestational diabetes mellitus. BMC Pregnancy Childb. 2015;15:255. PMID: 26459271. Wrong comparison.26459271
840 Wang C, Zhu W, Wei Y, . The Predictive Effects of Early Pregnancy Lipid Profiles and Fasting Glucose on the Risk of Gestational Diabetes Mellitus Stratified by Body Mass Index. J Diabetes Res. 2016;2016:3013567. PMID: 26981541. Wrong study design.26981541
841 Wang H, Jiang H, Yang L, . Impacts of dietary fat changes on pregnant women with gestational diabetes mellitus: a randomized controlled study. Asia Pac J Clin Nutr. 2015;24(1):58–64. PMID: 25740743. Wrong comparison.25740743
842 Wang J, Pan L, Liu E, . Gestational diabetes and offspring’s growth from birth to 6 years old. Int J Obes. 2019;43(4):663–72. PMID: 30181654. Wrong population other.30181654
843 Wang P, Lu MC, Yu CW, . Influence of food intake on the predictive value of the gestational diabetes mellitus screening test. Obstet Gynecol. 2013;121(4):750–8. PMID: 23635674. Wrong study design.23635674
844 Wang P, Ma HH, Hou XZ, . Reduced plasma level of irisin in first trimester as a risk factor for the development of gestational diabetes mellitus. Diabetes Res Clin. 2018;142:130–8. PMID: 29852234. Wrong outcome.29852234
845 Wang S, Ma JM, Yang HX. Lifestyle intervention for gestational diabetes mellitus prevention: A cluster-randomized controlled study. Chronic Dis Transl Med. 2015;1(3):169–74. PMID: 29063004. Wrong intervention.29063004
846 Wang X, Martinez MP, Chow T, . BMI growth trajectory from ages 2 to 6 years and its association with maternal obesity, diabetes during pregnancy, gestational weight gain, and breastfeeding. Pediatric Obesity. 2020;15(2):e12579. PMID: 31691508. Wrong population other.31691508
847 Wei Q, Sun Z, Yang Y, . Effect of a CGMS and SMBG on Maternal and Neonatal Outcomes in Gestational Diabetes Mellitus: a Randomized Controlled Trial. Sci Rep. 2016;6:19920. PMID: 26814139. Wrong comparison.26814139
848 Wei Y, Yang H, Zhu W, . Adverse pregnancy outcome among women with pre-gestational diabetes mellitus: a population-based multi-centric study in Beijing. J Matern-Fetal Neo M. 2017;30(20):2395–7. PMID: 27822972. Wrong index test KQ4.27822972
849 Wei YM, Liu XY, Shou C, . Value of fasting plasma glucose to screen gestational diabetes mellitus before the 24th gestational week in women with different pre-pregnancy body mass index. Chin Med J. 2019;132(8):883–8. PMID: 30958429. Wrong study design.30958429
850 Wei YM, Liu XY, Shou C, . Value of fasting plasma glucose to screen gestational diabetes mellitus before the 24th gestational week in women with different pre-pregnancy body mass index. Chin Med J.. 2019;132(8):883–8. PMID: 30958429. Wrong study design.30958429
851 Wei YM, Yan J, Yang HX. Identification of severe gestational diabetes mellitus after new criteria used in China. J Perinatol. 2016;36(2):90–4. PMID: 26562371. Wrong criteria KQ5.26562371
852 Wei YM, Yang HX, Zhu WW, . Effects of intervention to mild GDM on outcomes. J Matern-Fetal Neo M. 2015;28(8):928–31. PMID: 25068946. Wrong study design.25068946
853 Weiss C, Oppelt P, Mayer RB. The participation rate of migrant women in gestational diabetes screening in Austria: a retrospective analysis of 3293 births. Arch Gynecol Obstet. 2019;299(2):345–51. PMID: 30460613. Wrong outcome.30460613
854 White SL, Lawlor DA, Briley AL, . Early Antenatal Prediction of Gestational Diabetes in Obese Women: Development of Prediction Tools for Targeted Intervention. PLoS ONE [Electronic Resource]. 2016;11(12):e0167846. PMID: 27930697. Wrong population (KQ4 development cohort).27930697
855 Whitehead L. The Effects of Different Types of Dietary Advice for Women With Gestational Diabetes Mellitus on Pregnancy Outcomes. Clin Nurse Spec. 2018;32(4):175–6. PMID: 29878927. Not primary research.29878927
856 Wijeyaratne CN, Ginige S, Arasalingam A, . Screening for gestational diabetes mellitus: the Sri Lankan experience. Ceylon Med J. 2006 Jun;51(2):53–8. doi: 10.4038/cmj.v51i2.1353. PMID: 17180809. Wrong outcome.17180809
857 Wilson CA, Newham J, Rankin J, . Is there an increased risk of perinatal mental disorder in women with gestational diabetes? A systematic review and meta-analysis. Diabet Med. 2020;37(4):602–22. PMID: 31693201. Not primary research.31693201
858 Wiwanitkit V. Blood glucose test in gestational diabetes screening: A Forgotten Point. Turk J Endocrinol Metab 2012;16(1):29. PMID: 365181915. Not primary research.
859 Wong VW, Chong S, Mediratta S, . Measuring glycated haemoglobin in women with gestational diabetes mellitus: How useful is it? Aust NZ J Obstet Gynaecol. 2017;57(3):260–5. PMID: 27501522. Wrong comparison.27501522
860 Wong VW, Lin A, Russell H. Adopting the new World Health Organization diagnostic criteria for gestational diabetes: How the prevalence changes in a high-risk region in Australia. Diabetes Res Clin. 2017;129:148–53. PMID: 28528075. Wrong criteria KQ5.28528075
861 Worda K, Bancher-Todesca D, Husslein P, . Randomized controlled trial of induction at 38 weeks versus 40 weeks gestation on maternal and infant outcomes in women with insulin-controlled gestational diabetes. Wiener Klinische Wochenschrift. 2017;129(17-18):618–24. PMID: 28168363. Wrong intervention.28168363
862 Wouldes TA, Battin M, Coat S, . Neurodevelopmental outcome at 2 years in offspring of women randomised to metformin or insulin treatment for gestational diabetes. Arch Dis Child Fetal Neonatal Ed. 2016;101(6):F488–F93. PMID: 26912348. Wrong comparison.26912348
863 Wu ET, Nien FJ, Kuo CH, . Diagnosis of more gestational diabetes lead to better pregnancy outcomes: Comparing the International Association of the Diabetes and Pregnancy Study Group criteria, and the Carpenter and Coustan criteria. J Diabetes Invest. 2016;7(1):121–6. PMID: 26816609. Wrong study design.26816609
864 Yachi Y, Tanaka Y, Anasako Y, . Contribution of first trimester fasting plasma insulin levels to the incidence of glucose intolerance in later pregnancy: Tanaka women’s clinic study. Diabetes Res Clin. 2011;92(2):293–8. PMID: 21396732. Wrong index test KQ4.21396732
865 Yan B, Yu YX, Chen YL, . Assessment of the optimal cutoff value of fasting plasma glucose to establish diagnosis of gestational diabetes mellitus in Chinese women. Scientific Reports. 2019;9(1):15998. PMID: 31690787. Wrong study design.31690787
866 Yan Y, Liu Z, Liu D. Heterogeneity of glycometabolism in patients with gestational diabetes mellitus: Retrospective study of 1,683 pregnant women. J Diabetes Invest. 2017;8(4):554–9. PMID: 27863107. Wrong criteria KQ5.27863107
867 Yang P, Lo W, He ZL, . Medical nutrition treatment of women with gestational diabetes mellitus by a telemedicine system based on smartphones. J Obstet Gynaecol Res. 2018;44(7):1228–34. PMID: 29797375. Wrong comparison.29797375
868 Yang X, Hsu-Hage B, Zhang H, . Women with impaired glucose tolerance during pregnancy have significantly poor pregnancy outcomes. Diabetes Care. 2002 Sep;25(9):1619–24. doi: 10.2337/diacare.25.9.1619. PMID: 12196437. Wrong population.12196437
869 Yang X, Tian H, Zhang F, . Erratum to: a randomised translational trial of lifestyle intervention using a 3-tier shared care approach on pregnancy outcomes in Chinese women with gestational diabetes mellitus but without diabetes. J Transl Med. 2015;13:70. PMID: 25884384. Other reason.25884384
870 Yao J, Cong L, Zhu B, . Effect of dietary approaches to stop hypertension diet plan on pregnancy outcome patients with gestational diabetes mellitus. Bangladesh J Pharmacol. 2015 18 Sep;10(4):732–8. PMID: 606074197. Wrong comparison.
871 Ye M, Liu Y, Cao X, . The utility of HbA1c for screening gestational diabetes mellitus and its relationship with adverse pregnancy outcomes. Diabetes Res Clin. 2016;114:43–9. PMID: 27103368. Wrong study design.27103368
872 Yee LM, Cheng YW, Liddell J, . 50-Gram glucose challenge test: is it indicative of outcomes in women without gestational diabetes mellitus? J Matern-Fetal Neo M. 2011;24(9):1102–6. PMID: 21261449. Wrong study design.21261449
873 Yeral MI, Ozgu-Erdinc AS, Uygur D, . Prediction of gestational diabetes mellitus in the first trimester, comparison of fasting plasma glucose, two-step and one-step methods: a prospective randomized controlled trial. Endocrine. 2014;46(3):512–8. PMID: 24282036. Wrong outcome.24282036
874 Yew TW, Khoo CM, Thai AC, . The Prevalence of Gestational Diabetes Mellitus Among Asian Females is Lower Using the New 2013 World Health Organization Diagnostic Criteria. Endocrine Practice. 2014;20(10):1064–9. PMID: 24936548. Wrong criteria KQ5.24936548
875 Yilmaz H, Celik HT, Namuslu M, . Benefits of the neutrophil-to-lymphocyte ratio for the prediction of gestational diabetes mellitus in pregnant women. Exp Clin Endocr Diab. 2014;122(1):39–43. PMID: 24464596. Wrong index test KQ4.24464596
876 Yogev Y, Eisner M, Hiersch L, . The performance of the screening test for gestational diabetes in twin versus singleton pregnancies. J Matern-Fetal Neo M. 2014;27(1):57–61. PMID: 23617682. Wrong outcome.23617682
877 Yogev Y, Langer O, Xenakis EM, . Glucose screening in Mexican-American women. Obstet Gynecol. 2004 Jun;103(6):1241–5. doi: 10.1097/01.AOG.0000124781.98059.fe. PMID: 15172859. Wrong outcome.15172859
878 Youngwanichsetha S, Phumdoung S, Ingkathawornwong T. The effects of mindfulness eating and yoga exercise on blood sugar levels of pregnant women with gestational diabetes mellitus. Appl Nurs Res. 2014;27(4):227–30. PMID: 24629718. Wrong comparison.24629718
879 Youngwanichsetha S. Factors related to exclusive breastfeeding among postpartum Thai women with a history of gestational diabetes mellitus J Reprod Infant Psychol. 2013;31(2):208–17. doi: 10.1080/02646838.2012.755733. PMID: 104174022. Language: English. Entry Date: 20130531. Revision Date: 20150711. Publication Type: Journal Article. Wrong population.
880 Yu F, Lv L, Liang Z, . Continuous glucose monitoring effects on maternal glycemic control and pregnancy outcomes in patients with gestational diabetes mellitus: a prospective cohort study. J Clin Endocrinal Metab. 2014;99(12):4674–82. PMID: 25057872. Wrong comparison.25057872
881 Yu H, Wang J, Shrestha Y, . Importance of early elevated maternal HbA1c levels in identifying adverse fetal and neonatal events. Placenta. 2019;86:28–34. PMID: 31401007. Wrong comparison other.31401007
882 Yu Y, Arah OA, Liew Z, . Maternal diabetes during pregnancy and early onset of cardiovascular disease in offspring: population based cohort study with 40 years of follow-up. BMJ. 2019;367:l6398. PMID: 31801789. Wrong population other.31801789
883 Yuksel MA, Davutoglu EA, Yuksel IT, . Maternal serum atrial natriuretic peptide (ANP) and brain-type natriuretic peptide (BNP) levels in gestational diabetes mellitus. J Matern-Fetal Neo M. 2016 02 Aug;29(15):2527–30. PMID: 606525400. Wrong outcome.
884 Zaheri H, Najar S, Abbaspoor Z. Effectiveness of cognitive-behavioral stress management on psychological stress and glycemic control in gestational diabetes: a randomized controlled trial. J Matern-Fetal Neo M. 2017;30(11):1378–82. PMID: 27577608. Wrong intervention.27577608
885 Zakovicova E, Charvat J, Mokra D, . The optimal control of blood glucose is associated with normal blood pressure 24 hours profile and prevention of the left ventricular remodeling in the patients with gestational diabetes mellitus. Neuroendocrinol Letters. 2014;35(4):327–33. PMID: 25038606. Wrong comparison.25038606
886 Zareba-Szczudlik J, Pykalo-Gawinska D, Gawinski C, . New criteria for gestational diabetes mellitus - do they impact the outcome? Neuroendocrinology Lett. 2017;38(6):441–8. PMID: 29298286. Wrong criteria KQ5.29298286
887 Zareba-Szczudlik J, Pykalo-Gawinska D, Stepien A, . Gestational diabetes mellitus (GDM) - do the number of fulfilled diagnostic criteria predict the perinatal outcome? Ginekol Pol. 2018;89(7):381–7. PMID: 30091448. Wrong comparison.30091448
888 Zawiejska A, Wender-Ozegowska E, Radzicka S, . Maternal hyperglycemia according to IADPSG criteria as a predictor of perinatal complications in women with gestational diabetes: a retrospective observational study. J Matern-Fetal Neo M. 2014;27(15):1526–30. PMID: 24236477. Wrong study design.24236477
889 Zeng Y, Tang Y, Yue Y, . Cumulative evidence for association of parental diabetes mellitus and attention-deficit/hyperactivity disorder. Neurosci Biobehav Rev. 2019 PMID: 2003857323. Not primary research.
890 Zhang X, Xiao Y, Fan Y. Investigating the Reliability of HbA1c Monitoring for Blood Glucose Control During Late Pregnancy in Patients with Gestational Diabetes Mellitus (GDM) with and without beta-Thalassemia Minor. Diabetes Therapy. 2018;9(6):2305–13. PMID: 30284689. Wrong intervention.30284689
891 Zhang Y, Chen Z, Cao Z, . Associations of maternal glycemia and prepregnancy BMI with early childhood growth: a prospective cohort study. Ann N Y Acad Sci. 2020;1465(1):89–98. PMID: 31647576. Wrong population other.31647576
892 Zhang YJ, Jin H, Qin ZL, . Predictors of Gestational Diabetes Mellitus in Chinese Women with Polycystic Ovary Syndrome: A Cross-Sectional Study. Gynecol Obstet Invest. 2016 01 May;81(3):220–4. PMID: 606525738. Wrong outcome.26461523
893 Zheng T, Ye W, Wang X, . A simple model to predict risk of gestational diabetes mellitus from 8 to 20 weeks of gestation in Chinese women. BMC Pregnancy Childbirth. 2019;19(1):252. PMID: 31324151. Wrong population (KQ4 development cohort).31324151
894 Zhu J, Chen Y, Li C, . The diagnostic value of glycated albumin in gestational diabetes mellitus. J Endocrinol Invest. 2018;41(1):121–8. PMID: 28589381. Wrong study design.28589381
895 Zhu WW, Yang HX, Yan J, . Response to comment on: Zhu et al. Fasting plasma glucose at 24-28 weeks to screen for gestational diabetes mellitus: New evidence from China. Diabetes Care 2013; 36:2038-2040. Diabetes Care. 2013 Sep;36(9):e166. PMID: 372062833. Not primary research.23970737
896 Zwolinska-Kloc M, Zabel M, Czajkowski K, . Relations between gestational diabetes and postpartum depressive disorders and symptoms. Arch Psychiatry Psychother. 2017;19(1):43–6. PMID: 615241036. Wrong comparison KQ2.

## Appendix A6 Expert Reviewers of the Draft Report

- Andrew Garrison, MD, University of Utah Dept of Family & Preventive Medicine
- Joseph R. Biggio Jr, MD, MSc, Ochsner Health, New Orleans, LA; Ochsner Clinical School, University of Queensland, New Orleans, LA
- Diane Farrar, BSc, PhD, Bradford Institute for Health Research, Bradford Teaching Hospitals, Bradford, UK
- Florence M Brown, MD, Joslin Diabetes Center, Boston, MA
- Linda A Barbour, MD, MSPH, Professor of Medicine and Obstetrics and Gynecology, Divisions of Endocrinology, Metabolism, and Diabetes and Maternal-Fetal Medicine, University of Colorado School of Medicine at Anschutz Medical Campus, Aurora, Colorado
- Dr. Elena Gorodetsky, Office of Research on Women’s Health
- Cuilin Zhang, MD, PhD, MPH, National Institutes of Health, Division of Intramural Population Health Research, Eunice Kennedy Shriver National Institute of Child Health and Human Development
- Erin Abramsohn, MPH, DrPH and Jennifer Fuld, PhD, Centers for Disease Control and Prevention
- Representatives from the Centers for Disease Control and Prevention; the National Institutes of Health, Division of Intramural Population Health Research, Eunice Kennedy Shriver National Institute of Child Health and Human Development; the National Institutes of Health, Office of Research on Women’s Health

Note: Reviewers provided comments on a prior version of the draft report and may or may not agree with the report findings.