# References

1 Institute of Medicine and National Research Council Committee to Reexamine IOM Pregnancy Weight Guidelines. In: Rasmussen KM, Yaktine AL, eds. Weight Gain During Pregnancy: Reexamining the Guidelines. Washington, DC: National Academies Press; 2009.
2 World Health Organization. BMI classification. Switzerland: World Health Organization. http://apps.who.int/bmi/index.jsp?introPage=intro_3.html. Accessed March 4, 2019.
3 American College of Obstetricians and Gynecologists. ACOG committee opinion no. 548: weight gain during pregnancy. Obstet Gynecol. 2013 Jan;121(1):210–2. doi: 10.1097/01.AOG.0000425668.87506.4c. PMID: 23262962.23262962
4 Hales CM, Fryar CD, Carroll MD, . Trends in obesity and severe obesity prevalence in US youth and adults by sex and age, 2007-2008 to 2015-2016. JAMA. 2018;319(16):1723–5. doi: 10.1001/jama.2018.3060 %J JAMA. PMID: 29570750.29570750
5 Kim SY, Dietz PM, England L, . Trends in pre-pregnancy obesity in nine states, 1993–2003. Obesity (Silver Spring). 2007;15(4):986–93. doi: 10.1038/oby.2007.621. PMID: 17426334.17426334
6 Deputy NP, Dub B, Sharma AJ. Prevalence and trends in prepregnancy normal weight - 48 States, New York City, and District of Columbia, 2011-2015. MMWR Morb and Mortal Wkly Rep. 2018 Jan 5;66:1402–7. doi: 10.15585/mmwr.mm665152a3. PMID: 29300720.29300720
7 Branum AM, Kirmeyer SE, Gregory ECW. Prepregnancy body mass index by maternal characteristics and state: data from the birth certificate, 2014. Natl Vital Stat Rep. 2016 Aug Aug;65(6):1–11. PMID: 27508894.27508894
8 Kalliala I, Markozannes G, Gunter MJ, . Obesity and gynaecological and obstetric conditions: umbrella review of the literature. BMJ. 2017 Oct 26;359:j4511. doi: 10.1136/bmj.j4511 PMID: 29074629.29074629
9 Adane AA, Mishra GD, Tooth LR. Maternal pre-pregnancy obesity and childhood physical and cognitive development of children: a systematic review. Int J Obes (Lond). 2016 Aug;40:1608. doi: 10.1038/ijo.2016.140. PMID: 27528251.27528251
10 Álvarez-Bueno C, Cavero-Redondo I, Lucas-de la Cruz L, . Association between pre-pregnancy overweight and obesity and children’s neurocognitive development: a systematic review and meta-analysis of observational studies. Int J Epidemiol. 2017 Oct;46(5):1653–66. doi: 10.1093/ije/dyx122. PMID: 29040611.29040611
11 Bartsch E, Medcalf KE, Park AL, . Clinical risk factors for pre-eclampsia determined in early pregnancy: systematic review and meta-analysis of large cohort studies. BMJ (Clinical research ed.). 2016;353:i1753–i. doi: 10.1136/bmj.i1753. PMID: 27094586.27094586
12 Fuemmeler BF, Wang L, Iversen ES, . Association between prepregnancy body mass index and gestational weight gain with size, tempo, and velocity of infant growth: analysis of the Newborn Epigenetic Study Cohort. Child Obes. 2016;12(3):210–8. doi: 10.1089/chi.2015.0253. PMID: 27135650.27135650
13 Marchi J, Berg M, Dencker A, . Risks associated with obesity in pregnancy, for the mother and baby: a systematic review of reviews. Obes Rev. 2015 Aug;16(8):621–38. doi: 10.1111/obr.12288. PMID: 26016557.26016557
14 Mitanchez D, Chavatte-Palmer P. Review shows that maternal obesity induces serious adverse neonatal effects and is associated with childhood obesity in their offspring. Acta Paediatr. 2018;107(7):1156–65. doi: 10.1111/apa.14269. PMID: 29421859.29421859
15 Poorolajal J, Jenabi E. The association between body mass index and preeclampsia: a meta-analysis. J Matern Fetal Neonatal Med. 2016 Nov;29(22):3670–6. doi: 10.3109/14767058.2016.1140738. PMID: 26762770.26762770
16 Woo Baidal JA, Locks LM, Cheng ER, . Risk factors for childhood obesity in the first 1,000 days: a systematic review. Am J Prev Med. 2016 Jun;50(6):761–79. doi: 10.1016/j.amepre.2015.11.012. PMID: 26916261.26916261
17 Lisonkova S, Muraca GM, Potts J, . Association between prepregnancy body mass index and severe maternal morbidity. JAMA 2017 Nov;318(18):1777–86. doi: 10.1001/jama.2017.16191. PMID: 29136442.29136442
18 Voerman E, Santos S, Inskip H, . Association of gestational weight gain with adverse maternal and infant outcomes. JAMA. 2019 May 7;321(17):1702–15. doi: 10.1001/jama.2019.3820. PMID: 31063572.31063572
19 Khashan AS, Kenny LC. The effects of maternal body mass index on pregnancy outcome. Eur J Epidemiol. 2009;24(11):697–705. doi: 10.1007/s10654-009-9375-2. PMID: 19653107.19653107
20 Girsen AI, Mayo JA, Carmichael SL, . Women’s prepregnancy underweight as a risk factor for preterm birth: a retrospective study. BJOG. 2016 Nov;123(12):2001–7. doi: 10.1111/1471-0528.14027. PMID: 27172996.27172996
21 Brunner S, Stecher L, Ziebarth S, . Excessive gestational weight gain prior to glucose screening and the risk of gestational diabetes: a meta-analysis. Diabetologia. 2015 October 01;58(10):2229–37. doi: 10.1007/s00125-015-3686-5. PMID: 26141788.26141788
22 Goldstein RF, Abell SK, Ranasinha S, . Association of gestational weight gain with maternal and infant outcomes: a systematic review and meta-analysis. JAMA. 2017 Jun 6;317(21):2207–25. doi: 10.1001/jama.2017.3635. PMID: 28586887.28586887
23 Viswanathan M, Siega-Riz AM, Moos MK, . Outcomes of maternal weight gain, evidence report/technology assessment No. 168 (Prepared by RTI International-University of North Carolina Evidence-based Practice Center under contract No. 290-02-0016.) AHRQ Publication No. 08-E009. 1530-4396. Rockville, MD: Agency for Healthcare Research and Quality; May 2008. PMID: 1862047118620471.
24 Institute of Medicine Committee on Nutritional Status During Pregnancy and Lactation. Nutrition during pregnancy: part I weight gain: part II nutrient supplements. Washington, DC: National Acadamies Press; 1990.
25 Centers for Disease Control and Prevention. QuickStats: gestational weight gain among women with full-term, singleton births, compared with recommendations — 48 States and the District of Columbia, 2015. MMWR Morb Mortal Wkly Rep. 2016;65(40):1121. doi: 10.15585/mmwr.mm6540a10. PMID: 27736838.27736838
26 Deputy NP, Sharma AJ, Kim SY, . Prevalence and characteristics associated with gestational weight gain adequacy. Obstet Gynecol. 2015 Apr;125(4):773–81. doi: 10.1097/AOG.0000000000000739. PMID: 25751216.25751216
27 Guo Y, Miao Q, Huang T, . Racial/ethnic variations in gestational weight gain: a population-based study in Ontario. Canadian Journal of Public Health Revue Canadienne de Sante Publique. 2019 Aug 26;26:26. doi: 10.17269/s41997-019-00250-z. PMID: 31452112.31452112
28 Centers for Disease Control and Prevention. Prevalence of selected and child health indicators — United States, all sites, Pregnancy Risk Assessment Monitoring System (PRAMS), 2012 and 2013 Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion. Atlanta, GA. https://www.cdc.gov/prams/pramstat/pdfs/home/prams-all-sites_508tag.pdf.
29 Pitkin RM. Nutritional support in obstetrics and gynecology. Clin Obstet Gynecol. 1976 Sep;19(3):489–513. doi: 10.1097/00003081-197609000-00002. PMID: 954246.954246
30 Sewell MF, Huston-Presley L, Amini SB, . Body mass index: a true indicator of body fat in obese gravidas. J Reprod Med. 2007 Oct;52(10):907–11. PMID: 17977164.17977164
31 Berggren EK, Groh-Wargo S, Presley L, . Maternal fat, but not lean, mass is increased among overweight/obese women with excess gestational weight gain. Am J Obstet and Gynecol. 2016 Jun 01;214(6):745.e1-.e5. doi: 10.1016/j.ajog.2015.12.026. PMID: 26719212.26719212
32 Zhang S, Rattanatray L, Morrison JL, . Maternal obesity and the early origins of childhood obesity: weighing up the benefits and costs of maternal weight loss in the periconceptional period for the offspring. Exp Diabetes Res. 2011 Aug;2011:585749. doi: 10.1155/2011/585749. PMID: 22203829.22203829
33 Oken E. Maternal and child obesity: the causal link. Obstet and Gynecol Clin North Am. 2009 Jun;36(2):361–77. doi: 10.1016/j.ogc.2009.03.007. PMID: 19501319.19501319
34 Retnakaran R, Wen SW, Tan H, . Association of timing of weight gain in pregnancy with infant birth weight. JAMA Pediatr. 2018;172(2):136–42. doi: 10.1001/jamapediatrics.2017.4016 %J JAMA Pediatrics. PMID: 29279903.29279903
35 Ramsay JE, Ferrell WR, Crawford L, . Maternal obesity is associated with dysregulation of metabolic, vascular, and inflammatory pathways. J Clin Endocrinol Metab. 2002 Sep;87(9):4231–7. doi: 10.1210/jc.2002-020311. PMID: 12213876.12213876
36 Catalano P, Ehrenberg H. Review article: the short- and long-term implications of maternal obesity on the mother and her offspring. BJOG. 2006 Oct;113(10):1126–33. doi: 10.1111/j.1471-0528.2006.00989.x. PMID: 16827826.16827826
37 Taylor PD, Poston L. Developmental programming of obesity in mammals. Exp Physiol. 2007 Mar;92(2):287–98. doi: 10.1113/expphysiol.2005.032854. PMID: 17170060.17170060
38 Howell KR, Powell TL. Effects of maternal obesity on placental function and fetal development. Reproduction. 2017 Mar;153(3):R97–R108. doi: 10.1530/rep-16-0495. PMID: 27864335.27864335
39 Farley DM, Choi J, Dudley DJ, . Placental amino acid transport and placental leptin resistance in pregnancies complicated by maternal obesity. Placenta. 2010 Aug;31(8):718–24. doi: 10.1016/j.placenta.2010.06.006. PMID: 20609473.20609473
40 Neufeld LM, Haas JD, Grajeda R, . Changes in maternal weight from the first to second trimester of pregnancy are associated with fetal growth and infant length at birth. Am J Clin Nutr. 2004 Apr;79(4):646–52. doi: 10.1093/ajcn/79.4.646. PMID: 15051610.15051610
41 van Raaij JM, Peek ME, Vermaat-Miedema SH, . New equations for estimating body fat mass in pregnancy from body density or total body water. Am J Clin Nutr. 1988 Jul;48(1):24–9. doi: 10.1093/ajcn/48.1.24. PMID: 3389327.3389327
42 Gillman MW. Developmental origins of health and disease. N Engl J Med. 2005 Oct 27;353(17):1848–50. doi: 10.1056/NEJMe058187. PMID: 16251542.16251542
43 Barker DJP. Mothers, babies, and disease in later life. 2^nd^ ed. New York; Churchhill Livingstone; 1998.
44 Oken E, Gillman MW. Fetal origins of obesity. Obes Res. 2003 Apr;11(4):496–506. doi: 10.1038/oby.2003.69. PMID: 12690076.12690076
45 Heerman WJ, Samuels LR, Barr L, . The effect of a general healthy lifestyle intervention delivered around pregnancy on gestational weight gain and infant growth. Matern Child Health J. 2020 Aug 19doi: 10.1007/s10995-020-02998-0. PMID: 32815077.32815077
46 Finer LB, Lindberg LD, Desai S. A prospective measure of unintended pregnancy in the United States. Contraception. 2018 Dec;98(6):522–7. doi: 10.1016/j.contraception.2018.05.012. PMID: 2987939829879398
47 Baldwin MK, Overcarsh P, Patel A, . Pregnancy intention screening tools: a randomized trial to assess perceived helpfulness with communication about reproductive goals. Contracept Reprod Med. 2018 Dec;3:21. doi: 10.1186/s40834-018-0074-9. PMID: 30574355.30574355
48 ACOG practice bulletin no 156: obesity in pregnancy. Obstet Gynecol. 2015 Dec;126(6):e112–e26. doi: 10.1097/aog.0000000000001211. PMID: 26595582.26595582
49 Armstrong C. ACOG guidelines on pregnancy after bariatric surgery. Am Fam Physician. 2010;81(7):905–6.
50 Mahawar KK, Graham Y, Small PK. Optimum time for pregnancy after bariatric surgery. Surgery for obesity and related diseases : official journal of the American Society for Bariatric Surgery. 2016 Jun;12(5):1126–8. doi: 10.1016/j.soard.2016.05.005. PMID: 27350179.27350179
51 Mechanick JI, Youdim A, Jones DB, . Clinical practice guidelines for the perioperative nutritional, metabolic, and nonsurgical support of the bariatric surgery patient—2013 update: cosponsored by American Association of Clinical Endocrinologists, the Obesity Society, and American Society for Metabolic & Bariatric Surgery. Endocr Pract. 2013 Mar–Apr;19(2):337–72. doi: 10.4158/EP12437.GL. PMID: 23529351.23529351
52 American College of Obstetricians and Gynecologists. ACOG committee opinion no. 549: obesity in pregnancy. Obstet Gynecol. 2013 Jan;121(1):213–7. doi: 10.1097/01.AOG.0000425667.10377.60. PMID: 23262963.23262963
53 American College of Obstetricians and Gynecologists. Prepregnancy counseling: committee opinion no. 762. Fertil Steril. 2019 Jan;111(1):32–42. doi: 10.1016/j.fertnstert.2018.12.003. PMID: 30611411.30611411
54 Farahi N, Zolotor A. Recommendations for preconception counseling and care. Am Fam Physician. 2013 Oct 15;88(8):499–506. PMID: 24364570.24364570
55 Page CM, Ginsburg ES, Goldman RH, . Preconception consultations with maternal fetal medicine for obese women: a retrospective chart review. Fertil Res Pract. 2017 Jan 13;3(1):3. doi: 10.1186/s40738-016-0030-9. PMID: 28620542.28620542
56 Dodd JM, Turnbull D, McPhee AJ, . Antenatal lifestyle advice for women who are overweight or obese: LIMIT randomised trial. BMJ. 2014 Feb 10;348:g1285. doi: 10.1136/bmj.g1285. PMID: 24513442.24513442
57 Peaceman AM, Clifton RG, Phelan S, . Lifestyle interventions limit gestational weight gain in women with overweight or obesity: LIFE-Moms prospective meta-analysis. Obesity (Silver Spring). 2018 Sep;26(9):1396–404. doi: 10.1002/oby.22250. PMID: 30230252.30230252
58 Renault KM, Norgaard K, Nilas L, . The Treatment of Obese Pregnant women (TOP) study: a randomized controlled trial of the effect of physical activity intervention assessed by pedometer with or without dietary intervention in obese pregnant women. Am J Obstet Gynecol. 2014 Feb;210(2):134.e1–9. doi: 10.1016/j.ajog.2013.09.029. PMID: 24060449.24060449
59 Vinter CA, Jensen DM, Ovesen P, . The LiP (Lifestyle in Pregnancy) study: a randomized controlled trial of lifestyle intervention in 360 obese pregnant women. Diabetes Care. 2011 Dec;34(12):2502–7. doi: 10.2337/dc11-1150. PMID: 21972411.21972411
60 International Weight Management in Pregnancy Collaborative G. Effect of diet and physical activity based interventions in pregnancy on gestational weight gain and pregnancy outcomes: meta-analysis of individual participant data from randomised trials. BMJ. 2017 Jul 19;358:j3119. doi: 10.1136/bmj.j3119. PMID: 28724518.28724518
61 Power ML, Lott ML, Mackeen AD, . A retrospective study of gestational weight gain in relation to the Institute of Medicine’s recommendations by maternal body mass index in rural Pennsylvania from 2006 to 2015. BMC Pregnancy Childbirth. 2018 June 18;18(1):239. doi: 10.1186/s12884-018-1883-1. PMID: 29914428.29914428
62 Power ML, Schulkin J. Obstetrician/gynecologists’ knowledge, attitudes, and practices regarding weight gain during pregnancy. J Womens Health (Larchmt). 2017;26(11):1169–75. doi: 10.1089/jwh.2016.6236. PMID: 28604154.28604154
63 Whitaker KM, Becker C, Healy H, . Women’s report of health care provider advice and gestational weight gain: a systematic review. Journal of Women’s Health 2020. doi: 10.1089/jwh.2019.8223. PMID: 32343926.32343926
64 Weeks A, Liu RH, Ferraro ZM, . Inconsistent weight communication among prenatal healthcare providers and patients: a narrative review. Obstet Gynecol Surv. 2018 Aug;73(8):423–32. doi: 10.1097/ogx.0000000000000588. PMID: 30169887.30169887
65 U.S. Preventive Services Task Force. Procedure Manual. U.S. Preventive Services Task Force; 2018. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. Accessed April 17, 2019.
66 Garmendia ML, Casanello P, Flores M, . The effects of a combined intervention (docosahexaenoic acid supplementation and home-based dietary counseling) on metabolic control in obese and overweight pregnant women: the MIGHT study. Am J Obstet Gynecol. 2020 Nov 02;02:02. doi: 10.1016/j.ajog.2020.10.048. PMID: 33152314.33152314
67 Hoffmann J, Gunther J, Stecher L, . Infant growth during the first year of life following a pregnancy lifestyle intervention in routine care-Findings from the cluster-randomised GeliS trial. Pediatr Obes. 2021 Feb;16(2):e12705. doi: 10.1111/ijpo.12705. PMID: 32725809.32725809
68 Phillips JK, Skelly JM, Roberts LM, . Combined financial incentives and behavioral weight management to enhance adherence with gestational weight gain guidelines: a randomized controlled trial. Am J Obstet Gynecol MFM. 2019 Mar;1(1):42–9. doi: 10.1016/j.ajogmf.2019.02.002. PMID: 33319756.33319756
69 Holmes H, Palacios C, Wu Y, . Effect of a short message service intervention on excessive gestational weight gain in a low-income population: A randomized controlled trial. Nutrients. 2020;12(5):1428. doi: 10.3390/nu12051428. PMID: 32429069.32429069
70 Huang RC, Silva D, Beilin L, . Feasibility of conducting an early pregnancy diet and lifestyle e-health intervention: the Pregnancy Lifestyle Activity Nutrition (PLAN) project. J Dev Orig Health Dis. 2020 Feb;11(1):58–70. doi: 10.1017/s2040174419000400. PMID: 31391133.31391133
71 Ferrara A, Hedderson MM, Brown SD, . A telehealth lifestyle intervention to reduce excess gestational weight gain in pregnant women with overweight or obesity (GLOW): a randomised, parallel-group, controlled trial. Lancet Diabetes Endocrinol. 2020 Jun;8(6):490–500. doi: 10.1016/S2213-8587(20)30107-8. PMID: 32445736.32445736
72 American College of Obstetricians and Gynecologists. ACOG practice bulletin no. 202: gestational hypertension and preeclampsia. Obstet Gynecol. 2019 Jan;133(1):e1–e25. doi: 10.1097/aog.0000000000003018. PMID: 30575675.30575675
73 United Nations Development Programme. Human development report 2016: human development for everyone. New York: 2017. https://www.un-ilibrary.org/content/publication/b6186701-endoi: 10.18356/b6186701-en.
74 Higgins JPT, Thompson SG, Deeks JJ, . Measuring inconsistency in meta-analyses. BMJ. 2003 Sep 06;327(7414):557–60. doi: 10.1136/bmj.327.7414.557. PMID: 12958120.12958120
75 Aguilar-Cordero MJ, Sanchez-Garcia JC, Rodriguez-Blanque R, . Moderate physical activity in an aquatic environment during pregnancy (SWEP Study) and its influence in preventing postpartum depression. J Am Psychiatr Nurses Assoc. 2019 Apr;25(2):112–21. doi: 10.1177/1078390317753675. PMID: 29490560.29490560
76 Al Wattar BH, Dodds J, Placzek A, . Mediterranean-style diet in pregnant women with metabolic risk factors (ESTEEM): a pragmatic multicentre randomised trial. PLOS Medicine. 2019 Jul 23;16(7):e1002857. doi: 10.1371/journal.pmed.1002857. PMID: 3133587131335871
77 Altazan AD, Redman LM, Burton JH, . Mood and quality of life changes in pregnancy and postpartum and the effect of a behavioral intervention targeting excess gestational weight gain in women with overweight and obesity: a parallel-arm randomized controlled pilot trial. BMC Pregnancy Childbirth. 2019 Jan 29;19(1):50. doi: 10.1186/s12884-019-2196-8. PMID: 30696408.30696408
78 Althuizen E, van der Wijden CL, van Mechelen W, . The effect of a counselling intervention on weight changes during and after pregnancy: a randomised trial. BJOG. 2013 Jan;120(1):92–9. doi: 10.1111/1471-0528.12014. PMID: 23121074.23121074
79 Asbee SM, Jenkins TR, Butler JR, . Preventing excessive weight gain during pregnancy through dietary and lifestyle counseling: a randomized controlled trial. Obstet Gynecol. 2009 Feb;113(2 Pt 1):305–12. doi: 10.1097/AOG.0b013e318195baef. PMID: 19155899.19155899
80 Assaf-Balut C, Garcia de la Torre N, Duran A, . A Mediterranean diet with additional extra virgin olive oil and pistachios reduces the incidence of gestational diabetes mellitus (GDM): a randomized controlled trial: the St. Carlos GDM prevention study. PLoS ONE. 2017 Oct 19;12(10):e0185873. doi: 10.1371/journal.pone.0185873. PMID: 29049303.29049303
81 Bacchi M, Mottola MF, Perales M, . Aquatic activities during pregnancy prevent excessive maternal weight gain and preserve birth weight: a randomized clinical trial. Am J Health Promot. 2018 Mar;32(3):729–35. doi: 10.1177/0890117117697520. PMID: 28279085.28279085
82 Barakat R, Cordero Y, Coteron J, . Exercise during pregnancy improves maternal glucose screen at 24-28 weeks: a randomised controlled trial. Br J Sports Med. 2012 Jul;46(9):656–61. doi: 10.1136/bjsports-2011-090009. PMID: 21948120.21948120
83 Barakat R, Franco E, Perales M, . Exercise during pregnancy is associated with a shorter duration of labor. A randomized clinical trial. Eur J Obstet Gynecol Reprod Biol. 2018 May;224:33–40. doi: 10.1016/j.ejogrb.2018.03.009. PMID: 29529475.29529475
84 Barakat R, Pelaez M, Cordero Y, . Exercise during pregnancy protects against hypertension and macrosomia: randomized clinical trial. Am J Obstet Gynecol. 2016 May;214(5):649.e1–8. doi: 10.1016/j.ajog.2015.11.039. PMID: 26704894.26704894
85 Barakat R, Perales M, Bacchi M, . A program of exercise throughout pregnancy. Is it safe to mother and newborn? Am J Health Promot. 2014 Sep–Oct;29(1):2–8. doi: 10.4278/ajhp.130131-QUAN-56. PMID: 24200335.24200335
86 Barakat R, Refoyo I, Coteron J, . Exercise during pregnancy has a preventative effect on excessive maternal weight gain and gestational diabetes. A randomized controlled trial. Braz J Phys Ther. 2019 Apr;23(2):148–55. doi: 10.1016/j.bjpt.2018.11.005. PMID: 30470666.30470666
87 Bogaerts AF, Devlieger R, Nuyts E, . Effects of lifestyle intervention in obese pregnant women on gestational weight gain and mental health: a randomized controlled trial. Int J Obes (Lond). 2013 Jun;37(6):814–21. doi: 10.1038/ijo.2012.162. PMID: 23032404.23032404
88 Brownfoot FC, Davey MA, Kornman L. Routine weighing to reduce excessive antenatal weight gain: a randomised controlled trial. BJOG. 2016 Jan;123(2):254–61. doi: 10.1111/1471-0528.13735. PMID: 26840637.26840637
89 Bruno R, Petrella E, Bertarini V, . Adherence to a lifestyle programme in overweight/obese pregnant women and effect on gestational diabetes mellitus: a randomized controlled trial. Matern Child Nutr. 2017 Jul;13(3)doi: 10.1111/mcn.12333. PMID: 27647837.27647837
90 Cahill AG, Haire-Joshu D, Cade WT, . Weight control program and gestational weight gain in disadvantaged women with overweight or obesity: a randomized clinical trial. Obesity (Silver Spring). 2018 Mar;26(3):485–91. doi: 10.1002/oby.22070. PMID: 29464907.29464907
91 Claesson IM, Josefsson A, Sydsjo G. Prevalence of anxiety and depressive symptoms among obese pregnant and postpartum women: an intervention study. BMC Public Health. 2010 Dec 16;10:766. doi: 10.1186/1471-2458-10-766. PMID: 21162715.21162715
92 Daley A, Jolly K, Jebb S, . Feasibility and acceptability of regular weighing, setting weight gain limits and providing feedback by community midwives to prevent excess weight gain during pregnancy: randomised controlled trial and qualitative study. BMC Obesity. 2015 Sep 16;2(1):35. doi: 10.1186/s40608-015-0061-5. PMID: 26401345.26401345
93 Daley A, Jolly K, Jebb SA, . Effectiveness of a behavioural intervention involving regular weighing and feedback by community midwives within routine antenatal care to prevent excessive gestational weight gain: POPS2 randomised controlled trial. BMJ Open. 2019;9(9):e030174. doi: 10.1136/bmjopen-2019-030174. PMID: 31530608.31530608
94 Daly N, Farren M, McKeating A, . A medically supervised pregnancy exercise intervention in obese women: a randomized controlled trial. Obstet Gynecol. 2017 Nov;130(5):1001–10. doi: 10.1097/AOG.0000000000002267. PMID: 29016485.29016485
95 Dodd JM, McPhee AJ, Deussen AR, . Effects of an antenatal dietary intervention in overweight and obese women on 6 month infant outcomes: follow-up from the LIMIT randomised trial. Int J Obes (Lond). 2018 Jul;42(7):1326–35. doi: 10.1038/s41366-018-0019-z. PMID: 29568100.29568100
96 Dodd JM, Deussen AR, Louise J. A randomised trial to optimise gestational weight gain and improve maternal and infant health outcomes through antenatal dietary, lifestyle and exercise advice: the OPTIMISE randomised trial. Nutrients. 2019 Dec 02;11(12)doi: 10.3390/nu11122911. PMID: 31810217.31810217
97 Epel E, Laraia B, Coleman-Phox K, . Effects of a mindfulness-based intervention on distress, weight gain, and glucose control for pregnant low-income women: a quasi-experimental trial using the ORBIT model. Int J Behav Med. 2019 Apr 16;26(5):461–73. doi: 10.1007/s12529-019-09779-2. PMID: 30993601.30993601
98 Gallagher D, Rosenn B, Toro-Ramos T, . Greater neonatal fat-free mass and similar fat mass following a randomized trial to control excess gestational weight gain. Obesity (Silver Spring). 2018 Mar;26(3):578–87. doi: 10.1002/oby.22079. PMID: 29464905.29464905
99 Garnaes KK, Helvik AS, Stafne SN, . Effects of supervised exercise training during pregnancy on psychological well-being among overweight and obese women: secondary analyses of the ETIP-trial, a randomised controlled trial. BMJ Open. 2019;9(11)doi: 10.1136/bmjopen-2018-028252. PMID: 31753866.31753866
100 Garnaes KK, Morkved S, Salvesen KA, . Exercise training during pregnancy reduces circulating insulin levels in overweight/obese women postpartum: secondary analysis of a randomised controlled trial (the ETIP trial). BMC Pregnancy Childbirth. 2018 Jan 08;18(1):18. doi: 10.1186/s12884-017-1653-5. PMID: 29310617.29310617
101 Garnaes KK, Morkved S, Salvesen O, . Exercise training and weight gain in obese pregnant women: a randomized controlled trial (ETIP trial). PLoS Med. 2016 Jul 26;13(7):e1002079. doi: 10.1371/journal.pmed.1002079. PMID: 27459375.27459375
102 Garnaes KK, Nyrnes SA, Salvesen KA, . Effect of supervised exercise training during pregnancy on neonatal and maternal outcomes among overweight and obese women. Secondary analyses of the ETIP trial: a randomised controlled trial. PLoS ONE. 2017 Mar 21;12(3):e0173937. doi: 10.1371/journal.pone.0173937. PMID: 28323893.28323893
103 Gesell SB, Katula JA, Strickland C, . Feasibility and initial efficacy evaluation of a community-based cognitive-behavioral lifestyle intervention to prevent excessive weight gain during pregnancy in Latina women. Matern Child Health J. 2015 Aug;19(8):1842–52. doi: 10.1007/s10995-015-1698-x. PMID: 25874878.25874878
104 Gray-Donald K, Robinson E, Collier A, . Intervening to reduce weight gain in pregnancy and gestational diabetes mellitus in Cree communities: an evaluation. CMAJ. 2000 Nov 14;163(10):1247–51. PMID: 11107459.11107459
105 Guelfi KJ, Ong MJ, Crisp NA, . Regular exercise to prevent the recurrence of gestational diabetes mellitus: a randomized controlled trial. 2016 Oct;128(4):819–27. doi: 10.1097/aog.0000000000001632. PMID: 2760787627607876
106 Haakstad LA, Bo K. Effect of regular exercise on prevention of excessive weight gain in pregnancy: a randomised controlled trial. Eur J Contracept Reprod Health Care. 2011 Apr;16(2):116–25. doi: 10.3109/13625187.2011.560307. PMID: 21417561.21417561
107 Haire-Joshu D, Cahill AG, Stein RI, . Randomized controlled trial of home-based lifestyle therapy on postpartum weight in underserved women with overweight or obesity. Obes. 2019 Apr;27(4):535–41. doi: 10.1002/oby.22413. PMID: 30900408.30900408
108 Harrison CL, Lombard CB, Strauss BJ, . Optimizing healthy gestational weight gain in women at high risk of gestational diabetes: a randomized controlled trial. Obesity (Silver Spring). 2013 May;21(5):904–9. doi: 10.1002/oby.20163. PMID: 23784892.23784892
109 Harrison CL, Lombard CB, Teede HJ. Limiting postpartum weight retention through early antenatal intervention: the HeLP-her randomised controlled trial. Int J Behav Nutr Phys Act. 2014 Oct 31;11(134). doi: 10.1186/s12966-014-0134-8. PMID: 25358909.25358909
110 Hawkins M, Hosker M, Marcus BH, . A pregnancy lifestyle intervention to prevent gestational diabetes risk factors in overweight Hispanic women: a feasibility randomized controlled trial. Diabet Med. 2014 Oct;32(1):108–15. doi: 10.1111/dme.12601. PMID: 25306925.25306925
111 Herring SJ, Cruice JF, Bennett GG, . Intervening during and after pregnancy to prevent weight retention among African American women. Prev Med Rep. 2017 Jun 1;7:119–23. doi: 10.1016/j.pmedr.2017.05.015. PMID: 28660118.28660118
112 Herring SJ, Cruice JF, Bennett GG, . Preventing excessive gestational weight gain among African American women: a randomized clinical trial. Obesity (Silver Spring). 2016 Jan;24(1):30–6. doi: 10.1002/oby.21240. PMID: 26592857.26592857
113 Hoffmann J, Gunther J, Stecher L, . Effects of a lifestyle intervention in routine care on short- and long-term maternal weight retention and breastfeeding behavior-12 months follow-up of the cluster-randomized GeliS trial. J Clin Med. 2019 Jun 19;8(6):19. doi: 10.3390/jcm8060876. PMID: 31248138.31248138
114 Hui A, Back L, Ludwig S, . Lifestyle intervention on diet and exercise reduced excessive gestational weight gain in pregnant women under a randomised controlled trial. BJOG. 2012 Jan;119(1):70–7. doi: 10.1111/j.1471-0528.2011.03184.x. PMID: 22017967.22017967
115 Hui AL, Back L, Ludwig S, . Effects of lifestyle intervention on dietary intake, physical activity level, and gestational weight gain in pregnant women with different pre-pregnancy body mass index in a randomized control trial. BMC Pregnancy Childbirth. 2014 Sep 24;14(331). doi: 10.1186/1471-2393-14-331. PMID: 25248797.25248797
116 Huvinen E, Koivusalo SB, Meinila J, . Effects of a lifestyle intervention during pregnancy and first postpartum year: findings from the RADIEL study. J Clin Endocrinol Metab. 2018 Apr 1;103(4):1669–77. doi: 10.1210/jc.2017-02477. PMID: 29409025.29409025
117 Kinnunen TI, Raitanen J, Aittasalo M, . Preventing excessive gestational weight gain--a secondary analysis of a cluster-randomised controlled trial. Eur J Clin Nutr. 2012 Dec;66(12):1344–50. doi: 10.1038/ejcn.2012.146. PMID: 23211656.23211656
118 Koivusalo SB, Rono K, Klemetti MM, . Gestational diabetes mellitus can be prevented by lifestyle intervention: the Finnish gestational diabetes prevention study (RADIEL): a randomized controlled trial.[Erratum appears in Diabetes Care. 2017 Jun 14;:; PMID: 28615238]. Diabetes Care. 2016 Jan;39(1):24–30. doi: 10.2337/dc15-0511. PMID: 26223239.26223239
119 Kunath J, Gunther J, Rauh K, . Effects of a lifestyle intervention during pregnancy to prevent excessive gestational weight gain in routine care - the cluster-randomised GeliS trial. BMC Med. 2019 Jan 14;17(5)doi: 10.1186/s12916-018-1235-z. PMID: 30636636.30636636
120 Leblanc ES, Smith NX, Vesco KK, . Weight loss prior to pregnancy and subsequent gestational weight gain: prepare, a randomized clinical trial. Am J Obstet Gynecol. 2020 Jul 17doi: 10.1016/j.ajog.2020.07.027. PMID: 32687819.32687819
121 Luoto R, Kinnunen TI, Aittasalo M, . Primary prevention of gestational diabetes mellitus and large-for-gestational-age newborns by lifestyle counseling: a cluster-randomized controlled trial. PLoS Med. 2011 May;8(5):e1001036. doi: 10.1371/journal.pmed.1001036. PMID: 21610860.21610860
122 Magriples U, Boynton MH, Kershaw TS, . The impact of group prenatal care on pregnancy and postpartum weight trajectories. Am J Obstet Gynecol. 2015 Nov;213(5):688.e1–9. doi: 10.1016/j.ajog.2015.06.066. PMID: 26164694.26164694
123 McCarthy EA, Walker SP, Ugoni A, . Self-weighing and simple dietary advice for overweight and obese pregnant women to reduce obstetric complications without impact on quality of life: a randomised controlled trial. BJOG. 2016 May;123(6):965–73. doi: 10.1111/1471-0528.13919. PMID: 26875586.26875586
124 McGiveron A, Foster S, Pearce J, . Limiting antenatal weight gain improves maternal health outcomes in severely obese pregnant women: findings of a pragmatic evaluation of a midwife-led intervention. J Hum Nutr Diet. 2015 Jan;28: Suppl 1:29–37. doi: 10.1111/jhn.12240. PMID: 24809211.24809211
125 Okesene-Gafa KAM, Li M, McKinlay CJD, . Effect of antenatal dietary interventions in maternal obesity on pregnancy weight-gain and birthweight: Healthy Mums and Babies (HUMBA) randomized trial. Am J Obstet Gynecol 2019 Mar 13:pii. doi: 10.1016/j.ajog.2019.03.003. PMID: 30878323.30878323
126 Olson CM, Groth SW, Graham ML, . The effectiveness of an online intervention in preventing excessive gestational weight gain: the e-moms roc randomized controlled trial. BMC Pregnancy Childbirth. 2018 May 9;18(148). doi: 10.1186/s12884-018-1767-4. PMID: 29743026.29743026
127 Peccei A, Blake-Lamb T, Rahilly D, . Intensive prenatal nutrition counseling in a community health setting: a randomized controlled trial. Obstet Gynecol. 2017 Aug;130(2):423–32. doi: 10.1097/AOG.0000000000002134. PMID: 28697099.28697099
128 Pelaez M, Gonzalez-Cerron S, Montejo R, . Protective effect of exercise in pregnant women including those who exceed weight gain recommendations: a randomized controlled trial. Mayo Clin Proc. 2019 Oct;94(10):1951–9. doi: 10.1016/j.mayocp.2019.01.050. PMID: 31585579.31585579
129 Perales M, Rodríguez YC, Terrones MV, . Exercise and depression in overweight and obese pregnant women: a randomised controlled trial. Archivos de medicina del deporte: revista de la Federación Española de Medicina del Deporte y de la Confederación Iberoamericana de Medicina del Deporte. 2015(167):156–63.
130 Petrella E, Malavolti M, Bertarini V, . Gestational weight gain in overweight and obese women enrolled in a healthy lifestyle and eating habits program. J Matern Fetal Neonatal Med. 2014 Sep;27(13):1348–52. doi: 10.3109/14767058.2013.858318. PMID: 24175912.24175912
131 Phelan S, Phipps MG, Abrams B, . Does behavioral intervention in pregnancy reduce postpartum weight retention? Twelve-month outcomes of the fit for delivery randomized trial. Am J Clin Nutr. 2014 Feb;99(2):302–11. doi: 10.3945/ajcn.113.070151. PMID: 24284438.24284438
132 Phelan S, Phipps MG, Abrams B, . Randomized trial of a behavioral intervention to prevent excessive gestational weight gain: the fit for delivery study. Am J Clin Nutr. 2011 Apr;93(4):772–9. doi: 10.3945/ajcn.110.005306. PMID: 21310836.21310836
133 Phelan S, Wing RR, Brannen A, . Does partial meal replacement during pregnancy reduce 12-month postpartum weight retention? Obes. 2019 Feb;27(2):226–36. doi: 10.1002/oby.22361. PMID: 30421864.30421864
134 Phelan S, Wing RR, Brannen A, . Randomized controlled clinical trial of behavioral lifestyle intervention with partial meal replacement to reduce excessive gestational weight gain. Am J Clin Nutr. 2018 Feb 1;107(2):183–94. doi: 10.1093/ajcn/nqx043. PMID: 29529157.29529157
135 Polley BA, Wing RR, Sims CJ. Randomized controlled trial to prevent excessive weight gain in pregnant women. Int J Obes Relat Metab Disord. 2002 Nov;26(11):1494–502. doi: 10.1038/sj.ijo.0802130. PMID: 12439652.12439652
136 Rauh K, Gabriel E, Kerschbaum E, . Safety and efficacy of a lifestyle intervention for pregnant women to prevent excessive maternal weight gain: a cluster-randomized controlled trial. BMC Pregnancy Childbirth. 2013 Jul 16;13(151)doi: 10.1186/1471-2393-13-151. PMID: 23865624.23865624
137 Rauh K, Gunther J, Kunath J, . Lifestyle intervention to prevent excessive maternal weight gain: mother and infant follow-up at 12 months postpartum. BMC Pregnancy Childbirth. 2015 Oct 15;15(265)doi: 10.1186/s12884-015-0701-2. PMID: 26472133.26472133
138 Redman LM, Gilmore LA, Breaux J, . Effectiveness of SmartMoms, a novel eHealth intervention for management of gestational weight gain: randomized controlled pilot trial. JMIR Mhealth Uhealth. 2017 Sep 13;5(9):e133. doi: 10.2196/mhealth.8228. PMID: 28903892.28903892
139 Ronnberg AK, Ostlund I, Fadl H, . Intervention during pregnancy to reduce excessive gestational weight gain-a randomised controlled trial. BJOG. 2014 Nov;122(4):537–44. doi: 10.1111/1471-0528.13131. PMID: 25367823.25367823
140 Rönö K, Grotenfelt NE, Klemetti M, . Effect of a lifestyle intervention during pregnancy-findings from the Finnish gestational diabetes prevention trial (RADIEL). J Perinatol. 2018b Sep;38(9):1157–64. doi: 10.1038/s41372-018-0178-8 PMID: 3004247130042471
141 Rönö K, Stach-Lempinen B, Eriksson JG, . Prevention of gestational diabetes with a prepregnancy lifestyle intervention - findings from a randomized controlled trial. Int J Women Health. 2018a Aug 27;10:493–501. doi: 10.2147/IJWH.S162061. PMID: 30214318.30214318
142 Ruiz JR, Perales M, Pelaez M, . Supervised exercise-based intervention to prevent excessive gestational weight gain: a randomized controlled trial. Mayo Clin Proc. 2013 Dec;88(12):1388–97. doi: 10.1016/j.mayocp.2013.07.020. PMID: 24290112.24290112
143 Sagedal LR, Overby NC, Bere E, . Lifestyle intervention to limit gestational weight gain: the Norwegian fit for delivery randomised controlled trial. BJOG. 2017 Jan;124(1):97–109. doi: 10.1111/1471-0528.13862. PMID: 26768233.26768233
144 Sagedal LR, Sanda B, Overby NC, . The effect of prenatal lifestyle intervention on weight retention 12 months postpartum: results of the Norwegian fit for delivery randomised controlled trial. BJOG. 2017b Jan;124(1):111–21. doi: 10.1111/1471-0528.13863. PMID: 26786294.26786294
145 Seneviratne SN, Jiang Y, Derraik J, . Effects of antenatal exercise in overweight and obese pregnant women on maternal and perinatal outcomes: a randomised controlled trial. BJOG. 2016 Mar;123(4):588–97. doi: 10.1111/1471-0528.13738. PMID: 26542419.26542419
146 Simmons D, Devlieger R, van Assche A, . Effect of physical activity and/or healthy eating on GDM risk: the DALI lifestyle study. J Clin Endocrinol Metab. 2017 Mar 1;102(3):903–13. doi: 10.1210/jc.2016-3455. PMID: 27935767.27935767
147 Skouteris H, McPhie S, Hill B, . Health coaching to prevent excessive gestational weight gain: a randomized-controlled trial. Br J Health Psychol. 2016 Feb;21(1):31–51. doi: 10.1111/bjhp.12154. PMID: 26227112.26227112
148 Smith K, Lanningham-Foster L, Welch A, . Web-based behavioral intervention increases maternal exercise but does not prevent excessive gestational weight gain in previously sedentary women. J Phys Act Health. 2016 Jun;13(6):587–93. doi: 10.1123/jpah.2015-0219. PMID: 26594820.26594820
149 Tanvig M, Vinter CA, Jorgensen JS, . Effects of lifestyle intervention in pregnancy and anthropometrics at birth on offspring metabolic profile at 2.8 years: results from the Lifestyle in Pregnancy and Offspring (LiPO) study. J Clin Endocrinol Metab. 2015 Jan;100(1):175–83. doi: 10.1210/jc.2014-2675. PMID: 25343235.25343235
150 Tanvig M, Vinter CA, Jorgensen JS, . Anthropometrics and body composition by dual energy X-ray in children of obese women: a follow-up of a randomized controlled trial (the Lifestyle in Pregnancy and Offspring [LiPO] study). PLoS ONE. 2014 Feb 24;9(2):e89590. doi: 10.1371/journal.pone.0089590. PMID: 24586896.24586896
151 Thomson JL, Goodman MH, Tussing-Humphreys LM, . Infant growth outcomes from birth to 12 months of age: findings from the delta healthy sprouts randomized comparative impact trial. Obes Sci Pract. 2018 Aug;4(4):299–307. doi: 10.1002/osp4.272. PMID: 3015122530151225
152 Thomson JL, Tussing-Humphreys LM, Goodman MH, . Gestational weight gain: results from the Delta Healthy Sprouts comparative impact trial. J Pregnancy. 2016 Jul 12;2016(5703607). doi: 10.1155/2016/5703607. PMID: 27595023.27595023
153 Van Horn L, Peaceman A, Kwasny M, . Dietary approaches to stop hypertension diet and activity to limit gestational weight: maternal offspring metabolics family intervention trial, a technology enhanced randomized trial. Am J Prev Med. 2018 Nov;55(5):603–14. doi: 10.1016/j.amepre.2018.06.015. PMID: 3026214830262148
154 Vesco KK, Karanja N, King JC, . Efficacy of a group-based dietary intervention for limiting gestational weight gain among obese women: a randomized trial. Obesity (Silver Spring). 2014 Sep;22(9):1989–96. doi: 10.1002/oby.20831. PMID: 25164259.25164259
155 Vesco KK, Leo MC, Karanja N, . One-year postpartum outcomes following a weight management intervention in pregnant women with obesity. Obesity (Silver Spring). 2016 Oct;24(10):2042–9. doi: 10.1002/oby.21597. PMID: 27670399.27670399
156 Vinter CA, Jensen DM, Ovesen P, . Postpartum weight retention and breastfeeding among obese women from the randomized controlled Lifestyle in Pregnancy (LiP) trial. Acta Obstet Gynecol Scand. 2014 Aug;93(8):794–801. doi: 10.1111/aogs.12429. PMID: 24834792.24834792
157 Willcox JC, Wilkinson SA, Lappas M, . A mobile health intervention promoting healthy gestational weight gain for women entering pregnancy at a high body mass index: the txt4two pilot randomised controlled trial. BJOG. 2017 Oct;124(11):1718–28. doi: 10.1111/1471-0528.14552. PMID: 28220604.28220604
158 Wolff S, Legarth J, Vangsgaard K, . A randomized trial of the effects of dietary counseling on gestational weight gain and glucose metabolism in obese pregnant women. Int J Obes (Lond). 2008 Mar;32(3):495–501. doi: 10.1038/sj.ijo.0803710. PMID: 18227847.18227847
159 Brik M, Fernandez-Buhigas I, Martin-Arias A, . Does exercise during pregnancy impact on maternal weight gain and fetal cardiac function? A randomized controlled trial. Ultrasound Obstet Gynecol. 2019 May 53(5):583–9. doi: 10.1002/uog.20147. PMID: 30328169.30328169
160 Cordero Y, Mottola MF, Vargas J, . Exercise is associated with a reduction in gestational diabetes mellitus. Med Sci Sports Exerc. 2015 Jul;47(7):1328–33. doi: 10.1249/MSS.0000000000000547. PMID: 25333246.25333246
161 Di Carlo C, Iannotti G, Sparice S, . The role of a personalized dietary intervention in managing gestational weight gain: a prospective, controlled study in a low-risk antenatal population. Arch Gynecol Obstet. 2014 Apr;289(4):765–70. doi: 10.1007/s00404-013-3054-y. PMID: 24129610.24129610
162 Guelinckx I, Devlieger R, Mullie P, . Effect of lifestyle intervention on dietary habits, physical activity, and gestational weight gain in obese pregnant women: a randomized controlled trial. Am J Clin Nutr. 2010 Feb;91(2):373–80. doi: 10.3945/ajcn.2009.28166. PMID: 19955397.19955397
163 Haby K, Berg M, Gyllensten H, . Mighty Mums - a lifestyle intervention at primary care level reduces gestational weight gain in women with obesity. BMC Obes. 2018 Jun 4;5(16). doi: 10.1186/s40608-018-0194-4. PMID: 29881627.29881627
164 Ilmonen J, Isolauri E, Poussa T, . Impact of dietary counselling and probiotic intervention on maternal anthropometric measurements during and after pregnancy: a randomized placebo-controlled trial. Clin Nutr. 2011 Apr;30(2):156–64. doi: 10.1016/j.clnu.2010.09.009. PMID: 20970896.20970896
165 Kinnunen TI, Pasanen M, Aittasalo M, . Preventing excessive weight gain during pregnancy - a controlled trial in primary health care. Eur J Clin Nutr. 2007 Jul;61(7):884–91. doi: 10.1038/sj.ejcn.1602602. PMID: 17228348.17228348
166 Shirazian T, Monteith S, Friedman F, . Lifestyle modification program decreases pregnancy weight gain in obese women. Am J Perinatol. 2010 May;27(5):411–4. doi: 10.1055/s-0029-1243368. PMID: 20013602.20013602
167 Dodd JM, Grivell RM, Owens JA. Antenatal dietary and lifestyle interventions for women who are overweight or obese: outcomes from the LIMIT randomized trial. Curr Nutr Rep. 2014;3(4):392–9.
168 Giannakou K, Evangelou E, Papatheodorou SI. Genetic and non-genetic risk factors for pre-eclampsia: umbrella review of systematic reviews and meta-analyses of observational studies. Ultrasound Obstet Gynecol. 2018 Jun;51(6):720–30. doi: 10.1002/uog.18959. PMID: 29143991.29143991
169 Liu P, Xu L, Wang Y, . Association between perinatal outcomes and maternal pre-pregnancy body mass index. Obes Rev. 2016 Nov;17(11):1091–102. doi: 10.1111/obr.12455. PMID: 27536879.27536879
170 Lutsiv O, Mah J, Beyene J, . The effects of morbid obesity on maternal and neonatal health outcomes: a systematic review and meta-analyses. Obes Rev. 2015 Jul;16(7):531–46. doi: 10.1111/obr.12283. PMID: 25912896.25912896
171 Schummers L, Hutcheon JA, Bodnar LM, . Risk of adverse pregnancy outcomes by prepregnancy body mass index: a population-based study to inform prepregnancy weight loss counseling. Obstet Gynecol. 2015 Jan;125(1):133–43. doi: 10.1097/AOG.0000000000000591. PMID: 25560115.25560115
172 Oteng-Ntim E, Mononen S, Sawicki O, . Interpregnancy weight change and adverse pregnancy outcomes: a systematic review and meta-analysis. BMJ Open. 2018;8(6):e018778–e. doi: 10.1136/bmjopen-2017-018778. PMID: 29866719.29866719
173 Whiteman VE, Aliyu MH, August EM, . Changes in prepregnancy body mass index between pregnancies and risk of gestational and type 2 diabetes. Arch Gynecol Obstet. 2011 Jul;284(1):235–40. doi: 10.1007/s00404-011-1917-7. PMID: 21544736.21544736
174 Lecorguillé M, Jacota M, de Lauzon-Guillain B, . An association between maternal weight change in the year before pregnancy and infant birth weight: ELFE, a French national birth cohort study. PLoS medicine. 2019;16(8):e1002871–e. doi: 10.1371/journal.pmed.1002871. PMID: 31430274.31430274
175 Patnode CD, Evans CV, Senger CA, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Behavioral Counseling to Promote a Healthful Diet and Physical Activity for Cardiovascular Disease Prevention in Adults Without Known Cardiovascular Disease Risk Factors: Updated Systematic Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2017.
176 Faucher MA, Barger MK. Gestational weight gain in obese women by class of obesity and select maternal/newborn outcomes: a systematic review. Women Birth. 2015 Sep;28(3):e70–e9. doi: 10.1016/j.wombi.2015.03.006. PMID: 25866207.25866207
177 Tian C, Hu C, He X, . Excessive weight gain during pregnancy and risk of macrosomia: a meta-analysis. Arch Gynecol Obstet. 2016 January 01;293(1):29–35. doi: 10.1007/s00404-015-3825-8. PMID: 26246412.26246412
178 LeBlanc ES, Patnode CD, Webber EM, . Behavioral and pharmacotherapy weight loss interventions to prevent obesity-related morbidity and mortality in adults: updated evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2018 Sep 18;320(11):1172–91. doi: 10.1001/jama.2018.7777. PMID: 30326501.30326501
179 Patnode CD, Evans CV, Senger CA, . Behavioral counseling to promote a healthful diet and physical activity for cardiovascular disease prevention in adults without known cardiovascular disease risk factors: updated evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2017 Jul 11;318(2):175–93. doi: 10.1001/jama.2017.3303. PMID: 28697259.28697259
180 Cornell JE, Mulrow CD, Localio R, . Random-effects meta-analysis of inconsistent effects: a time for change. Ann of Intern Med. 2014;160(4):267–70. doi: 10.7326/m13-2886. PMID: 24727843.24727843
181 LeBlanc ES, Vesco KK, Funk KL, . Prepare, a randomized trial to promote and evaluate weight loss among overweight and obese women planning pregnancy: study design and rationale. Contemp Clin Trials. 2016 Jul;49:174–80. doi: 10.1016/j.cct.2016.07.002. PMID: 27394386.27394386
182 NCT02763150. Pre-pregnancy lifestyle intervention to prevent the recurrence of gestational diabetes in overweight and obese women. 2016. https://ClinicalTrials.gov/show/NCT02763150. Accessed April 19, 2019.
183 NCT03146156. Lifestyle Intervention in Preparation for Pregnancy (LIPP). 2017.
184 NCT03244722. Preconception maternal nutrition and obesity and impact on fetal outcomes, child health and weight. 2017. https://www.clinicaltrials.gov/ct2/show/NCT03244722. Accessed April 19, 2019.
185 Erickson ML, Mey JT, Axelrod CL, . Rationale and study design for lifestyle intervention in preparation for pregnancy (LIPP): A randomized controlled trial. Contemp Clin Trials. 2020 2020/07/01/;94:106024. doi: 10.1016/j.cct.2020.106024. PMID: 32389808.32389808
186 Bellanca HK, Hunter MS. ONE KEY QUESTION®: Preventive reproductive health is part of high quality primary care. Contraception. 2013 Jul;88(1):3–6. doi: 10.1016/j.contraception.2013.05.003. PMID: 23773527.23773527
187 Centers for Disease Control and Prevention. Unintended Pregnancy. 2019. https://www.cdc.gov/reproductivehealth/contraception/unintendedpregnancy/index.htm. Accessed January 25, 2021.
188 Finer LB, Henshaw SK. Disparities in rates of unintended pregnancy in the United States, 1994 and 2001. Perspect Sex Reprod Health. 2006 Jun;38(2):90–6. doi: 10.1363/psrh.38.090.06. PMID: 16772190.16772190
189 National Institute on Minority Health and Health Disparities. HD Pulse: an ecosystem of health disparities and minority health resources. 2017. https://hdpulse.nimhd.nih.gov/. Accessed May, 2019.
190 Frick AP. Advanced maternal age and adverse pregnancy outcomes. Best Pract Res Clin Obstet Gynaecol. 2020 Jul 15 doi: 10.1016/j.bpobgyn.2020.07.005. PMID: 32741623.32741623
191 Danilack VA, Brousseau EC, Phipps MG. The effect of gestational weight gain on persistent increase in body mass index in adolescents: a longitudinal study. J Womens Health (Larchmt). 2018;27(12):1456–8. doi: 10.1089/jwh.2017.6635. PMID: 29608127.29608127
192 Groth SW. The long-term impact of adolescent gestational weight gain. Res Nurs Health. 2008 Apr;31(2):108–18. doi: 10.1002/nur.20243. PMID: 18181102.18181102
193 Phelan S, Clifton RG, Haire-Joshu D, . One-year postpartum anthropometric outcomes in mothers and children in the LIFE-Moms lifestyle intervention clinical trials. Int J Obes (Lond). 2019b Jul 10;44(1):57–68. doi: 10.1038/s41366-019-0410-4. PMID: 31292531.31292531
194 Clifton RG, Evans M, Cahill AG, . Design of lifestyle intervention trials to prevent excessive gestational weight gain in women with overweight or obesity. Obesity (Silver Spring). 2016 Feb;24(2):305–13. doi: 10.1002/oby.21330. PMID: 26708836.26708836
195 Deruelle P, Lelorain S, Deghilage S, . Rationale and design of ePPOP-ID: a multicenter randomized controlled trial using an electronic-personalized program for obesity in pregnancy to improve delivery. BMC Pregnancy Childbirth. 2020 Oct 07;20(1):602. doi: 10.1186/s12884-020-03288-x. PMID: 33028261.33028261
196 Flanagan EW, Altazan AD, Comardelle NR, . The design of a randomized clinical trial to evaluate a pragmatic and scalable ehealth intervention for the management of gestational weight gain in low-income women: Protocol for the SmartMoms in WIC Trial. JMIR Res Protoc. 2020 Sep 10;9(9):e18211. doi: 10.2196/18211. PMID: 32909954.32909954
197 Martínez-Hortelano JA, Cavero-Redondo I, Álvarez-Bueno C, . Interpregnancy weight change and hypertension during pregnancy: a systematic review and meta-analysis. Obstet Gynecol. 2020 Jan;135(1):68–79. doi: 10.1097/aog.0000000000003573. PMID: 31809428.31809428
198 Louise J, Deussen AR, Dodd JM. Gestational Weight Gain-Re-Examining the Current Paradigm. Nutrients. 2020 Aug 1;12(8)doi: 10.3390/nu12082314. PMID: 32752149.32752149
199 Champion ML, Harper LM. Gestational Weight Gain: Update on Outcomes and Interventions. Curr Diab Rep. 2020 Feb 27;20(3):11. doi: 10.1007/s11892-020-1296-1. PMID: 32108283.32108283
200 Donofry SD, Emery RL, Kolko Conlon RP, . Documenting the course of loss of control over eating prior to, during and after pregnancy among women with pre-pregnancy overweight and obesity. Int J Eat Disord. 2020 Dec 23;23:23. doi: 10.1002/eat.23454. PMID: 33368433.33368433
201 Hinkle SN, Schieve LA, Stein AD, . Associations between maternal prepregnancy body mass index and child neurodevelopment at 2 years of age. Int J Obes (Lond). 2012 Oct;36(10):1312–9. doi: 10.1038/ijo.2012.143. PMID: 22964791.22964791
202 National Institute for Health and Care Excellence. Weight management, before, during, and after pregnancy. Public Health Guideline [PH27]. London; 2010. https://www.nice.org.uk/guidance/ph27/chapter/introduction. Accessed January 2, 2018.
203 Modder J, Fitzsimmons KJ. Management of women with obesity in pregnancy CMAE/RCOG joint guideline. Centre for Maternal and Child Enquiries and the Royal College of Obstetricians and Gynaecologists; 2010. https://www.rcog.org.uk/globalassets/documents/guidelines/cmacercogjointguidelinemanagementwomenobesitypregnancya.pdf. Accessed January 2, 2018.
204 Davies GAL, Maxwell C, McLeod L, . Obesity in pregnancy: No. 239, February 2010. Int J Gyneacol Obstet. 2010 Aug;110(2):167–73. doi: 10.1016/j.ijgo.2010.03.008. PMID: 20641146.20641146