# Acknowledgments

The authors thank AHRQ Medical Officer Iris Mabry-Hernandez, MD, MPH, as well as the U.S. Preventive Services Task Force.