# Chapter 4 Discussion

## Summary of Review Findings

This report synthesizes evidence on the effect of healthy weight and weight gain interventions during pregnancy on maternal and infant health outcomes, maternal weight outcomes, and harms. Table 19 summarizes the evidence for this review; Appendix E summarizes the study characteristics of the included trials (Appendix E Table 1) and provides examples for potential implementation (Appendix E Table 2).

Table 19 Summary of Evidence

Outcome Category | Outcome | Studies (k); observations (n); study Designs | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
Maternal Health Outcomes | Gestational diabetes mellitus | 43 RCTs, 2 CCTs (N=20,149) | Reduced rates of GDM (43 trials, RR, 0.87 [95% CI, 0.79 to 0.95]; I^2^=16.4%; ARD −1.6% [95% CI, −2.5 to −0.7]).; No effect when stratified by prepregnancy BMI subgroups (p=0.14 for interaction), intervention type (p=0.68), or intensity (p=0.92). | Consistent; reasonably precise | Variation in diagnostic criteria for GDM; differences in study groups by maternal BMI. | Moderate | Moderate
Maternal Health Outcomes | Gestational hypertension | 28 RCTs, 1 CCT (N=15,053) | No effect on rates of gestational hypertension (28 trials; RR, 0.87 [95% CI, 0.70 to 1.04]; I^2^=32.5%; ARD, −0.8% [95% CI, −1.9 to 0.2]).; Statistically significant effects when stratified by intervention type (p<0.001 for interaction) and intensity (p=0.006), but not BMI subgroup (p=0.08). | Consistent; reasonably precise | Variation in timing of outcome assessment and followup; interventions heterogeneous and varied in intensity; variations in prepregnancy weight and other demographic characteristics. | Moderate | Moderate
Maternal Health Outcomes | Cesarean delivery | 46 RCTs, 2 CCTs (N=19,970) | No effect on rates of cesarean delivery (any type, 34 trials; RR, 0.98 [95% CI, 0.91 to 1.04]; I^2^=10.8%; ARD, −0.7% [95% CI, −2.4 to 0.8]); increased risk of emergency cesarean (14 trials; RR, 0.85 [95% CI, 0.74 to 0.96]; I^2^=0%; ARD, −2.4% [95% CI, −4.2 to −0.3]).; No effect when cesarean delivery (any type) stratified by BMI subgroup (p=0.70 for interaction), intervention type (p=0.37), or intensity (p=0.37). | Consistent; reasonably precise | Indication for cesarean delivery not reported in any study; unclear indications for cesarean among the studies reporting statistical differences between groups, including lack of reporting of parameters to determine elective or emergency cesarean. | Moderate | Moderate
Maternal Health Outcomes | Preeclampsia | 27 RCTs, 1 CCT (N=17,716) | No association between interventions and rates of preeclampsia (27 trials; RR, 0.98 [95% CI, 0.84 to 1.13]; I^2^=0.0%; ARD, 0.1% [95% CI, −0.6 to 0.5]).; No effect when stratified by BMI subgroup (p=0.86 for interaction), intervention type (p=0.25), or intensity (p=0.29). | Consistent; precise | Differences in followup duration and outcome assessment timing; low event rates; heterogeneous interventions; populations varied in prepregnancy weight and demographic characteristics. | High | Moderate
Maternal Health Outcomes | Postpartum hemorrhage | 9 RCTs, 1 CCT (N=6,484) | No effect was on rates of postpartum hemorrhage (9 trials; RR, 1.00 [95% CI, 0.88 to 1.15]; I^2^=0%; ARD, −0.1% [95% CI, −1.3 to 1.5]).; No effect when stratified by BMI subgroup (p=0.65 for interaction), intervention type (p=1.00), or intensity (p=0.99). | Consistent; precise | Variation in outcome definition; majority of studies not powered to detect statistical differences in outcomes; low event rates. | Low | Low
Maternal Health Outcomes | Perineal trauma | 8 RCTs (N=5,707) | No effect on rates of perineal trauma (8 trials; RR, 0.86 [95% CI, 0.52 to 1.50]; I^2^=57%; ARD, −0.7%, [95% CI, −3.2 to 1.7]).; Statistically significant effects when stratified by BMI subgroup (p=0.003 for interaction) and intervention intensity (p=0.003), but not type (p=0.73). | Consistent; imprecise | Variation in outcome definition; majority of studies not powered to detect statistical differences in outcomes; low event rates. | Low | Moderate
Maternal Health Outcomes | Maternal mortality | 2 RCTs (N=2,994) | No effect on rates of maternal death in 2 trials. No deaths were reported to be related to the interventions. | Consistent; imprecise | Low event rates; studies not designed or powered to detect statistical differences in outcomes; rare events unrelated to intervention. | Low | Low
Prepregnancy Weight Reduction Outcomes | Weight outcomes | 1 RCT (N=326) | No effect on rates of excess gestational weight gain; increased GWG for intervention vs. controls (13.2 kg [SD, 8.2] vs. 10.3 kg [SD, 7.4], p=0.03). | N/A | Only one study included; large confidence intervals in some analyses. | Insufficient | Low
Infant Health Outcomes | Macrosomia | 25 RCTs, 1 CCT (N=14,209) | Reduction in rates of macrosomia (25 trials; RR, 0.77, [95% CI, 0.65 to 0.92]; I^2^=38.3%; ARD, −1.9% [95% CI, −3.3 to −0.7]).; Statistically significant effects when stratified by intervention intensity (p=0.03 for interaction) but not BMI subgroup (p=0.24) or intervention type (p=1.00). | Consistent; imprecise | Varied definitions for outcome (less than 4,000 g and more than 4,500 g); low event rates. | Moderate | Moderate
Infant Health Outcomes | Large for gestational age | 26 RCTs (N=13,000) | Reduced rates of LGA (26 trials; RR, 0.89 [95% CI, 0.80 to 0.99]; I^2^=0%; ARD, −1.3% [95% CI, −2.3 to −0.3]).; No effect when stratified by BMI subgroup (p=0.98 for interaction), intervention type (p=0.18), or intensity (p=0.22). | Consistent; precise | Studies not powered to address LGA; low event rates. | Moderate | Moderate
Infant Health Outcomes | Preterm birth | 33 RCTs, 1 CCT (N=17,152) | No effect on rates of preterm birth (33 trials; RR, 0.93 [95% CI, 0.81 to 1.07]; I^2^=2.2%; ARD, −0.2% [95% CI, −1.1 to 0.7]).; No effect when stratified by BMI subgroup (p=0.10 for interaction), intervention type (p=0.56), or intensity (p=0.42). | Consistent; precise | Studies not powered to address preterm birth; varied definitions used for preterm birth (less than 36 weeks, 37 weeks, or not reported); low event rates. | Moderate | Moderate
Infant Health Outcomes | Respiratory distress syndrome | 8 RCTs (N=3,155) | No effect on rates of RDS (8 trials; RR, 1.00 [95% CI, 0.67 to 1.42]; I^2^=0%; ARD −0.3% [95% CI, −1.3 to 0.7]).; No effect when stratified by BMI subgroup (p=0.19 for interaction), intervention type (p=0.25), or intensity (p=0.42). | Consistent; precise | Studies not powered to address RDS; low event rates. | Low | Low
Infant Health Outcomes | Shoulder dystocia | 8 RCTs (N=6,467) | No effect on rates of shoulder dystocia (8 trials; RR, 1.05 [95% CI, 0.63 to 1.47]; I^2^=0%; ARD, 0.0%, [95% CI, −0.4 to 0.5]).; No effect when stratified by BMI subgroup (p=0.55 for interaction), intervention type (p=0.61), or intensity (p=0.89). | Consistent; precise | Studies not powered to address shoulder dystocia; low event rates. | Low | Low
Infant Health Outcomes | NICU admissions | 14 RCTs (N=8,426) | No effect of rates of NICU admission (14 trials; RR, 0.98 [95% CI, 0.86 to 1.08]; I^2^=0%; ARD, −0.7%, [95% CI, −1.9 to 0.5]).; No effect when stratified by BMI subgroup (p=0.38 for interaction), intervention type (p=0.47), or intensity (p=0.82). | Consistent; precise | Studies not powered to address NICU admission; low event rates. | Low | Low
Infant Health Outcomes | Infant mortality / stillbirth | 11 RCTs (N=7,090) | No effect reported for neonatal death or stillbirth. No deaths were reported to be related to the interventions. | Consistent; imprecise | Studies not powered to address infant mortality/ stillbirth; low event rates. | Low | Low
Infant Health Outcomes | Growth during first year of life | 3 RCTs (N=2,516) | No differences between interventions during pregnancy versus usual care on infant growth during the first year of life | Consistent; imprecise | Studies not powered to address growth during first year of life. | Low | Low
Gestational Weight Outcomes | Mean gestational weight gain | 63 RCTs, 4 CCTs (N=25,789) | Greater reductions in overall gestational weight gain for interventions versus controls (55 trials; MD, −1.02 kg [95% CI, −1.30 to −0.75]; I^2^=60.3%).; Statistically significant effect when stratified by intervention intensity (p<0.001 for interaction), but not BMI subgroup (p=0.06), intervention type (p=0.07), weight assessment timepoint (p=0.26), or intervention quality (p=0.30). | Reasonably consistent direction within BMI categories but inconsistent magnitude of effect; imprecise | Variation in timing of outcome assessment (e.g., from one month prior to delivery to delivery); type of GWG not defined (e.g., fat vs. fluid retention); variation in prepregnancy weight categories enrolled; few studies report on enrollment or outcomes related to subgroups of importance (e.g., SES or racial and ethnic minorities); heterogeneous interventions, components not always well-described; differences in timing of initiation and/or duration of intervention. | Moderate | Moderate
Gestational Weight Outcomes | Exceeding IOM recommendations for GWG | 39 RCTs, 1 CCT (N=14,449) | Lower likelihood of gaining weight in excess of IOM recommendations (39 trials; RR, 0.83 [95% CI, 0.77 to 0.89]; I^2^=63.8%; ARD, −7.6% [95% CI, −11.0 to −4.6]).; Statistically significant effect for excess GWG and intervention type (p=0.003 for interaction) and intensity (p<0.001), but not BMI (p=0.60). | Consistent; imprecise | Same as above | Moderate | Moderate
Gestational Weight Outcomes | Adherence to IOM recommendations for GWG | 19 RCTs (N=5,835) | No effect on rates of adherence to IOM recommendations for GWG (19 trials; RR, 1.10, [95% CI, 0.89 to 1.35]; I^2^=84.3%; ARD, 4.2% [95% CI, −1.2 to 10]).; No effect when stratified by BMI subgroup (p=0.09 for interaction), intervention type (p=1.00), or intensity (p=1.00). | Relatively consistent; imprecise | Same as above | Low | Moderate
Gestational Weight Outcomes | Postpartum weight retention | 13 RCTs, 1 CCT (N=5,060) | Greater reductions in postpartum weight retention at followup time of 12 months (MD, −0.63 kg [95% CI, −1.44 to −0.01]; I^2^=65.5%), but not followup times of less than 6 months (MD, −0.81 kg [95% CI, −2.40 to 0.55]; I^2^=84.4%) or 6 months (MD, −0.85 kg [95% CI, −3.67 to 0.81]; I^2^=70.6%).; No effect when stratified by BMI subgroup at less than 6 months (p=0.41 for interaction) or 12 months (p=0.75). | Reasonably consistent; imprecise | Differences in followup time; differing duration of interventions; limited or no reporting of known factors associated with postpartum weight retention (e.g. breastfeeding); substantial heterogeneity of pooled estimates. | Low | Moderate
Harms | Depression and anxiety | 10 RCTs, 2 CCT (N=3,116) | Mixed effects reported for rates of depression and anxiety as measured by various, validated symptom scales. | Inconsistent, imprecise | Not reported as harms of intervention; measured as changes in symptoms; heterogeneous intervention components, duration, intensity, and followup, and few studies overall. | Low | Moderate
Harms | Small for gestational age, low birth weight | 29 RCTs, 1 CCT (N=14,168) | No difference in rates of SGA (20 trials; RR, 0.94 [95% CI, 0.80 to 1.10]; I^2^=0.0%; ARD, −0.4% [95% CI, −1.7 to 1.0]).; No differences between interventions during pregnancy versus usual care on low birth weight in 12 trials.; Statistically significant effect when stratified by intervention intensity (p=0.04 for interaction), but not BMI subgroup (p=0.91) or intervention type (p=0.77). | Consistent; reasonably precise | Studies not powered to address SGA; varied definitions used for SGA (less than 10% for gestational age) or low birth weight (less than 2,500 g); low event rates. | Moderate | Moderate

Abbreviations: ARD = absolute risk difference; BMI = body mass index; CCT = controlled clinical trials; CI = confidence interval; GDM = gestational diabetes mellitus; GWG = gestational weight gain; I^2^ = statistic for heterogeneity; IOM = Institute of Medicine; LGA = large for gestational age; MD = mean difference; N = number; NA = not applicable; NICU = neonatal intensive care unit; RCT = randomized controlled trials; RDS = respiratory distress syndrome; RR = relative risk; SGA = small for gestational age.

Evidence on effects of GWG interventions on maternal outcomes was most robust for gestational diabetes, gestational hypertension, preeclampsia, and cesarean delivery. Counseling-only and active GWG interventions were associated with decreased risk of GDM and emergency cesarean delivery. The absolute risk difference (ARD) for GDM was 1.6 percent; with a number needed to treat (NNT) to prevent one case of GDM of approximately 63. There were no statistically significant interactions between BMI categories, intervention type or intensity and effects on GDM. While the point estimate favored GWG interventions and was nearly statistically significant, there was no overall effect of GWG interventions on rates of gestational hypertension. Effects were observed in some stratified analyses for gestational hypertension, specifically decreased rates for high intensity interventions and active interventions, which may be related to a more direct relationship between these factors and effects on blood pressure. Interactions were also observed between effects of GWG interventions on perineal trauma and BMI category (p=0.003 for interaction) and intervention intensity (p=0.003 for interaction), but not for other maternal health outcomes. There was also no effect of GWG interventions on preeclampsia, a multisystem syndrome with less clear associations with BMI.^175^ Importantly, studies included for this review that reported rates of hypertensive diseases of pregnancy distinguished between gestational hypertension and preeclampsia based on predefined diagnostic criteria.

Evidence on effects of GWG interventions on infant outcomes was most robust for macrosomia, LGA, and preterm birth. GWG interventions were associated with decreased risk of macrosomia and LGA, with ARD between 1 and 2 percent for both outcomes, resulting in a NNT of approximately 53 (95% CI, 31 to 250) to prevent one case of macrosomia and approximately 77 (95% CI, 42 to 333) to prevent one case of LGA. Evidence did not indicate effects of GWG interventions on risk of respiratory distress syndrome, shoulder dystocia, NICU admission, neonatal death, or stillbirth.

For weight-related outcomes, GWG interventions were associated with slightly less overall weight gain (MD, −1.02 kg) versus controls. The effects of interventions on GWG also tended to be greater in trials of high-intensity interventions (MD, −1.47 kg) compared with moderate- (MD, −0.32 kg) or low-intensity interventions (MD, −0.64 kg; p<0.001 for intensity subgroup interaction).

While the overall interaction between BMI and GWG was not statistically significant, the effects of GWG interventions on gestational weight gain were greater in women in the obese (MD, −1.63 kg) and overweight (MD, −0.89 kg) categories compared with women with normal prepregnancy BMI (MD, −0.48 kg; p=0.06 for BMI category interaction). Although average GWG differed according to prepregnancy BMI category, women with normal weight may experience greater relative benefit (percent change in overall BMI) for the same effects on weight gain compared with women categorized as obese (the IOM recommendations for GWG are higher [25-35 lbs.] in women with normal weight than in women in the obese category [11-20 lbs.]). Additionally, there were no statistically significant interactions between the type of intervention (counseling-only versus active, p=0.07) or timing of weight gain assessment (p=0.26) and effects of GWG interventions on the amount of weight gain.

GWG interventions also were associated with decreased likelihood of weight gain in excess of IOM recommendations versus controls. The absolute risk difference was approximately 7 percent, with the NNT to prevent one woman experiencing GWG in excess of IOM recommendations approximately 13. There were statistically significant interactions between effects of GWG interventions on likelihood of weight gain in excess of IOM recommendations and active interventions (p=0.003 for interaction) and high intensity interventions (p<0.001 for interaction), but not BMI category (p=0.60 for interaction).

There was no association between GWG interventions and likelihood of adhering to IOM recommendations for GWG (defined as neither gaining excess weight nor not gaining enough weight). The discrepancy between positive effects of GWG interventions on likelihood of gaining excess weight and no effect on likelihood of adhering to IOM recommendations could be explained by an increased likelihood of some women failing to gain enough weight. However, data were not available to verify this, as most studies did not report the proportion of women unable to gain sufficient weight. GWG interventions were associated with effects on postpartum weight retention at 12 months followup but not at less than 6 months or 6 months, although data were limited and estimates were imprecise.

Evidence on harms of GWG interventions was limited. Most studies were not designed to assess harms, though some reported outcomes unrelated to interventions (SGA, psychological outcomes) that could be considered either potential benefits or harms. Evidence on effects of GWG interventions on maternal depression and anxiety was limited and showed mixed results based on various symptom scales. There was no association between GWG interventions versus controls and risk of SGA. As noted above, studies did not report the proportion of women who failed to gain sufficient weight during pregnancy.

Reviews of observational studies evaluating associations between GWG interventions and maternal and infant outcomes were generally consistent with our findings,^21–23,176,177^ although some differences could be explained by use of observational data. Importantly, our findings are generally consistent with obesity and behavioral intervention literature that demonstrates more promising effects of interventions that offer frequent patient contact, and for more pronounced effects on absolute weight loss in obese populations.^178,179^

## Limitations

We excluded non-English language studies and did not search for studies published only as abstracts. There was substantial variability in interventions, comparisons, and timing and method of assessment of outcomes, with statistical heterogeneity in some pooled analysis that was only partially accounted for in stratified or subgroup analyses based on these and other factors. Because of anticipated heterogeneity, we performed random effects analyses, which resulted in wider confidence intervals than fixed effects models when statistical heterogeneity is present, reflecting the greater uncertainty in estimates. In addition, we used the profile-likelihood method for conducting meta-analysis, which may be more reliable when statistical heterogeneity is present.^180^

There were limitations in the evidence. There was a lack of data on prepregnancy weight loss interventions. One trial of a prepregnancy intervention showed that intentional weight loss prior to pregnancy did not impact adherence to weight gain guidelines during pregnancy and, instead, resulted in increased gestational weight gain.^120^ One arm of a trial that focused on reducing GDM risk through a lifestyle intervention included women who were planning pregnancy. However, not all women in the intervention arm were encouraged to lose weight, and weight change before pregnancy was not reported, precluding the evaluation of the effects of prepregnancy weight loss on pregnancy outcomes.^141^ Many individual trials had methodological limitations, though we excluded poor-quality trials due to serious flaws. Trials primarily focused on the effects of GWG interventions on mean GWG, an intermediate outcome, with less evidence on the direct effects of GWG interventions on maternal and infant health outcomes. Some of the subgroup analyses were underpowered to evaluate subgroup effects. Additionally, some trials enrolled mixed populations of women with different BMI categories, limiting the usefulness of stratified analyses. Evidence on harms was limited, particularly for effects on psychological well-being and quality of life. Most studies had some methodological limitations, though results were similar in analyses stratified by study quality.

Another limitation was inconsistent outcome measurement or characterization. For example, for studies of gestational diabetes, there was significant variation in diagnostic criteria. Maternal hemorrhage and infant outcomes (e.g., SGA) were also inconsistently defined. Studies reporting PPWR were limited by sparse data and lack of reporting on factors other than the GWG interventions that could influence PPWR (e.g., breastfeeding status, intentional weight loss efforts). For studies evaluating rates of cesarean delivery, indications for cesarean or emergency cesarean were not reported or were poorly defined (e.g., “failure to progress”). We pooled results separately for nonemergency or mixed cesarean section and emergency cesarean, with similar findings of no effects of GWG interventions on nonemergency cesarean, but statistically significant effects of interventions on emergency cesarean.

## Emerging Issues/Next Steps

Given the lack of studies evaluating interventions to reduce weight before pregnancy, trials examining the impact of prepregnancy weight loss interventions are an important next step, and several are ongoing.^181–184^ Importantly, for prepregnancy interventions to be effective it is necessary to identify women who intend to become pregnant; therefore, studies that incorporate methods for evaluating pregnancy intention are needed for optimally implementing prepregnancy interventions.^120,185^ For example, the One Key Question© initiative works to improve pregnancy outcomes based on the premise that providing clinicians with a framework to routinely assess pregnancy intention offers an opportunity for patient-centered counseling that can be tailored based on a woman’s desire or ambivalence about pregnancy.^186^ Nearly half of all U.S. pregnancies are unplanned or unintended, further highlighting the potential impact of initiatives that assess pregnancy intention or contraceptive needs, as these pregnancies are more often associated with poor prepregnancy health and pregnancy outcomes.^187,188^ Additional emphasis on evaluating counseling content and methods in order to insure careful consideration of the impact on body image and weight stigma or bias is also important when counseling women in any weight category.

## Relevance for Priority Populations

Data were too limited to determine how effects of GWG interventions on health outcomes or weight-related outcomes varied in populations defined by race or ethnicity, age (e.g., adolescents, older maternal age), or socioeconomic status given that outcomes were not reported according to these groups. However, 28 of the 68 included studies (41%) enrolled more than 20 percent of patients from diverse backgrounds, including those who are socioeconomically disadvantaged, racial or ethnic minorities, rural populations, or others as defined by the National Institute on Minority Health and Health Disparities as populations adversely affected by disparities.^189^ As such, the potential applicability of various interventions is favorable given the diversity of enrolled study populations. Although the reported ages of enrolled participants in study samples ranged from 14 to 49 years, studies did not include large numbers of women of advanced maternal age or did not report data separately in this subgroup. A recent review summarized the associations between advanced maternal age and risks for adverse pregnancy outcomes; however, many of these associations were considered weak.^190^ Additional data are needed to further characterize the impact of age on adverse pregnancy outcomes to help facilitate accurate counseling. No study was specifically conducted in pregnant adolescents. Evidence suggests an association with increased risk in adolescent mothers for developing and maintaining unhealthy BMI during and after pregnancy, which can be intensified by GWG.^191^ Excess GWG in pregnant adolescents may have lasting effects for future pregnancies and into adulthood.^192^ Trials did not address issues of health care disparities, access to prenatal care (or lack thereof), or feasibility of interventions in settings where access to care is limited or arrival to care is delayed.

## Future Research

Research is needed to determine the effectiveness of interventions to limit GWG in populations of women of advanced maternal age (e.g., older than 34 years), adolescents, and in the priority populations described above. While there were many studies on effects of interventions on GWG, the effects on maternal and infant health outcomes is more limited, as these were mostly reported as secondary outcomes of interventions to reduce GWG. A recently published consortium of trials (Lifestyle Interventions for Expectant Moms) found diverse behavioral intervention modalities implemented in a large, racially and socioeconomically diverse U.S. population of pregnant women were associated with modest, beneficial effect on GWG, but had no effects on health outcomes including preeclampsia, GDM, cesarean delivery, or birth weight.^57^ At 12 months, they found beneficial effects on maternal postpartum weight retention but no effects on infant anthropometric outcomes.^181,193,194^ Eligible trials from this consortium that were completed and published are included this review.^90,98,107,134,138,153^ Future trials could evaluate more intensive behavioral interventions, which may be more effective, and whether components should be tailored to specific populations.^69^ Research would be helpful for determining the optimal frequency, length of sessions, and number of sessions needed for an intervention to provide additional evidence on effectiveness, including approaches that utilize telehealth modalities to deliver care.^195,196^ Future trials could consider evaluating the impact of GWG and PPWR in the context of inter-conception care, which may be a key factor in determining prepregnancy BMI for multiparous women.^197^ Another consideration is whether GWG is the most appropriate outcome measure, or whether an alternative indicator of gestational weight, such as maternal fat accumulation or weight gain relative to prepregnancy BMI, is more informative. Given that GWG is a composite outcome influenced by many factors, causal relationships may be difficult to measure,^198^ as are indirect links between maternal weight and perinatal outcomes.^199^ Future trials of interventions to limit GWG should evaluate health outcomes using standardized measures of postpartum hemorrhage, gestational hypertension, preeclampsia, and gestational diabetes, and should report indications for cesarean delivery, as well as stratify effects of interventions by BMI category. Given the lack of data directly evaluating harms of interventions to limit GWG, further investigation into the potential harms related to these interventions, including the harms of insufficient weight gain and harms related to the effect on eating disorders or disordered eating behavior, is needed.^200^ Other harms may include the effects of musculoskeletal injuries in women due to body changes occurring during the relatively short timeline of pregnancy.

## Conclusions

Counseling and active behavioral interventions to limit GWG in pregnant women are associated with a modestly decreased risk of GDM, emergency cesarean delivery, macrosomia, and large for gestational age. GWG interventions are also associated with modest reductions in weight gain and decreased likelihood of exceeding IOM recommendations for GWG. Effects of these interventions on mean GWG are slightly more pronounced for high intensity interventions.