# Chapter 3 Results

## Included Studies

Our literature search resulted in 8,511 unique citations. Following dual title and abstract review and dual evaluation of 845 full-text articles, we identified 68 studies of interventions to limit excess GWG, reported in 87 publications that addressed Key Questions 1-3.^56,58,59,75–158^ Of the 578 articles that were excluded at the full text level, the most common reasons for exclusion were: publication type other than an original peer-reviewed study (i.e., conference abstracts or literature reviews) (161 articles), study design outside the scope of the review (i.e., not trials) (109 articles), wrong outcome (96 articles), or wrong intervention (62 articles). Eight studies^159–166^ were excluded at the full-text level due to poor quality.

The search and selection of articles, including reasons for exclusion (Appendix A5), are summarized in the literature flow diagram (Appendix A3).

## Study Characteristics

Of the 68 included studies, 64 were randomized controlled clinical trials (RCTs, N=24,829)^56,58,59,75–90,92–96,98,100–103,105–123,125–158^ and four were controlled clinical trials (CCTs, N=960)^91,97,104,124^ (Appendix B Table 1). All studies included pregnant women. Sixty-seven trials evaluated interventions during pregnancy, one evaluated a prepregnancy intervention,^120^ and one study included a preconception component;^141^ however, no other studies evaluated the effectiveness of prepregnancy interventions to limit excessive GWG in women prior to pregnancy, limiting the number of studies to address Part B of any Key Question.

All studies conducted during pregnancy reported at least one maternal outcome: GWG (all studies), weight gain in excess of (40 studies^59,77–79,81,83–86,88,90,92–94,96,101,103,112,114,115,117,119,122,124,126,128,129,132,134–136,138,139,142,146–148,153,154,157^) or according to IOM recommendations (19 trials),^59,79,85,88,93,96,103,123,127,129,130,132,135,139,142,146,147,152,154^ cesarean delivery (48 studies),^56,58,59,76,78–80,82,84–90,93,94,96,98,102,104,105,112,114,115,118,119,123–130,132,134–136,140,142,143,145,147,152–154,158^ GDM (45 studies),^56,58,59,76,80,82,84–90,93,94,96,101,104,105,108,112,114,115,118,119,121,123–125,127,128,130,132,134–136,140–143,145,146,153,154^ gestational hypertension (29 studies),^56,58,59,80,84,87–90,96,101,118,119,123–127,130,132,134,135,140–142,145,152,154,158^ preeclampsia (28 studies),^56,58,59,76,80,84,87,88,93,96,105,118,119,121,123–127,132,134,135,140,141,143,145,152,158^ postpartum weight retention (14 studies),^78,94,100,104,106,107,109,113,119,131–133,135–137,144,155,158^ postpartum hemorrhage (10 studies),^56,76,88,96,105,123,124,127,143,145^ perineal trauma (8 trials),^56,80,88,96,102,123,143,145^ maternal depression and anxiety (12 studies),^75,87,91–93,96,97,99,105,125,129,147^ or maternal mortality (2 trials).^88,123^ Fifty studies (in 67 publications)^56,58,59,76,78,80,81,83–86,88–90,93–96,98,104,105,112,114,115,118,119,121,125–128,130–132,134–137,140–143,145–147,151–154^ also reported at least one infant outcome, including preterm birth (34 studies),^56,58,76,78,81,83–86,89,90,93,95,96,98,101,105,111,112,119,125,126,130–132,134–137,140,142,143,145,147,151–155^ macrosomia (26 studies),^56,58,59,78,80,81,83,84,86,88,89,95,96,101,102,104,116–119,121,128,131,132,134,135,142,145,149,150,152,154–156^ LGA (26 trials),^56,58,59,76,80,89,90,94–96,98,105,111,112,114,115,117,119,121,125,127,136,137,140,143,145,146,149,150,152–156^ SGA and low birth weight (30 studies),^76,80,89,90,94,96,98,105,111,112,117,119,121,125,127,136,137,143–146,152–155^ NICU admission (14 trials),^56,59,76,88–90,93–96,101,102,105,125,127,143–145,149,150,154–156^ infant respiratory distress syndrome (8 trials),^80,88–90,118,140,141,145,154,155^ shoulder dystocia (8 trials),^56,80,88,93,96,123,127,143^ and neonatal mortality (11 trials)^59,76,88–90,93,96,125,143–145,149,150,156^ (Appendix B Table 3).

Across all studies, sample sizes ranged from 50 to 2,261 (N=25,789; median n=230), and studies enrolled women aged 18 years and older; reported sample mean ages ranged from 18.6 years to 33.8 years (median 30.4 years, SD 2.8), with enrolled study participants ranging in age from 14 to 49 years depending on study inclusion criteria (Appendix B Table 1). There were no studies exclusively of pregnant adolescents or women with advanced maternal age. Thirty-four trials^58,59,75,76,78,80,82–87,89,91–94,100–102,106,113,116–119,121,124,128–130,136,137,139–144,146,149,150,156,158^ were conducted in Europe, 22 trials^77,79,90,97,98,103,104,107,110–112,114,115,122,126,127,131–135,138,148,151–155^ in the United States and Canada, 10 trials^56,88,95,96,105,108,109,123,125,145,147,157^ in Australia and New Zealand, and 1 trial^81^ in Argentina. Studies did not report outcomes by age, race and ethnicity, socioeconomic status, parity, or smoking status.

Studies included women in three prepregnancy BMI categories: mixed (all BMI categories), overweight and obesity only, and obesity only. One study enrolled pregnant women with normal weight only^96^; 34 studies^75,76,78–86,88,93,103–106,113–115,119,122,126,128,131,132,135–137,139,142,143,147,148,151,152^ enrolled pregnant women of mixed weight categories (including 1 trial^92^ enrolling women with normal weight and overweight only); 19 studies^56,77,89,90,95,97,98,100–102,107–112,117,121,123,127,129,130,133,134,138,145,153,157^ enrolled women with overweight or obesity only; and 13 studies^58,59,87,91,94,118,124,125,140,141,146,149,150,154–156,158^ enrolled women with obesity only (Appendix B Table 1). The majority of trials recruited women directly from the primary care setting, including obstetric and prenatal care settings, at the initial prenatal visit or through electronic health records. Eight studies recruited participants more widely via newspaper or online advertisements, referrals from social services, health fairs, or flyers posted in community spaces.^101,103,106,115,118,126,148,152^

Sixty-seven trials evaluated interventions during pregnancy; six included interventions continuing into postpartum period.^78,97,107,119,126,151^ Forty-five studies (in 56 publications)^56,58,76–80,87–90,92,93,95–98,104,107–113,116–119,121–127,130–132,135–141,146–148,151–155,157,158^ evaluated counseling-only interventions, where providers either offered advice or specific recommendations on behavior change (e.g., weight monitoring, dietary changes, physical activity); 22 studies (in 29 publications)^59,75,81–86,91,94,100–103,105,106,114,115,128,129,133,134,142–145,149,150,156^ were considered active interventions where providers implemented a structured, physical element such as medically supervised exercise or meal replacement (Appendix B Tables 1-2; see Appendix E Table 2 for examples of implementation). Interventions addressed advice about nutrition (5 studies),^76,80,123,127,158^ physical activity (16 studies),^75,81,82,84–86,94,100–102,105,106,129,139,142,145,148^ lifestyle and behavioral change (6 studies),^97,108–112,122,125^ or serial weight measurement (3 studies),^88,92,93^ with the remainder addressing multiple components (Appendix B Table 2).

The interventions were highly variable in intensity (number of sessions or contacts) and modes of delivery (Appendix B Table 1). Ten trials^79,80,88,92,93,123,130,135–137,139^ were considered low intensity (fewer than 2 contacts during the intervention period); 23 trials^56,76,78,87,89,95,96,104,108–110,113,116–119,121,122,124,126,127,131,132,140,141,146–148,158^ evaluated moderate-intensity interventions (3-11 contacts); and 34 trials^58,59,75,77,81–86,90,91,94,97,98,100–103,105–107,111,112,114,115,125,128,129,133,134,138,142–145,149–157^ evaluated high-intensity interventions (12 or more contacts). Moderate and high-intensity interventions included the potential to refer participants to external providers (e.g., registered dieticians, qualified fitness specialists, physiotherapists, health coaches, etc., not embedded in the research team) and/or settings (e.g., local community fitness center). Interventions evaluated in the nine low-intensity trials included healthy behavior counseling at an initial session with a dietician, midwife, or other provider, followed by tailored counseling on iterative weight gain during regularly scheduled visits. In five trials, research team and external providers also made specific recommendations for supervised physical activity based on ACOG guidelines.^79,80,135–137,139^ The 57 moderate-^56,76,78,87,89,95,96,104,108–110,113,116–119,121,122,124,126,127,131,132,140,141,146–148,158^ or high-^58,59,75,77,81–86,90,91,94,97,98,100–103,105–107,111,112,114,115,125,128,129,133,134,138,142–145,149–157^ intensity trials included interactions with participants in person, by telephone, or both, and generally included individual or group education or counseling on healthy diet and exercise, or medically supervised group exercise classes with or without counseling for those characterized as active interventions. The mode of delivery for the interventions was primarily face-to-face in 59 studies and by computer, internet, or telephone in 5 trials^111,112,126,148,153,157^; 3 trials^58,77,138^ compared a face-to-face arm and a telehealth arm with a control group (Appendix B Tables 1-2).

The comparison, or control intervention, consisted of usual care in 56 trials and minimal intervention in 11 trials (Appendix B Table 2).^59,89,90,98,103,108,126,148,152,153^ Minimal intervention or attention controls typically included general education sessions on healthy behaviors in pregnancy; in three trials^90,125,152^ evaluating a peer-educator program, control participants received home visits and group education. Usual care involved routine antenatal care with obstetricians, midwives, or other providers and included information on healthy pregnancy behaviors delivered by clinic staff or via printed information; the intensity, frequency, and content of usual care varied according to standards in the country where the intervention occurred.

The timing of initiation and study duration varied across trials, with the initial intervention generally occurring at the end of the first trimester or the beginning of the second trimester, and generally ending prior to delivery. For the outcome of total GWG, the timing and evaluation of weight gain assessments differed across trials, with one trial assessing final weight at 28 weeks, 18 trials at 34-36 weeks, 27 trials at 36 weeks up to delivery, 19 trials at delivery, one trial at 2 weeks postpartum, and one trial did not report timing (Appendix B Table 3). The followup period for the majority of studies ended at the time of the final weight measurement; however, 14 studies followed participants postpartum and reported the outcome of postpartum weight retention at various timepoints, specifically within 6 months of delivery^100,104,106,109,111,113,116,132,135,136,156,158^ and at 12 months postpartum^78,107,111,113,116,131,133,137,144,155^ (Appendix B Table 3).

Given the overlap of studies included for more than one Key Question and the limited trials on prepregnancy weight loss interventions, results are organized by outcome into the following sections: maternal health outcomes, infant health outcomes, prepregnancy weight loss, maternal weight outcomes, and harms (Appendix B Table 3). Data regarding subgroup effects were primarily available for BMI categories and are reported within the results for each outcome.

## Study Quality

Among the 68 included studies, 15 RCTs^56,58,78,80,90,95,96,108,109,117,120,121,125,129,143,145,146,154,155^ and 1 CCT^97^ were rated good-quality, and 49 RCTs and 3 CCTs^59,75–77,79,81–89,91–94,98,101,103–107,110–116,118,119,122–124,126–128,130–142,147–153,156–158^ were rated fair-quality (Appendix C Tables 1-2). Methodological limitations in the fair-quality trials included lack of reporting details about blinding of care providers^56,58,59,78–85,87–93,95,96,98,101–104,106,110–112,114–118,121–124,126–132,134–139,142–144,146–150,152,154–158^ or outcome assessors or analysts,^58,59,79,81–85,87,88,91,92,104,110–112,114–118,121,124,126–130,135–137,139,148–150,152,156–158^ relatively higher (i.e., greater than 20%) and differential attrition,^81,89,91,94,106,114,122,126,139,147,158^ lack of or unclear reporting of allocation concealment,^96,110,114,115,126,128,135,142,152,158^ no attempt to or did not report on intention-to-treat analyses,^59,114,123,128,148–150,156^ and significant differences in groups at baseline.^92,124,136,137,157^ The main limitations for the eight poor-quality intervention studies were multiple or very serious flaws in the domains of attrition,^159–166^ lack of reporting details of blinding of outcome assessors or analysts,^159–165^ significant differences between groups at baseline,^160–165^ or lack of reporting methods of randomization.^160–162^

## Effects of Interventions to Limit Excess Gestational Weight Gain on Maternal Health Outcomes

### Summary

- GWG interventions were associated with decreased risk of GDM versus controls (43 trials; RR, 0.87 [95% CI, 0.79 to 0.95]; I^2^=16.4%; ARD, −1.6% [95% CI, −2.5 to −0.7]); there were no statistically significant interactions between effects of GWG intervention on rates of GDM and BMI category (p=0.14 for interaction), intervention type (p=0.68 for interaction), or intervention intensity (p=0.92 for interaction).
- GWG interventions were associated with decreased risk of emergency cesarean delivery, but indications were rarely reported (14 trials; RR, 0.85 [95% CI, 0.74 to 0.96]; I^2^=0.0%; ARD, −2.4% [95% CI, −4.2 to −0.3]).
- GWG interventions were not associated with risk of gestational hypertension (28 trials; RR, 0.87 [95% CI, 0.70 to 1.04]; I^2^=32.5%; ARD, −0.8% [95% CI, −1.9 to 0.2]); cesarean delivery (34 trials; RR, 0.98 [95% CI, 0.91 to 1.04], I^2^=10.8%; ARD, −0.7%, [95% CI, −2.4 to 0.8]), preeclampsia (27 trials; RR, 0.98 [95% CI, 0.84 to 1.13]; I^2^=0.0%; ARD, 0.1% [95% CI, −0.6 to 0.5]), postpartum hemorrhage (9 trials; RR, 1.00 [95% CI, 0.88 to 1.15]; I^2^=0.0%; ARD, −0.1% [95% CI, −1.3 to 1.5]) or perineal trauma (third- or fourth-degree perineal tear, 8 trials; RR, 0.86 [95% CI, 0.52 to 1.50]; I^2^=57.0%; ARD, −0.7% [95% CI, −3.2 to 1.7]) versus controls.
- Statistically significant interactions between effects of GWG interventions on perineal trauma and BMI category and intervention intensity were present, and between effects of GWG interventions on gestational hypertension and intervention intensity and active interventions.
- Evidence was too limited to determine effects of GWG interventions on maternal mortality.

### Evidence

#### Gestational Diabetes Mellitus

Forty-five studies (43 RCTs, N=19,752 and 2 CCTs, N=397) of counseling-only and active interventions versus controls reported on the outcome of GDM (Appendix B Tables 1-3).^56,58,59,76,80,82,84–90,93,94,96,101,104,105,108,112,114,115,118,119,121,123–125,127,128,130,132,134–136,140–143,145,146,153,154,158^ Twelve trials were rated good quality^56,58,80,90,96,108,121,125,143,145,146,154^ and 33 studies were rated fair quality (Appendix C Tables 1-2). The criteria used to define GDM varied among studies and included criteria based on country-specific guidelines (16 studies);^56,58,59,85,87,104,105,114,115,118,121,123,128,136,143,158^ IADPSG criteria using the 1-step approach to diagnosis with a 75 g glucose load (18 trials),^76,80,86,89,90,94,96,101,108,119,125,130,134,140,141,145,146,153^ and review of medical records (9 studies)^84,93,124,126,127,132,135,142,154^; two trials used unclear criteria to define GDM.^82,88^ Forty-two trials reported timing of screening, which occurred between 24 to 28 weeks’ gestation in all trials; one trial^141^ also screened for GDM at 12 to 16 weeks.

One trial^96^ enrolled women with normal BMI, 20 trials enrolled women in mixed prepregnancy BMI categories,^76,80,82,84–86,88,93,105,114,115,118,119,121,126,128,135,136,142,143^ 12 studies included women categorized only as obese (BMI greater than 29^87,146^ or greater than or equal to 30^58,59,94,124,125,140,141,154,158^ kg/m^2^), and 12 studies included women in overweight or obese categories.^56,89,90,101,104,108,112,123,127,130,132,134,145,153^ There were 29 studies of counseling-only interventions,^56,58,76,87–90,93,96,104,108,112,118,119,121,123–125,127,130,132,135,136,140,141,146,153,154,158^ and 16 trials that included an active component.^59,80,82,84–86,94,102,105,114,115,128,134,142,143,145^ Intervention intensity was low in 7 trials,^80,88,93,123,130,135,136^ moderate in 17 studies,^56,76,87,89,96,104,108,118,119,121,124,127,132,140,141,146,158^ and high in 21 trials.^58,59,82,84–86,90,94,101,105,112,114,115,125,128,134,142,143,145,153,154^

GWG interventions were associated with decreased risk of GDM versus control (43 trials; RR, 0.87 [95% CI, 0.79 to 0.95]; I^2^=16.4%; ARD, −1.6% [95% CI, −2.5 to −0.7]) (Table 2, Figure 2). In the stratified analyses, there were no subgroup interactions between rates of GDM and BMI category (p=0.14 for interaction), intervention type (p=0.68 for interaction), or intervention intensity (p=0.92 for interaction; Table 2).

Figure 2 Meta-Analysis of Trials: Gestational Diabetes Mellitus

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; O/O = overweight and obese combined BMI category.

Figure 2 is a forest plot examining association of gestational diabetes mellitus with interventions to limit gestational weight gain. The overall relative risk is 0.87 (95% confidence interval 0.79 to 0.95) with an I-squared value of 16.4%.

Table 2 Meta-Analysis of Trials: Gestational Diabetes Mellitus Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 43 | 0.87 (0.79 to 0.95) | 16.4% | NA
BMI Category | Normal only | 1 | 0.99 (0.65 to 1.50) | NA | 0.14
BMI Category | Overweight only | 0 | NA | NA | 0.14
BMI Category | Obese only | 11 | 0.98 (0.84 to 1.13) | 0% | 0.14
BMI Category | Overweight-obese combined | 11 | 0.80 (0.67 to 0.94) | 0% | 0.14
BMI Category | Mixed | 20 | 0.83 (0.69 to 0.97) | 26.5% | 0.14
Intervention Intensity | Low | 6 | 0.75 (0.47 to 1.08) | 29% | 0.92
Intervention Intensity | Moderate | 16 | 0.88 (0.79 to 0.99) | 9.8% | 0.92
Intervention Intensity | High | 21 | 0.86 (0.70 to 1.03) | 22.9% | 0.92
Intervention Type | Active | 15 | 0.82 (0.63 to 1.01) | 26.3% | 0.68
Intervention Type | Counseling-only | 25 | 0.88 (0.80 to 0.98) | 11% | 0.68

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; NA = not applicable; RR = relative risk.

#### Gestational Hypertension

Twenty-eight RCTs (N=14,875) and one CCT^124^ (N=178) reported rates of gestational hypertension (Appendix B Tables 1-3).^56,58,59,80,84,87–90,96,101,118,119,123–127,130,132,134,135,140–142,145,152,154,158^ Eight RCTs were rated good quality^56,58,80,90,96,125,145,154^ and 20 RCTs and one CCT^124^ fair quality^59,84,87–89,101,118,119,123,126,127,130,132,134,135,140–142,152,158^ (Appendix C Tables 1-2). Gestational hypertension was defined as persistent or repeated measures of blood pressure greater than or equal to 140/90 mmHg after 20 weeks’ gestation, and was generally consistent with the U.S. guideline defined by two measurements of elevated blood pressure (greater than or equal to 140/90 mmHg) at least 4 hours apart.^72^

There was 1 trial^96^ enrolling women with normal prepregnancy weight, 9 trials enrolling women with mixed prepregnancy weight,^80,84,88,119,126,132,135,142,152^ 9 trials with prepregnancy overweight or obesity,^56,89,90,101,123,127,130,134,145^ and 10 studies of women with obesity.^58,59,87,118,124,125,140,141,154,158^ Six trials reported the effects of interventions in women with normal prepregnancy BMI.^84,96,126,132,135,142^ Seven trials evaluated active exercise interventions^59,84,101,127,134,142,145^ while the remaining studies evaluated counseling-only interventions. The intensity of interventions was low in 5 trials,^80,88,123,130,135^ moderate in 13 studies,^56,87,89,96,118,119,124,126,127,132,140,141,158^ and high in 11 trials.^58,59,84,90,101,125,134,142,145,152,154^

GWG interventions were not associated with reduced likelihood of gestational hypertension compared to controls (28 trials; RR, 0.87 [95% CI, 0.70 to 1.04]; I^2^=32.5%; ARD, −0.8%, [95% CI, −1.9 to 0.2]) (Table 3, Figure 3).^56,58,59,80,84,87–90,101,118,119,123,125–127,130,132,134,135,140–142,145,154,158^ However, stratified analysis demonstrated statistically significant interactions between effects of GWG interventions on gestational hypertension and active interventions (p<0.001 for interaction) and high intensity interventions (p=0.006 for interaction), but not BMI category (p=0.08 for interaction; Table 3).

Figure 3 Meta-Analysis of Trials: Gestational Hypertension

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; O/O = overweight and obese combined BMI category.

Figure 3 is a forest plot examining association of gestational hypertension with interventions to limit gestational weight gain. The overall relative risk is 0.87 (95% confidence interval 0.70 to 1.04) with an I-squared value of 32.5%.

Table 3 Meta-Analysis of Trials: Gestational Hypertension Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 28 | 0.87 (0.70 to 1.04) | 32.5% | NA
BMI Category | Normal only | 6 | 0.46 (0.21 to 0.93) | 40.8% | 0.08
BMI Category | Overweight only | 2 | 0.71 (0.25 to 2.06) | 0% | 0.08
BMI Category | Obese only | 10 | 0.93 (0.70 to 1.25) | 0% | 0.08
BMI Category | Overweight-obese combined | 12 | 0.98 (0.67 to 1.18) | 0% | 0.08
BMI Category | Mixed | 9 | 0.81 (0.54 to 1.14) | 55% | 0.08
Intervention Intensity | Low | 4 | 0.89 (0.48 to 1.33) | 0% | 0.006
Intervention Intensity | Moderate | 12 | 1.12 (0.86 to 1.35) | 5.3% | 0.006
Intervention Intensity | High | 12 | 0.69 (0.50 to 0.91) | 23.5% | 0.006
Intervention Type | Active | 7 | 0.60 (0.41 to 0.82) | 0% | <0.001
Intervention Type | Counseling only | 21 | 1.05 (0.84 to 1.23) | 7.1% | <0.001

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; NA = not applicable; RR = relative risk.

#### Cesarean Delivery

Forty-eight studies reported effects of GWG interventions on rates of cesarean delivery (Appendix B Tables 1-3).^56,58,59,76,78–80,82,84–90,93,94,96,98,102,104,105,114,115,118,119,123–129,132,134–136,140,142,143,145,147,152–154,158^ These included 46 RCTs (N=19,573),^56,58,59,76,78–80,82,84–90,93,94,96,98,102,105,114,115,118,119,123,125–129,132,134–136,140,142,143,145,147,152–154,158^ of which 11 met criteria for good quality^56,58,78,80,90,96,125,129,143,145,154^ and 33 were fair quality^59,76,79,82,84–89,93,94,98,102,105,114,115,118,119,123,126–128,132,134–136,140,142,147,152–154,158^ (Appendix C Table 1). The remaining two studies were fair-quality CCTs (N=397) (Appendix C Table 2).^104,124^

One trial enrolled women with normal BMI at baseline,^96^ 24 studies enrolled women in mixed BMI categories,^76,78–80,82,84–86,88,93,104,105,114,115,119,126,128,132,135,136,142,143,147,152^ 10 were studies of women in the obese category only,^58,59,87,94,118,124,125,140,154,158^ and 13 were trials of women in overweight or obese categories.^56,89,90,98,101,123,127,129,134,145,153^ There were 32 studies of counseling-only interventions and 16 trials of active interventions, 7 of which also included counseling plus an active component. The intensity of interventions was low in 8 trials,^79,80,88,93,123,130,135,136^ moderate in 16 studies,^56,76,78,87,89,96,104,118,119,124,126,127,132,140,147,158^ and high in 24 trials.^58,59,82,84–86,90,94,98,101,105,114,115,125,128,129,142,143,145,152–154^ Thirty-four trials reported on the outcome of cesarean delivery,^56,58,76,78,82,84–86,89,90,93,96,98,101,105,114,115,118,119,125–129,132,134–136,140,142,145,153,154,158^ not specified as emergency or elective (N=15,908), while 12 trials^59,80,87,88,94,105,119,123,143,147,152^ specified outcomes as elective cesarean (N=6,222) and 14 trials^58,59,80,87,88,94,96,105,119,123,125,143,147,152^ reported separate rates of emergency cesarean (N=7,520); one trial^153^ reported indications for emergency cesarean.

GWG interventions were not associated with decreased likelihood of cesarean delivery, not specified as emergency or elective, versus controls (34 trials; RR, 0.98 [95% CI, 0.91 to 1.04]; I^2^=10.8%; ARD, −0.7% [95% CI, −2.4 to 0.8]) (Table 4, Figure 4). However, when pooled separately, GWG interventions were associated with a reduced risk of emergency cesarean (14 trials; RR, 0.85 [95% CI, 0.74 to 0.96]; I^2^=0%; ARD, −2.4% [95% CI, −4.2 to −0.3]). Indications for emergency cesarean were rarely reported. Based on stratified analysis, there was no statistically significant interactions between effects of GWG interventions on likelihood of cesarean delivery and BMI category (p=0.70 for interaction), intervention type (p=0.37 for interaction), or intensity (p=0.37 for interaction; Table 4).

Figure 4 Meta-Analysis of Trials: Cesarean Delivery*

* Any cesarean delivery outcome.

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; O/O = overweight and obese combined BMI category.

Figure 4 is a forest plot examining association of cesarean delivery with interventions to limit gestational weight gain. The overall relative risk is 0.98 (95% confidence interval 0.91 to 1.04) with an I-squared value of 10.8%.

Table 4 Meta-Analysis of Trials: Cesarean Delivery Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Cesarean (type not specified)^*^ | 34 | 0.98 (0.91 to 1.04) | 10.8% | NA
Study Population | Emergency Cesarean | 14 | 0.85 (0.74 to 0.96) | 0% | NA
BMI Category | Normal only | 5 | 1.02 (0.81 to 1.27) | 0% | 0.70
BMI Category | Overweight only | 3 | 0.78 (0.44 to 1.34) | 23% | 0.70
BMI Category | Obese only | 9 | 0.98 (0.82 to 1.21) | 13% | 0.70
BMI Category | Overweight-obese combined | 15 | 1.02 (0.89 to 1.16) | 24% | 0.70
BMI Category | Mixed | 17 | 0.98 (0.87 to 1.07) | 15.4% | 0.70
Intervention Intensity | Low | 3 | 0.85 (0.57 to 1.12) | 0% | 0.37
Intervention Intensity | Moderate | 12 | 1.00 (0.91 to 1.08) | 6.9% | 0.37
Intervention Intensity | High | 19 | 0.97 (0.87 to 1.09) | 15.8% | 0.37
Intervention Type | Active | 13 | 0.94 (0.81 to 1.07) | 0% | 0.37
Intervention Type | Counseling only | 21 | 0.99 (0.91 to 1.06) | 13.3% | 0.37

* Reported as any cesarean delivery (type not specified), excluding emergency or elective. Stratified analyses (BMI, intervention intensity and type) conducted only for type not specified.

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; NA = not applicable; RR = relative risk.

#### Preeclampsia

Twenty-eight studies reported effects of GWG interventions on rates of preeclampsia (Appendix B Tables 1-3).^56,58,59,76,80,84,87,93,96,105,118,119,121,123,124,126,127,132,134,135,140,141,143,145,152,154,158^ Of 27 included RCTs (N=17,538), 8 were rated good quality^56,58,80,96,121,143,145,154^ and 19 were rated fair quality^59,84,87,93,118,123,126,127,132,134,135,152,158^ (Appendix C Table 1). The remaining trial was a fair-quality CCT (N=178) (Appendix C Table 2).^124^ Most studies defined preeclampsia as gestational hypertension accompanied by proteinuria (greater than 300 mg/24 hours). The remaining trials reported preeclampsia as a clinically distinct event from gestational hypertension but did not provide a formal definition.

There was one trial of women in normal BMI category,^96^ 12 trials of women with mixed prepregnancy BMI categories,^76,80,84,93,105,119,121,126,132,135,143,152^ 6 trials of women in overweight or obese category,^56,123,127,134,145^ and 9 studies of women categorized as obese only.^58,59,87,118,124,140,141,154,158^ Some trials included multiple discrete populations. Six trials assessed active exercise interventions,^59,84,105,134,143,145^ while the remaining 22 studies evaluated counseling-only interventions.^56,58,76,80,87,93,96,118,119,121,123,124,126,127,132,135,140,141,152,154,158^ Intensity of the intervention was rated low in 5 trials,^80,88,93,123,135^ moderate in 14 studies,^56,76,87,96,118,119,121,124,126,127,132,140,141,158^ and high in 9 trials.^58,59,84,105,134,143,145,152,154^

Interventions for GWG were not associated with a risk of preeclampsia versus controls (27 trials; RR, 0.98 [95% CI, 0.84 to 1.13]; I^2^=0%; ARD, 0.1% [95% CI, −0.6 to 0.5]; Table 5, Figure 5). Based on stratified analysis, there were no statistically significant interactions between effects of GWG interventions on risk of preeclampsia and BMI category (p=0.86 for interaction), intervention type (p=0.25 for interaction), or intensity (p=0.29 for interaction; Table 5).

Figure 5 Meta-Analysis of Trials: Preeclampsia

Note: Some trials reported multiple discrete BMI subcategories.

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; O/O = overweight and obese combined BMI category.

Figure 5 is a forest plot examining association of preeclampsia with interventions to limit gestational weight gain. The overall relative risk is 0.98 (95% confidence interval 0.84 to 1.13) with an I-squared value of 0%.

Table 5 Meta-Analysis of Trials: Preeclampsia Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 27 | 0.98 (0.84 to 1.13) | 0% | NA
BMI Category | Normal only | 2 | 0.87 (0.43 to 1.55) | 0% | 0.86
BMI Category | Overweight only | 0 | NA | NA | 0.86
BMI Category | Obese only | 10 | 1.09 (0.79 to 1.70) | 0% | 0.86
BMI Category | Overweight-obese combined | 6 | 1.00 (0.73 to 1.35) | 0% | 0.86
BMI Category | Mixed | 12 | 0.93 (0.72 to 1.17) | 0% | 0.86
Intervention Intensity | Low | 4 | 0.79 (0.48 to 1.24) | 0% | 0.29
Intervention Intensity | Moderate | 16 | 1.06 (0.89 to 1.27) | 0% | 0.29
Intervention Intensity | High | 10 | 0.84 (0.62 to 1.16) | 0% | 0.29
Intervention Type | Active | 6 | 0.80 (0.52 to 1.19) | 0% | 0.25
Intervention Type | Counseling only | 24 | 1.01 (0.86 to 1.19) | 0% | 0.25

Note: Some trials reported multiple discrete populations. Overall number of trials reflects number of unique trials.

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; NA = not applicable; RR = relative risk.

#### Postpartum Hemorrhage

Ten studies reported the association between GWG interventions and risk of postpartum hemorrhage during or immediately following delivery (Appendix B Tables 1-3).^56,76,88,96,105,123,124,127,144,145^ Of the nine trials (N=6,306), four were rated good quality and five fair quality; one CCT (N=178) was fair quality (Appendix C Tables 1-2). There was one trial of women with normal BMI, four trials of women with mixed prepregnancy BMI categories, four trials of women in the overweight or obese BMI category, and one study of women in the obesity only category.^124^ Three trials^105,143,145^ assessed active exercise interventions, while the remaining seven studies evaluated counseling-only interventions. Interventions were of low (2 trials),^88,123^ moderate (5 studies),^56,76,96,124,127^ or high intensity (3 trials).^105,143,145^ Hemorrhage was defined as greater than 500 milliliters (mL)^144^ in one trial, 600 mL^56,96^ in or 1,000 mL^123,145^ in two trials each, and was not formally defined in five studiess.^76,88,105,124,127^

Pooled results of nine trials demonstrated no effect of interventions on likelihood of postpartum hemorrhage (RR, 1.00 [95% CI, 0.88 to 1.15]; I^2^=0%; ARD, −0.1% [95% CI, −1.3 to 1.5]) (Table 6, Figure 6). Based on stratified analysis, there were no statistically significant interactions between effects of GWG interventions on likelihood of postpartum hemorrhage and BMI category (p=0.65 for interaction), intervention type (p=1.00 for interaction), or intensity (p=0.99 for interaction; Table 6).

Figure 6 Meta-Analysis of Trials: Postpartum Hemorrhage

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; O/O = overweight and obese combined BMI category.

Figure 6 is a forest plot examining association of postpartum hemorrhage with interventions to limit gestational weight gain. The overall relative risk is 1.00 (95% confidence interval 0.88 to 1.15) with an I-squared value of 0%.

Table 6 Meta-Analysis of Trials: Postpartum Hemorrhage Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 9 | 1.00 (0.88 to 1.15) | 0% | NA
BMI Category | Normal only | 1 | 1.17 (0.81 to 1.68) | NA | 0.65
BMI Category | Overweight only | 0 | NA | NA | 0.65
BMI Category | Obese only | 0 | NA | NA | 0.65
BMI Category | Overweight-obese combined | 4 | 0.96 (0.77 to 1.35) | 0% | 0.65
BMI Category | Mixed | 4 | 1.01 (0.78 to 1.25) | 0% | 0.65
Intervention Intensity | Low | 2 | 1.02 (0.72 to 1.45) | 0% | 0.99
Intervention Intensity | Moderate | 4 | 0.99 (0.83 to 1.34) | 0% | 0.99
Intervention Intensity | High | 3 | 1.01 (0.53 to 1.46) | 0% | 0.99
Intervention Type | Active | 3 | 1.01 (0.53 to 1.46) | 0% | 1.00
Intervention Type | Counseling only | 6 | 1.00 (0.87 to 1.20) | 0% | 1.00

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; NA = not applicable; RR = relative risk.

#### Perineal Trauma

Eight RCTs (N=5,707) reported the association between GWG interventions and risk of perineal trauma during delivery (Appendix B Tables 1-3).^56,80,88,96,102,123,144,145^ Five trials were good quality^56,80,96,143,145^ and three trials were fair quality (Appendix C Tables 1-2).^88,101,123^ There was one trial of women with normal BMI,^96^ three trials of women with mixed categories of prepregnancy BMI, and four trials of women with prepregnancy BMI categories of overweight or obese. Three trials^101,143,145^ assessed active exercise interventions, while the other five trials^56,80,88,96,123^ evaluated counseling-only interventions. The intensity of interventions was low in three trials,^80,88,123^ moderate in two trials,^56,96^ and high in three trials.^101,143,145^ Perineal trauma was defined as third- or fourth-degree perineal tear in five trials^56,88,102,123,144^ and tear of any degree in two trials^80,145^; one trial reported both definitions.^96^

Pooled analysis from eight trials showed no effect of interventions on risk of perineal trauma (RR, 0.86 [95% CI, 0.52 to 1.50]; I^2^=57.0%; ARD, −0.7% [95% CI, −3.2 to 1.7]) (Table 7, Figure 7). Based on stratified analysis, there was a statistically significant interaction between effects of GWG intervention on risk of perineal trauma and mixed BMI category (p=0.003 for interaction) and low or high intervention intensity (p=0.003 for interaction), but not intervention type (p=0.73 for interaction; Table 7).

Figure 7 Meta-Analysis of Trials: Perineal Trauma

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; O/O = overweight and obese combined BMI category.

Figure 7 is a forest plot examining association of perineal trauma with interventions to limit gestational weight gain. The overall relative risk is 0.86 (95% confidence interval 0.52 to 1.50) with an I-squared value of 57.0%.

Table 7 Meta-Analysis of Trials: Perineal Trauma Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 8 | 0.86 (0.52 to 1.50) | 57.0% | NA
BMI Category | Normal only | 1 | 1.78 (0.60 to 5.26) | NA | 0.003
BMI Category | Overweight only | 0 | NA | NA | 0.003
BMI Category | Obese only | 0 | NA | NA | 0.003
BMI Category | Overweight-obese combined | 4 | 1.18 (0.66 to 2.01) | 0% | 0.003
BMI Category | Mixed | 3 | 0.51 (0.24 to 1.28) | 46.3% | 0.003
Intervention Intensity | Low | 3 | 0.54 (0.22 to 1.67) | 54% | 0.003
Intervention Intensity | Moderate | 2 | 1.47 (0.81 to 2.90) | 0% | 0.003
Intervention Intensity | High | 3 | 0.86 (0.45 to 1.95) | 0% | 0.003
Intervention Type | Active | 3 | 0.86 (0.45 to 1.95) | 0% | 0.73
Intervention Type | Counseling only | 5 | 0.85 (0.41 to 1.89) | 69.5% | 0.73

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; NA = not applicable; RR = relative risk.

#### Maternal Mortality

One good-quality, moderate-intensity and one fair-quality, low-intensity counseling-only RCT (reported in three publications; N=2,994) reported rates of maternal death (Appendix B Tables 1-3).^56,88,95^ Three maternal deaths total were reported in two trials, with two in the control group and one in the intervention group. None of the deaths reported were related to the interventions.

## Effects of Interventions to Reduce Prepregnancy Weight on Weight and Health Outcomes in Women Who Are Overweight or Obese and Their Infants

One trial evaluated a prepregnancy intervention.^120^ One trial, aimed at preventing GDM in high risk pregnant women, included a prepregnancy arm.^141^ A good quality counseling RCT (N=326) evaluated the effect of intentional weight loss for women with overweight or obese BMI before pregnancy on gestational weight gain and other pregnancy outcomes.^120^ The high intensity behavioral weight loss intervention consisted of weekly health-coaching phone sessions that included information on weight loss, healthy diet, and exercise aimed at women planning pregnancy within two years. Phone coaching continued monthly throughout pregnancy. There was a significant difference in prepregnancy weight loss for the intervention participants versus controls (mean kg per week [SD]: −0.25 (0.51) vs. −0.03 (0.21), p<0.001). However, intervention participants gained more weight than controls during pregnancy (mean kg [SD]: 13.2 (8.2) vs. 10.3 (7.41); p=0.03), with no difference in rates of exceeding GWG guidelines at any time point.

A fair quality counseling RCT (N=128) had an arm that enrolled high-risk women with obesity or with a history of GDM planning a pregnancy.^141^ Women planning pregnancy received lifestyle counseling every 3 months and those with BMI ≥ 25 were also encouraged to lose 5-10% of their weight before pregnancy. The number of women who were given weight loss advice and the weight change in the groups prior to pregnancy were not reported. GDM was defined as one or more pathological glucose values in a 75 g 2-hour oral glucose tolerance test, performed between 12 and 16 weeks of gestation, inconsistent with current definitions of GDM. For those testing negative, the test was repeated between 24-28 weeks gestation. The incidence of GDM as traditionally defined (24-28 weeks) was high in both the intervention and the control groups (21.5% vs 23.8%, respectively), but the difference was not statistically significant.

## Effects of Interventions to Limit Excess Gestational Weight Gain on Infant Health Outcomes

### Summary

- GWG interventions were associated with decreased risk of infant macrosomia (25 trials; RR, 0.77 [95% CI, 0.65 to 0.92]; I^2^=38.3%; ARD, −1.9% [95% CI, −3.3 to −0.7]) and large for gestational age (26 trials; RR, 0.89 [95% CI, 0.80 to 0.99]; I^2^=0%; ARD, −1.3% [95% CI, −2.3 to −0.3]) versus controls.
- GWG interventions were not associated with risk of preterm birth (33 trials; RR, 0.93 [95% CI, 0.81 to 1.07]; I^2^=2.2%; ARD, −0.2% [95% CI, −1.1 to 0.7]); respiratory distress syndrome (8 trials; RR, 1.00 [95% CI, 0.67 to 1.42]; I^2^=0%; ARD, −0.3% [95% CI, −1.3 to 0.7]), shoulder dystocia (8 trials; RR, 1.05 [95% CI, 0.63 to 1.47]; I^2^=0%; ARD, 0.0% [95% CI, −0.4 to 0.5]), or NICU admissions (14 trials; RR, 0.98 [95% CI, 0.86 to 1.08]; I^2^=0%; ARD, −0.7% [95% CI, −1.9 to 0.5]).
- GWG interventions were not associated with effects on infant growth during first year of life, or with neonatal death/stillbirth.

### Evidence

#### Macrosomia

Twenty-five trials (N=13,990) and one CCT (N=219) evaluated effects of GWG interventions on risk of macrosomia; 9 were good quality^56,58,78,80,96,121,143,145,154^ and 18 fair quality^59,81,83,84,86,89,94,102,104,118,119,126,128,132,134,135,142,152^ (Appendix B Tables 1-3 and Appendix C Tables 1-2). Macrosomia was defined as term infants weighing more than 4 kg (21 RCTs,^58,59,78,81,83,84,86,89,96,121,126,128,132,134,135,142,143,145,152,154,167^ 1 CCT^104^) or 4.5 kg (6 RCTs),^80,94,96,118,119,121^ with two trials^96,121^ reporting outcomes for both definitions. There was one trial with women with normal BMI,^96^ 15 studies with women with mixed BMI categories,^78,80,81,83,84,86,104,119,121,126,128,132,135,142,143,152^ 5 of women with prepregnancy BMI categories of overweight or obese,^56,89,102,134,145^ and 5 of women with BMI category of obesity only.^58,59,94,118,154^ Twelve interventions were active^59,81,83,84,86,94,128,134,142,143,145^ and 14 were counseling-only; intensity was rated low in 2 trials,^80,135^ moderate in 10 studies,^78,89,95,96,104,118,119,121,126,132^ and high in 14 trials.^58,59,81,83,84,86,94,128,134,142,143,145,152,154^

GWG interventions were associated with decreased risk of macrosomia versus controls (25 trials; RR, 0.77 [95% CI, 0.65 to 0.92]; I^2^=38.3%; ARD, −1.9% [95% CI, −3.3 to −0.7]) (Table 8, Figure 8). When stratified by definition, GWG interventions were associated with decreased risk of macrosomia in trials using the definition of greater than 4 kg (21 trials; RR, 0.75 [95% CI, 0.62 to 0.89]; I^2^=39.0%), but not using the definition of greater than 4.5 kg (4 trials; RR, 1.47 [95% CI, 0.53 to 3.14]; I^2^=0%). Stratified analysis demonstrated interactions between effects of GWG interventions on risk of macrosomia and higher intervention intensity (p=0.03 for interaction), but not BMI category (p=0.24 for interaction) or intervention type (p=1.00 for interaction; Table 8).

Figure 8 Meta-Analysis of Trials: Macrosomia

Note: Outcome column reflects study definition of macrosomia as greater than 4 kg or 4.5 kg. Outcome with Dodd 2019 defining macrosomia as >4.5 kg: RR 0.76, 95% CI, 0.63 to 0.92, I^2^=40%.

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; O/O = overweight and obese combined BMI category.

Figure 8 is a forest plot examining association of macrosomia with interventions to limit gestational weight gain. The overall relative risk is 0.77 (95% confidence interval 0.65 to 0.92) with an I-squared value of 38.3%.

Table 8 Meta-Analysis of Trials: Macrosomia Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 25 | 0.77 (0.65 to 0.92) | 38.3% | NA
BMI Category | Normal only | 5 | 0.73 (0.51 to 1.30) | 0% | 0.24
BMI Category | Overweight only | 0 | NA | NA | 0.24
BMI Category | Obese only | 3 | 1.00 (0.68 to 1.26) | 0% | 0.24
BMI Category | Overweight-obese combined | 7 | 0.83 (0.68 to 1.04) | 0% | 0.24
BMI Category | Mixed | 14 | 0.76 (0.56 to 0.93) | 0% | 0.24
Intervention Intensity | Low | 2 | 0.71 (0.03 to 19.79) | 0% | 0.03
Intervention Intensity | Moderate | 9 | 0.86 (0.75 to 1.08) | 0% | 0.03
Intervention Intensity | High | 14 | 0.65 (0.49 to 0.84) | 37% | 0.03
Intervention Type | Active | 11 | 0.70 (0.49 to 0.94) | 30.7% | 1.00
Intervention Type | Counseling only | 14 | 0.82 (0.65 to 1.07) | 45.6% | 1.00

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; NA = not applicable; RR = relative risk.

#### Large for Gestational Age (LGA)

Twenty-six RCTs (N=13,000) reported the outcome of LGA infants, defined as birthweight greater than the 90^th^ percentile for gestational age.^56,58,59,76,80,88–90,94,96,98,105,114,115,119,121,125,127,136,140,143,145,146,152–154^ Ten were rated good quality^56,58,80,90,121,125,143,145,146,154^ and 16 were fair-quality trials (Appendix B Tables 1-3 and Appendix C Tables 1-2).^59,76,88,89,94,96,98,105,114,115,119,127,136,140,152,153^ There was one trial with women with normal BMI,^96^ 10 trials with women with mixed BMI categories,^76,80,88,105,114,115,119,136,143,152^ 8 of women with prepregnancy BMI categories of overweight or obese,^56,89,90,98,121,127,145,153^ and 7 of women with prepregnancy BMI category of obese.^58,59,94,125,140,146,154^ Seven trials were active,^59,94,105,114,115,143,145^ and the remainder were counseling-only interventions. Intervention intensity was rated low in 3 trials,^80,88,136^ moderate in 9,^56,76,89,96,119,121,127,140,146^ and high in 14 trials.^58,59,90,94,98,105,114,115,125,143,152–154^

Pooled estimates demonstrated a statistically significant effect of GWG interventions on LGA (26 trials; RR, 0.89 [95% CI, 0.80 to 0.99]; I^2^=0%; ARD, −1.3% [95% CI, −2.3 to −0.3]) (Table 9, Figure 9). Stratified analysis demonstrated no interactions between effects of GWG interventions on risk of LGA and BMI category (p=0.98 for interaction), intervention type (p=0.18 for interaction), or intensity (p=0.22 for interaction; Table 9).

Figure 9 Meta-Analysis of Trials: Large for Gestational Age

Note: Large for gestational age defined as birthweight above the 90^th^ percentile for gestational age.

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; O/O = overweight and obese combined BMI category.

Figure 9 is a forest plot examining association of large for gestational age with interventions to limit gestational weight gain. The overall relative risk is 0.89 (95% confidence interval 0.80 to 0.99) with an I-squared value of 0%.

Table 9 Meta-Analysis of Trials: Large for Gestational Age Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 26 | 0.89 (0.80 to 0.99) | 0% | NA
BMI Category | Normal only | 1 | 0.87 (0.64 to 1.27) | NA | 0.98
BMI Category | Overweight only | 0 | NA | NA | 0.98
BMI Category | Obese only | 7 | 0.88 (0.59 to 1.19) | 12% | 0.98
BMI Category | Overweight-obese combined | 8 | 0.87 (0.64 to 1.20) | 0% | 0.98
BMI Category | Mixed | 10 | 0.92 (0.75 to 1.11) | 0% | 0.98
Intervention Intensity | Low | 3 | 0.64 (0.22 to 1.49) | 46% | 0.22
Intervention Intensity | Moderate | 9 | 0.86 (0.71 to 0.97) | 0% | 0.22
Intervention Intensity | High | 14 | 1.05 (0.83 to 1.34) | 0% | 0.22
Intervention Type | Active | 7 | 1.10 (0.78 to 1.59) | 0% | 0.18
Intervention Type | Counseling only | 19 | 0.87 (0.75 to 0.97) | 0% | 0.18

Note: Large for gestational age defined as birthweight above the 90^th^ percentile for gestational age.

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; NA = not applicable; RR = relative risk.

#### Preterm Birth

Thirty-three RCTs (N=16,974) and one CCT^124^ (N=178) reported on the outcome of preterm birth.^56,58,76,78,80,81,83–86,89,90,93,94,96,98,105,119,125,126,130,132,134–136,140,142,144,145,147,152–154^ Ten were rated good quality^56,58,78,80,90,96,125,143,145,154^ and 24 were fair quality (Appendix B Tables 1-3 and Appendix C Tables 1-2). There was 1 trial with women with normal BMI,^96^ 19 studies with women with mixed BMI categories,^76,78,80,81,83–86,93,105,119,124,126,132,136,142,143,147,152^ 8 trials in women with prepregnancy BMI categories of overweight or obese,^56,89,90,98,130,134,145,153^ and 6 in women with prepregnancy BMI category of obese.^58,94,124,125,140,154^ Eleven were active,^81,83–86,94,105,134,142,143,145^ and 23 were counseling-only interventions. Intervention intensity was rated low in 5 trials,^80,93,130,135,136^ moderate in 11 studies,^56,76,78,89,96,119,124,126,132,140,147^ and high in 18 trials.^58,81,83–86,90,94,98,105,125,134,142,143,145,152–154^ Preterm birth was defined as delivery at less than 37 weeks in 25 studies,^56,58,76,78,80,81,83–86,90,93,94,96,98,119,124–126,140,144,145,152–154^ less than 36 weeks in 4 trials,^132,134,135,142^ and 5 trials did not report a definition.^89,105,130,136,147^ GWG interventions were not associated with a lower risk of preterm birth (33 trials; RR, 0.93 [95% CI, 0.81 to 1.07]; I^2^=2.2%; ARD, −0.2% [95% CI, −1.1 to 0.7]) (Table 10, Figure 10).

Figure 10 Meta-Analysis of Trials: Preterm Birth

Note: Outcome column reflects study definition of preterm birth as prior to 36 weeks’ gestation (<36 w), 37 weeks’ gestation (<37 w), or not reported.

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; NR = not reported; O/O = overweight and obese combined BMI category.

Figure 10 is a forest plot examining association of preterm birth with interventions to limit gestational weight gain. The overall relative risk is 0.93 (95% confidence interval 0.81 to 1.07) with an I-squared value of 2.2%.

Table 10 Meta-Analysis of Trials: Preterm Birth Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 33 | 0.93 (0.81 to 1.07) | 2.2% | NA
BMI Category | Normal only | 1 | 1.14 (0.64 to 2.03) | NA | 0.10
BMI Category | Overweight only | 0 | NA | NA | 0.10
BMI Category | Obese only | 5 | 1.72 (0.95 to 4.78) | 0% | 0.10
BMI Category | Overweight-obese combined | 8 | 0.77 (0.47 to 1.07) | 0% | 0.10
BMI Category | Mixed | 19 | 0.94 (0.79 to 1.09) | 0% | 0.10
Intervention Intensity | Low | 5 | 0.58 (0.20 to 1.17) | 43% | 0.42
Intervention Intensity | Moderate | 10 | 0.92 (0.77 to 1.12) | 4.6% | 0.42
Intervention Intensity | High | 18 | 1.03 (0.81 to 1.35) | 0% | 0.42
Intervention Type | Active | 11 | 1.01 (0.76 to 1.43) | 0% | 0.56
Intervention Type | Counseling only | 22 | 0.91 (0.77 to 1.07) | 6.2% | 0.56

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; NA = not applicable; RR = relative risk.

When stratified by definition, GWG interventions were not associated with risk of preterm birth before 37 weeks’ gestation (24 trials; RR, 0.94 [95% CI, 0.81 to 1.10]; I^2^=3.5%), birth before 36 weeks’ gestation (4 trials; RR, 1.04 [95% CI, 0.61 to 2.08]; I^2^=0%) or undefined preterm birth (5 trials; RR, 0.50 [95% CI, 0.10 to 1.33]; I^2^=7.1%). There were no statistically significant interactions between effects of GWG interventions on risk of preterm birth and BMI category (p=0.10 for interaction), intervention type (p=0.56 for interaction), or intensity (p=0.42 for interaction; Table 10).

#### Respiratory Distress Syndrome

Eight counseling-only RCTs (N=3,155; 4 good and 4 fair quality) of women with mixed (2 trials), overweight or obese (2 trials), or obese only (4 trials) prepregnancy BMI categories evaluated effects of GWG interventions on risk of respiratory distress syndrome (Appendix B Tables 1-3 and Appendix C Tables 1-2).^80,88,90,118,140,141,145,154^ Intervention intensity was low in two trials, moderate in three trials, and high in three trials. Pooled estimates demonstrated no effect of GWG interventions on risk of respiratory distress syndrome (8 trials; RR, 1.00 [95% CI, 0.67 to 1.42]; I^2^=0%; ARD, −0.3% [95% CI, −1.3 to 0.7]) (Table 11, Figure 11). There were no statistically significant interactions between effects of GWG interventions on risk of respiratory distress syndrome and BMI category (p=0.19 for interaction), intervention type (p=0.25 for interaction), or intensity (p=0.42 for interaction; Table 11).

Figure 11 Meta-Analysis of Trials: Infant Respiratory Distress Syndrome

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; O/O = overweight and obese combined BMI category.

Figure 11 is a forest plot examining association of infant respiratory distress syndrome with interventions to limit gestational weight gain. The overall relative risk is 1.00 (95% confidence interval 0.67 to 1.42) with an I-squared value of 0%.

Table 11 Meta-Analysis of Trials: Infant Respiratory Distress Syndrome Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 8 | 1.00 (0.67 to 1.42) | 0% | NA
BMI Category | Normal only | 0 | NA | NA | 0.19
BMI Category | Overweight only | 0 | NA | NA | 0.19
BMI Category | Obese only | 4 | 0.91 (0.48 to 1.50) | 0% | 0.19
BMI Category | Overweight-obese combined | 2 | 1.60 (0.72 to 4.32) | 0% | 0.19
BMI Category | Mixed | 2 | 0.64 (0.25 to 1.69) | 0% | 0.19
Intervention Intensity | Low | 2 | 0.64 (0.25 to 1.69) | 0% | 0.42
Intervention Intensity | Moderate | 3 | 1.03 (0.54 to 1.80) | 0% | 0.42
Intervention Intensity | High | 3 | 1.23 (0.45 to 2.93) | 0% | 0.42
Intervention Type | Active | 1 | 2.43 (0.50 to 11.77) | NA | 0.25
Intervention Type | Counseling only | 7 | 0.95 (0.61 to 1.37) | 0% | 0.25

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; NA = not applicable; RR = relative risk.

#### Shoulder Dystocia

Eight counseling RCTs (N=6,467; 4 good quality and 4 fair quality) found no difference in rates of shoulder dystocia for normal (1 trial), mixed (4 studies), or overweight or obese (3 studies) prepregnancy BMI categories for one active and seven counseling-only interventions compared to controls (Appendix B Tables 1-3 and Appendix C Tables 1-2).^56,80,88,93,96,123,127,143^ Intervention intensity was low in four trials, moderate in three trials, and high in one trial. There was no effect of GWG interventions on rates of shoulder dystocia based on pooled estimates (8 trials; RR, 1.05 [95% CI, 0.63 to 1.47]; I^2^=0%; ARD, 0.0% [95% CI, −0.4 to 0.5]; Table 12, Figure 12). There were no statistically significant interactions between effects of GWG interventions on risk of shoulder dystocia and BMI category (p=0.55 for interaction), intervention type (p=0.61 for interaction), or intensity (p=0.89 for interaction; Table 12).

Figure 12 Meta-Analysis of Trials: Shoulder Dystocia

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; O/O = overweight and obese combined BMI category.

Figure 12 is a forest plot examining association of shoulder dystocia with interventions to limit gestational weight gain. The overall relative risk is 1.05 (95% confidence interval 0.63 to 1.47) with an I-squared value of 0%.

Table 12 Meta-Analysis of Trials: Shoulder Dystocia Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 8 | 1.05 (0.63 to 1.47) | 0% | NA
BMI Category | Normal only | 1 | 0.69 (0.30 to 1.58) | NA | 0.55
BMI Category | Overweight only | 0 | NA | NA | 0.55
BMI Category | Obese only | 0 | NA | NA | 0.55
BMI Category | Overweight-obese combined | 3 | 1.12 (0.75 to 1.68) | 0% | 0.55
BMI Category | Mixed | 4 | 1.22 (0.44 to 3.44) | 0% | 0.55
Intervention Intensity | Low | 4 | 1.06 (0.41 to 2.74) | 0% | 0.89
Intervention Intensity | Moderate | 3 | 1.06 (0.73 to 1.55) | 0% | 0.89
Intervention Intensity | High | 1 | 0.67 (0.11 to 3.96) | 0% | 0.89
Intervention Type | Active | 1 | 0.67 (0.11 to 3.96) | NA | 0.61
Intervention Type | Counseling only | 7 | 1.06 (0.75 to 1.51) | 0% | 0.61

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; NA = not applicable; RR = relative risk.

#### NICU Admission

Fourteen RCTs (N=8,426) of women (7 of good quality, 7 fair quality) with normal (1 trial), mixed (6 trials), overweight or obese (4 trials), or obese (3 trials) prepregnancy BMI categories reported on rates of NICU or special care nursery admission, with no reported differences in rates between intervention and control groups in five active or 9 counseling-only intervention trials (Appendix B Tables 1-3 and Appendix C Tables 1-2).^56,59,76,80,88,90,93,94,96,105,125,127,143,145^ Intensity was rated low in three trials, moderate in four, and high in 7 trials. Pooled estimates demonstrated no effect of GWG interventions on rates of NICU admission (14 trials; RR, 0.98 [95% CI, 0.86 to 1.08]; I^2^=0%; ARD, −0.7% [95% CI, −1.9 to 0.5]; Table 13, Figure 13). There were no statistically significant interactions between effects of GWG interventions on risk of NICU admission and BMI category (p=0.38 for interaction), intervention type (p=0.47 for interaction), or intensity (p=0.82 for interaction; Table 13).

Figure 13 Meta-Analysis of Trials: Neonatal Intensive Care Unit Admission

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; O/O = overweight and obese combined BMI category.

Figure 13 is a forest plot examining association of neonatal intensive care unit admission with interventions to limit gestational weight gain. The overall relative risk is 0.98 (95% confidence interval 0.86 to 1.08) with an I-squared value of 0%.

Table 13 Meta-Analysis of Trials: NICU Admission Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 14 | 0.98 (0.86 to 1.08) | 0% | NA
BMI Category | Normal only | 1 | 0.79 (0.49 to 1.27) | NA | 0.38
BMI Category | Overweight only | 0 | NA | NA | 0.38
BMI Category | Obese only | 3 | 1.04 (0.84 to 1.12) | 0% | 0.38
BMI Category | Overweight-obese combined | 4 | 1.03 (0.89 to 1.31) | 0% | 0.38
BMI Category | Mixed | 6 | 0.87 (0.71 to 1.06) | 0% | 0.38
Intervention Intensity | Low | 3 | 0.90 (0.59 to 1.32) | 0% | 0.82
Intervention Intensity | Moderate | 4 | 0.98 (0.76 to 1.10) | 0% | 0.82
Intervention Intensity | High | 7 | 1.02 (0.78 to 1.32) | 0% | 0.82
Intervention Type | Active | 5 | 0.89 (0.61 to 1.19) | 0% | 0.47
Intervention Type | Counseling only | 9 | 0.99 (0.86 to 1.10) | 0% | 0.47

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; NA = not applicable; RR = relative risk.

#### Neonatal Death

Eleven RCTs (N=7,090) of women with normal (1 trial), mixed (4 trials), overweight or obese (4 trials), or obese (2 trials) prepregnancy BMI categories reported rates of neonatal death or stillbirth, with no significant differences reported between intervention versus control groups (Appendix B Tables 1-3).^56,59,76,88–90,93,96,125,143,145^ In the six good-quality^56,90,125,143,145^ and five fair-quality trials,^59,76,88,89^ three interventions were considered active and eight were counseling-only, and intervention intensity was rated low in two studies, moderate in four, and high in five studies. Data were not pooled for this outcome given heterogeneity in outcome categorization and low event rates.

#### Growth During the First Year of Life

Three counseling-only RCTs (N=2,516) of low, moderate, or high intensity found no differences between interventions during pregnancy versus usual care on infant growth during the first year of life (Appendix B Tables 1-3).^95,137,151^ One good-quality RCT^95^ of women with overweight or obese prepregnancy BMI categories reported the incidence of infant BMI z-score greater than or equal to both 85 percent and 90 percent at 6 months of age, and found no differences between groups. Two fair-quality RCTs of women with mixed BMI categories reported infant weight at 12 months postpartum following a counseling-only intervention during pregnancy and reported no difference between intervention and controls.^137,151^

## Effects of Interventions to Limit Excess Gestational Weight Gain on Gestational Weight Outcomes

### Summary

- Interventions were associated with decreased mean GWG versus controls (55 trials; MD, −1.02 kg [95% CI, −1.30 to −0.75]; I^2^=60.3%). Statistically significant interactions were present between effects of GWG intervention on mean GWG and high intensity interventions (p<0.001 for interaction), but not for BMI category (p=0.06 for interaction), intervention type (p=0.07 for interaction), study quality (p=0.30 for interaction), or weight assessment timepoint (p=0.26 for interaction).
- Interventions were associated with decreased likelihood of exceeding IOM recommendations for GWG (39 trials; RR, 0.83 [95% CI, 0.77 to 0.89]; I^2^=63.8%; ARD, −7.6% [95% CI, −11.0 to −4.6]); stratified analysis demonstrated statistically significant interactions between effects of GWG interventions on likelihood of GWG and active interventions (p=0.003 for interaction) and high intensity interventions (p<0.001 for interaction), but not BMI category (p=0.60 for interaction).
- GWG interventions were not associated with improved adherence to IOM recommendations for GWG, defined by neither gaining excessive weight nor failing to gain sufficient weight (19 trials; RR, 1.10 [95% CI, 0.89 to 1.35]; I^2^=84.3%; ARD, 4.2% [95% CI, −1.2 to 10.0]). There were no interactions between effects of GWG interventions on adherence to GWG recommendations and BMI category (p=0.09 for interaction), intervention type (p=1.00 for interaction), or intensity (p=1.00 for interaction).
- GWG interventions were associated with decreased postpartum weight retention (PPWR) at the followup time point of 12 months (10 trials; MD, −0.63 kg [95% CI, −1.44 to −0.01]; I^2^=65.5%), but not less than 6 months (6 trials; MD, −0.81 kg [95% CI, −2.40 to 0.55]; I^2^=84.4%) or 6 months (3 trials; MD, −0.85 kg [95% CI, −3.67 to 0.81]; I^2^=70.6%). There were no interactions between effects of GWG interventions on PPWR and BMI category at up to 6 months (p=0.41) or 12 months (p=0.75) postpartum; however, the number of trials was small and estimates were imprecise.

### Evidence

All 67 included trials (reported in 86 publications) conducted during pregnancy evaluated effects of GWG interventions on mean GWG (Appendix B Tables 1-3).^56,58,59,75–119,121–158^ Fifteen studies were rated good quality^56,58,78,80,90,95–97,100,108,109,117,121,125,129,143,145,146,154,155^ and 52 were rated fair quality.^59,75–77,79,81–89,91–94,98,101,103–107,110–116,118,119,122–124,126–128,130–142,147–153,156–158^ Sample sizes ranged from 50 to 2,261 (N=25,789, median=230), and reported sample mean ages ranged from 18.6 years to 33.8 years. One trial reported outcomes in women with normal prepregnancy BMI category,^96^ 34 studies^75,76,78–86,88,93,103–106,113–115,119,122,126,128,131,132,135–137,139,142,143,147,148,151,152^ reported outcomes in women with mixed prepregnancy BMI categories (including one^92^ with women whose prepregnancy BMI was normal or overweight only); 19 with women with overweight or obese categories^56,77,89,90,95,97,98,100–102,107–112,117,121,123,127,129,130,133,134,138,145,153,157^; and 13 with women with prepregnancy BMI category of obesity only.^58,59,87,91,94,118,124,125,140,141,146,149,150,154–156,158^

#### Mean Gestational Weight Gain

GWG interventions were associated with reduced gestational weight gain during pregnancy of approximately one kilogram versus controls (55 trials; N=20,090; MD, −1.02 kg [95% CI, −1.30 to −0.75]; I^2^=60.3%) (Table 14, Figure 14). Fourteen trials were rated good quality, and 41 were fair quality (Appendix C Table 1). High-intensity interventions were associated with greater effects (28 trials; MD, −1.47 kg [95% CI, −1.78 to −1.22]; I^2^=13.0%) than moderate (18 trials; MD, −0.32 kg [95% CI, −0.71 to −0.04]; I^2^=17.6%) or low-intensity interventions (9 trials; MD, −0.64 kg [94% CI, −1.44 to 0.02]; I^2^=48.4%; p<0.001 for intensity subgroup interaction) (Table 14, Appendix D Figure 1).

Figure 14 Meta-Analysis of Trials: Mean Gestational Weight Gain

Note: Outcome excluding Wolff, 2008: MD −0.99 kg, 95% CI, −1.26 to −0.73, I^2^ = 58.8%, p<0.001.

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; MD = mean difference; N = number; NR = not reported; PP = postpartum; SD = standard deviation.

Figure 14 is a forest plot examining association of mean gestational weight with interventions to limit gestational weight gain. The overall adjusted mean difference is −1.02 kg (95% confidence interval −1.30 to −0.75) with an I-squared value of 60.3%.

Table 14 Meta-Analysis of Trials: Mean Gestational Weight Gain Stratified Analysis

Stratified Analysis | Category | Number of Trials | Mean Difference (kg) (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 55 | −1.02 (−1.30 to −0.75) | 60.3% | NA
BMI Category | Normal only | 8 | −0.48 (−0.96 to −0.21) | 0.0% | 0.06
BMI Category | Overweight only | 10 | −0.89 (−1.54 to −0.32) | 15.5% | 0.06
BMI Category | Obese only | 18 | −1.63 (−2.45 to −0.91) | 63.0% | 0.06
BMI Category | Overweight-obese combined | 20 | −0.90 (−1.38 to −0.46) | 31.1% | 0.06
BMI Category | Mixed | 28 | −0.81 (−1.16 to −0.46) | 60.7% | 0.06
Intervention Intensity | Low | 9 | −0.64 (−1.44 to 0.02) | 48.4% | <0.001
Intervention Intensity | Moderate | 18 | −0.32 (−0.71 to −0.04) | 17.6% | <0.001
Intervention Intensity | High | 28 | −1.47 (−1.78 to −1.22) | 13.0% | <0.001
Intervention Type | Active | 19 | −1.29 (−1.60 to −1.04) | 2.2% | 0.07
Intervention Type | Counseling only | 36 | −0.86 (−1.27 to −0.50) | 66.0% | 0.07
Weight Assessment Timepoint | 28 weeks | 1 | −0.80 (−1.62 to 0.03) | NA | 0.26
Weight Assessment Timepoint | 34-36 weeks | 13 | −1.16 (−2.13 to −0.29) | 66.9% | 0.26
Weight Assessment Timepoint | 36 weeks to delivery | 27 | −0.89 (−1.24 to −0.58) | 59.9% | 0.26
Weight Assessment Timepoint | Delivery | 12 | −1.22 (−1.83 to −0.69) | 17.5% | 0.26
Weight Assessment Timepoint | 2 weeks postpartum | 1 | −3.40 (−5.03 to −1.77) | NA | 0.26
Weight Assessment Timepoint | NR | 1 | 0.09 (−0.79 to 0.97) | NA | 0.26
Intervention Quality | Fair | 41 | −1.11 (−1.42 to −0.81) | 45.7% | 0.30
Intervention Quality | Good | 14 | −0.82 (−1.42 to −0.31) | 73.3% | 0.30

Note: Overall, excluding Wolff (2008): 54 trials; −0.99 kg, 95% CI, −1.26 to −0.73, I^2^=58.8%, p<0.001.

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; kg = kilogram; NA = not applicable.

There was no association between effects of GWG interventions and prepregnancy BMI category (p=0.06 for BMI category interaction). Subgroup analyses demonstrated a greater effect of GWG interventions for women in the obesity category (18 trials; MD, −1.63 [95% CI, −2.45 to −0.91]; I^2^=63.0%) than in the overweight category (10 trials; MD, −0.89 [95% CI, −1.54 to −0.32]; I^2^=15.5%), overweight and obesity weight categories combined (20 trials; MD, −0.90 [95% CI, −1.38 to −0.46]; I^2^=31.1%), mixed weight categories (28 trials; MD, −0.81 [95% CI, −1.16 to −0.46]; I^2^=60.7%); or normal weight category (8 trials; MD, −0.48 [95% CI, -96 to −0.21]; I^2^=0.0%; Table 14, Appendix D Figure 2).

Additional subgroup analyses did not show any statistically significant interactions between effects of GWG interventions on weight gain and the intervention type (counseling-only vs. active; p=0.07), study quality (p=0.30), or timing of assessment of weight gain (p=0.26) (Table 14, Appendix D Figures 3-5).

Subgroup analyses based on demographic characteristics or socioeconomic status could not be conducted due to sparse data (Appendix B Table 3). Two trials enrolled low-income African American women exclusively,^90,112^ two enrolled low-income Latina women (one study exclusively of Latina women),^103,110^ and one enrolled low-income White (61%) and Black (39%) women.^135^ Results in these trials generally were consistent with overall findings, although the estimates of mean GWG in the two studies of African American women were slightly higher (MDs of −1.59 and −3.10 kg) than the studies of Latina women, which reported more inconsistent effects (MDs of −0.14 and −1.32 kg). One trial found no interaction between BMI category, income level, and effects of GWG interventions on mean GWG (p=0.16).^126^

#### Exceeding IOM Recommendations for Gestational Weight Gain

Thirty-nine RCTs^59,77–79,81,83–86,88,90,92–94,96,101,103,112,114,115,117,119,122,126,128,129,132,134–136,138,139,142,146–148,153,154,157^ (N=14,271) and one CCT^124^ (N=178) reported GWG in excess of the IOM recommendations as a dichotomous outcome (Appendix B Tables 1-3). Seven trials were rated good quality, and 33 studies fair quality (Appendix C Tables 1-2); 15 were active interventions^59,81,83–86,94,101,103,114,115,128,129,134,142^ and the remainder were counseling-only (Appendix B Table 1). GWG interventions were associated with decreased likelihood of gaining weight in excess of IOM recommendations (39 trials; RR, 0.83 [95% CI, 0.77 to 0.89]; I^2^=63.8%; ARD, −7.6% [95% CI, −11.0 to −4.6]) (Table 15, Figure 15).

Figure 15 Meta-Analysis of Trials: Exceeding IOM Recommendations for Gestational Weight Gain

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; IOM = Institute of Medicine; O/O = overweight and obese combined BMI category.

Figure 15 is a forest plot examining association of gestational weight gain in excess of IOM recommendations with interventions to limit gestational weight gain. The overall relative risk is 0.83 (95% confidence interval 0.77 to 0.89) with an I-squared value of 63.8%.

Table 15 Meta-Analysis of Trials: Exceeding IOM Recommendations for Gestational Weight Gain Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 39 | 0.83 (0.77 to 0.89) | 63.8% | NA
BMI Category | Normal only | 9 | 0.74 (0.56 to 0.88) | 38.7% | 0.60
BMI Category | Overweight only | 5 | 0.91 (0.78 to 1.01) | 0% | 0.60
BMI Category | Obese only | 8 | 0.81 (0.66 to 0.97) | 58.5% | 0.60
BMI Category | Overweight-obese combined | 13 | 0.85 (0.76 to 0.94) | 13.7% | 0.60
Intervention Intensity | Low | 7 | 0.91 (0.72 to 1.13) | 71.8% | <0.001
Intervention Intensity | Moderate | 10 | 0.97 (0.92 to 1.02) | 0% | <0.001
Intervention Intensity | High | 22 | 0.74 (0.69 to 0.79) | 0% | <0.001
Intervention Type | Active | 15 | 0.73 (0.67 to 0.80) | 0% | 0.003
Intervention Type | Counseling only | 24 | 0.89 (0.81 to 0.97) | 68.2% | 0.003

Note: Mixed BMI category removed from analysis, as participants would be double-counted in other categories.

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; IOM = Institute of Medicine; NA = not applicable; RR = relative risk.

Stratified analysis demonstrated statistically significant interactions between effects of GWG interventions on likelihood of exceeding GWG recommendations and active interventions (p=0.003 for interaction) and high intensity interventions (p<0.001 for interaction), but not BMI category (p=0.60) (Table 15).

#### Adherence to IOM Recommendations for Gestational Weight Gain

Nineteen trials^59,79,85,88,103,123,127,129,130,132,135,139,142,146,147,152,154^ (N=5,835) reported on the outcome of rates of adherence to GWG guidelines according to ranges recommended by the IOM (i.e., neither gaining excessive weight nor failing to gain sufficient weight) by prepregnancy BMI category (Appendix B Tables 1-3).^59,79,85,88,93,96,103,123,127,129,130,132,135,139,142,146,147,152,154^ Four trials were rated good quality and 15 fair quality (Appendix C Table 1). There were five active trials,^59,85,103,129,142^ and the remainder included counseling-only interventions (Appendix B Table 1). There was no difference between GWG interventions and controls in likelihood of adherence to IOM recommendations for GWG (19 trials; RR, 1.10 [95% CI, 0.89 to 1.35]; I^2^=84.3%; ARD, 4.2% [95% CI, −1.2 to 10.0]), although statistical heterogeneity was substantial (Table 16, Figure 16).

Figure 16 Meta-Analysis: Adherence to IOM Recommendations for Gestational Weight Gain

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; IOM = Institute of Medicine; O/O = overweight and obese combined BMI category.

Figure 16 is a forest plot examining association of gestational weight gain in adherence with IOM recommendations with interventions to limit gestational weight gain. The overall relative risk is 1.10 (95% confidence interval 0.89 to 1.35) with an I-squared value of 84.3%.

Table 16 Meta-Analysis of Trials: Adherence to IOM Recommendations for Gestational Weight Gain Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 19 | 1.10 (0.89 to 1.35) | 84.3% | NA
BMI Category | Normal only | 1 | 1.15 (0.94 to 1.41) | NA | 0.09
BMI Category | Overweight only | 0 | NA | NA | 0.09
BMI Category | Obese only | 3 | 1.27 (1.05 to 1.80) | 0% | 0.09
BMI Category | Overweight-obese combined | 4 | 1.27 (0.94 to 1.84) | 39% | 0.09
BMI Category | Mixed | 11 | 0.95 (0.68 to 1.31) | 88% | 0.09
Intervention Intensity | Low | 7 | 1.09 (0.94 to 1.32) | 0% | 1.00
Intervention Intensity | Moderate | 5 | 1.17 (1.02 to 1.34) | 0% | 1.00
Intervention Intensity | High | 7 | 1.01 (0.52 to 2.00) | 94% | 1.00
Intervention Type | Active | 5 | 0.98 (0.46 to 2.09) | 95.4% | 1.00
Intervention Type | Counseling only | 14 | 1.12 (1.02 to 1.25) | 0% | 1.00

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; IOM = Institute of Medicine; NA = not applicable; RR = relative risk.

There was no statistically significant interaction between effects of GWG interventions on adherence to IOM recommendations for GWG and BMI category (p=0.09 for interaction), intervention type (p=1.00 for interaction), or intensity (p=1.00 for interaction) (Table 16).

#### Postpartum Weight Retention

Fourteen studies in 26 publications evaluated the effects of GWG interventions on postpartum weight retention (Appendix B Tables 1-3).^59,78,100,104,106–109,111–113,116,118,119,131–133,135–137,143,144,154–156,158^ There were 13 RCTs (N=4,841; 4 rated good quality^78,108,109,143,144,154,155^ and 9 rated fair quality)^59,106,111–113,116,118,131,132,135–137,156,158^ and one fair-quality CCT^104^ (N=219) (Appendix C Tables 1-2). Two trials enrolled women with prepregnancy BMI categories of overweight or obese,^109,111^ four enrolled women categorized as obese only,^116,155,156,158^ and eight studies enrolled women with mixed BMI categories.^78,104,106,113,131,132,135–137,144^ Three trials^59,106,143^ evaluated active exercise interventions, while 11 studies assessed counseling-only interventions. Intensity was rated as low in two trials,^135–137^ moderate in seven studies,^78,104,109,113,116,132,158^ and high in five trials.^106,111,143,155,156^ Weight gain was reported from less than 6 months to 12 months postpartum.

GWG interventions were associated with statistically significant effects on postpartum weight retention at 12 months (10 trials; MD, −0.63 kg [95% CI, −1.44 to −0.01]; I^2^=65.5%),^78,107,111,113,116,131,133,137,144,155^ but not at less than 6 months (9 trials; MD, −0.81 kg [95% CI, −2.40 to 0.55]; I^2^=84.4%)^100,109,113,114,116,135,136,158^ or 6 months postpartum (3 trials; MD, −0.85 kg [95% CI, −3.67 to 0.81]; I^2^=70.6%)^111,132,156^ (Table 17, Figure 17). There were no statistically significant interactions between effects of GWG interventions on postpartum weight retention and BMI category at followup time of up to 6 months (p=0.41) or 12 months (p=0.75) (Table 17; Appendix D Figures 6-8).

Figure 17 Meta-Analysis of Trials: Mean Postpartum Weight Retention

Note: Outcome (<6 months) excluding Wolff, 2008: MD −0.17 kg, 95% CI, −0.97 to 0.53, I^2^ = 69.5%, p=0.003.

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; O/O = overweight and obese combined BMI category; N = number; SD = standard deviation.

Figure 17 is a forest plot examining association of mean postpartum weight retention with interventions to limit gestational weight gain by weight assessment timepoint. At less than 6 months, the adjusted mean difference is −0.81 (95% confidence interval −2.40 to 0.55) with an I-squared value of 84.4%. At 6 months, the adjusted mean difference is −0.85 (95% confidence interval −3.67 to 0.81) with an I-squared value of 70.6%. At 12 months, the adjusted mean difference is −0.63 (95% confidence interval −1.44 to −0.01) with an I-squared value of 65.5%.

Table 17 Meta-Analysis of Trials: Postpartum Weight Retention Stratified Analysis

Study Population (Followup Assessment) | Number of Trials | Mean Difference (kg) (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Less than 6 months | 9 | −0.81 (−2.40 to 0.55) | 84.4% | NA
Normal only | 1 | −1.80 (−4.30 to 0.70) | NA | 0.41
Overweight only | 1 | −1.85 (−3.65 to −0.05) | NA | 0.41
Obese only | 3 | −2.30 (−7.35 to 2.49) | 88.5% | 0.41
Overweight-obese combined | 3 | 0.32 (−1.97 to 3.34) | 83.3% | 0.41
Mixed | 4 | −0.35 (−1.06 to 0.35) | 0.0% | 0.41
6 months | 3 | −0.85 (−3.67 to 0.81) | 70.6% | NA
Normal only | 1 | −1.20 (−2.39 to −0.01) | NA | NA
Overweight only | 0 | - | - | NA
Obese only | 1 | 0.10 (−1.12 to 1.32) | NA | NA
Overweight-obese combined | 2 | −1.88 (−6.27 to 1.79) | 74.1% | NA
Mixed | 1 | −0.91 (−1.97 to 0.15) | NA | NA
12 months | 10 | −0.63 (−1.44 to −0.01) | 65.5% | NA
Normal only | 0 | - | - | 0.75
Overweight only | 0 | - | - | 0.75
Obese only | 2 | −0.12 (−2.35 to 1.98) | 0.0% | 0.75
Overweight-obese combined | 3 | −1.38 (−4.26 to 0.88) | 82.2% | 0.75
Mixed | 5 | −0.69 (−1.39 to 0.11) | 40.5% | 0.75

Note: Less than 6 months, excluding Wolff (2008): 8 trials; MD −0.17 kg, 95% CI, −0.97 to 0.53, I^2^=69.5%.

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; NA = not applicable.

## Harms of Interventions to Limit Excess Gestational Weight Gain Among Pregnant Women and Their Infants

### Summary

- Evidence was mixed on the effect of GWG interventions on maternal anxiety and depression based on various validated symptom scales in twelve studies.
- Interventions were not associated with SGA infants based on pooled analysis (20 trials; RR, 0.94 [95% CI, 0.80 to 1.10]; I^2^=0.0%; ARD, −0.4% [95% CI, −1.7 to 1.0]). There was a statistically significant interaction between effects of GWG interventions on risk of SGA and intervention intensity (p=0.04 for interaction), but not BMI category (p=0.91 for interaction) or intervention type (p=0.77 for interaction).

### Evidence

Evidence on harms associated with GWG interventions was very limited, with most studies not reporting harms related to the intervention (Appendix B Table 3). Limited data were available on effects of GWG interventions on psychological symptoms related to GWG interventions and risk of SGA infants. No study reported effects of GWG interventions on the outcomes of stigma, maternal musculoskeletal injuries, or other harms.

#### Depression and Anxiety

Twelve studies of GWG interventions reported effects on maternal depression and anxiety (Appendix B Tables 1-3).^75,87,91–93,96,97,99,105,125,129,147^ Ten were randomized trials (N=2,553; three good quality and seven fair quality), and two were controlled prospective cohort studies (N=563); one good quality, one fair quality)^91,97^ (Appendix C Tables 1-2). Different validated scales were used to measure anxiety and depression symptoms in these studies; therefore, pooling was not possible. Eight trials evaluated symptoms with the Edinburgh Postnatal Depression Scale (EPDS) scale at various time points or postpartum,^75,87,91,96,99,105,125,147^ but three trials did not report scores^87,91,125^; two trials reported scores based on the Hospital Anxiety Depression Scale (HADS)^92,93^; and a number of trials used different validated scales for measuring anxiety or depression.^87,91,96,97,99,105,125,129^ One trial enrolled women with normal BMI category,^96^ five trials enrolled women in mixed BMI categories,^75,92,93,105,147^ three studies enrolled women in prepregnancy categories of overweight and obese,^97,99,129^ and three studies enrolled women in the obese only prepregnancy BMI category.^87,91,125^ There were five active^75,91,99,105,129^ and seven counseling-only^87,92,93,96,97,125,147^ interventions. Intervention intensity was low in two trials,^92,93^ moderate in three trials,^87,96,147^ and high in seven trials.^75,91,97,99,105,125,129^

Effects of GWG interventions on maternal depression and anxiety were mixed. A fair quality trial (N=140)^75^ evaluating a high intensity, active intervention found that scores on the Edinburgh Postnatal Depression Scale (EPDS) were lower in women in a water exercise group than in controls (EPDS score, mean (SD): 6.41 (3.7) vs. 10.2 (2.4), p<0.001). An additional fair quality trial (N=172)^105^ evaluating a high intensity, active exercise intervention did not report differences between groups in EPDS scores over time, but reported a significant difference in psychological distress using the 21-item Depression Anxiety Stress Scale (DASS-21), used to evaluate general psychological distress (DASS-21 score, median (IQR): 6 (2-10) vs. 7 (4-11), p<0.05). A good quality, high intensity counseling intervention (N=230)^125^ found that dietary education was not associated with differences in anxiety or depression based on the State and Trait Anxiety Inventory (STAI) or EPDS. Another good quality trial (N=215)^97^ evaluating a high intensity counseling intervention used standardized measures used to assess intervention effects on changes in psychological outcomes. There were significant decreases in depressive symptoms from baseline to the post-intervention period in the intervention group versus controls (4.5 (3.7) vs. 6.1 (4.5); −1.95, 95% CI, −3.35 to −0.55, p=0.007), but no difference between groups in pregnancy-related anxiety using the pregnancy-related anxiety scale. A fair quality trial (N=261)^147^ evaluating a moderate intensity counseling intervention demonstrated no difference in psychological variables between intervention and control groups as measured by the EPDS and the DASS-21 at 15 weeks and 33 weeks gestation. A good quality counseling trial (N=633) in women with normal weight used three different scales to measure maternal quality of life and emotional well-being.^96^ There were no differences between intervention and control groups for the EPDS, SF-12, or STAI scores at any of the three measured time points (trial entry, 28, and 36 weeks).

A fair quality active trial (N=91), designed as a secondary analysis to evaluate the outcome of psychological well-being among women with overweight and obese BMI, used the Psychological General Well-Being Index to measure outcomes during pregnancy and the EPDS for assessing postpartum depression.^99^ There were no differences in either set of scores between intervention and control groups, demonstrating no effect of a supervised exercise program during pregnancy on psychological well-being. One good quality RCT (N=106)^129^ found an active GWG intervention associated with decreased likelihood of third trimester depression based on Center for Epidemiological Studies Depression Scale score (with depression indicated by scores greater than or equal to 16). Scores in the intervention group were significantly lower in the third trimester compared to the first trimester for the entire group (χ^2^=16.36, p=0.00) and in all BMI categories. One fair quality trial (N=205)^87^ found a high intensity counseling intervention was associated with small differences in anxiety symptom scores using the STAI, but no difference in depressed mood based on the EPDS. There was a statistically significant decrease in levels of anxiety in the intervention group and a statistically significant increase in anxiety among controls based on a multivariate model of state of anxiety by group (β-estimate [standard error], 1.04 [1.42] vs. 1.90 [1.52] vs. controls, p=0.02). One fair quality prospective intervention trial (N=348)^91^ found no effects on depression or anxiety symptoms using the Beck Anxiety Inventory and the EPDS.^91^ One fair quality RCT (N=78),^92^ designed as a feasibility RCT to test the acceptability of a counseling intervention with community midwives, used the Hospital Anxiety and Depression Scale to evaluate symptoms of anxiety and depression. In this trial, and the follow up fair quality RCT (N=616) evaluating the same intervention, there were no significant differences in scores for anxiety or depression between intervention and control groups (anxiety, adjusted mean −0.58, 95% CI: −1.25 to −0.8; depression, adjusted mean −0.60, 95% CI: −1.24 to −0.05).^93^

#### Small for Gestational Age

Thirty studies reported effects of GWG interventions on risk of infants small for gestational age (SGA); 29 were RCTs^58,76,80,81,84,88–90,94,96,98,104,105,112,119,121,125–127,132,134–136,142,143,145,146,152–154^ (N=13,820) and 1 was a CCT^91^ (N=348) (Appendix B Tables 1-3). SGA was defined as birthweight less than the 10^th^ percentile for gestational age (21 studies),^58,76,80,89–91,94,96,98,105,119,121,125,127,136,143,145,146,152–154^ low birth weight less than 2,500 g (12 studies),^81,84,94,96,104,126,132,134,135,142,145,152^ or intrauterine growth restriction (1 study)^88^; three RCTs^96,145,152^ reported both SGA and low birth weight. SGA, low birth weight, and intrauterine growth restriction were reported as secondary outcomes rather than as harms of GWG interventions. Ten RCTs trials met criteria for good quality,^58,80,90,96,121,125,143,145,146,154^ and the remaining 20 studies (19 RCTs and 1 CCT) were rated fair quality (Appendix Table C Tables 1-2); eight were active interventions^81,84,94,105,134,142,143,145^ and the remainder were counseling-only (Appendix B Table 1). One trial enrolled women with normal weight, 14 trials enrolled women with mixed weight categories, 10 with women with overweight or obesity, and 5 with women with obesity; intensity was rated low in 4 trials, moderate in 10, and high in 16 (Appendix B Table 1).

In the 20 SGA trials (N=8,981), there was one trial in women with normal BMI,^96^ eight trials in women with mixed BMI categories,^76,80,104,105,119,136,143,152^ seven of women in the overweight or obese category,^89,90,98,121,127,145,153^ and four of women in the obese category only.^58,125,146,154^ Intensity was low in two trials,^80,136^ moderate in seven trials,^76,89,96,119,121,127,146^ and high in 11 trials^58,90,94,98,105,125,143,145,152–154^; four were active interventions^94,105,143,145^ and the remainder were counseling-only.

GWG interventions were not associated with increased risk of SGA in 20 trials (RR, 0.94 [95% CI, 0.80 to 1.10]; I^2^=0.0%; ARD, −0.4% [95% CI, −1.7 to 1.0]) (Table 18, Figure 18).^76,78,105,111,112,116,118,119,125,131,132,136,137,143–145,153,155^ There was a statistically significant interaction between effects of GWG interventions on SGA and intervention intensity (p=0.04 for interaction), but not BMI category (p=0.91 for interaction) or intervention type (p=0.77 for interaction; Table 18).

Figure 18 Meta-Analysis of Trials: Small for Gestational Age

Note: Small for gestational age defined as birthweight below the 10^th^ percentile for gestational age.

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; O/O = overweight and obese combined BMI category.

Figure 18 is a forest plot examining association of small for gestational age with interventions to limit gestational weight gain. The overall relative risk is 0.94 (95% confidence interval 0.80 to 1.10) with an I-squared value of 0%.

Table 18 Meta-Analysis of Trials: Small for Gestational Age Stratified Analysis

Stratified Analysis | Category | Number of Trials | RR (95% Confidence Interval) | I^2^ | p for Subgroup Interaction
Study Population | Overall | 20 | 0.94 (0.80 to 1.10) | 0% | NA
BMI Category | Normal only | 1 | 0.83 (0.48 to 1.45) | NA | 0.91
BMI Category | Overweight only | 0 | NA | NA | 0.91
BMI Category | Obese only | 5 | 1.06 (0.55 to 1.96) | 0% | 0.91
BMI Category | Overweight-obese combined | 7 | 1.01 (0.74 to 1.42) | 0% | 0.91
BMI Category | Mixed | 7 | 0.87 (0.47 to 1.42) | 43.6% | 0.91
Intervention Intensity | Low | 2 | 0.39 (0.07 to 3.02) | 42% | 0.04
Intervention Intensity | Moderate | 7 | 0.97 (0.79 to 1.25) | 0% | 0.04
Intervention Intensity | High | 11 | 0.99 (0.76 to 1.29) | 0% | 0.04
Intervention Type | Active | 4 | 1.00 (0.42 to 1.58) | 0% | 0.77
Intervention Type | Counseling only | 16 | 0.93 (0.78 to 1.12) | 0% | 0.77

Note: SGA defined as birthweight below the 10^th^ percentile for gestational age; analyses do not include infants with low birth weight (less than 2,500 g, k=12).

Abbreviations: BMI = body mass index; I^2^ = index of heterogeneity; NA = not applicable; RR = relative risk.

## Contextual Questions

### Contextual Question 1. What Is the Association Between Gestational Weight Gain and Adverse Maternal and Infant Outcomes?

A 2008 systematic evidence review commissioned by AHRQ evaluated the association between GWG and infant and maternal outcomes.^23^ Nearly all of the studies in the review were observational. Of 11 maternal and intrapartum outcomes reported, cesarean delivery was the only maternal outcome with evidence showing a moderate association with GWG; the association was stronger among women with overweight or obesity (OR, 1.3 [95% CI, 1.2 to 1.3]).^22^ The review described the evidence on the association between GWG and other maternal outcomes (hypertensive disorders, abnormal glucose metabolism) as weak. For infant health outcomes (i.e., birth outcomes) there was moderate to strong evidence for an association between low GWG and preterm birth, low birth weight, and SGA, and strong evidence for the association between high GWG and high birthweight, macrosomia, and LGA. This systematic evidence review was used to inform the revised 2009 IOM GWG guidelines.

Systematic evidence reviews and meta-analyses of observational data conducted since the 2008 AHRQ review report similar findings.^23^ GWG above 2009 guidelines was associated with higher risk of LGA, macrosomia, and cesarean section. Weight gain below guidelines was associated with higher risk of SGA and preterm birth. Most recently, the LifeCycle Project-Maternal Obesity and Childhood Outcomes Study Group conducted an individual participant-level meta-analysis using data from over 196,000 singleton pregnancies within 25 cohort studies from Europe and North America.^18^ Excessive GWG in each prepregnancy weight category (including different obesity classes) was associated with adverse perinatal outcomes (e.g., the presence of one or more of the following outcomes: preeclampsia, gestational hypertension, gestational diabetes, cesarean delivery, preterm birth, SGA, or LGA). However, the predictive power of GWG for the different adverse pregnancy outcomes was either low or moderate. In fact, the study group concluded that while optimal GWG may inform prenatal counseling, the optimal GWG ranges had limited predictive value for the adverse outcomes assessed.

### Contextual Question 2. What Is the Association Between High Prepregnancy BMI and Risk of Adverse Maternal and Infant Outcomes?

A key result of the LifeCycle Project-Maternal Obesity and Childhood Outcomes Study was that prepregnancy BMI was more strongly associated with adverse maternal and infant outcomes than GWG.^18^ Numerous observational studies have demonstrated an association between elevated BMI at pregnancy onset and adverse perinatal outcomes.^11,13,15,168–170^ A 2017 umbrella review of 156 meta-analyses of cohort studies^8^ evaluated the association between adiposity and multiple obstetric and gynecological outcomes; evidence was strongest for elevated prepregnancy BMI and increased risk of cesarean delivery (BMI less than 25 vs. greater than 30; OR, 2.00 [95% CI, 1.87 to 2.15]), preeclampsia (BMI less than 25 vs. 25-30; OR, 1.70 [95% CI, 1.60 to 1.81]), and antenatal depression (BMI less than 25 vs. greater than 30; OR, 1.48 [95% CI, 1.32 to 1.66]; p<0.001 for all comparisons). The evidence was highly suggestive for associations between elevated prepregnancy BMI and GDM, LGA, macrosomia, stillbirth, postpartum hemorrhage, and preterm birth. There was a dose-dependent association between increasing degree of maternal obesity and increased maternal morbidity.^17^

A large (N=226,958) population-based cohort study from Canada^171^ examined the relationship between prepregnancy BMI and adverse pregnancy outcomes. The study estimated a 10 percent reduction in prepregnancy BMI would be associated with at least a 10 percent lower risk of preeclampsia, gestational diabetes, preterm delivery, macrosomia, and stillbirth. For example, women with a BMI of 36 kg/m^2^ would have a 10 percent lower risk of these complications than women with a BMI of 40 kg/m^2^. Larger declines in prepregnancy BMI (20% to 30%) were necessary to reduce risks of cesarean, shoulder dystocia, NICU stay 48 hours or longer, and in-hospital newborn mortality. Prepregnancy BMI was not associated with risk of postpartum hemorrhage requiring intervention, severe maternal morbidity or maternal mortality, or spontaneous preterm delivery before 32 weeks of gestation.

### Contextual Question 3. Among Women With a High Prepregnancy BMI, What Is the Association Between Reduction in Prepregnancy Weight and Risk of Adverse Maternal and Infant Outcomes?

A 2018 systematic evidence review and meta-analysis found an interpregnancy BMI decrease (greater than 1 BMI unit) was associated with decreased risk of LGA (3 trials; adjusted odds ratio [aOR], 0.7 [95% CI, 0.6 to 0.9]), macrosomia (3 trials; aOR, 0.5 [95% CI, 0.4 to 0.7]), and GDM (3 trials; aOR, 0.3 [95% CI, 0.6 to 1.0]), but increased risk of SGA (3 trials; aOR, 1.3 [95% CI, 1.1 to 1.6]) and low birth weight (less than 2,500 g) (3 trials; aOR, 2.2 [95% CI, 1.4 to 3.5]).^172^ One study that stratified women by BMI category found that those with normal BMI who lost weight had a similar risk for SGA as those who were overweight/obese and lost weight.^173^

Increases in BMI between pregnancies among women with prepregnancy BMI greater than 25 kg/m^2^ were associated with adverse pregnancy outcomes. A moderate increase in BMI was associated with increased risk of cesarean delivery and GDM; there was also an association with increased risk of LGA but this was not statistically significant.^172^ A substantial increase in BMI (greater than 3 BMI units) was associated with significantly increased risk of LGA and GDM, and an increased risk of cesarean delivery that was not statistically significant.^172^ However, the time between pregnancies was variable in these studies and could be quite long (years), which might not directly reflect the consequences of intentional weight loss prior to pregnancy.

A recent observational study of 16,395 women from the ELFE French national birth cohort examined the association between self-reported weight loss in the year prior to pregnancy and infant birthweight.^174^ For women with normal or high BMI, GWG was higher for women with weight loss before pregnancy, compared with women with stable or moderate weight variation. For women with prepregnancy BMI <25 kg/m^2^, infants of mothers with prepregnancy weight loss had higher mean birth weight compared to those from mothers with stable weight. For women with prepregnancy BMI >25 kg/m^2^, weight loss before pregnancy was not associated with infant birth weight. Prepregnancy weight loss was not significantly associated with the risk of SGA and LGA for any group. In mediation analyses, the authors concluded that the increased GWG among those with prepregnancy weight loss seemed to negate an expected reduction of infant birth weight due to prepregnancy weight loss.^174^