# Chapter 2 Methods

## Key Questions and Analytic Framework

Using methods developed by the USPSTF,^65^ the Evidence-based Practice Center (EPC) developed the scope and Key Questions in collaboration with the USPSTF and Agency for Healthcare Research and Quality (AHRQ).^65^ Investigators created an analytic framework with the key questions and the patient populations, interventions, outcomes, and adverse effects reviewed (Figure 1). The research plan was externally reviewed and modified prior to finalization.

Figure 1 Analytic Framework and Key Questions

Abbreviations: BMI = body mass index; GWG = gestational weight gain.

The analytic framework depicts the relationship between the population, intervention, outcomes, and potential harms of interventions. The far left of the framework describes the target population as pregnant women with normal and high body mass index, as well as overweight and obese women planning a pregnancy (including adolescents). To the right of the population is an arrow which represents effects of interventions to limit excess gestational weight gain on gestational weight gain, postpartum weight retention, or obesity-related adverse perinatal conditions (key question 2). Another arrow leads to potential harms of interventions to limit excess gestational weight gain (key question 3). An arrow above the population leads to outcomes of morbidity and mortality (key question 1). There is a dotted line linking gestational weight gain and obesity-related conditions (key question 2) and morbidity and mortality.

## Key Questions

This review addresses three Key Questions on the effects of counseling and active behavioral interventions on healthy weight and weight gain during pregnancy. The populations addressed were pregnant women with normal and high BMI and women with overweight and obesity planning a pregnancy, including adolescents.

### Key Questions

1a Do interventions to limit excess gestational weight gain improve health outcomes among pregnant women and their infants?
1b Do interventions to reduce prepregnancy weight in women who are overweight or obese improve health outcomes among women who become pregnant and their infants?
1c Does the effectiveness of these interventions differ by age, race/ethnicity, socioeconomic status, parity, smoking status, or body mass index (BMI) category?
2a Do interventions to limit excess gestational weight gain reduce gestational weight gain, postpartum weight retention, or obesity-related adverse perinatal conditions among pregnant women and their infants?
2b Do interventions to reduce prepregnancy weight in women who are overweight or obese improve weight outcomes or reduce obesity-related adverse perinatal conditions among women who become pregnant and their infants?
2c Does the effectiveness of these interventions differ by age, race/ethnicity, socioeconomic status, parity, smoking status, or body mass index (BMI) category?
3a What are the harms of interventions to limit excess gestational weight gain among pregnant women and their infants?
3b What are the harms of interventions to reduce prepregnancy weight among women or who are overweight or obese?
3c Do the harms of these interventions differ by age, race/ethnicity, socioeconomic status, parity, smoking status, or BMI category?

Key Question 1 focuses on the effect of interventions to limit excess gestational weight gain or reduce prepregnancy weight on health outcomes (i.e., maternal or infant morbidity and mortality). Key Question 2 evaluates the effect of interventions on weight outcomes (i.e., weight loss or gain, excessive gestational weight gain based on IOM recommendations, preconception weight loss, and postpartum weight loss or retention). Key Question 3 examines the harms of these interventions.

### Contextual Questions

Contextual Questions were also requested by the USPSTF to help inform the report. Contextual Questions are not reviewed using systematic review methodology.

1. What is the association between gestational weight gain and adverse maternal and infant outcomes?
2. What is the association between high prepregnancy BMI and risk of adverse maternal and infant outcomes?
3. Among women with a high prepregnancy BMI, what is the association between reduction in prepregnancy weight and risk of adverse maternal and infant outcomes?

## Search Strategies

We searched the Cochrane Database of Systematic Reviews (2005 through March 20, 2020), Cochrane Central Register of Controlled Trials, PsychINFO, Ovid MEDLINE In-Process & Other Non-Indexed Citations (through March 20, 2020), and Ovid MEDLINE (1946 through March 20, 2020) for relevant English-language studies and systematic reviews. Search strategies are available in Appendix A1. Electronic searches were supplemented by review of reference lists of relevant articles. Ongoing surveillance was conducted to identify major studies published since March 20, 2020 that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on February 5, 2021 and identified no studies affecting review conclusions. Six additional trials have recently been published, reporting similar results to this report from in-person^66–68^ or e-health lifestyle interventions.^69–71^

## Study Selection

Two reviewers independently evaluated each study to determine inclusion based on predetermined eligibility criteria developed for each Key Question (Appendix A2). After an initial dual review of citations and abstracts, investigators retrieved full-text articles of potentially relevant material. Two reviewers conducted full-text review of articles; discrepancies were resolved through consensus or with input from a third reviewer. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists the included studies, and Appendix A5 lists excluded studies with reasons for exclusion.

The target population was women, including adolescents, who were pregnant with normal or high BMI, or who were overweight or obese and planning pregnancy. Women with low prepregnancy BMI (underweight) were outside the scope of this review. This review focused on interventions conducted in, or recruiting from, primary care or primary care-referable settings, including routine prenatal care settings. Broader, community-based interventions were excluded. Pharmacologic interventions were excluded because they are not recommended in pregnancy.

Interventions were classified as either counseling-only or active behavioral interventions. Counseling-only interventions consisted of advice provided during the course of an intervention without an active component. Active interventions consisted of a structured, physical element and could include a counseling component. Active interventions included supervised exercise programs, prescribed exercise or dietary programs, or intensive weight management. The intensity of interventions varied with regard to the number of sessions or contacts, the duration and frequency of sessions, and the length of treatment. Intervention intensity was defined by the number of participant contacts beyond usual care or the comparison group, and was categorized as low (fewer than 2 contacts during the intervention period), moderate (3-11 contacts), or high intensity (12 or more contacts). Comparisons were behavioral interventions versus a control (i.e., usual care, attention control, minimal intervention). Minimal interventions (e.g., generic print materials) and attention controls (i.e., similar format but different content than intervention) commonly consisted of initial sessions with a provider regarding general education on healthy behavior in pregnancy, group education on general health topics, or access to websites promoting healthy behaviors during pregnancy. In some trials, usual care could include nutrition or physical activity materials based on national guidelines or access to additional support (e.g., access to midwives) as needed.

Outcomes were classified as weight-related intermediate outcomes (GWG, exceeding IOM recommendations for GWG, adherence to IOM recommendations for GWG, and postpartum weight loss or retention) or health outcomes. Women were defined as exceeding IOM recommendations if they had normal BMI and gained more than 35 lbs., overweight and gained more than 25 lbs., or obesity and gained more than 20 lbs. Adherence to IOM recommendations was defined as neither gaining excessive weight nor failing to gain sufficient weight according to IOM recommendations by BMI category.

Maternal health outcomes included maternal mortality, maternal morbidity (i.e., postpartum hemorrhage, perineal trauma, depression), and health outcomes (i.e., gestational diabetes, gestational hypertension, preeclampsia, cesarean delivery). For studies of gestational diabetes, diagnostic criteria varied and included methods such as use of the International Association of Diabetes and Pregnancy Study Group (IADPSG) criteria that used the 1-step approach to diagnosis with a 75 g glucose load, country-specific guidelines as defined by national criteria, or diagnosis per chart review with no specific criteria reported. Gestational hypertension was defined as systolic blood pressure of 140 millimeters of mercury [mm Hg] or higher, or a diastolic blood pressure of 90 mm Hg or higher after 20 weeks of gestation in a woman with previously normal blood pressure. Studies reporting the standard definition of gestational hypertension (two measurements of greater than 140/90 mm Hg at least 4 hours apart) were also included.^72^ Preeclampsia was defined as gestational hypertension accompanied by one or more new-onset systemic abnormalities (i.e., new-onset proteinuria greater than 300 mg/24 hours, protein/creatinine ratio of greater than or equal to 0.3, or dipstick reading of 1+, disturbances in hematologic, liver, renal, or visual symptoms, edema).^72^ Some studies did not provide a formal definition of preeclampsia but reported the outcome categorically.

Infant health outcomes included infant mortality (including stillbirth), infant morbidity (i.e., birth trauma, shoulder dystocia, respiratory distress syndrome), and infant health outcomes (i.e., macrosomia, large for gestational age, preterm birth, growth during first year of life).

Macrosomia was defined as term infants weighing more than 4,000 g, while large for gestational age was defined as birthweight above the 90^th^ percentile for gestational age. Preterm birth included infants born before 37 weeks gestation, before 36 weeks, or were defined categorically. Harms were those associated with interventions (e.g., anxiety, depression, maternal musculoskeletal injuries, stigma, and harms related to insufficient weight gain, including small for gestational age). Small for gestational age was defined as birthweight below the 10^th^ percentile for gestational age. Studies reporting only behavioral changes or intermediate cardio-metabolic measures were excluded.

Studies conducted in countries rated “very high” on the 2016 Human Development Index (considered applicable to U.S. populations and primary or prenatal care practice) were included.^73^ For all Key Questions, only randomized and nonrandomized controlled clinical trials that focused on diet, exercise, and/or behavioral counseling were included; cohort or case-control studies reporting harms (Key Question 3) were also eligible for inclusion.

Inclusion was restricted to English-language articles. Other exclusion criteria were studies published only as abstracts, non-systematic literature reviews, editorials or other opinion letters, and research protocols. Studies of nonhuman subjects were excluded, and studies had to report original data. Articles reporting overall consortium results, including trials that have not yet been published individually, were excluded.

## Data Abstraction and Quality Rating

For studies meeting inclusion criteria, we created data abstraction forms to summarize characteristics of each study. One investigator abstracted details about the study design, patient population, setting, interventions, analysis, followup, and results (Appendix B Tables 1-3). A second investigator reviewed data abstraction for accuracy. Two investigators independently applied predefined criteria developed by the USPSTF (Appendix A6) to assess the quality of individual controlled trials, systematic reviews, and observational studies and rate them as “good,” “fair,” or “poor,” depending on the seriousness of the methodological shortcomings.^65^ Discrepancies were resolved by consensus. Studies that were rated poor quality were excluded because results are more likely to be biased and highly unreliable.^65^

## Data Synthesis

To summarize evidence on the effects of GWG interventions, data were synthesized separately for each Key Question by outcome, including weight-related outcomes and health outcomes. Only randomized controlled trials were considered for meta-analysis. For both continuous and dichotomous outcomes, a random effects model based on the profile likelihood method was used to combine trials that evaluated comparable populations and interventions. Random effects meta-analyses were performed in STATA version 14 (Stata Corp, College Station, TX).

For continuous outcomes (GWG and postpartum weight retention), meta-analysis was conducted to combine the mean difference between the intervention and the control groups. If a study reported mean difference adjusted for baseline characteristics, the adjusted mean difference was used in the meta-analysis; otherwise, the difference in weight change from baseline to followup was used as the measure for mean difference. As imbalance in baseline weight was generally not observed in studies, sensitivity analysis was not conducted using the difference in followup weights. If weight change was not reported but baseline and followup weights were reported, the weight change was calculated based on these data points, and the correlation between baseline and followup weights was assumed to be the average correlation calculated from studies that reported all standard deviations (SD) from baseline, followup weights, and weight changes. Missing SDs were imputed, if necessary, by assuming the same coefficient of variation at baseline and followup; the SDs at baseline and followup were similar in studies that reported both.

For dichotomous outcomes with at least five trials, sufficient sample size, and comparable outcomes (GDM, gestational hypertension, preeclampsia, cesarean delivery, postpartum hemorrhage, perineal trauma, macrosomia, preterm birth, LGA, SGA, respiratory distress syndrome, shoulder dystocia, neonatal intensive care unit [NICU] admission, and exceeding or adhering to IOM recommendations for GWG), risk ratios were combined across eligible studies. Data were also pooled for 14 trials that reported emergency cesarean as separate, and clinically distinct, events; the other studies of cesarean did not provide separate data or descriptions. Results from arms of comparable interventions and outcome definitions within the same study were combined so each study was represented only once in each meta-analysis.

Stratified analyses were conducted when sufficient data were available to evaluate subgroup effects based on BMI category (normal, overweight, obese, overweight or obese combined, or mixed BMI populations), weight assessment time point (28 weeks, 34-36 weeks, 36 weeks up to delivery, and at delivery), intervention type (counseling-only or active) and intensity (low, moderate, or high, as defined in the Study Selection section), and study quality (good or fair). One study could contribute data for more than one subgroup in stratified analyses. We assessed statistical heterogeneity with the Cochran Q-test and the I^2^ statistic, which assesses the percentage of variation across studies that is due to heterogeneity rather than chance.^74^ The p-value for subgroup interaction was calculated to test for subgroup differences.

For all Key Questions, the overall quality of evidence was determined using the approach described in the USPSTF Procedure Manual.^65^ We assessed the aggregate internal validity (quality) of the overall body of evidence for each Key Question (insufficient, low, moderate, and high) using methods developed by the USPSTF, based on the number, quality, and size of studies, consistency of results between studies, and directness of evidence.^65^ A summary of evidence table was developed to assess the overall quality of evidence for each Key Question using the approach described in the USPSTF Procedure Manual.^65^

## Expert Review and Public Comment

A draft research plan for this topic was posted on the USPSTF Web site for public comment from April 26^th^ through May 3^rd^, 2018. The USPSTF received minor comments related to the included populations and outcomes. In response to these comments, the USPSTF added parity and smoking status to the included subpopulations for Key Questions (KQ) 1c, 2c, and 3c. In addition, the USPSTF revised the list of eligible outcomes for KQ 1 to clarify that stillbirth, depression, and shoulder dystocia are included. Finally, the USPSTF revised the list of eligible outcomes for KQ 3 to clarify that harms related to insufficient weight gain among infants were included. A final version of the research plan was posted on the USPSTF website in July 2019. A draft version of this report was reviewed by content experts (Appendix A7), representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and have been incorporated into the final report. Additionally, a draft version of this report was posted for public comment from December 8^th^, 2020, to January 11^th^, 2021 and few comments were received. In response, we revised the future research section. No other changes were necessary.