# Chapter 1 Introduction and Background

## Purpose

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to inform a recommendation on counseling and behavioral interventions for women in primary care settings to prevent adverse health outcomes associated with obesity during pregnancy and excess gestational weight gain (GWG) during pregnancy. The USPSTF has not previously made a recommendation on this topic.

## Condition Background

### Condition Definition

The 2009 Institute of Medicine (IOM) recommendations for healthy GWG vary according to prepregnancy weight category.^1^ Gestational weight gain is usually defined as change in weight measured before pregnancy (prepregnancy) or during the first trimester, to weight measured at the end of pregnancy (e.g., prior to delivery). Weight measured during the first prenatal visit is commonly accepted as a baseline measurement since many women gain little weight during the first trimester of pregnancy.^1^ Prepregnancy weight categories are based on the World Health Organization categories for nonpregnant persons, defined as underweight (body mass index [BMI] less than 18.5 kg/m^2^), normal or healthy weight (BMI 18.5 to 24.9 kg/m^2^), overweight (BMI 25 to 29.9 kg/m^2^), and obese (BMI 30 kg/m^2^ and greater).^1–3^ The 2009 IOM recommendations for healthy GWG are 28-40 pounds (lbs.) for women in the prepregnancy underweight category, 25-35 lbs. for normal prepregnancy weight, 15-25 lbs. for prepregnancy overweight category, and 11-20 lbs. for prepregnancy obese category.^1^ The IOM did not make recommendations about weight gain for women in different classes of obesity. The 2009 guidelines also include recommendations for weight gain by trimester and weight gain per week in the 2^nd^ and 3^rd^ trimester, which can be used to compare GWG among women with different lengths of gestation. Because prepregnancy BMI is an independent predictor of many adverse outcomes of pregnancy, the IOM recommends that women begin pregnancy with a normal BMI.

### Prevalence and Burden of Disease/Illness

#### Obesity and Overweight in Pregnancy

The prevalence of overweight and obesity is increasing among women of childbearing age and pregnant women, similar to trends observed in nonpregnant populations. Based on the 2015-2016 National Health and Nutrition Examination Survey, the estimated prevalence of obesity was 36 percent among women ages 20 to 39 years.^4^ Data suggests that obesity rates during pregnancy in the United States increased from 13 percent in 1993 to 24 percent in 2015.^5^ In 2015, it was estimated that almost half of all women entered pregnancy with overweight or obesity (24% with obesity and 24% with overweight).^6^ Reported rates of overweight and obesity are generally higher among non-Hispanic black, Alaska Native/American Indian, and Hispanic women, and lower among non-Hispanic white and Asian women.^7^

Since the IOM 2009 recommendations, observational studies have continued to report strong associations between elevated prepregnancy BMI and adverse pregnancy outcomes.^8–16^ A 2017 review of 156 meta-analyses of cohort studies^8^ found that elevated prepregnancy BMI was associated with increased risk of cesarean delivery, antenatal depression, gestational diabetes mellitus (GDM), large for gestational age (LGA), macrosomia, stillbirth, postpartum hemorrhage, and preterm birth, and that the association was stronger for those with increasing degrees of maternal obesity.^17^ Most recently, the LifeCycle Project-Maternal Obesity and Childhood Outcomes Study Group conducted an individual participant-level meta-analysis using data from over 196,000 singleton pregnancies within 25 cohort studies from Europe and North America. Prepregnancy BMI was the strongest risk factor associated with adverse maternal and infant outcomes including preeclampsia, gestational hypertension, gestational diabetes, cesarean delivery, preterm birth, and small for gestational age (SGA) or LGA, and was a stronger risk factor than GWG.^18^ Observational data also support associations between women with underweight BMI prior to pregnancy and increased risk of preterm birth.^19,20^ However, there are limited data to support whether change in weight before pregnancy is associated with a change in perinatal outcomes.

#### Excess Gestational Weight Gain

Observational studies have examined the association between health outcomes as they relate to GWG above and below the 2009 IOM guidelines. Excessive GWG, defined as weight gain above that recommended by the IOM in any category, has been associated with lower risk of SGA and preterm birth, but higher risk of LGA and higher risk of cesarean delivery.^21,22^ GWG below recommended IOM guidelines has been associated with higher risk of SGA and preterm birth, but lower risk of LGA and macrosomia, and no difference in cesarean delivery.^22^

In 2009, the IOM committee determined that the maternal health outcomes most closely associated with GWG were postpartum weight retention, cesarean delivery, GDM, and pregnancy-induced hypertension or preeclampsia.^23^ However, there was insufficient evidence to determine a causal link between risk of preeclampsia or GDM. For infant outcomes, measures of infant size at birth (e.g., SGA and LGA), preterm birth, and childhood obesity were most strongly associated with GWG.^24^

In 2015, GWG was within the recommended IOM guideline range for 32 percent of women in any BMI category giving birth to full-term, singleton infants; 48 percent gained more weight and 21 percent gained less weight than recommended in the IOM guidelines. Weight gain above IOM recommendations was highest among women who were overweight (61%) or had obesity (55%) before pregnancy.^25^ The association between race and ethnicity and likelihood of adhering to IOM guidelines is not clear, although the association tends to vary by baseline BMI.^26,27^

#### Etiology and Natural History

The etiologic factors that contribute to higher BMI before pregnancy are similar to factors that contribute to overweight and obesity in nonpregnant persons. The combination of individual factors (e.g., genetics, health behaviors, dietary patterns, physical activity, comorbid illnesses) and societal factors (e.g., environment, education and skills, food marketing and promotion) interact to produce weight gain, including an increase in body weight prior to pregnancy.^28^ However, unlike the nonpregnant adult state, weight gain during pregnancy can be attributed to both the fetal compartment (fetus, placenta, amniotic fluid) and the maternal compartment, including increased maternal blood volume, uterus and breast tissue, extracellular fluid, and fat accumulation.^29^ When maternal fat mass accrual is excessive, it may also be associated with adverse metabolic consequences during pregnancy.^24,30,31^

Entering pregnancy at an elevated BMI or gaining excessive fat during pregnancy can be associated with metabolic dysfunction (e.g., hyperinsulinemia, inflammation, oxidative stress) and may negatively affect organogenesis, metabolic programming, maternal adipose tissue deposition and expansion, and placenta development. These effects can result in a metabolically dysregulated intrauterine environment, leading to placental and fetal dysfunction throughout pregnancy.^32–41^ The Developmental Origins of Health and Disease hypothesizes that the events that occur during the earliest stages of human development may influence the development of diabetes, cardiovascular disease, asthma, cancers, osteoporosis, and neuropsychiatric disorders later in life.^42–45^

#### Interventions/Treatment

Preconception care for women with overweight or obesity may include counseling related to the risks of obesity in pregnancy and weight-loss interventions prior to conception. Given that nearly half of pregnancies in the United States are unplanned,^46^ the window for preconception counseling to optimize prepregnancy BMI often is unclear. Efforts to assess pregnancy intention may provide additional opportunities to address or reduce these risks.^47^ For pregnant women, interventions to reduce excess GWG may include one or more of the following: patient education and/or counseling related to potential adverse effects of excess GWG, behavioral counseling related to healthy diet or physical activity (or both), referral to nutrition services, or referral to a structured exercise program to help prevent excessive weight gain. The intensity, duration, and frequency of GWG interventions vary. Weight loss medications are not recommended for use in women planning pregnancy or during pregnancy due to safety concerns and adverse effects.^48^ Although bariatric surgery may be considered treatment for weight loss in reproductive age women considering a future pregnancy, the timing of pregnancy in relation to bariatric surgery is controversial; pregnancy is generally not recommended until weight loss has stabilized in women who have undergone surgery (at least 12 to 24 months).^49–51^

#### Current Clinical Practice/Recommendations of Other Groups

Current guidelines emphasize the importance of preconception counseling and weight loss for women with overweight or obesity. The American College of Obstetricians and Gynecologists recommends that primary health care providers of women of reproductive age with obesity provide specific information regarding the maternal and fetal risks of obesity in pregnancy and provide resources or encourage women to undertake a weight-reduction program before conceiving, including access to contraception to help them achieve a healthy weight prior to conception.^1,48,52–55^ Numerous organizations and clinical guidelines, including those from the IOM and National Institutes of Health (NIH), recommend counseling about healthy weight gain during pregnancy, adherence to IOM recommendations about GWG, and/or providing women at risk of excess GWG with lifestyle interventions (Table 1).^53^ Guidelines also note that abnormally high or low BMI is associated with infertility and pregnancy complications. In response to these recommendations, there has been a proliferation of randomized clinical trials on the effect of interventions on GWG published in the last decade.^56–60^

Table 1 Recommendations Made by Organizations Regarding Obesity in Pregnancy and Gestational Weight Gain

Organization | Year | Title | Recommendation
American College of Obstetricians and Gynecologists^3^ | 2013, 2016 | Committee Opinion Number 548: Weight Gain During Pregnancy; Committee Opinion Number 591: Challenges for Overweight and Obese Women | Recommends nutrition assessment and counseling during preconception and prenatal visits, including counseling on nutrition, exercise, and weight gain based on height and prepregnancy weight.^201^; Health care providers who care for pregnant women should determine a woman’s BMI at the initial prenatal visit. It is important to discuss appropriate weight gain, diet, and exercise at the initial visit and periodically throughout the pregnancy.; Individualized care and clinical judgment are necessary in managing overweight or obese women who are gaining (or wish to gain) less weight than recommended but have an appropriately growing fetus. Balancing the risks of fetal growth, obstetric complications, and maternal weight retention is essential but will remain challenging until research provides evidence to further refine the recommendations for GWG, especially among women with high degrees of obesity.
National Institute for Health and Care Excellence^202^ | 2010 | Weight Management Before, During and After Pregnancy | Women with a BMI greater than or equal to 30 kg/m^2^ who may become pregnant should be told that their weight poses a risk and should be advised about the health benefits of losing weight before pregnancy and referred to weight loss support programming. Women with a BMI of 30 kg/m^2^ or greater when pregnant should be advised of the risk but that they should not diet during pregnancy. These women should be offered a referral to a dietician or appropriately trained health professional for assessment and personalized advice on healthy eating and physical activity.
Centre for Maternal and Child Enquiries & Royal College of Obstetricians and Gynaecologists^203^ | 2010 | Joint Guideline: Management of Women with Obesity in Pregnancy | All pregnant women with a booking BMI greater than or equal to 30 kg/m^2^ should be provided with accurate and accessible information about the risks associated with obesity in pregnancy and how they may be minimized. Women should be given the opportunity to discuss this information.
Society of Obstetricians and Gynaecologists of Canada^204^ | 2010 | Clinical Practice Guideline Number 239: Obesity in Pregnancy | Pregnant women with a prepregnancy BMI greater than 30 kg/m^2^ should receive counseling about weight gain, nutrition, food choices, and the risks to themselves and their fetus associated with obesity.
Institute of Medicine^1^ | 2009 | Weight Gain During Pregnancy: Reexamining the Guidelines | Recommends that providers of prenatal care should offer women counseling, such as guidance on dietary intake and physical activity that is tailored to their life circumstances.; Federal, State, and local agencies, as well as health care providers, should inform women of the importance of conceiving at a normal BMI, and those who provide healthcare or related services to women of childbearing age should include preconception counseling in their care.

Abbreviations: BMI = body mass index (kilograms per meter squared); GWG = gestational weight gain.

Standard prenatal care usually includes weight monitoring to identify inadequate or excessive gestational weight. However, the degree to which women with overweight and obesity receive recommended preconception counseling or referrals to interventions is unclear.^61,62^ Women also report receiving conflicting information among different health care providers. A 2018 review of 54 articles documenting GWG discussions between women and their providers found variable prevalence and content of GWG counseling, although rates of counseling were often reported to be low and the content inaccurate. A newer systematic review reported a high percentage of women receiving advice on GWG, but the accuracy of the advice was less than optimal.^63^ Factors associated with receipt of GWG advice include being a woman with higher socioeconomic status, older age, nulliparity, a history of dieting, low physical activity, and having overweight or obesity.^64^