# Appendix E Supplementary Tables

Appendix E Table 1 Summary of Included Studies

Author, Year Study Name | Study Design N | Setting | Population BMI Category | Intervention Type; Intensity | Estimated Time | Description Intervention Comparison | Maternal Health Outcomes | Infant Health Outcomes | Weight Outcomes | Harms | Quality Rating
Aguilar-Cordero et al., 2019^71^; SWEP | RCT; N=140 | One university-affiliated aquatic facility Granada, Spain | Mixed | Active; High intensity | 1 hour classes 3x per week (planned 54 classes), weeks 20-37 | A. Intervention: supervised aquatic exercise classes from weeks 20 to 37.; B. Comparison: usual prenatal care. | | | X | X | Fair
Al Wattar et al., 2019^72^; ESTEEM | RCT; N=1,218 | 5 inner-city maternity units London and Birmingham, UK | Mixed | Counseling; Moderate intensity | 3 in-person sessions, 2 phone calls | A. Intervention: in-person sessions; initial individual consultation with dietician, group sessions (20 weeks and 28 weeks), phone calls from team (24 weeks and 32 weeks). Provided mixed nuts (30 g/day walnuts, hazelnuts, almonds) and extra-virgin olive oil (0.5 L/week). Fact sheets on olive oil and mixed nuts, educational presentations, weekly individual food portion plan.; B. Comparison: usual prenatal care. | X | X | X | X | Fair
Altazan et al., 2019^73^; Expecting Success / SmartMoms | RCT; N=54 | Clinic or smartphone Baton Rouge, LA | Overweight and obese | Counseling; High intensity | 18 lessons (time NR) | A. Intervention: in-person SmartMoms intervention, received dietary intake advice, exercise advice, weight graph created from dynamic GWG models to determine the trimester specific increase in energy intake required to adhere to the IOM recommendations. Structured intervention consisted of lessons and behavior modification counseling weekly (13-24 weeks), then biweekly (week 25 to delivery).; B. Intervention: remote SmartMoms Intervention, same as above intervention, but delivered via intensity-matched phone app at least once weekly. C: Comparison: usual prenatal care. | | | X | | Fair
Althuizen et al., 2013^74^; New Life(style) | RCT; N=246 | Eight midwifery clinics, Netherlands | Mixed | Counseling; Moderate intensity | 30-min phone call; three 15-min in person; one 15-min phone call | A. Intervention: counseling modules on healthy lifestyle, personalized feedback on weight gain.; B. Comparison: usual prenatal care. | X | X | X | | Good
Asbee et al., 2009^75^ | RCT; N=144 | One prenatal care center, Charlotte, North Carolina | Mixed | Counseling; Low intensity | NR - one initial study visit | A. Intervention: counseling on healthy lifestyle, recommended physical activity, personalized feedback on weight gain.; B. Comparison: usual prenatal care | X | | X | | Fair
Assaf-Balut et al., 2017^76^ | RCT; N=1,000 | One hospital-affiliated clinic, Madrid, Spain | Mixed | Counseling; Low intensity | 1 hour initial study visit | A. Intervention: lifestyle guidance, emphasis on including healthy fats (olive oil and pistachio consumption).; B. Comparison: usual prenatal care, emphasis on restricting fat. | X | X | X | X | Good
Bacchi et al., 2018^77^ | RCT; N=140 | One primary care obstetric clinic, Buenos Aires, Argentina | Mixed | Active; High intensity | 55-60 min 3x per week | A. Intervention: aerobic and aquatic exercises per ACOG guidelines.; B. Comparison: usual prenatal care. | | X | X | X | Fair
Barakat et al., 2012^78^ | RCT; N=100 | One primary care obstetric clinic, Madrid, Spain | Mixed | Active; High intensity | 35-45 min 3x per week | A. Intervention: aerobic and aquatic exercise.; B. Comparison: usual prenatal care. | X | | X | | Fair
Barakat et al., 2014^81^ | RCT; N=251 | One maternity care hospital, Madrid, Spain | Mixed | Active; High intensity | 55-60 min 3x per week | A. Intervention: aerobic exercise.; B. Comparison: usual prenatal care. | X | X | X | | Fair
Barakat et al., 2016^80^ | RCT; N=840 | One hospital, Madrid, Spain | Mixed | Active; High intensity | 55-60 min 3x per week | A. Intervention: aerobic exercise per ACOG guidelines.; B. Comparison: usual prenatal care. | X | X | X | X | Fair
Barakat et al., 2018^79^ | RCT; N=429 | 2 primary care medical centers; Madrid, Spain | Mixed | Active; High intensity | 55-60 min; 3x per week | A. Intervention: structured, supervised exercise classes from gestational week 9-11 to week 38-39.; B. Comparison: usual prenatal care. | | X | X | | Fair
Barakat et al., 2019^82^ | RCT; N=456 | 2 tertiary care hospitals Madrid, Spain | Mixed | Active; High intensity | 55-60 min 3x per week | A. Intervention: structured, supervised exercise classes from gestational week 8-10 to week 38-39; final motivational talk on importance of active pregnancy.; B. Comparison: usual prenatal care. | X | X | X | | Fair
Bogaerts et al., 2013^83^ | RCT; N=205 | Three hospital-based antenatal units, Belgium | Obese | Counseling; Moderate intensity | Four 1.5-2 hour in person groups | A. Intervention A: motivational lifestyle intervention sessions and brochure about nutritional advice and physical activity during pregnancy, with information to limit excessive gestational weight gain.; B. Intervention B: brochure only.; C. Comparison: usual prenatal care. | X | | X | X | Fair
Brownfoot et al., 2016^84^ | RCT; N=782 | One tertiary obstetric hospital, Melbourne, Australia | Mixed | Counseling; Low intensity | NR – during visits | A. Intervention: weight recording at each prenatal visit with IOM guidelines prominently displayed; discussion with clinician about appropriate weight gain according to IOM guidelines.; B. Comparison: usual prenatal care, did not have access to scales or weighing themselves as part of the visit. | X | X | X | X | Fair
Bruno et al., 2017^85^ | RCT; N=191 | One university hospital, Modena, Italy | Overweight and obese | Counseling; Moderate intensity | 1 hour initial study visit; four follow-up visits (time NR) | A. Intervention: counselling session at enrollment with dietician for prescribed personalized dietary plan.; B. Comparison: counselling session at enrollment with dietitian for general recommendations on diet and physical activity, given basic nutrition booklet, plus usual prenatal care. | X | X | X | X | Fair
Cahill et al., 2018^86^; PreGO | RCT; N=240 | One university hospital, St. Louis, Missouri | Overweight and obese | Counseling; High intensity | 10 biweekly 1-hour visits | A. Intervention: PAT+Lifestyle curriculum, including biweekly home visits by a parent educator with individualized counseling on diet and exercise, behavior change, reinforcement of lifestyle behaviors in postpartum period to return to baseline weight, plus parenting strategies and social support postpartum.; B. Comparison: PAT curriculum, including biweekly home visits by a parent educator with parenting strategies and social support. | X | X | X | X | Good
Haire-Joshu et al., 2019^103^ | Same as Cahill et al., 2018; N=185 | Same as Cahill et al., 2018 | Same as Cahill et al., 2018 | Same as Cahill et al., 2018 | 10 prenatal biweekly visits, 12 monthly postpartum visits (1 hour) | A. Same as Cahill et al., 2018; plus monthly visits from delivery to 12 months postpartum.; B. Same as Cahill et al., 2018; plus monthly visits from delivery to 12 months postpartum. | | | X | | Fair
Claesson et al., 2010^87^ | CCT; N=348 | Multiple antenatal care clinics, Sweden | Obese | Active; High intensity | Weekly 30-min in person; 1-2x per week exercise class (time NR), 3 follow-up visits (time NR) | A. Intervention: motivational interviewing during extra visits to midwife on weight control and counseling weekly; invitation to aqua aerobics class semiweekly.; B. Comparison: usual prenatal care. | | | X | X | Fair
Daley et al., 2015^88^ | RCT; N=76 | One community midwifery clinic, Birmingham, UK | Mixed | Counseling; Low intensity | NR - during visits | A. Intervention: personalized feedback at each visit on weight gain, self-weighing, brief counseling on diet and exercise as needed based on weight gain.; B. Comparison: usual prenatal care. | | | X | X | Fair
Daley et al., 2019^89^; POPS2 | RCT; N=616 | Four maternity centers, England | Mixed | Counseling; Low intensity | NR – during visits | A. Intervention: personalized feedback at each visit on weight gain, self-weighing, brief counseling on diet and exercise as needed based on weight gain.; B. Comparison: usual prenatal care. | X | X | X | X | Fair
Daly et al., 2017^90^; Healthy eating, Exercise and Lifestyle Trial | RCT; N=88 | One university hospital, Dublin, Ireland | Obese | Active; High intensity | 50-60 min 3x per week | A. Intervention: participation in medically supervised exercise classes during pregnancy and up to 6 weeks postpartum; personal goal setting; Facebook group.; B. Comparison: usual prenatal care. | X | X | X | X | Fair
Dodd et al., 2014^56^; LIMIT | RCT; N=2,212 | Three maternity hospitals, Adelaide, Australia | Overweight and obese | Counseling; Moderate intensity | 3 in-person visits; 3 phone calls (time NR) | A. Intervention: tailored dietary advice, recommendation for exercise, goal setting via in-person visits and phone calls.; B. Comparison: usual prenatal care. | X | X | X | X | Good
Dodd et al., 2018^91^ | Same as Dodd et al., 2014 | Same as Dodd et al., 2014 | Same as Dodd et al., 2014 | Same as Dodd et al., 2014 | Same as Dodd et al., 2014 | Same as Dodd et al., 2014 | | X | | | Same as Dodd et al., 2014
Dodd et al., 2019^92^; OPTIMISE | RCT; N=633 | One hospital Adelaide, Australia | Normal | Counseling; Moderate intensity | 3 in-person visits; 3 phone calls (time NR) | A. Intervention: tailored dietary advice, recommendation for exercise, goal setting via in-person visits and phone calls.; B. Comparison: usual prenatal care. | X | X | X | X | Good
Epel et al., 2019^93^; MMT | Prospective cohort; N=215 | Hospital and community health centers San Francisco, CA | Overweight and obese | Counseling; High intensity | 1 initial session, 8 group classes (2 hours 1x/wk), 2 phone calls (time NR), 1 postpartum group session | A. Intervention: Obesity-Related Behavioral Intervention Trials model, with sessions on mindful breathing, eating, and movement - nutritional and eating behavior, mindfulness-based eating awareness training, physical activity, and stress reduction.; B. Comparison: treatment as usual group, comprised of women unable to attend group classes, or gestational age 20-23 weeks but otherwise would have been eligible for the intervention. | | | | X | Good
Gallagher et al., 2018^94^; LIFT | RCT; N=210 | Multiple hospital-affiliated clinics, U.S. | Overweight and obese | Counseling; High intensity | 3 visits | A. Intervention: intensive counseling (individual and group) on behavior, nutrition, exercise; food and exercise logs; phone and email contact.; B. Comparison: usual prenatal care, plus group education sessions on healthy lifestyle during pregnancy. | X | X | X | X | Fair
Garnaes et al., 2016^97^; ETIP | RCT; N=91 | One university hospital, Trondheim, Norway | Overweight and obese | Active; High intensity | 60 mins sessions 3x per week | A. Intervention: supervised aerobic and strength exercise classes from gestational week 12-18 until delivery, recommended exercise at home, individualized IOM weight gain curve.; B. Comparison: usual prenatal care. | X | X | X | | Fair
Garnaes et al., 2017^98^ | Same as Garnaes et al., 2016 | Same as Garnaes et al., 2016 | Same as Garnaes et al., 2016 | Same as Garnaes et al., 2016 | Same as Garnaes et al., 2016 | Same as Garnaes et al., 2016 | X | X | X | | Same as Garnaes et al., 2016
Garnaes et al., 2018^96^ | Same as Garnaes et al., 2016 | Same as Garnaes et al., 2016 | Same as Garnaes et al., 2016 | Same as Garnaes et al., 2016 | Garnaes et al., 2016 | Same as Garnaes et al., 2016 | | | X | | Good
Garnaes et al., 2019^95^ | Same as Garnaes et al., 2016 | Same as Garnaes et al., 2016 | Same as Garnaes et al., 2016 | Same as Garnaes et al., 2016 | Same as Garnaes et al., 2016 | Same as Garnaes et al., 2016 | | | | X | Fair
Gesell et al., 2015^99^; Madre Sana, Bebé Sano / Healthy Mother, Healthy Baby | RCT; N=135 | Community center, Nashville, Tennessee | Mixed | Active; High intensity | 12 weekly 90-min group sessions | A. Intervention: group intervention sessions (8-10 women plus facilitator) at community recreation center for healthy lifestyle intervention; also received infant injury prevention intervention.; B. Comparison: home visits on infant injury prevention. | | | X | | Fair
Gray-Donald, et al., 2000^100^ | CCT; N=219 | Community-based prenatal clinics in Cree villages, Quebec | Mixed | Counseling; Moderate intensity | NR | A. Intervention: unclear; intervention based on social learning theory, administered by 2 nutritionists working with a team of health care workers, including a community nutritionist working in the Cree villages; frequency and type of contact not described.; B. Comparison: no intervention. | X | X | X | X | Fair
Guelfi et al., 2016^101^ | RCT; N=172 | Home-based supervised exercise Perth, Australia | Mixed | Active; High intensity | 3 sessions per week (20-60 min) from weeks 14 to 28 | A. Intervention: supervised home-based upright cycling, with progression to longer duration sessions depending on participant fitness.; B. Comparison: usual prenatal care. | X | X | X | X | Fair
Haakstad et al., 2011^102^ | RCT; N=105 | Community location, Oslo, Norway | Mixed | Active; High intensity | 60 mins 2x week for 12 weeks | A. Intervention: supervised sessions of aerobic dance exercises for at least 12 weeks; weekly self-imposed physical activity.; B. Comparison: usual prenatal care. | | X | X | | Fair
Harrison et al., 2013^104^; HeLP-her | RCT; N=228 | Three teaching hospitals, Victoria, Australia | Overweight and obese | Counseling; Moderate intensity | 4 sessions | A. Intervention: behavior change lifestyle intervention based on Social Cognitive Theory, including individualized dietary and PA advice, goal setting, self-monitoring.; B. Comparison: educational control on general Australian dietary and PA guidelines. | X | | X | | Good
Harrison et al., 2014^105^ | Same as Harrison et al., 2013 | Same as Harrison et al., 2013 | Same as Harrison et al., 2013 | Same as Harrison et al., 2013 | Same as Harrison, 2013 | Same as Harrison et al., 2013 | | | X | | Same as Harrison et al., 2013
Hawkins et al., 2014^106^; Estudio Vida | RCT; N=68 | Two medical centers, Massachusetts | Overweight and obese | Counseling; Moderate intensity | 1 in-person session per month for 6 months, 5 phone booster sessions | A. Intervention: Six-month lifestyle intervention tailored to Hispanic women, based on the Transtheoretical model and Social Cognitive Theory; telephone booster sessions.; B. Comparison: usual prenatal care. | | | X | | Fair
Herring et al., 2016^108^ | RCT; N=66 | Two hospital-affiliated obstetric clinics, Philadelphia, Pennsylvania | Overweight and obese | Counseling; High intensity | 1 in-person session, 7 calls over 12 weeks | A. Intervention: eHealth intervention based on the Social Ecological Model delivered over 12 weeks.; B. Comparison: usual prenatal care. | X | X | X | X | Fair
Herring et al., 2017^107^ | Same as Herring et al., 2016 | Same as Herring et al., 2016 | Same as Herring et al., 2016 | Same as Herring et al., 2016 | Same as Herring et al., 2016 | Same as Herring et al., 2016 | | | X | | Same as Herring et al., 2016
Hui et al., 2012^110^ | RCT; N=224 | One prenatal clinic, Winnipeg, Manitoba | Mixed | Active; High intensity | 30-45 mins per session 3-5x per week | A. Intervention: exercise regimen (walking, mild-to-moderate aerobic, stretching and strength exercises), in groups and at home. Dietary interviews and counselling were provided twice to each participant in the intervention group by registered dietitians.; B. Comparison: usual prenatal care. | X | X | X | | Fair
Hui et al., 2014^111^ | RCT; N=113 | Community location, Winnipeg, Manitoba | Mixed | Active; High intensity | 30-45 mins per session 3-5x per week | A. Intervention: community-based weekly exercise program, one-on-one private dietary consultation at baseline and 2 months later, used Food Choice Map software to assess dietary intake.; B. Comparison: usual prenatal care. | X | X | X | | Fair
Koivusalo et al., 2016^114^; RADIEL | RCT; N=293 | Four maternity hospitals, Finland | Obese | Counseling; Moderate intensity | Three 2-hour sessions | A. Intervention: structured, individualized lifestyle counseling, dietary advice, and PA program, plus initial group visit with dietician and usual care. Counseling from study nurse. For prepregnancy BMI ≥30 kg/m^2^, recommended no weight gain during first two trimesters.; B. Comparison: usual prenatal care, information leaflets on healthy diet and exercise. | X | X | X | | Fair
Huvinen et al., 2018^108^ | Same as Koivusalo et al., 2016 | Same as Koivusalo et al., 2016 | Same as Koivusalo et al., 2016 | Same as Koivusalo et al., 2016 | Same as Koivusalo et al., 2016 | Same as Koivusalo et al., 2016 | | | X | | Same as Koivusalo et al., 2016
Rono et al., 2018a^137^ | Same as Koivusalo et al., 2016; N=128 | Same as Koivusalo et al., 2016 | Same as Koivusalo et al., 2016 | Same as Koivusalo et al., 2016 | 1x every 3 months before pregnancy (time NR), three 2-hour sessions | Same as Koivusalo et al., 2016.; *Specific to Rono 2018a: prepregnancy recommendation for 5-10% weight loss prior to pregnancy for women BMI ≥25 kg/m^2^. | X | X | X | | Fair
Rono et al., 2018b^136^ | Same as Koivusalo et al., 2016; N=492 | Same as Koivusalo et al., 2016 | Same as Koivusalo et al., 2016 | Same as Koivusalo et al., 2016 | 2 hour x3 sessions | Same as Koivusalo et al., 2016 | X | X | X | | Fair
Kunath et al., 2019^115^; GeliS | Cluster RCT; N=2,261 | Gynecologic and midwifery practices Bavaria, Germany | Mixed | Counseling; Moderate intensity | 4 sessions (30-45 min each; 3 prenatal, 1 postpartum) | A. Intervention: individual prenatal and postpartum in-person counseling sessions; counseling on self-monitoring weight gains based on IOM recommendations, healthy nutrition and balanced diet based on Healthy Start guidelines, recommended physical activity.; B. Comparison: usual prenatal care, general information leaflets on healthy lifestyle in pregnancy. | X | X | X | X | Fair
Hoffman et al., 2019^109^ | Same as Kunath et al., 2019 | Same as Kunath et al., 2019; N=1,998 | Same as Kunath et al., 2019 | Same as Kunath et al., 2019 | Same as Kunath et al., 2019 | Same as Kunath et al., 2019 | | | X | | Same as Kunath et al., 2019
LeBlanc et al., 2020^116^; PREPARE | RCT; N=326 | Telephone and online, Oregon and Washington | Overweight and Obese | Counseling; High | 30-40 min initial session, 20-30 min session weekly (6 months) and monthly (up to 18 months or until pregnancy end) | A. Intervention: prepregnancy counseling focused on losing weight (dietary [DASH] and physical activity counseling); during pregnancy counseling focused on adhering to GWG guidelines, logging weight, food, and exercise into study website.; B. Comparison: usual prenatal care, information on having a healthy pregnancy. | | | X | | Good
Luoto et al., 2011^117^; NELLI | RCT; N=442 | Primary health care center-affiliated maternity clinics, 14 municipalities, Finland | Mixed | Counseling; Moderate intensity | One 2-hour PA session; one dietary counseling session; 3-4 booster sessions | A. Intervention: physical activity counseling session, diet counseling session, physical activity boosters and diet boosters during visits, invitations to group meetings.; B. Comparison: usual prenatal care. | X | X | X | X | Good
Kinnunen et al., 2012^113^ | Same as Luoto et al., 2011 | Same as Luoto et al., 2011 | Same as Luoto et al., 2011 | Same as Luoto et al., 2011 | Same as Luoto et al., 2011 | Same as Luoto et al., 2011 | | | X | | Same as Luoto et al., 2011
Magriples et al., 2015^118^; Centering Pregnancy Plus | RCT; N=984 | 14 community health centers and hospitals, New York City, New York | Mixed | Counseling; Moderate intensity | 10 sessions (120 mins each) | A. Intervention: group prenatal care, standard clinical intake, then groups of 8-12 women at same gestational age facilitated by 2 health providers, manualized curriculum.; B. Comparison: usual prenatal care. | | | X | | Fair
McCarthy et al., 2016^119^; FFF | RCT; N=382 | One tertiary obstetric hospital, Melbourne, Australia | Overweight and obese | Counseling; Low intensity | 30 mins x1 session | A. Intervention: Serial self-weighing and simple dietary advice.; B. Comparison: usual prenatal care | X | X | X | X | Fair
McGiveron et al., 2015^120^; Bumps and Beyond | CCT; N=178 | One antenatal clinic, Lincolnshire, UK | Obese | Counseling; Moderate intensity | 8 sessions | A. Intervention: Bumps and Beyond intervention, including an educational booklet and one-on-one counseling sessions regarding diet, exercise, and healthy weight gain in pregnancy delivered approximately from 16 weeks until 6 weeks postpartum.; B. Comparison: declined intervention. | X | X | X | | Fair
Okesene-Gafa et al., 2019^121^; HUMBA | RCT; N=230 | University, home-based visits South Auckland, Australia | Obese | Counseling; High intensity | 4 sessions (1 at 1.5 hr, 3 at 30-60 min); text messages 3x per week | A. Intervention: individual, home-based education sessions including feedback on weight gain and SMARTER goals, HUMBA handbook with nutrition information, recipes, management of cravings, physical activity tips, motivational text messages worded as if from the baby regarding nutrition, plus probiotic or placebo capsules; B. Comparison: usual prenatal care, NZ pamphlet on healthy eating and weight gain during pregnancy, plus probiotic or placebo capsules | X | X | X | X | Good
Olson et al., 2018^122^; e-Moms | RCT; N=1,689 | Online, Rochester, New York | Mixed | Counseling; Moderate intensity | NR | A. Intervention: intervention website, including weight gain tracker, a diet and exercise goal-setting tool, and health information, accessed through 6 weeks postpartum.; B. Intervention: intervention website, weight gain tracker, a diet and exercise goal-setting tool, and health information, accessed until delivery only.; C. Comparison: control website, including only health information. | X | X | X | X | Fair
Peccei et al., 2017^123^ | RCT; N=272 | One hospital-affiliated prenatal clinic, Revere, Massachusetts | Overweight and obese | Counseling; Moderate intensity | 60-90 mins initial session, 10-30 mins 2x per month | A. Intervention: culturally appropriate, individualized meal plans and counseling on nutrition, exercise, reading food labels, shopping for food on a budget, and breastfeeding; weight tracking.; B. Comparison: standard counseling on diet and exercise at randomization, and again at 6 weeks postpartum. | X | X | X | X | Fair
Pelaez et al., 2019^124^ | RCT; N=301 | One university hospital, Madrid, Spain | Mixed | Active; High intensity | 70-78 sessions (60-65 min 3x per week) | A. Intervention: structured, supervised exercise from weeks 12 to 36; 60-65 min sessions 3x per week (planned 70-78 sessions).; B. Comparison: usual prenatal care. | X | X | X | | Fair
Perales et al., 2015^125^ | RCT; N=129 | One university hospital, Madrid | Overweight and obese | Active; High intensity | 85 sessions (55-60 min) | A. Intervention: exercise sessions planned for a total of 85 sessions.; B. Comparison: usual prenatal care. | X | | X | X | Good
Petrella et al., 2014^126^ | RCT; N=63 | One hospital-based obstetrics unit, Modena, Italy | Overweight and obese | Counseling; Low intensity | 4 sessions (initial session 60 min; remainder time NR) | A. Intervention: Therapeutic Lifestyle Changes diet and exercise intervention, follow-up sessions to track adherence to program.; B. Comparison: nutritional booklet, usual prenatal care. | X | X | X | | Fair
Phelan et al., 2011^128^; Fit For Delivery | RCT; N=401 | Six obstetrics offices, Providence, Rhode Island | Mixed | Counseling; Moderate intensity | One in-person session, three 10-15 min phone calls | A. Intervention: in-person meeting plus phone calls following the Fit for Delivery behavioral intervention targeting diet and physical activity; women who were over or under guidelines received additional calls.; B. Comparison: in-person meeting, usual prenatal care, study newsletters. | X | X | X | X | Fair
Phelan et al., 2014^127^ | Same as Phelan et al., 2011 | Same as Phelan et al., 2011 | Same as Phelan et al., 2011 | Same as Phelan et al., 2011 | Same as Phelan et al., 2011 | Same as Phelan et al., 2011 | | | X | | Same as Phelan et al., 2011
Phelan et al., 2018^130^; Healthy Beginnings / Comienzo Saludables | RCT; N=264 | Two hospitals, San Luis Obispo, California and Providence, Rhode Island | Overweight and obese | Active; High intensity | Biweekly session (20 min) until 20 weeks’ gestation, monthly session until delivery | A. Intervention: biweekly in-person sessions until 20 weeks’ gestation, then monthly until delivery, on appropriate weight gain, physical activity, behavioral strategies for daily self-monitoring; partial meal replacement plan; goal setting for postnatal period.; B. Comparison: usual prenatal care, plus initial welcome visit, study newsletters. | X | X | X | X | Fair
Phelan et al., 2019^129^ | Same as Phelan et al., 2018 | Same as Phelan et al., 2018 | Same as Phelan et al., 2018 | Same as Phelan et al., 2018 | Same as Phelan et al., 2018 | Same as Phelan et al., 2018 | | | X | | Fair
Polley et al., 2002^131^ | RCT; N=120 | One obstetric clinic, Pittsburgh, Pennsylvania | Mixed | Counseling; Low intensity | NR | A. Intervention: written information on targeting appropriate weight gain in pregnancy, exercise, and diet; newsletters; personalized graph of weight gain; stepped care for with more structure for goals if weight exceeded recommendations; check-in phone calls.; B. Comparison: usual prenatal care. | X | X | X | X | Fair
Rauh et al., 2013^132^; FeLIPO | RCT; N=250 | Eight gynecology practices, Munich, Germany | Mixed | Counseling; Low intensity | Two sessions (initial 60 min, second 30 min) | A. Intervention: individual counseling module intervention targeting healthy lifestyle information, self-monitoring of diet and physical activity, self-monitoring of weight gain, and setting personal behavioral goals.; B. Comparison: usual prenatal care. | X | X | X | X | Fair
Rauh et al., 2015^133^ | Same as Rauh et al., 2013 | Same as Rauh et al., 2013 | Same as Rauh et al., 2013 | Same as Rauh et al., 2013 | Same as Rauh et al., 2013 | Same as Rauh et al., 2013 | | X | X | | Same as Rauh et al., 2013
Redman et al., 2017^134^; SmartMoms | RCT; N=54 | Social media or community clinics, U.S. | Overweight and obese | Counseling; High intensity | 18 lessons | A. Intervention: in-person SmartMoms intervention, received dietary intake advice, exercise advice, weight graph for trimester-specific increase in energy intake for adherence to IOM recommendation. Structured intervention consisted of lessons and behavior modification counseling weekly (13-24 weeks), then biweekly (week 25 to delivery).; B. Intervention: remote SmartMoms Intervention, same as above intervention, but delivered via intensity-matched phone app.; C. Comparison: usual prenatal care. | | | X | | Fair
Renault et al., 2014^58^; TOP | RCT; N=425 | Hospital-based clinic, Copenhagen, Denmark | Obese | Counseling; High intensity | 11-13 biweekly sessions | A. Intervention: PA plus D (physical activity and dietary intervention), with followup on dietary advice and encouragement to increase physical activity as assessed by pedometer.; B. Intervention: PA (physical activity) only, encouraged to increase physical activity as assessed by pedometer.; C. Comparison: usual prenatal care. | X | X | X | X | Good
Ronnberg et al., 2014^135^ | RCT; N=445 | 14 antenatal clinics, Örebro County, Sweden | Mixed | Counseling; Low intensity | 1 session | A. Intervention: individual education on IOM guidelines for recommended GWG by BMI category, personalized graph to monitor with midwife, weight discussed at each visit, formalized prescription of PA (recommended daily moderate PA).; B. Comparison: usual prenatal care. | | | X | | Fair
Ruiz et al., 2013^138^ | RCT; N=962 | Three primary care medical centers, Madrid, Spain | Mixed | Active; High intensity | 50-55 min exercise session 3x per week (planned 85 sessions) | A. Intervention: structured, supervised, light-to-moderate intensity exercise intervention program from week 9 to weeks 38/39. A mean of 85 training sessions were planned for each participant in the event of no preterm delivery.; B. Comparison: usual prenatal care. | X | X | X | X | Fair
Sagedal et al., 2017^139^; Norwegian Fit For Delivery | RCT; N=606 | Eight healthcare clinics, Norway | Mixed | Active; High intensity | Two 20-min dietary counseling sessions, 60 mins recommended exercise sessions 2x per week | A. Intervention: dietary counseling sessions on awareness of food choices, access to exercise classes, lifestyle recommendations from booklets and trial website, cooking class.; B. Comparison: usual prenatal care. | X | X | X | X | Good
Sagedal et al., 2017b^140^ | Same as Sagedal et al., 2017 | Same as Sagedal et al., 2017 | Same as Sagedal et al., 2017 | Same as Sagedal et al., 2017 | Same as Sagedal et al., 2017 | Same as Sagedal et al., 2017 | | | X | | Same as Sagedal et al., 2017
Seneviratne et al., 2016^136^ | RCT; N=75 | Home-based supervised exercise Auckland, New Zealand | Overweight and obese | Active; High intensity | 15-30 min exercise 3-5x per week (planned 67 sessions, from 20-35 weeks’ gestation) | A. Intervention: written program prescribing frequency and duration of weekly moderate-intensity exercise using magnetic stationary bicycle.; B. Comparison: usual prenatal care. | X | X | X | X | Good
Simmons et al., 2017^142^; DALI Lifestyle | RCT; N=436 | Antenatal clinics across 11 centers in nine European countries (Austria, Belgium, Denmark, Ireland, Italy, Netherlands, Poland, Spain, UK) | Obese | Counseling; Moderate intensity | 5 in-person sessions (30-45 min); ≤4 telephone calls (≤20 min) or emails | A. Intervention A: assigned healthy eating (HE) lifestyle coach, individual sessions on 7 messages promoting healthy eating, study toolkit.; B. Intervention B: assigned physical activity (PA) lifestyle coach, 5 messages promoting aerobic and resistance PA, study toolkit.; C. Intervention C: HE and PA interventions combined.; D. Comparison: usual prenatal care. | X | X | X | X | Good
Skouteris et al., 2016^143^; HIPP | RCT; N=261 | Two antenatal clinics, Melbourne, Australia | Mixed | Counseling; Moderate intensity | Initial in-person session (60 min at 18 weeks), followup session (30 min at 24 weeks), 2 phone calls (15 min) | A. Intervention: individual health coaching intervention, telephone followup sessions, and educational group sessions.; B. Comparison: education group session for control. | X | X | X | X | Fair
Smith et al., 2016^144^ | RCT; N=51 | Online, U.S. | Mixed | Counseling; Moderate intensity | 1 in-person training session | A. Intervention: web-based behavioral intervention including exercise goal-setting modules, problem-solving modules, journal, calendar to track all exercise until delivery, community forum to interact with other participants in the intervention.; B. Comparison: usual prenatal care, plus access to the website’s general pages with information on recommended PA and weight gain during pregnancy. | | | X | | Fair
Thomson et al., 2016^148^; Delta Healthy Sprouts | RCT; N=105 | Homes, Lower Delta region, Mississippi | Mixed | Counseling; High intensity | Monthly home visits (intervention 90-120 min; control 60-90 min) | A. Intervention (PATE): home visits using PAT curriculum plus culturally tailored maternal weight management and early childhood obesity prevention components. Based on DPP and inFANT trial, with emphasis placed on healthy eating and weight control during pregnancy.; B. Comparison (PAT): home visits using PAT curriculum, monthly group meetings, developmental screenings, and a resource network for families. | X | X | X | X | Fair
Thomson et al., 2018^147^ | Same as Thomson et al., 2016; N=54 | Same as Thomson et al., 2016 | Same as Thomson et al., 2016 | Same as Thomson et al., 2016 | 18 monthly visits (gestational month 4 - postpartum month 12; 90-120 min) | Same as Thomson et al., 2016 | | X | | | Fair
Van Horn et al., 2018^149^; MOMFIT | RCT; N=281 | University hospital Chicago, Illinois | Overweight and obese | Counseling; High intensity | 3 individual visits (time NR), 9 telephone calls (time NR), six 30-min group sessions | A. Intervention: education on MAMA-DASH diet (modified DASH diet for pregnancy), food intake tracking, PA guidelines, individual emails, text messages, and phone calls using motivational interviewing from registered dietician nurse, emails with educational materials and resources, MOMFIT website, group sessions on lifestyle and breastfeeding.; B. Comparison: usual prenatal care, access to MOMFIT website with general dietary and pregnancy care information. | X | X | X | X | Fair
Vesco et al., 2014^150^; Healthy Moms | RCT; N=118 | One managed care organization, Oregon and Washington | Obese | Counseling; High intensity | 2 individual sessions (time NR), 16 group sessions (90 min) | A. Intervention: individual counseling session, group sessions, diet and exercise intervention, with diet based on DASH and recommended daily moderate PA.; B. Comparison: usual prenatal care, with a single general health education session as control. | X | X | X | X | Good
Vesco et al., 2016^151^ | Same as Vesco et al., 2014 | Same as Vesco et al., 2014 | Same as Vesco et al., 2014 | Same as Vesco et al., 2014 | Same as Vesco et al., 2014 | Same as Vesco et al., 2014 | | X | X | | Same as Vesco et al., 2014
Vinter et al., 2011^59^; LiP | RCT; N=360 | Two university hospitals, Denmark | Obese | Active; High intensity | 4 sessions | A. Intervention: dietary counseling at 15, 20, 28, and 35 weeks’ gestation, recommended daily moderate PA, pedometer, free full-time membership in a fitness center for 6 months, closed individual and group training classes with physiotherapists.; B. Comparison: access to a website with general advice about dietary habits and PA in pregnancy. | X | X | X | X | Fair
Vinter et al., 2014^152^ | Same as Vinter et al., 2011 | Same as Vinter et al., 2011 | Same as Vinter et al., 2011 | Same as Vinter et al., 2011 | Same as Vinter et al., 2011 | Same as Vinter et al., 2011 | | | X | | Same as Vinter et al., 2011
Tanvig et al., 2014^146^ | Same as Vinter et al., 2011 | Same as Vinter et al., 2011 | Offspring of women with obesity | Same as Vinter et al., 2011 | Same as Vinter et al., 2011 | Same as Vinter et al., 2011 | | X | | | Same as Vinter et al., 2011
Tanvig et al., 2015^145^ | Same as Vinter et al., 2011 | Same as Vinter et al., 2011 | Offspring of women with obesity | Same as Vinter et al., 2011 | Same as Vinter et al., 2011 | Same as Vinter et al., 2011 | | X | | | Same as Vinter et al., 2011
Willcox et al., 2017^153^; txt4two | RCT; N=100 | Mobile devices, Melbourne, Australia | Overweight and obese | Counseling; High intensity | 15 min introduction meeting | A. Intervention: multimodal, including face-to-face introduction, text messages, website, video messages, chat room interaction, all informed by Social Cognitive Theory and CALO-RE taxonomy of behavior changes, emphasize daily moderate PA.; B. Comparison: usual prenatal care. | | | X | | Fair
Wolff et al., 2008^154^ | RCT; N=50 | Two hospitals, Denmark | Obese | Counseling; Moderate intensity | Ten 60-min sessions | A. Intervention: in-person visits with nutritionist on eating a healthy diet; given energy restricted diet plan.; B. Comparison: usual prenatal care. | X | | X | | Fair

Note: Low intensity = 0-2 contacts during intervention; Moderate intensity = 3-11 contacts during intervention; High intensity = 12 or more contacts during intervention.

Abbreviations: ACOG = American College of Obstetricians and Gynecologists; BMI = body mass index; CALO-RE = Coventry, Aberdeen, and London-Refined; CCT = controlled clinical trial; DASH = Dietary Approaches to Stopping Hypertension; DPP = Diabetes Prevention Program; ESTEEM = Effect of Simple, Targeted Diet in Pregnant Women with Metabolic Risk Factors on Pregnancy Outcomes; ETIP = Exercise Training in Pregnancy; GWG = gestational weight gain; HE = healthy eating; HUMBA = Healthy Mums and Babies; inFANT = infant Feeding Activity and Nutrition Trial; IOM = Institute of Medicine; LIFT= Lifestyle Interventions For Two; MMT = Mindful MAMAS Training; MOMFIT = Maternal Offspring Metabolics Family Intervention Trial; NR = not reported; PA = physical activity; PAT = Parents As Teachers; RCT = randomized clinical trial; SWEP = Study Water Exercise Pregnant; TOP = Treatment of Obese Pregnant Women.

Appendix E Table 2 Behavioral and Counseling Intervention Implementation Table: Summary and Examples of Included Interventions for Healthy Weight and Weight Gain During Pregnancy

Primary Population | Pregnant women with normal, overweight, or obese BMI.
Primary outcomes | Pregnancy weight-related intermediate outcomes; maternal health outcomes including maternal mortality, maternal morbidity, and health outcomes; infant outcomes, including infant mortality, infant, and infant health outcomes.
Study Findings | Counseling and active behavioral interventions to limit GWG in pregnant women are associated with modest reductions in weight gain and decreased likelihood of exceeding IOM recommendations for GWG. Effects of these interventions on mean GWG are slightly more pronounced for high intensity interventions. GWG interventions are also associated with a modestly decreased risk of GDM, macrosomia, large for gestational age, and reduced postpartum weight retention at 12 months
Behavior change goals and techniques | A variety of therapeutic approaches to help participants limit excess GWG through counseling, active interventions, or a combination. Counseling included education regarding healthy diet and/or physical activity during pregnancy in person, online, or via telephone. Active interventions included structured medically-supervised exercise classes or partial meal replacement. Behavior change techniques included goal setting, active use of self-monitoring, and addressing barriers related to healthy lifestyle adoption and maintenance.
Intervention duration and Intensity | The majority of interventions began at the end of the first trimester or beginning of second trimester, and concluded prior to or at delivery. Intensity was defined as high (12 or more contacts beyond usual care during the intervention period), moderate (3-11 contacts), or low (fewer than 2 contacts).
Settings of studies | Primary care or primary care-referable settings, and routine prenatal care settings including obstetric and gynecology or midwifery clinics, and hospitals.
To whom is intervention targeted? | Most of the effective interventions were targeted to women with obesity or combined obesity or overweight prepregnancy BMI. Much of the available evidence is for interventions beginning after the first trimester and ending in the third trimester. Evidence for women of advanced maternal age or adolescence and those planning pregnancy was limited, as was evidence for effects of interventions reported out by women identifying as socioeconomic, racial or ethnic minority, or other populations experiencing health disparities.
| Effective interventions defined by type and intensity of intervention
EXAMPLE INTERVENTIONS TO LIMIT EXCESS GWG^*^,^†^ | Active / Supervised Exercise | Counseling
EXAMPLE INTERVENTIONS TO LIMIT EXCESS GWG^*^,^†^ | High Intensity; k=22 | High Intensity; k=13 | Moderate Intensity; k=23 | Low Intensity; k=10
Mode and intensity of delivery * ^†^ | Structured, supervised exercise classes one to three time per week (average 45-60 minutes). Classes included aerobic, resistance, and flexibility exercises based on American College of Obstetricians and Gynecology recommendations for exercise during pregnancy. Intervention participants generally used free weights and/or resistance equipment. | Individual or group counseling in person, online, or over the phone. Sessions ranged from once a week to once a month, lasting from 30 minutes to 2 hours. Counseling focused on nutrition, goal-setting, physical activity, behavioral and social support strategies. Few interventions followed evidence-based, structured curricula. Interventions may have included phone call or email followups one to two times per week; eHealth interventions offered online or text message support. | Individual or group counseling in person or over the phone. Sessions ranged from once a month to once a trimester, lasting from 15 to 45 minutes. Counseling focused on recommendations for healthy eating and/or or physical activity based on ACOG guidelines. Interventions may have included phone call ‘booster’ sessions and toolkits with educational materials or physical activity accessories for participants. | Individual sessions as part of usual antenatal care, or one to two brief extra sessions. Counseling focused on maintaining healthy weight, and often included personalized graphs with weight gain guidance based on IOM recommendations.
Example interventions * ^†^ | Bacchi 2018; Barakat 2014; Barakat 2016; Barakat 2018; Barakat 2019; Pelaez 2019; Phelan 2018 (Healthy Beginnings); Ruiz 2013; Sagedal 2017 (Norwegian Fit for Delivery); Seneviratne 2016; Vinter 2011 (LiP) | Altazan 2019 (Expecting Success / SmartMoms); Cahill 2018 (PreGO); Gallagher 2018 (LIFT); Renault 2014 (TOP); Van Horn 2018 (MOMFIT); Vesco 2014 (Healthy Moms); Willcox 2017 (txt4two) | Al Wattar 2019 (ESTEEM); Bogaerts 2013; Bruno 2017; Phelan 2011 (Fit for Delivery) | Assaf-Balut 2017; Rauh 2013 (FeLIPO); Ronnberg 2014
Materials and practice ^§^ | https://lifemoms.bsc.gwu.edu/; https://www.acog.org/-/media/Committee-Opinions/Committee-on-Obstetric-Practice/co650.pdf?dmc=1&ts=20191118T2204318485 | https://www.nhlbi.nih.gov/health-topics/dash-eating-plan; https://www.webcitation.org/6QR3k6uaM; https://www.ncbi.nlm.nih.gov/pmc/articles/PMC6352352/bin/12884_2019_2196_MOESM1_ESM.docx | https://www.ncbi.nlm.nih.gov/pmc/articles/PMC6650045/bin/pmed.1002857.s005.docx; https://www.ncbi.nlm.nih.gov/pmc/articles/PMC6650045/bin/pmed.1002857.s006.docx; https://www.ncbi.nlm.nih.gov/pmc/articles/PMC6650045/bin/pmed.1002857.s007.docx | https://oldwayspt.org/traditional-diets/mediterranean-diet; http://resources.nationalacademies.org/Pregnancy/WhatToGain.html
Evidence of effect modification | Evidence that providing these specific counseling or active interventions was more effective than usual care in limiting excess gestational weight gain, particularly among women with overweight or obesity; and in reducing rates of gestational diabetes mellitus and risk of emergency cesarean delivery. Evidence of association between mean gestational weight gain and intervention intensity. No association with BMI group, weight assessment timepoint, type of intervention, or study quality. Evidence of association with BMI subgroup for perineal trauma; intervention intensity and gestational hypertension, perineal trauma, macrosomia, exceeding GWG recommendations, and SGA; and intervention type and gestational hypertension and exceeding GWG recommendations. Evidence of association with weight assessment at 12 months postpartum and postpartum weight retention.
Comparison group | Minimal weight loss intervention or usual care consisting of generic print or web-based materials focused on healthy lifestyle during pregnancy, diet and physical activity changes, or limiting excess gestational weight gain.
Interventionist and training required | Midwives, health educators, physical therapists, fitness specialists, or clinical and registered dieticians. Interventionists had professional certification in their respective fields, education regarding study goals and processes, and/or training on standard study curricula.
Reported intervention adherence | 9.7% to 100% of intervention participants completed the full intervention in studies reporting adherence.

Note: Low intensity = 0-2 contacts during intervention; Moderate intensity = 3-11 contacts during intervention; High intensity = 12 or more contacts during intervention.

* Examples selected from good- or fair-quality‡ RCTs with low risk of bias, statistically significant effect on outcomes in meta-analysis (mean or excess GWG, reducing rates of GDM), n>100, transparent access to intervention details (e.g., public website or protocol paper). See Appendix B for intervention details and practice materials (where applicable).

† Included of studies is for example purposes only and does not indicate endorsement by the USPSTF.

‡ As assessed using criteria developed by the USPSTF to rate the quality of each study as good, fair, or poor.

§ Materials and Practice sources were identified by examining published studies and public resources.