# Appendix D Supplementary Figures

Appendix D Figure 1 Meta-Analysis of Trials: Mean Gestational Weight Gain by Intervention Intensity

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; N = number; NR = not reported; SD = standard deviation.

Appendix D Figure 1 is a forest plot examining association of mean gestational weight gain with interventions to limit gestational weight gain by intervention intensity. In low intensity studies, the adjusted mean difference is -0.64 (95% confidence interval -1.44 to 0.02) with an I-squared value of 48.4%. In moderate intensity studies, the adjusted mean difference is -0.32 (95% confidence interval -0.71 to -0.04) with an I-squared value of 17.6%. In high intensity studies, the adjusted mean difference is -1.47 (95% confidence interval -1.78 to -1.22) with an I-squared value of 13.0%.

Appendix D Figure 2 Meta-Analysis of Trials: Mean Gestational Weight Gain by BMI Category

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; N = number; NR = not reported; SD = standard deviation.

Appendix D Figure 2 is a forest plot examining association of mean gestational weight gain with interventions to limit gestational weight gain by BMI category. In the obese subcategory, the adjusted mean difference is -1.63 (95% confidence interval -2.45 to -0.91) with an I-squared value of 63%. In the overweight subcategory, the adjusted mean difference is -0.89 (95% confidence interval -1.54 to -0.32) with an I-squared value of 15.5%. In the overweight and obese combined subcategory, the adjusted mean difference is -0.90 (95% confidence interval -1.38 to -0.46) with an I-squared value of 31.1%. In the mixed population subcategory, the adjusted mean difference is -0.81 (95% confidence interval -1.16 to -0.46) with an I-squared value of 60.7%.

Appendix D Figure 3 Meta-Analysis of Trials: Mean Gestational Weight Gain by Intervention Type

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; N = number; NR = not reported; SD = standard deviation.

Appendix D Figure 3 is a forest plot examining association of mean gestational weight gain with interventions to limit gestational weight gain by intervention type. For active interventions, the adjusted mean difference is -1.29 (95% confidence interval -1.60 to -1.04) with an I-squared value of 2.2%. For counseling interventions, the adjusted mean difference is -0.86 (95% confidence interval -1.27 to -0.50) with an I-squared value of 66%.

Appendix D Figure 4 Meta-Analysis of Trials: Mean Gestational Weight Gain by Intervention Quality

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; N = number; NR = not reported; SD = standard deviation.

Appendix D Figure 4 is a forest plot examining association of mean gestational weight gain with interventions to limit gestational weight gain by intervention quality. In good quality studies, the adjusted mean difference is -0.82 (95% confidence interval -1.42 to -0.31) with an I-squared value of 73.3%. In fair quality studies, the adjusted mean difference is -1.11 (95% confidence interval -1.42 to -0.81) with an I-squared value of 45.7%.

Appendix D Figure 5 Meta-Analysis of Trials: Mean Gestational Weight Gain by Outcome Assessment Timepoint

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; N = number; NA= not applicable; NR = not reported; SD = standard deviation.

Appendix D Figure 5 is a forest plot examining association of mean gestational weight gain with interventions to limit gestational weight gain by weight assessment timepoint. At 28 weeks, the adjusted mean difference is -0.80 (95% confidence interval -1.62 to 0.03), and I-squared value could not be calculated. At 34 to 36 weeks, the adjusted mean difference is -1.16 (95% confidence interval -2.13 to -0.29) with an I-squared value of 66.9%. At 36 weeks to delivery, the adjusted mean difference is -0.89 (95% confidence interval -1.24 to -0.58) with an I-squared value of 59.9%. At delivery, the adjusted mean difference is -1.22 (95% confidence interval -1.83 to -0.69) with an I-squared value of 17.5%. At postpartum 2 weeks, the adjusted mean difference is -3.40 (95% confidence interval -5.03 to -1.77), and the I-squared value could not be calculated. When the timepoint is not reported, the adjusted mean difference is 0.09 (95% confidence interval -0.79 to 0.97), and the I-squared value could not be calculated.

Appendix D Figure 6 Meta-Analysis of Trials: Mean Postpartum Weight Retention by BMI – Less Than 6 Months

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; NA = not applicable.

Appendix D Figure 6 is a forest plot examining association of mean postpartum weight retention with interventions to limit gestational weight gain, measured at less than 6 months and stratified by BMI. In the mixed population subcategory, the adjusted mean difference is -0.35 (95% confidence interval -1.06 to 0.35) with an I-squared value of 0%. In the obese subcategory, the adjusted mean difference is -2.30 (95% confidence interval -7.35 to 2.49) with an I-squared value of 88.5%. In the overweight subcategory, the adjusted mean difference is -1.85 (95% confidence interval -3.65 to -0.05), and the I-squared value could not be calculated. In the overweight and obese combined subcategory, the adjusted mean difference is 0.32 (95% confidence interval -1.97 to 3.34) with an I-squared value of 83.3%.

Appendix D Figure 7 Meta-Analysis of Trials: Mean Postpartum Weight Retention by BMI – 6 Months

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate; NA = not applicable.

Appendix D Figure 7 is a forest plot examining association of mean postpartum weight retention with interventions to limit gestational weight gain, measured at 6 months and stratified by BMI. In the mixed population subcategory, the adjusted mean difference is -0.91 (95% confidence interval -1.97 to 0.15), and the I-squared value could not be calculated. In the obese subcategory, the adjusted mean difference is 0.10 (95% confidence interval -1.12 to 1.32), and the I-squared value could not be calculated. In the overweight and obese combined subcategory, the adjusted mean difference is -1.88 (95% confidence interval -6.27 to 1.79) with an I-squared value of 74.1%.

Appendix D Figure 8 Meta-Analysis of Trials: Mean Postpartum Weight Retention by BMI – 12 Months

Abbreviations: CI = confidence interval; I-squared = test for heterogeneity using profile-likelihood estimate.

Appendix D Figure 8 is a forest plot examining association of mean postpartum weight retention with interventions to limit gestational weight gain, measured at 12 months and stratified by BMI. In the mixed population subcategory, the adjusted mean difference is -0.69 (95% confidence interval -1.39 to 0.11) with an I-squared value of 40.5%. In the obese subcategory, the adjusted mean difference is -0.12 (95% confidence interval -2.35 to 1.98) with an I-squared value of 0%. In the overweight and obese combined subcategory, the adjusted mean difference is -1.38 (95% confidence interval -4.26 to 0.88) with an I-squared value of 82.2%.