# Appendix C Quality Tables

Appendix C Table 1 Quality Assessment of Randomized, Controlled Trials

Author, Year Study Name | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Attrition and withdrawals reported? | Important loss to followup? | Analyze people in the groups in which they were randomized? | Funding source reported? | Quality Rating
Aguilar-Cordero et al., 2019^71^; SWEP | Yes | Yes | Yes | Yes | Unclear | No | No | Yes | No | Yes | Yes | Fair
Al Wattar et al., 2019^72^; ESTEEM | Yes | Yes | Yes | Yes | Yes | No | No | Yes | No | No | Yes | Fair
Altazan et al., 2019^73^; Expecting Success / SmartMoms | Unclear | Yes | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Fair
Althuizen et al., 2013^74^; New Life (style) | Yes | Unclear | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Good
Asbee et al., 2009^75^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Fair
Assaf-Balut et al., 2017^76^ | Yes | Yes | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Good
Bacchi et al., 2018^77^ | Yes | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes | Yes | Fair
Barakat et al., 2012^78^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Fair
Barakat et al., 2014^81^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Fair
Barakat et al., 2016^80^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Fair
Barakat et al., 2018^79^ | Yes | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes | No | Fair
Barakat et al., 2019^82^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | No | Fair
Bogaerts et al., 2013^83^ | Yes | Unclear | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Fair
Brownfoot et al., 2016^84^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Fair
Bruno et al., 2017^85^ | Yes | Yes | Unclear | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Fair
Cahill et al., 2018^86^; PreGO | Yes | Yes | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Good
Haire-Joshu et al., 2019^103^ | Yes | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes | Yes | Fair
Daley et al., 2015^88^ | Yes | Yes | No | Yes | No | No | No | Yes | No | Yes | Yes | Fair
Daley et al., 2019^89^; POPS2 | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Fair
Daly et al., 2017^90^; Healthy eating, Exercise and Lifestyle Trial | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Fair
Dodd et al., 2014^56^; LIMIT | Yes | Yes | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Good
Dodd et al., 2018^91^ | Yes | Yes | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Good
Dodd et al., 2019^92^; OPTIMISE | Yes | Unclear | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Good
Gallagher et al., 2018^94^; LIFT | Unclear | Unclear | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Fair
Garnaes et al., 2016^97^; ETIP | Yes | Yes | Yes | Yes | Unclear | No | No | Yes | No | Yes | Yes | Fair
Garnaes et al., 2017^98^ | Yes | Yes | Yes | Yes | Unclear | No | No | Yes | No | Yes | Yes | Fair
Garnaes et al., 2018^96^ | Yes | Yes | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Good
Garnaes et al., 2019^95^ | Yes | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Fair
Gesell et al., 2015^99^; Madre Sana, Bebé Sano / Healthy Mother, Healthy Baby | Yes | Yes | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Fair
Guelfi et al., 2016^101^ | Yes | Yes | Yes | Yes | Unclear | No | No | Yes | No | Yes | Yes | Fair
Haakstad et al., 2011^102^ | Yes | Yes | Yes | Yes | Unclear | No | No | Yes | Yes | Yes | No | Fair
Harrison et al., 2013^104^; HeLP-her | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Yes | Yes | Good
Harrison et al., 2014^105^ | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Yes | Yes | Good
Hawkins et al., 2014^106^; Estudio Vida | Yes | Unclear | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Fair
Herring et al., 2016^108^ | Yes | Yes | Yes | Yes | Unclear | No | No | Yes | No | Yes | Yes | Fair
Herring et al., 2017^107^ | Yes | Yes | Yes | Yes | Unclear | No | No | Yes | No | Yes | Yes | Fair
Hui et al., 2012^110^ | Yes | Unclear | Yes | Yes | No | No | No | Yes | Yes | No | Yes | Fair
Hui et al., 2014^111^ | Yes | Unclear | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Fair
Koivusalo et al., 2016^114^; RADIEL | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Fair
Huvinen et al., 2018^112^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Fair
Rono et al., 2018a^137^ | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes | Fair
Rono et al., 2018b^136^ | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | No | Yes | Yes | Fair
Kunath et al., 2019^115^; GeliS | Yes | Yes | Yes | Yes | Unclear | No | No | Yes | No | Yes | Yes | Fair
Hoffman et al., 2019^109^ | Yes | Yes | Yes | Yes | Unclear | No | No | Yes | No | Yes | Yes | Fair
LeBlanc et al., 2020^116^; PREPARE | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | No | Yes | Yes | Good
Luoto et al., 2011^117^; NELLI | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Good
Kinnunen et al., 2012^113^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Good
Magriples et al., 2015^118^; Centering Pregnancy Plus | Yes | Yes | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes | Fair
McCarthy et al., 2016^119^; FFF | Yes | Yes | Yes | Yes | Unclear | No | No | Yes | No | Unclear | Yes | Fair
Okesene-Gafa et al., 2019^121^; HUMBA | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Good
Olson et al., 2018^122^; e-Moms | Yes | Unclear | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Fair
Peccei et al., 2017^123^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Fair
Pelaez et al., 2019^124^ | Yes | Unclear | Yes | Yes | No | No | No | Yes | Yes | No | Yes | Fair
Perales et al., 2015^125^ | Yes | Yes | Yes | Yes | No | Unclear | Unclear | Yes | No | Yes | Yes | Good
Petrella et al., 2014^126^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | No | Fair
Phelan et al., 2011^128^; Fit For Delivery | Yes | Yes | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Fair
Phelan et al., 2014^127^ | Yes | Yes | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Fair
Phelan et al., 2018^130^; Healthy Beginnings / Comienzo Saludables | Yes | Unclear | Yes | Yes | Yes | No | No | Yes | No | No | Yes | Fair
Phelan et al., 2019^129^ | Yes | No | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Fair
Polley et al., 2002^131^ | Unclear | Unclear | Yes | Yes | Unclear | No | No | Yes | No | Yes | Yes | Fair
Rauh et al., 2013^132^; FeLIPO | Yes | Yes | No | Yes | No | No | No | Yes | No | Unclear | Yes | Fair
Rauh et al., 2015^133^ | Yes | Yes | No | Yes | No | No | No | Yes | No | Unclear | Yes | Fair
Redman et al., 2017^134^; SmartMoms | Yes | No | Yes | Yes | No | No | No | No | NR | Yes | Yes | Fair
Renault et al., 2014^58^; TOP | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Good
Ronnberg et al., 2014^135^ | Yes | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes | Yes | Fair
Ruiz et al., 2013^138^ | Yes | Unclear | Yes | Yes | Unclear | No | No | Yes | Yes | Yes | Yes | Fair
Sagedal et al., 2017^139^; Norwegian Fit For Delivery | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | No | Yes | Yes | Good
Sagedal et al., 2017b^140^ | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | No | Yes | Yes | Good
Seneviratne et al., 2016^141^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes | Yes | Good
Simmons et al., 2017^142^; DALI Lifestyle | Yes | Yes | Yes | Yes | Yes | Unclear | No | Yes | No | Yes | Yes | Good
Skouteris et al., 2016^143^; HIPP | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Fair
Smith et al., 2016^144^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | No | Yes | Fair
Thomson et al., 2016^148^; Delta Healthy Sprouts | Yes | Unclear | Yes | Yes | Unclear | No | No | Yes | No | Yes | Yes | Fair
Thomson et al., 2018^147^ | Yes | Unclear | Yes | Yes | No | Unclear | No | Yes | Yes | Yes | Yes | Fair
Van Horn et al., 2018^149^; MOMFIT | Yes | Yes | No | Yes | Yes | No | Unclear | Yes | No | Yes | Yes | Fair
Vesco et al., 2014^150^; Healthy Moms | Yes | Yes | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Good
Vesco et al., 2016^151^ | Yes | Yes | Yes | Yes | Yes | No | No | Yes | No | Yes | Yes | Good
Vinter et al., 2011^59^; LiP | Yes | Yes | Yes | Yes | No | No | No | Yes | No | No | Yes | Fair
Vinter et al., 2014^152^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | No | Yes | Fair
Tanvig et al., 2014^146^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | No | Yes | Fair
Tanvig et al., 2015^145^ | Yes | Yes | Yes | Yes | No | No | No | Yes | No | No | Yes | Fair
Willcox et al., 2017^153^; txt4two | Yes | Yes | Unclear | Yes | Unclear | No | No | Yes | No | Yes | Yes | Fair
Wolff et al., 2008^154^ | Unclear | Unclear | Yes | Yes | Unclear | Yes | No | Yes | Yes | Yes | Yes | Fair

Appendix C Table 2 Quality Assessment of Controlled Clinical Trials

Author, Year Study Name | Random or consecutive patient enrollment? | Groups comparable at baseline? | Accurate methods to find potential confounders and outcomes? | Outcome assessors and/or data analysts blinded? | Reporting of attrition? | Appropriate statistical analyses on potential confounders? | Important loss to followup? | Outcomes pre-specified and defined? | Funding source reported? | Quality Rating
Claesson et al., 2010^83^ | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Fair
Epel et al., 2019^89^; MMT | Yes | Yes | Yes | Unclear | Yes | Yes | No | Yes | Yes | Good
Gray-Donald et al. 2000^96^ | Yes | Yes | Yes | Unclear | Unclear | Yes | Unclear | Yes | Yes | Fair
McGiveron et al., 2015^115^; Bumps and Beyond | Yes | No | Yes | Unclear | Yes | Yes | No | Yes | Yes | Fair