# Appendix B Evidence Tables

Appendix B Table 1 Included Studies – Study Characteristics

Appendix B Table 2 Included Studies – Intervention Characteristics

Appendix B Table 3 Included Studies – Outcomes and Harms