# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Ovid MEDLINE® Database Searches

Search Strategy:

1. Pregnant Women/
2. exp Pregnancy/
3. perinatal care/ or prenatal care/
4. (pregnan* or maternal or gestation* or perinatal or prenatal or antenatal or postpartum).ti,ab.
5. or/1-4
6. PRECONCEPTION CARE/
7. (prepregnan* or preconception* or “pre-pregnan*” or “pre-conception”).ti,ab.
8. 6 or 7
9. Pregnancy Outcome/
10. exp Pregnancy Complications/
11. 9 or 10
12. 5 or 8 or 11
13. body weight/ or exp body weight changes/ or exp overweight/
14. body mass index/
15. (weight or overweight or obes* or BMI).ti,ab.
16. 12 and (13 or 14 or 15)
17. exp Life Style/
18. exp Diet Therapy/
19. exp Exercise/
20. exp Physical Fitness/
21. counseling/ or exp directive counseling/
22. exp Behavior Therapy/
23. exp Motivation/
24. health behavior/ or risk reduction behavior/
25. exp Patient Education as Topic/
26. exp social support/
27. health education/ or exp health promotion/
28. (diet or exercise or lifestyle or “life style” or advice or advise or behavior* or behaviour* or nonpharma* or “non-pharma*”).ti,ab.
29. or/17-28
30. 16 and 29
31. limit 30 to (english language and humans)
32. limit 31 to (clinical trial, all or comparative study or controlled clinical trial or randomized controlled trial)
33. 31 and (random* or control* or cohort or trial).ti,ab,kw.
34. 32 or 33

### Ovid MEDLINE® In-Process & Other Non-Indexed Citations

Search Strategy:

1. (pregnan* or maternal or gestation* or perinatal or prenatal or antenatal or postpartum).ti,ab.
2. (prepregnan* or preconception* or “pre-pregnan*” or “pre-conception”).ti,ab.
3. (weight or overweight or obes* or BMI).ti,ab.
4. (diet or exercise or lifestyle or “life style” or counsel* or advice or advise or behavior* or behaviour* or nonpharma* or “non-pharma*”).ti,ab.
5. (1 or 2) and 3 and 4
6. 5 and (random* or control* or trial or cohort).ti,ab,kw.

### EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

1. Pregnant Women/
2. exp Pregnancy/
3. perinatal care/ or prenatal care/
4. (pregnan* or maternal or gestation* or perinatal or prenatal or antenatal or postpartum).ti,ab.
5. or/1-4
6. PRECONCEPTION CARE/
7. (prepregnan* or preconception* or “pre-pregnan*” or “pre-conception”).ti,ab.
8. 6 or 7
9. Pregnancy Outcome/
10. exp Pregnancy Complications/
11. 9 or 10
12. 5 or 8 or 11
13. body weight/ or exp body weight changes/ or exp overweight/
14. body mass index/
15. (weight or overweight or obes* or BMI).ti,ab.
16. 12 and (13 or 14 or 15)
17. exp Life Style/
18. exp Diet Therapy/
19. exp Exercise/
20. exp Physical Fitness/
21. counseling/ or exp directive counseling/
22. exp Behavior Therapy/
23. exp Motivation/
24. health behavior/ or risk reduction behavior/
25. exp Patient Education as Topic/
26. exp social support/
27. health education/ or exp health promotion/
28. (diet or exercise or lifestyle or “life style” or advice or advise or behavior* or behaviour* or nonpharma* or “non-pharma*”).ti,ab.
29. or/17-28
30. 16 and 29
31. limit 30 to english language

### EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

1. pregnan*,ti,ab.mp. [mp=title, short title, abstract, full text, keywords, caption text]
2. (pregnant or pregnancy or gestation*).ti,ab.
3. 2 and (weight or Overweight and obese or obesity).ti,ab.
4. 3 and (diet or exercise or counsel* or advise or advise or behavior* of behaviour* or nonpharm* or “non-pharma*”).ti,ab.

### PsycINFO

Search Strategy:

1. exp Pregnancy/
2. perinatal care/ or prenatal care/
3. (pregnan* or maternal or gestation* or perinatal or prenatal or antenatal or postpartum).ti,ab.
4. (prepregnan* or preconception* or “pre-pregnan*” or “pre-conception”).ti,ab.
5. Pregnancy Outcome/
6. body weight/ or exp body weight changes/ or exp overweight/
7. body mass index/
8. (weight or overweight or obes* or BMI).ti,ab.
9. exp Exercise/
10. exp Physical Fitness/
11. counseling/ or exp directive counseling/
12. exp Behavior Therapy/
13. exp Motivation/
14. health behavior/ or risk reduction behavior/
15. exp social support/
16. health education/ or exp health promotion/
17. (diet or exercise or lifestyle or “life style” or counsel* or advice or advise or behavior* or behaviour* or nonpharma* or “non-pharma*”).ti,ab.
18. (or/1-5) and (or/6-8)
19. 18 and (or/9-17)
20. 19 and (random* or control* or trial or cohort).ti,ab.

## Appendix A2 Included and Excluded Criteria

| Included | Excluded
Population | - Pregnant women with normal or high BMI; - Women who are overweight and obese (defined by BMI) and planning pregnancy, including adolescents and adults | - Studies limited to pregnant women with gestational diabetes mellitus; - Women with preexisting diabetes
Intervention | - Primary care–relevant interventions that aim to limit excess gestational weight gain or reduce prepregnancy weight, and focus on one or more of the following: diet, exercise, behavioral counseling; - Conducted in or recruited from primary care or health care system, or could feasibly be implemented in or referred from primary care | - Pharmacologic interventions; - Broader community-based programs (e.g., mass media, changes to community-built environment)
Outcome | KQ1 – health outcomes:; - Maternal or infant mortality (incl. stillbirth); - Maternal morbidity (e.g., postpartum hemorrhage, perineal trauma, depression); - Infant morbidity (e.g., birth trauma, shoulder dystocia, respiratory distress syndrome); KQ2 – weight outcomes:; - Preconception weight loss (kg or BMI); - Excessive gestational weight gain (per IOM recommendation or as described by authors); - Measured gestational weight gain (kg or BMI); - Maternal postpartum weight loss or retention; - Incidence or prevalence of maternal obesity-related perinatal conditions (e.g., macrosomia, preterm birth, gestational diabetes mellitus, hypertension, cesarean delivery); KQ3 – harms; - Harms associated with interventions (e.g., anxiety, stigma, maternal musculoskeletal injuries); - Harms related to insufficient weight gain (e.g., ‘small for gestational age’ infants) | KQ1; - Behavioral changes (e.g., physical activity level); KQ2; - Cardiometabolic measures (e.g., glucose level, blood pressure, lipid level)
Comparator | - Interventions with a comparator or control group; for example:; ○ No treatment (wait-list, usual care); ○ Attention control; ○ Minimal intervention | Interventions without a control / comparator group
Study Design | KQ1-KQ3; - Controlled clinical trial; KQ3; - Cohort or case-control studies reporting harms related to interventions to reduce gestational weight gain and prepregnancy weight | All other study designs
Study Quality | Fair- or good-quality studies | Poor-quality studies
Country | Countries considered ‘very high’ on the 2016 Human Development Index | Countries not rated ‘very high’

### Notes on Included/Excluded criteria

[underlined: Mode of delivery]: Interventions may be delivered via face-to-face contact, telephone, print materials, or technology (e.g., computer-based, text messages) and can be delivered by numerous potential providers (e.g., clinicians, nurses, exercise specialists, dietitians, nutritionists, behavioral health specialists, etc.)

### Countries rated ‘very high’ on the 2016 HDI

- Australia
- Andorra
- Argentina
- Austria
- Bahrain
- Belgium
- Brunei
- Canada
- Chile
- Croatia
- Cyprus
- Czech Republic
- Denmark
- Estonia
- Finland
- France
- Germany
- Greece
- Hong Kong
- Hungary
- Iceland
- Ireland
- Israel
- Italy
- Japan
- South Korea
- Kuwait
- Latvia
- Liechtenstein
- Lithuania
- Luxembourg
- Malta
- Montenegro
- Netherlands
- New Zealand
- Norway
- Poland
- Portugal
- Qatar
- Romania
- Russia
- Saudi Arabia
- Singapore
- Slovakia
- Slovenia
- Spain
- Sweden
- Switzerland
- U.K.
- U.S.
- U.A.E.

## Appendix A3 Literature Flow Diagram

*Some included publications are counted in multiple sections.

Note: Targeted searches for the contextual questions are not included in the current diagram.

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the review. The diagram shows that 8,511 citations were identified through literature database searches and other sources (including lists of relevant articles and systematic reviews, reviewer suggestions, etc.). 845 articles were reviewed at the full-text level after excluding 7,666 citations based on review of title and abstract. From the 845 articles reviewed for inclusion, 578 were excluded. Articles were excluded due to ineligible population (36); incorrect intervention (62); wrong outcome(s) (96); incorrect comparison (14); wrong publication type (161); wrong study design for KQ (109); non-English language (1); study conducted in country not on the ‘very high’ HDI list (17); companion paper with outdated data (13); systematic review or meta-analysis used as source document (55); sample size <50 (6); and poor quality (8). 68 studies in 87 publications were included that provide evidence for the key questions, organized as follows: maternal health outcomes (57); prepregnancy weight reduction (1); infant health outcomes (50); gestational weight gain outcomes (68); and harms (42). The number of included studies does not sum to the total listed because some trials are included in multiple key questions or subcategories.

## Appendix A4 List of Included Studies

1 Aguilar-Cordero MJ, Sanchez-Garcia JC, Rodriguez-Blanque R, . Moderate physical activity in an aquatic environment during pregnancy (SWEP Study) and its influence in preventing postpartum depression. J Am Psychiatr Nurses Assoc. 2019 Apr;25(2):112–21. doi: 10.1177/1078390317753675. PMID: 29490560.29490560
2 Al Wattar BH, Dodds J, Placzek A, . Mediterranean-style diet in pregnant women with metabolic risk factors (ESTEEM): a pragmatic multicentre randomised trial. PLOS Medicine. 2019 Jul 23;16(7):e1002857. doi: 10.1371/journal.pmed.1002857. PMID: 3133587131335871
3 Altazan AD, Redman LM, Burton JH, . Mood and quality of life changes in pregnancy and postpartum and the effect of a behavioral intervention targeting excess gestational weight gain in women with overweight and obesity: a parallel-arm randomized controlled pilot trial. BMC Pregnancy Childbirth. 2019 Jan 29;19(1):50. doi: 10.1186/s12884-019-2196-8. PMID: 30696408.30696408
4 Althuizen E, van der Wijden CL, van Mechelen W, . The effect of a counselling intervention on weight changes during and after pregnancy: a randomised trial. BJOG. 2013 Jan;120(1):92–9. doi: 10.1111/1471-0528.12014. PMID: 23121074.23121074
5 Asbee SM, Jenkins TR, Butler JR, . Preventing excessive weight gain during pregnancy through dietary and lifestyle counseling: a randomized controlled trial. Obstet Gynecol. 2009 Feb;113(2 Pt 1):305–12. doi: 10.1097/AOG.0b013e318195baef. PMID: 19155899.19155899
6 Assaf-Balut C, Garcia de la Torre N, Duran A, . A Mediterranean diet with additional extra virgin olive oil and pistachios reduces the incidence of gestational diabetes mellitus (GDM): a randomized controlled trial: the St. Carlos GDM prevention study. PLoS ONE. 2017 Oct 19;12(10):e0185873. doi: 10.1371/journal.pone.0185873. PMID: 29049303.29049303
7 Bacchi M, Mottola MF, Perales M, . Aquatic activities during pregnancy prevent excessive maternal weight gain and preserve birth weight: a randomized clinical trial. Am J Health Promot. 2018 Mar;32(3):729–35. doi: 10.1177/0890117117697520. PMID: 28279085.28279085
8 Barakat R, Cordero Y, Coteron J, . Exercise during pregnancy improves maternal glucose screen at 24-28 weeks: a randomised controlled trial. Br J Sports Med. 2012 Jul;46(9):656–61. doi: 10.1136/bjsports-2011-090009. PMID: 21948120.21948120
9 Barakat R, Franco E, Perales M, . Exercise during pregnancy is associated with a shorter duration of labor. A randomized clinical trial. Eur J Obstet Gynecol Reprod Biol. 2018 May;224:33–40. doi: 10.1016/j.ejogrb.2018.03.009. PMID: 29529475.29529475
10 Barakat R, Pelaez M, Cordero Y, . Exercise during pregnancy protects against hypertension and macrosomia: randomized clinical trial. Am J Obstet Gynecol. 2016 May;214(5):649.e1–8. doi: 10.1016/j.ajog.2015.11.039. PMID: 26704894.26704894
11 Barakat R, Perales M, Bacchi M, . A program of exercise throughout pregnancy. Is it safe to mother and newborn? Am J Health Promot. 2014 Sep–Oct;29(1):2–8. doi: 10.4278/ajhp.130131-QUAN-56. PMID: 24200335.24200335
12 Barakat R, Refoyo I, Coteron J, . Exercise during pregnancy has a preventative effect on excessive maternal weight gain and gestational diabetes. A randomized controlled trial. Braz J Phys Ther. 2019 Apr;23(2):148–55. doi: 10.1016/j.bjpt.2018.11.005. PMID: 30470666.30470666
13 Bogaerts AF, Devlieger R, Nuyts E, . Effects of lifestyle intervention in obese pregnant women on gestational weight gain and mental health: a randomized controlled trial. Int J Obes (Lond). 2013 Jun;37(6):814–21. doi: 10.1038/ijo.2012.162. PMID: 23032404.23032404
14 Brownfoot FC, Davey MA, Kornman L. Routine weighing to reduce excessive antenatal weight gain: a randomised controlled trial. BJOG. 2016 Dec;123(2):254–61. doi: 10.1111/1471-0528.13735. PMID: 26840637.26840637
15 Bruno R, Petrella E, Bertarini V, . Adherence to a lifestyle programme in overweight/obese pregnant women and effect on gestational diabetes mellitus: a randomized controlled trial. Matern Child Nutr. 2017 Jul;13(3) doi: 10.1111/mcn.12333. PMID: 27647837.27647837
16 Cahill AG, Haire-Joshu D, Cade WT, . Weight control program and gestational weight gain in disadvantaged women with overweight or obesity: a randomized clinical trial. Obesity (Silver Spring). 2018 Mar;26(3):485–91. doi: 10.1002/oby.22070. PMID: 29464907.29464907
17 Claesson IM, Josefsson A, Sydsjo G. Prevalence of anxiety and depressive symptoms among obese pregnant and postpartum women: an intervention study. BMC Public Health. 2010 Dec 16;10:766. doi: 10.1186/1471-2458-10-766. PMID: 21162715.21162715
18 Daley A, Jolly K, Jebb S, . Feasibility and acceptability of regular weighing, setting weight gain limits and providing feedback by community midwives to prevent excess weight gain during pregnancy: randomised controlled trial and qualitative study. BMC Obesity. 2015 Sep 16;2(1):35. doi: 10.1186/s40608-015-0061-5. PMID: 26401345.26401345
19 Daley A JKJSARAMLLACSUMOCKSMCAP. Effectiveness of a behavioural intervention involving regular weighing and feedback by community midwives within routine antenatal care to prevent excessive gestational weight gain: POPS2 randomised controlled trial. BMJ Open; 2019. p. e030174.
20 Daly N, Farren M, McKeating A, . A medically supervised pregnancy exercise intervention in obese women: a randomized controlled trial. Obstet Gynecol. 2017 Nov;130(5):1001–10. doi: 10.1097/AOG.0000000000002267. PMID: 29016485.29016485
21 Dodd JM, McPhee AJ, Deussen AR, . Effects of an antenatal dietary intervention in overweight and obese women on 6 month infant outcomes: follow-up from the LIMIT randomised trial. Int J Obes (Lond). 2018 Jul;42(7):1326–35. doi: 10.1038/s41366-018-0019-z. PMID: 29568100.29568100
22 Dodd JM, Turnbull D, McPhee AJ, . Antenatal lifestyle advice for women who are overweight or obese: LIMIT randomised trial. Br Med J. 2014 Feb 10;348:g1285. doi: 10.1136/bmj.g1285. PMID: 24513442.24513442
23 Dodd Jm DARLJ. A randomised trial to optimise gestational weight gain and improve maternal and infant health outcomes through antenatal dietary, lifestyle and exercise advice: the OPTIMISE randomised trial. Nutrients. 2019 Dec 02;11(12) doi: 10.3390/nu11122911. PMID: 31810217.31810217
24 Epel E, Laraia B, Coleman-Phox K, . Effects of a mindfulness-based intervention on distress, weight gain, and glucose control for pregnant low-income women: a quasi-experimental trial using the ORBIT model. Int J Behav Med. 2019 Apr 16;26(5):461–73. doi: 10.1007/s12529-019-09779-2. PMID: 30993601.30993601
25 Gallagher D, Rosenn B, Toro-Ramos T, . Greater neonatal fat-free mass and similar fat mass following a randomized trial to control excess gestational weight gain. Obesity (Silver Spring). 2018 Mar;26(3):578–87. doi: 10.1002/oby.22079. PMID: 29464905.29464905
26 Garnaes KK, Morkved S, Salvesen KA, . Exercise training during pregnancy reduces circulating insulin levels in overweight/obese women postpartum: secondary analysis of a randomised controlled trial (the ETIP trial). BMC Pregnancy Childbirth. 2018 Jan 08;18(1):18. doi: 10.1186/s12884-017-1653-5. PMID: 29310617.29310617
27 Garnaes KK, Morkved S, Salvesen O, . Exercise training and weight gain in obese pregnant women: a randomized controlled trial (ETIP trial). PLoS Med. 2016 Jul 26;13(7):e1002079. doi: 10.1371/journal.pmed.1002079. PMID: 27459375.27459375
28 Garnaes KK, Nyrnes SA, Salvesen KA, . Effect of supervised exercise training during pregnancy on neonatal and maternal outcomes among overweight and obese women. Secondary analyses of the ETIP trial: a randomised controlled trial. PLoS ONE. 2017 Mar 21;12(3):e0173937. doi: 10.1371/journal.pone.0173937. PMID: 28323893.28323893
29 Garnaes Kk HASSSNMSSKSOMT. Effects of supervised exercise training during pregnancy on psychological well-being among overweight and obese women: secondary analyses of the ETIP-trial, a randomised controlled trial. BMJ Open. 2019;9(11) doi: 10.1136/bmjopen-2018-028252. PMID: 31753866.31753866
30 Gesell SB, Katula JA, Strickland C, . Feasibility and initial efficacy evaluation of a community-based cognitive-behavioral lifestyle intervention to prevent excessive weight gain during pregnancy in Latina women. Matern Child Health J. 2015 Aug;19(8):1842–52. doi: 10.1007/s10995-015-1698-x. PMID: 25874878.25874878
31 Gray-Donald K, Robinson E, Collier A, . Intervening to reduce weight gain in pregnancy and gestational diabetes mellitus in Cree communities: an evaluation. CMAJ. 2000 Nov 14;163(10):1247–51. PMID: 11107459.11107459
32 Guelfi KJ, Ong MJ, Crisp NA, . Regular exercise to prevent the recurrence of gestational diabetes mellitus: a randomized controlled trial. 2016 Oct;128(4):819–27. doi: 10.1097/aog.0000000000001632. PMID: 2760787627607876
33 Haakstad LA, Bo K. Effect of regular exercise on prevention of excessive weight gain in pregnancy: a randomised controlled trial. Eur J Contracept Reprod Health Care. 2011 Apr;16(2):116–25. doi: 10.3109/13625187.2011.560307. PMID: 21417561.21417561
34 Haire-Joshu D, Cahill AG, Stein RI, . Randomized controlled trial of home-based lifestyle therapy on postpartum weight in underserved women with overweight or obesity. Obes. 2019 Apr;27(4):535–41. doi: 10.1002/oby.22413. PMID: 30900408.30900408
35 Harrison CL, Lombard CB, Strauss BJ, . Optimizing healthy gestational weight gain in women at high risk of gestational diabetes: a randomized controlled trial. Obesity (Silver Spring). 2013 May;21(5):904–9. doi: 10.1002/oby.20163. PMID: 23784892.23784892
36 Harrison CL, Lombard CB, Teede HJ. Limiting postpartum weight retention through early antenatal intervention: the HeLP-her randomised controlled trial. Int J Behav Nutr Phys Act. 2014 Oct 31;11(134) doi: 10.1186/s12966-014-0134-8. PMID: 25358909.25358909
37 Hawkins M, Hosker M, Marcus BH, . A pregnancy lifestyle intervention to prevent gestational diabetes risk factors in overweight Hispanic women: a feasibility randomized controlled trial. Diabet Med. 2014 Oct;32(1):108–15. doi: 10.1111/dme.12601. PMID: 25306925.25306925
38 Herring SJ, Cruice JF, Bennett GG, . Intervening during and after pregnancy to prevent weight retention among African American women. Prev Med Rep. 2017 Jun 1;7:119–23. doi: 10.1016/j.pmedr.2017.05.015. PMID: 28660118.28660118
39 Herring SJ, Cruice JF, Bennett GG, . Preventing excessive gestational weight gain among African American women: a randomized clinical trial. Obesity (Silver Spring). 2016 Jan;24(1):30–6. doi: 10.1002/oby.21240. PMID: 26592857.26592857
40 Hoffmann J, Gunther J, Stecher L, . Effects of a lifestyle intervention in routine care on short- and long-term maternal weight retention and breastfeeding behavior-12 months follow-up of the cluster-randomized GeliS trial. J Clin Med. 2019 Jun 19;8(6):19. doi: 10.3390/jcm8060876. PMID: 31248138.31248138
41 Hui A, Back L, Ludwig S, . Lifestyle intervention on diet and exercise reduced excessive gestational weight gain in pregnant women under a randomised controlled trial. BJOG. 2012 Jan;119(1):70–7. doi: 10.1111/j.1471-0528.2011.03184.x. PMID: 22017967.22017967
42 Hui AL, Back L, Ludwig S, . Effects of lifestyle intervention on dietary intake, physical activity level, and gestational weight gain in pregnant women with different pre-pregnancy body mass index in a randomized control trial. BMC Pregnancy Childbirth. 2014 Sep 24;14(331) doi: 10.1186/1471-2393-14-331. PMID: 25248797.25248797
43 Huvinen E, Koivusalo SB, Meinila J, . Effects of a lifestyle intervention during pregnancy and first postpartum year: findings from the RADIEL study. J Clin Endocrinol Metab. 2018 Apr 1;103(4):1669–77. doi: 10.1210/jc.2017-02477. PMID: 29409025.29409025
44 Kinnunen TI, Raitanen J, Aittasalo M, . Preventing excessive gestational weight gain--a secondary analysis of a cluster-randomised controlled trial. Eur J Clin Nutr. 2012 Dec;66(12):1344–50. doi: 10.1038/ejcn.2012.146. PMID: 23211656.23211656
45 Koivusalo SB, Rono K, Klemetti MM, . Gestational diabetes mellitus can be prevented by lifestyle intervention: the Finnish gestational diabetes prevention study (RADIEL): a randomized controlled trial.[Erratum appears in Diabetes Care. 2017 Jun 14;:; PMID: 28615238]. Diabetes Care. 2016 Jan;39(1):24–30. doi: 10.2337/dc15-0511. PMID: 26223239.26223239
46 Kunath J, Gunther J, Rauh K, . Effects of a lifestyle intervention during pregnancy to prevent excessive gestational weight gain in routine care - the cluster-randomised GeliS trial. BMC Med. 2019 Jan 14;17(5) doi: 10.1186/s12916-018-1235-z. PMID: 30636636.30636636
47 Leblanc ES, Smith NX, Vesco KK, . Weight loss prior to pregnancy and subsequent gestational weight gain: prepare, a randomized clinical trial. Am J Obstet Gynecol. 2020 Jul 17. doi: 10.1016/j.ajog.2020.07.027. PMID: 32687819.32687819
48 Luoto R, Kinnunen TI, Aittasalo M, . Primary prevention of gestational diabetes mellitus and large-for-gestational-age newborns by lifestyle counseling: a cluster-randomized controlled trial. PLoS Med. 2011 May;8(5):e1001036. doi: 10.1371/journal.pmed.1001036. PMID: 21610860.21610860
49 Magriples U, Boynton MH, Kershaw TS, . The impact of group prenatal care on pregnancy and postpartum weight trajectories. Am J Obstet Gynecol. 2015 Nov;213(5):688.e1–9. doi: 10.1016/j.ajog.2015.06.066. PMID: 26164694.26164694
50 McCarthy EA, Walker SP, Ugoni A, . Self-weighing and simple dietary advice for overweight and obese pregnant women to reduce obstetric complications without impact on quality of life: a randomised controlled trial. BJOG. 2016 May;123(6):965–73. doi: 10.1111/1471-0528.13919. PMID: 26875586.26875586
51 McGiveron A, Foster S, Pearce J, . Limiting antenatal weight gain improves maternal health outcomes in severely obese pregnant women: findings of a pragmatic evaluation of a midwife-led intervention. J Hum Nutr Diet. 2015 Jan;28: Suppl 1:29–37. doi: 10.1111/jhn.12240. PMID: 24809211.24809211
52 Okesene-Gafa KAM, Li M, McKinlay CJD, . Effect of antenatal dietary interventions in maternal obesity on pregnancy weight-gain and birthweight: Healthy Mums and Babies (HUMBA) randomized trial. Am J Obstet Gynecol. 2019 Mar 13:pii. doi: 10.1016/j.ajog.2019.03.003. PMID: 30878323.30878323
53 Olson CM, Groth SW, Graham ML, . The effectiveness of an online intervention in preventing excessive gestational weight gain: the e-moms roc randomized controlled trial. BMC Pregnancy Childbirth. 2018 May 9;18(148) doi: 10.1186/s12884-018-1767-4. PMID: 29743026.29743026
54 Peccei A, Blake-Lamb T, Rahilly D, . Intensive prenatal nutrition counseling in a community health setting: a randomized controlled trial. Obstet Gynecol. 2017 Aug;130(2):423–32. doi: 10.1097/AOG.0000000000002134. PMID: 28697099.28697099
55 Pelaez M, Gonzalez-Cerron S, Montejo R, . Protective effect of exercise in pregnant women including those who exceed weight gain recommendations: a randomized controlled trial. Mayo Clin Proc. 2019 Oct;94(10):1951–9. doi: 10.1016/j.mayocp.2019.01.050. PMID: 31585579.31585579
56 Perales M, Rodríguez YC, Terrones MV, . Exercise and depression in overweight and obese pregnant women: a randomised controlled trial. Archivos de medicina del deporte: revista de la Federación Española de Medicina del Deporte y de la Confederación Iberoamericana de Medicina del Deporte. 2015(167):156–63.
57 Petrella E, Malavolti M, Bertarini V, . Gestational weight gain in overweight and obese women enrolled in a healthy lifestyle and eating habits program. J Matern Fetal Neonatal Med. 2014 Sep;27(13):1348–52. doi: 10.3109/14767058.2013.858318. PMID: 24175912.24175912
58 Phelan S, Phipps MG, Abrams B, . Does behavioral intervention in pregnancy reduce postpartum weight retention? Twelve-month outcomes of the fit for delivery randomized trial. Am J Clin Nutr. 2014 Feb;99(2):302–11. doi: 10.3945/ajcn.113.070151. PMID: 24284438.24284438
59 Phelan S, Phipps MG, Abrams B, . Randomized trial of a behavioral intervention to prevent excessive gestational weight gain: the fit for delivery study. Am J Clin Nutr. 2011 Apr;93(4):772–9. doi: 10.3945/ajcn.110.005306. PMID: 21310836.21310836
60 Phelan S, Wing RR, Brannen A, . Does partial meal replacement during pregnancy reduce 12-month postpartum weight retention? Obes. 2019 Feb;27(2):226–36. doi: 10.1002/oby.22361. PMID: 30421864.30421864
61 Phelan S, Wing RR, Brannen A, . Randomized controlled clinical trial of behavioral lifestyle intervention with partial meal replacement to reduce excessive gestational weight gain. Am J Clin Nutr. 2018 Feb 1;107(2):183–94. doi: 10.1093/ajcn/nqx043. PMID: 29529157.29529157
62 Polley BA, Wing RR, Sims CJ. Randomized controlled trial to prevent excessive weight gain in pregnant women. Int J Obes Relat Metab Disord. 2002 Nov;26(11):1494–502. doi: 10.1038/sj.ijo.0802130. PMID: 12439652.12439652
63 Rauh K, Gabriel E, Kerschbaum E, . Safety and efficacy of a lifestyle intervention for pregnant women to prevent excessive maternal weight gain: a cluster-randomized controlled trial. BMC Pregnancy Childbirth. 2013 Jul 16;13(151) doi: 10.1186/1471-2393-13-151. PMID: 23865624.23865624
64 Rauh K, Gunther J, Kunath J, . Lifestyle intervention to prevent excessive maternal weight gain: mother and infant follow-up at 12 months postpartum. BMC Pregnancy Childbirth. 2015 Oct 15;15(265) doi: 10.1186/s12884-015-0701-2. PMID: 26472133.26472133
65 Redman LM, Gilmore LA, Breaux J, . Effectiveness of SmartMoms, a novel eHealth intervention for management of gestational weight gain: randomized controlled pilot trial. JMIR Mhealth Uhealth. 2017 Sep 13;5(9):e133. doi: 10.2196/mhealth.8228. PMID: 28903892.28903892
66 Renault KM, Norgaard K, Nilas L, . The Treatment of Obese Pregnant women (TOP) study: a randomized controlled trial of the effect of physical activity intervention assessed by pedometer with or without dietary intervention in obese pregnant women. Am J Obstet Gynecol. 2014 Feb;210(2):134.e1–9. doi: 10.1016/j.ajog.2013.09.029. PMID: 24060449.24060449
67 Ronnberg AK, Ostlund I, Fadl H, . Intervention during pregnancy to reduce excessive gestational weight gain-a randomised controlled trial. BJOG. 2014 Nov;122(4):537–44. doi: 10.1111/1471-0528.13131. PMID: 25367823.25367823
68 Rönö K, Grotenfelt NE, Klemetti M, . Effect of a lifestyle intervention during pregnancy-findings from the Finnish gestational diabetes prevention trial (RADIEL). J Perinatol. 2018b Sep;38(9):1157–64. doi: 10.1038/s41372-018-0178-8 PMID: 3004247130042471
69 Rönö K, Stach-Lempinen B, Eriksson JG, . Prevention of gestational diabetes with a prepregnancy lifestyle intervention - findings from a randomized controlled trial. Int J Women Health. 2018a Aug 27;10:493–501. doi: 10.2147/IJWH.S162061. PMID: 30214318.30214318
70 Ruiz JR, Perales M, Pelaez M, . Supervised exercise-based intervention to prevent excessive gestational weight gain: a randomized controlled trial. Mayo Clin Proc. 2013 Dec;88(12):1388–97. doi: 10.1016/j.mayocp.2013.07.020. PMID: 24290112.24290112
71 Sagedal LR, Overby NC, Bere E, . Lifestyle intervention to limit gestational weight gain: the Norwegian fit for delivery randomised controlled trial. BJOG. 2017 Jan;124(1):97–109. doi: 10.1111/1471-0528.13862. PMID: 26768233.26768233
72 Sagedal LR, Sanda B, Overby NC, . The effect of prenatal lifestyle intervention on weight retention 12 months postpartum: results of the Norwegian fit for delivery randomised controlled trial. BJOG. 2017b Jan;124(1):111–21. doi: 10.1111/1471-0528.13863. PMID: 26786294.26786294
73 Seneviratne SN, Jiang Y, Derraik J, . Effects of antenatal exercise in overweight and obese pregnant women on maternal and perinatal outcomes: a randomised controlled trial. BJOG. 2016 Mar;123(4):588–97. doi: 10.1111/1471-0528.13738. PMID: 26542419.26542419
74 Simmons D, Devlieger R, van Assche A, . Effect of physical activity and/or healthy eating on GDM risk: the DALI lifestyle study. J Clin Endocrinol Metab. 2017 Mar 1;102(3):903–13. doi: 10.1210/jc.2016-3455. PMID: 27935767.27935767
75 Skouteris H, McPhie S, Hill B, . Health coaching to prevent excessive gestational weight gain: a randomized-controlled trial. Br J Health Psychol. 2016 Feb;21(1):31–51. doi: 10.1111/bjhp.12154. PMID: 26227112.26227112
76 Smith K, Lanningham-Foster L, Welch A, . Web-based behavioral intervention increases maternal exercise but does not prevent excessive gestational weight gain in previously sedentary women. J Phys Act Health. 2016 Jun;13(6):587–93. doi: 10.1123/jpah.2015-0219. PMID: 26594820.26594820
77 Tanvig M, Vinter CA, Jorgensen JS, . Effects of lifestyle intervention in pregnancy and anthropometrics at birth on offspring metabolic profile at 2.8 years: results from the Lifestyle in Pregnancy and Offspring (LiPO) study. J Clin Endocrinol Metab. 2015 Jan;100(1):175–83. doi: 10.1210/jc.2014-2675. PMID: 25343235.25343235
78 Tanvig M, Vinter CA, Jorgensen JS, . Anthropometrics and body composition by dual energy X-ray in children of obese women: a follow-up of a randomized controlled trial (the Lifestyle in Pregnancy and Offspring [LiPO] study). PLoS ONE. 2014 Feb 24;9(2):e89590. doi: 10.1371/journal.pone.0089590. PMID: 24586896.24586896
79 Thomson JL, Goodman MH, Tussing-Humphreys LM, . Infant growth outcomes from birth to 12 months of age: findings from the delta healthy sprouts randomized comparative impact trial. Obes Sci Pract. 2018 Aug;4(4):299–307. doi: 10.1002/osp4.272. PMID: 3015122530151225
80 Thomson JL, Tussing-Humphreys LM, Goodman MH, . Gestational weight gain: results from the Delta Healthy Sprouts comparative impact trial. J Pregnancy. 2016 Jul 12;2016(5703607) doi: 10.1155/2016/5703607. PMID: 27595023.27595023
81 Van Horn L, Peaceman A, Kwasny M, . Dietary approaches to stop hypertension diet and activity to limit gestational weight: maternal offspring metabolics family intervention trial, a technology enhanced randomized trial. Am J Prev Med. 2018 Nov;55(5):603–14. doi: 10.1016/j.amepre.2018.06.015. PMID: 3026214830262148
82 Vesco KK, Karanja N, King JC, . Efficacy of a group-based dietary intervention for limiting gestational weight gain among obese women: a randomized trial. Obesity (Silver Spring). 2014 Sep;22(9):1989–96. doi: 10.1002/oby.20831. PMID: 25164259.25164259
83 Vesco KK, Leo MC, Karanja N, . One-year postpartum outcomes following a weight management intervention in pregnant women with obesity. Obesity (Silver Spring). 2016 Oct;24(10):2042–9. doi: 10.1002/oby.21597. PMID: 27670399.27670399
84 Vinter CA, Jensen DM, Ovesen P, . The LiP (Lifestyle in Pregnancy) study: a randomized controlled trial of lifestyle intervention in 360 obese pregnant women. Diabetes Care. 2011 Dec;34(12):2502–7. doi: 10.2337/dc11-1150. PMID: 21972411.21972411
85 Vinter CA, Jensen DM, Ovesen P, . Postpartum weight retention and breastfeeding among obese women from the randomized controlled Lifestyle in Pregnancy (LiP) trial. Acta Obstet Gynecol Scand. 2014 Aug;93(8):794–801. doi: 10.1111/aogs.12429. PMID: 24834792.24834792
86 Willcox JC, Wilkinson SA, Lappas M, . A mobile health intervention promoting healthy gestational weight gain for women entering pregnancy at a high body mass index: the txt4two pilot randomised controlled trial. BJOG. 2017 Oct;124(11):1718–28. doi: 10.1111/1471-0528.14552. PMID: 28220604.28220604
87 Wolff S, Legarth J, Vangsgaard K, . A randomized trial of the effects of dietary counseling on gestational weight gain and glucose metabolism in obese pregnant women. Int J Obes (Lond). 2008 Mar;32(3):495–501. doi: 10.1038/sj.ijo.0803710. PMID: 18227847.18227847

## Appendix A5 List of Excluded Studies

1 ACOG. Nutrition during pregnancy. ACOG Technical Bulletin Number 179--April 1993. Int J Gynaecol Obstet. 1993 Oct;43(1):67–74. doi: 10.1016/0020-7292(93)90281-Z. PMID: 7904962. Exclusion: wrong publication type.7904962
2 Adam LM, Jarman M, Barker M, . Use of healthy conversation skills to promote healthy diets, physical activity and gestational weight gain: results from a pilot randomised controlled trial. Patient Educ Couns. 2020 Jul. doi: 10.1016/j.pec.2020.01.001. Exclusion: wrong intervention.
3 Adamo KB, Ferraro ZM, Brett KE. Can we modify the intrauterine environment to halt the intergenerational cycle of obesity? Int J Environ Res Public Health. 2012 Apr;9(4):1263–307. doi: 10.3390/ijerph9041263. PMID: 22690193. Exclusion: wrong publication type.22690193
4 Adamo KB, Ferraro ZM, Goldfield G, . The Maternal Obesity Management (MOM) trial protocol: a lifestyle intervention during pregnancy to minimize downstream obesity. Contemp Clin Trials. 2013 May;35(1):87–96. doi: 10.1016/j.cct.2013.02.010. PMID: 23459089. Exclusion: wrong publication type.23459089
5 Adane AA, Tooth LR, Mishra GD. Pre-pregnancy weight change and incidence of gestational diabetes mellitus: a finding from a prospective cohort study. Diabetes Res Clin Pract. 2017 Feb;124:72–80. doi: 10.1016/j.diabres.2016.12.014. PMID: 28110238. Exclusion: wrong intervention.28110238
6 Adesegun D, Cai C, Sivak A, . Prenatal exercise and pre-gestational diseases: a systematic review and meta-analysis. J Obstet Gynaecol Can. 2018 Dec 28;41(8):1134–43. doi: 10.1016/j.jogc.2018.10.007. PMID: 30598427. Exclusion: systematic review or meta-analysis used only as a source document for pearling.30598427
7 Agricola E, Pandolfi E, Gonfiantini MV, . A cohort study of a tailored web intervention for preconception care. BMC Med Inf Decis Mak. 2014 Apr 15;14(33) doi: 10.1186/1472-6947-14-33. PMID: 24731520. Exclusion: wrong outcome.24731520
8 Aguilera M, Sidebottom AC, McCool BR. Examination of routine use of prenatal weight gain charts as a communication tool for providers. Matern Child Health J. 2017 Oct;21(10):1927–38. doi: 10.1007/s10995-017-2308-x. PMID: 28707103. Exclusion: wrong outcome.28707103
9 Ainscough K, Kennelly M, Lindsay KL, . Impact of an mHealth supported healthy lifestyle intervention on behavioural stage of change in overweight and obese pregnancy. Proc Nutr Soc. 2016;Conference: summer meeting. 2016: new technology in nutrition research and practice. Ireland 75(OCE3):E85. Exclusion: wrong publication type.
10 Ainscough K, Kennelly M, O’Sullivan E, . Impact of an mHealth-supported behavioural lifestyle intervention on exercise stage-of-change and physical activity in overweight and obese pregnancy: pEARs randomised controlled trial (RCT). BJOG. Conference: 19th annual conference of the british maternal and fetal medicine society, BMFMS. 2017;124:96–7. Exclusion: wrong publication type.28009123
11 Ainscough K, Kennelly MA, O’Sullivan EJ, . Impact of a smartphone app supporting a lifestyle intervention in overweight and obese pregnancy on on maternal health and lifestyle outcomes. Am J Obstet Gynecol. 2018;Conference: 38th annual meeting of the society for maternal-fetal medicine: the pregnancy meeting. United states. 218(1 Supplement 1):S598–S9. Exclusion: wrong publication type.
12 Ainscough KM, Kennelly MA, O’Sullivan EJ, . Impact of an mhealth-supported behavioral lifestyle intervention on behavioral stage of change and physical activity in overweight and obese pregnancy: pears randomized controlled trial. Reprod Sci. 2017;Conference: 64th annual scientific meeting of the society for gynecologic investigation, SGI. 2017. United states 24(1 Supplement 1):186A. Exclusion: wrong publication type.
13 Ainscough KM, Lindsay KL, Gibney ER, . A review of the integration of behaviour change methodologies in randomised controlled trial lifestyle interventions among overweight and obese women during pregnancy. Obes Facts. 2016;9(207). Exclusion: wrong publication type.
14 Al Wattar BH. Mediterranean-style diet in pregnancies with metabolic risk factors (ESTEEM): a pragmatic multicente. Int J Gynaecol Obstet. 2018;143:192. doi: 10.1371/journal.pmed.1002857. PMID: 31335871. Exclusion: wrong publication type.31335871
15 Al Wattar BH, Mylrea-Lowndes B, Moore A, . Dietary assessment methods in pregnancy: a systematic review of literature. BJOG. 2015;122(254). Exclusion: wrong publication type.
16 Al Wattar BH, Mylrea-Lowndes B, Morgan C, . Use of dietary assessment tools in randomized trials evaluating diet-based interventions in pregnancy: a systematic review of literature. Curr Opin Obstet Gynecol. 2016 Dec;28(6):455–63. doi: 10.1097/GCO.0000000000000322. PMID: 27755129. Exclusion: systematic review or meta-analysis used only as a source document for pearling.27755129
17 Allen R, Rogozinska E, Sivarajasingam P, . Effect of diet- and lifestyle-based metabolic risk-modifying interventions on preeclampsia: a meta-analysis. Acta Obstet Gynecol Scand. 2014 Oct;93(10):973–85. doi: 10.1111/aogs.12467. PMID: 25138651. Exclusion: systematic review or meta-analysis used only as a source document for pearling.25138651
18 Al-Ofi EA, Mosli HH, Ghamri KA, . Management of postprandial hyperglycaemia and weight gain in women with gestational diabetes mellitus using a novel telemonitoring system. J Int Med Res. 2019 Feb;47(2):754–64. doi: 10.1177/0300060518809872. PMID: 30442052. Exclusion: wrong population.30442052
19 Anand SS, Gupta M, Teo KK, . Causes and consequences of gestational diabetes in South Asians living in Canada: results from a prospective cohort study. CMAJ Open. 2017 Aug 9;5(3):E604–E11. doi: 10.9778/cmajo.20170027. PMID: 28800568. Exclusion: wrong intervention.28800568
20 Anderson LN, Knight JA, Hung RJ, . The Ontario Birth Study: a prospective pregnancy cohort study integrating perinatal research into clinical care. Paediatr Perinat Epidemiol. 2018 May;32(3):290–301. doi: 10.1111/ppe.12473. PMID: 29750375. Exclusion: wrong intervention.29750375
21 Angel MD, De Haene J, Perez M, . Dietary patterns associated with gestational weight gain and fat mass gain in overweight and obese pregnant women. Faseb J. 2011;25(9). Exclusion: wrong study design.
22 Anleu E, Reyes M, Araya BM, . Effectiveness of an intervention of dietary counseling for overweight and obese pregnant women in the consumption of sugars and energy. Nutrients. 2019 Feb 13;11(2):13. doi: 10.3390/nu11020385. PMID: 30781781. Exclusion: wrong outcome.30781781
23 AprOn, Teams ES. Adherence to Canada’s food guide recommendations during pregnancy: nutritional epidemiology and public health. Curr Dev Nutr. 2017 Jul;1(7):e000356. doi: 10.3945/cdn.116.000356. PMID: 29955709. Exclusion: wrong outcome.29955709
24 Arden MA, Duxbury AM, Soltani H. Responses to gestational weight management guidance: a thematic analysis of comments made by women in online parenting forums. BMC Pregnancy Childbirth. 2014 Jun 30;14(216) doi: 10.1186/1471-2393-14-216. PMID: 24981024. Exclusion: wrong publication type.24981024
25 Arendas K, Qiu Q, Gruslin A. Obesity in pregnancy: pre-conceptional to postpartum consequences. J Obstet Gynaecol Can. 2008 Jun;30(6):477–88. doi: 10.1016/S1701-2163(16)32863-8. PMID: 18611299. Exclusion: wrong publication type.18611299
26 Arianas EA, Rankin KM, Norr KF, . Maternal weight status and responsiveness to preterm infant behavioral cues during feeding. BMC Pregnancy Childbirth. 2017 Apr 11;17(113) doi: 10.1186/s12884-017-1298-4. PMID: 28399825. Exclusion: wrong population.28399825
27 Arinze NV, Karp SM, Gesell SB. Evaluating provider advice and women’s beliefs on total weight gain during pregnancy. J Immigr Minor Health. 2016 Feb;18(1):282–6. doi: 10.1007/s10903-015-0162-8. PMID: 25649967. Exclusion: wrong intervention.25649967
28 Daily weight monitoring in pregnancy-a randomised controlled trial. Aust N Z J Obstet Gynaecol; 2016. 56. Exclusion: wrong comparator.
29 Asci O, Rathfisch G. Effect of lifestyle interventions of pregnant women on their dietary habits, lifestyle behaviors, and weight gain: a randomized controlled trial. J Health Popul Nutr. 2016 Feb 24;35(7) doi: 10.1186/s41043-016-0044-2. PMID: 26911204. Exclusion: wrong country.26911204
30 Babbar S, Porter BW, Williams KB. The impact of prenatal yoga on exercise attitudes and behavior: teachable moments from a randomized controlled trial. In J Yoga Therap. 2017 Nov;27(1):37–48. doi: 10.17761/IJYT2017_Research_Babbar_Epub. PMID: 29131740. Exclusion: wrong outcome.29131740
31 Badon SE, Enquobahrie DA, Wartko PD, . Healthy lifestyle during early pregnancy and risk of gestational diabetes mellitus. Am J Epidemiol. 2017 Aug 1;186(3):326–33. doi: 10.1093/aje/kwx095. PMID: 28481961. Exclusion: wrong study design.28481961
32 Badon SE, Littman AJ, Chan KCG, . Maternal sedentary behavior during pre-pregnancy and early pregnancy and mean offspring birth size: a cohort study. BMC Pregnancy Childbirth. 2018 Jun 27;18(267) doi: 10.1186/s12884-018-1902-2. PMID: 29945548. Exclusion: wrong intervention.29945548
33 Bain E, Crane M, Tieu J, . Diet and exercise interventions for preventing gestational diabetes mellitus. Cochrane Database Syst Rev. 2015 Apr 12(4):CD010443. doi: 10.1002/14651858.CD010443.pub2. PMID: 25864059. Exclusion: systematic review or meta-analysis used only as a source document for pearling.25864059
34 Bannon AL, Waring ME, Leung K, . Comparison of self-reported and measured pre-pregnancy weight: implications for gestational weight gain counseling. Matern Child Health J. 2017 Jul;21(7):1469–78. doi: 10.1007/s10995-017-2266-3. PMID: 28155023. Exclusion: wrong study design.28155023
35 Bao H, Yu P, Song X, . The influence of home-based exercise on gestational diabetes: a meta-analysis of randomized controlled trials. J Matern Fetal Neonatal Med. 2019 Jan 09:1–6. doi: 10.1080/14767058.2018.1548595. PMID: 30626247. Exclusion: systematic review or meta-analysis used only as a source document for pearling.30626247
36 Bao W, Tobias DK, Olsen SF, . Pre-pregnancy fried food consumption and the risk of gestational diabetes mellitus: a prospective cohort study. Diabetologia. 2014 Dec;57(12):2485–91. doi: 10.1007/s00125-014-3382-x. PMID: 25303998. Exclusion: wrong outcome.25303998
37 Barakar R, Pelaez M, Lopez C, . Exercise-based intervention to prevent excessive gestational weight gain: a randomized controlled trial. Ann Nutr Metab. 2013;63:723–4. Exclusion: wrong publication type.
38 Barakat R, Lucia A, Ruiz JR. Resistance exercise training during pregnancy and newborn’s birth size: a randomised controlled trial. Int J Obes (Lond). 2009 Sep;33(9):1048–57. doi: 10.1038/ijo.2009.150. PMID: 19636320. Exclusion: wrong outcome.19636320
39 Barakat R, Pelaez M, Lopez C, . Exercise during pregnancy and gestational diabetes-related adverse effects: a randomised controlled trial. Br J Sports Med. 2013 Jul;47(10):630–6. doi: 10.1136/bjsports-2012-091788. PMID: 23365418. Exclusion: wrong outcome.23365418
40 Barakat R, Perales M, Cordero Y, . Influence of land or water exercise in pregnancy on outcomes: a cross-sectional study. Med Sci Sports Exerc. 2017 Jul;49(7):1397–403. doi: 10.1249/MSS.0000000000001234. PMID: 28198729. Exclusion: wrong study design.28198729
41 Barden A, Singh R, Walters B, . A simple scoring method using cardiometabolic risk measurements in pregnancy to determine 10-year risk of type 2 diabetes in women with gestational diabetes. Nutr Diabetes. 2013 Jun 3;3(6):e72. doi: 10.1038/nutd.2013.15. PMID: 23732679. Exclusion: wrong intervention.23732679
42 Bartok CJ, Schaefer EW, Beiler JS, . Role of body mass index and gestational weight gain in breastfeeding outcomes. Breastfeed Med. 2012 Dec;7(6):448–56. doi: 10.1089/bfm.2011.0127. PMID: 23215909. Exclusion: wrong study design.23215909
43 Bautista-Castano I, Henriquez-Sanchez P, Aleman-Perez N, . Maternal obesity in early pregnancy and risk of adverse outcomes.[Erratum appears in PLoS One. 2013 Dec 19;8(12):; PMID: 29364987]. PLoS ONE. 2013 Nov;8(11):e80410. doi: 10.1371/journal.pone.0080410. PMID: 24278281. Exclusion: wrong study design.24278281
44 Bechtel-Blackwell DA. Computer-assisted self-interview and nutrition education in pregnant teens. Clin Nurs Res. 2002 Nov;11(4):450–62. doi: 10.1177/105477302237456 PMID: 12413116. Exclusion: wrong study design.12413116
45 Beetham KS, Giles C, Noetel M, . The effects of vigorous intensity exercise in the third trimester of pregnancy: a systematic review and meta-analysis. BMC Pregnancy Childbirth. 2019 Aug 07;19(1):281. doi: 10.1186/s12884-019-2441-1. PMID: 31391016. Exclusion: systematic review or meta-analysis used only as a source document for pearling.31391016
46 Bell RJ, Palma SM, Lumley JM. The effect of vigorous exercise during pregnancy on birth-weight. Aust N Z J Obstet Gynaecol. 1995 Feb;35(1):46–51. doi: 10.1111/j.1479-828X.1995.tb01829.x. PMID: 7771999. Exclusion: wrong publication type.7771999
47 Bennett CJ, Walker RE, Blumfield ML, . Interventions designed to reduce excessive gestational weight gain can reduce the incidence of gestational diabetes mellitus: a systematic review and meta-analysis of randomised controlled trials. Diabetes Res Clin Pract. 2018 Jul;141:69–79. doi: 10.1016/j.diabres.2018.04.010. PMID: 29698713. Exclusion: systematic review or meta-analysis used only as a source document for pearling.29698713
48 Bennett CJ, Walker RE, Blumfield ML, . Attenuation of maternal weight gain impacts infant birthweight: systematic review and meta-analysis. J Dev Orig Health Dis. 2018 Nov 09;10(4):387–405. doi: 10.1017/S2040174418000879. PMID: 30411697. Exclusion: systematic review or meta-analysis used only as a source document for pearling.30411697
49 Bergmann MM, Flagg EW, Miracle-McMahill HL, . Energy intake and net weight gain in pregnant women according to body mass index (BMI) status. Int J Obes Relat Metab Disord. 1997 Nov;21(11):1010–7. doi: 10.1038/sj.ijo.0800509. PMID: 9368824. Exclusion: wrong intervention.9368824
50 Bevier WC, Fischer R, Jovanovic L. Treatment of women with an abnormal glucose challenge test (but a normal oral glucose tolerance test) decreases the prevalence of macrosomia. Am J Perinatol. 1999;16(6):269–75. doi: 10.1055/s-2007-993871. PMID: 10586979. Exclusion: wrong outcome.10586979
51 Bhandari HM, Quenby S. Obesity and recurrent miscarriage. Obesity: A ticking time bomb for reproductive health. Amsterdam, Netherlands: Elsevier; Netherlands; 2013:117–26. Exclusion: wrong publication type.
52 Birdsall KM, Vyas S, Khazaezadeh N, . Maternal obesity: a review of interventions. Int J Clin Pract. 2009 Mar;63(3):494–507. doi: 10.1111/j.1742-1241.2008.01910.x. PMID: 19222635. Exclusion: wrong publication type.19222635
53 Bish CL, Chu SY, Shapiro-Mendoza CK, . Trying to lose or maintain weight during pregnancy-United States, 2003. Matern Child Health J. 2009 Mar;13(2):286–92. doi: 10.1007/s10995-008-0349-x. PMID: 18449630. Exclusion: wrong study design.18449630
54 Bisson M, Almeras N, Dufresne SS, . A 12-week exercise program for pregnant women with obesity to improve physical activity levels: an open randomised preliminary study. PLoS ONE. 2015 Sep 16;10(9):e0137742. doi: 10.1371/journal.pone.0137742. PMID: 26375471. Exclusion: wrong intervention.26375471
55 Bisson M, Croteau J, Guinhouya BC, . Physical activity during pregnancy and infant’s birth weight: results from the 3D Birth Cohort. BMJ Open Sport Exerc Med. 2017 Jun 19;3(1):e000242. doi: 10.1136/bmjsem-2017-000242. PMID: 28761717. Exclusion: wrong study design.28761717
56 Bjork Ingul C, Krohn Garnaes K, Moholdt T, . Cardiac function in newborns of obese women and the effect of an exercise intervention during pregnancy. Eur Heart J. 2017;Conference: european society of cardiology, ESC congress. 2017. Spain 38(Supplement 1):124. Exclusion: wrong intervention.
57 Bodnar LM, Simhan HN, Parker CB, . Racial or ethnic and socioeconomic inequalities in adherence to national dietary guidance in a large cohort of US pregnant women. Journal of the Academy of Nutrition and Dietetics. 2017 Jun 1;117(6):867–77.e3. doi: 10.1016/j.jand.2017.01.016. PMID: 28320597. Exclusion: wrong intervention.28320597
58 Bogaerts A, Devlieger R, Nuyts E, . Effect of psycho-education in obese pregnant women on pregnancy outcomes, randomized controlled trial. Reprod Sci. START: 2012 Mar 21 CONFERENCE END: 2012 Mar 24, 59th Annual Scientific Meeting of the Society for Gynecologic Investigation, SGI 2012 San Diego, CA United States;19(3 SUPPL. 1):114A. Exclusion: wrong publication type.
59 Breslow S, Belafsky HA, Shangold JE, . Control of weight gain in pregnancy: double blind study of a dieting aid. Clin Med (Northfield Il). 1963 May;70:931–8. PMID: 15446005. Exclusion: wrong population.15446005
60 Brik M, Fernandez-Buhigas I, Martin-Arias A, . Does exercise during pregnancy impact on maternal weight gain and fetal cardiac function? A randomized controlled trial. Ultrasound Obstet Gynecol. 2019 May 53(5):583–9. doi: 10.1002/uog.20147. PMID: 30328169. Exclusion: quality rating is poor.30328169
61 Briley AL, Barr S, Badger S, . A complex intervention to improve pregnancy outcome in obese women; the UPBEAT randomised controlled trial.[Erratum appears in BMC Pregnancy Childbirth. 2015;15:111; PMID: 25953385]. BMC Pregnancy Childbirth. 2014 Feb 18;14(74) doi: 10.1186/1471-2393-14-74. PMID: 24533897. Exclusion: wrong publication type.24533897
62 Broekhuizen K, Simmons D, Devlieger R, . Cost-effectiveness of healthy eating and/or physical activity promotion in pregnant women at increased risk of gestational diabetes mellitus: economic evaluation alongside the DALI study, a European multicenter randomized controlled trial. Int J Behav Nutr Phys Act. 2018 Mar 14;15(23) doi: 10.1186/s12966-018-0643-y. PMID: 29540227. Exclusion: wrong outcome.29540227
63 Brown SD, Hedderson MM, Ehrlich SF, . Gestational weight gain and optimal wellness (GLOW): rationale and methods for a randomized controlled trial of a lifestyle intervention among pregnant women with overweight or obesity. BMC Pregnancy Childbirth. 2019 Apr 30;19(1):145. doi: 10.1186/s12884-019-2293-8. PMID: 31039753. Exclusion: wrong publication type.31039753
64 Brownfoot FC, Davey M, Kornman L. Weighing In Pregnancy study (WIP): a randomised controlled trial of the effect of routine weighing to reduce excessive antenatal weight gain. BJOG. 2015;122(260). Exclusion: wrong publication type.
65 Bruce L, Tchabo JG. Nutrition intervention program in a prenatal clinic. Obstet Gynecol. 1989 Sep;74(3 Pt 1):310–2. PMID: 2761905. Exclusion: wrong study design.2761905
66 Brumley J, Cain M, Stern M, . Gestational weight gain and breastfeeding outcomes in group prenatal care. J Midwifery Womens Health. 2016 Sep–Oct;61(5):557–62. doi: 10.1111/jmwh.12484. PMID: 27428789 Exclusion: wrong study design.27428789
67 Buckingham-Schutt LM, Ellingson LD, Vazou S, . The behavioral wellness in pregnancy study: a randomized controlled trial of a multi-component intervention to promote appropriate weight gain. Am J Clin Nutr. 2019 Apr 01;109(4):1071–9. doi: 10.1093/ajcn/nqy359. PMID: 30949691. Exclusion: inadequate sample size.30949691
68 Bye A, Shawe J, Stephenson J, . Differences in pre-conception and pregnancy healthy lifestyle advice by maternal BMI: findings from a cross sectional survey. Midwifery. 2016 Nov;42:38–45. doi: 10.1016/j.midw.2016.09.013. PMID: 27744203. Exclusion: wrong intervention.27744203
69 Cahill AG, Haire-Joshu D, Cade WT, . Randomized controlled trial of home-based weight management therapy in pregnant socioeconomically disadvantaged (SED) women with overweight/obesity. Am J Obstet Gynecol. 2017;Conference: 37th annual meeting of the society for maternal-fetal medicine: the pregnancy meeting. United states. Conference start:. 20170123. Conference end: 20170128 216(1 Supplement 1):S56–S7. Exclusion: wrong publication type.
70 Callaway L, McIntyre D, Colditz P, . Exercise in obese pregnant women: a randomized study to assess feasibility. Hypertens Pregnancy. 2008;27(4):549. Exclusion: wrong publication type.
71 Callaway LK, Colditz PB, Byrne NM, . Prevention of gestational diabetes: feasibility issues for an exercise intervention in obese pregnant women. Diabetes Care. 2010 Jul;33(7):1457–9. doi: 10.2337/dc09-2336. PMID: 20357374. Exclusion: wrong outcome.20357374
72 Callaway LK, Prins JB, Chang AM, . The prevalence and impact of overweight and obesity in an Australian obstetric population. Med J Aust. 2006 Jan 16;184(2):56–9. PMID: 16411868. Exclusion: wrong study design.16411868
73 Cambos S, Rigalleau V, Blanco L. A medically supervised pregnancy exercise intervention in obese women: a randomized controlled trial. Obstet Gynecol. 2018 Mar;131(3):599. doi: 10.1097/AOG.0000000000002505. PMID: 29470327. Exclusion: wrong publication type.29470327
74 Campbell F, Johnson M, Messina J, . Behavioural interventions for weight management in pregnancy: a systematic review of quantitative and qualitative data. BMC Public Health. 2011 Jun 22;11:491. doi: 10.1186/1471-2458-11-491. PMID: 21696589. Exclusion: systematic review or meta-analysis used only as a source document for pearling.21696589
75 Carolan-Olah M, Sayakhot P. A randomized controlled trial of a web-based education intervention for women with gestational diabetes mellitus. Midwifery. 2019 Jan;68:39–47. doi: 10.1016/j.midw.2018.08.019. PMID: 30343264. Exclusion: wrong population.30343264
76 Cassidy D, John E, Copeland L, . Weight management in pregnancy: participants’ experiences of ‘Healthy Eating and Lifestyle in Pregnancy (HELP)’, a maternity care intervention for obese pregnant women. Pregnancy Hypertension. 2014 Jul;4(3):233. doi: 10.1016/j.preghy.2014.03.012. PMID: 26104617. Exclusion: wrong intervention.26104617
77 Catalano PM. Obesity, insulin resistance, and pregnancy outcome. Reproduction. 2010 Sep;140(3):365–71. doi: 10.1530/REP-10-0088. PMID: 20457594. Exclusion: wrong publication type.20457594
78 Cavalcante SR, Cecatti JG, Pereira RI, . Water aerobics II: maternal body composition and perinatal outcomes after a program for low risk pregnant women. Reprod Health. 2009 Jan 6;6(1) doi: 10.1186/1742-4755-6-1. PMID: 19126239. Exclusion: wrong country.19126239
79 CDC. From the Centers for Disease Control and Prevention. Pregnancy-related behaviors among migrant farm workers--four states, 1989-1993. JAMA. 1997 May 21;277(19):1512. PMID: 9153357. Exclusion: wrong study design.9153357
80 Chan RS, Tam WH, Ho IC, . Randomized trial examining effectiveness of lifestyle intervention in reducing gestational diabetes in high risk Chinese pregnant women in Hong Kong. Sci Rep. 2018 Sep 14;8(1):13849. doi: 10.1038/s41598-018-32285-6. PMID: 30218012. Exclusion: wrong population.30218012
81 Chao AM, Srinivas SK, Studt SK, . A pilot randomized controlled trial of a technology-based approach for preventing excess weight gain during pregnancy among women with overweight. Front Nutr. 2017 Nov 22;4:57. doi: 10.3389/fnut.2017.00057. PMID: 29214155. Exclusion: inadequate sample size.29214155
82 Charkamyani F, Khedmat L, Hosseinkhani A. Decreasing the main maternal and fetal complications in women undergoing in vitro fertilization (IVF) trained by nutrition and healthy eating practices during pregnancy. J Matern Fetal Neonatal Med. 2019 Aug 20:1–13. doi: 10.1080/14767058.2019.1651267. PMID: 31429355. Exclusion: wrong country.31429355
83 Chasan-Taber L, Schmidt MD, Pekow P, . Physical activity and gestational diabetes mellitus among Hispanic women. J Womens Health. 2008 Jul–Aug;17(6):999–1008. doi: 10.1089/jwh.2007.0560. PMID: 18582171. Exclusion: wrong study design.18582171
84 Chatzakis C, Goulis DG, Mareti E, . Prevention of gestational diabetes mellitus in overweight or obese pregnant women: a network meta-analysis. Diabetes Res Clin Pract. 2019 Dec;158:107924. doi: 10.1016/j.diabres.2019.107924. PMID: 31738997. Exclusion: wrong outcome.31738997
85 Chauhan SP, Johnson TL, Magann EF, . Compliance with regulations on weight gain 6 months after delivery in active duty military women. Mil Med. 2013 Apr;178(4):406–11. doi: 10.7205/MILMED-D-12-00394. PMID: 23707825. Exclusion: wrong population.23707825
86 Chia A-R, Tint M-T, Han CY, . Adherence to a healthy eating index for pregnant women is associated with lower neonatal adiposity in a multiethnic Asian cohort: the Growing Up in Singapore Towards healthy Outcomes (GUSTO) Study. Am J Clin Nutr. 2018 Jan 1;107(1):71–9. doi: 10.1093/ajcn/nqx003. PMID: 29381790. Exclusion: wrong study design.29381790
87 Chiavaroli V, Derraik JGB, Hopkins SA, . Excessive gestational weight gain is associated with adverse health outcomes in the offspring at age 7 years. Int J Pediatr Endocrinol. Conference: 9th biennial scientific meeting of the asia pacific paediatric endocrine society, APPES and the 50th annual meeting of the japanese society for pediatric endocrinology, JSPE. Japan. 2017. Exclusion: wrong publication type.
88 Chiavaroli V, Derraik JGB, Hopkins SA, . Greater maternal BMI early in pregnancy is associated with increased adiposity in 7-year-old offspring, but without adverse effects on metabolism. Int J Pediatr Endocrinol. Conference: 9th biennial scientific meeting of the asia pacific paediatric endocrine society, APPES and the 50th annual meeting of the japanese society for pediatric endocrinology, JSPE. Japan. 2017. Exclusion: wrong intervention.
89 Chiavaroli V, Hopkins S, Biggs J, . Regular, moderate intensity maternal exercise reduces birth weight but increases the risk of later childhood adiposity. Int J Pediatr Endocrinol. Conference: 8th biennial scientific meeting of the asia pacific paediatric endocrine society, APPES. 2014. Exclusion: wrong publication type.
90 Choi J, Fukuoka Y, Lee JH. The effects of physical activity and physical activity plus diet interventions on body weight in overweight or obese women who are pregnant or in postpartum: a systematic review and meta-analysis of randomized controlled trials. Prev Med. 2013 Jun;56(6):351–64. doi: 10.1016/j.ypmed.2013.02.021. PMID: 23480971. Exclusion: systematic review or meta-analysis used only as a source document for pearling.23480971
91 Chu L, Retnakaran R, Zinman B, . Impact of maternal physical activity and infant feeding practices on infant weight gain and adiposity. Int J Endocrinol. 2012 Jul 11;2012doi: 10.1155/2012/293821. PMID: 23056043. Exclusion: wrong study design.23056043
92 Chwah SR, Reilly A, Hall B, . Engagement with and outcomes of a midwifery-led intervention group for pregnant women of high body mass index. Obstet Med. 2016 Sep;9(3):120–5. doi: 10.1177/1753495X16638560. PMID: 27630748. Exclusion: wrong study design.27630748
93 Claesson IM, Josefsson A, Sydsjo G. Weight six years after childbirth: a follow-up of obese women in a weight-gain restriction programmme. Midwifery. 2014 May;30(5):506–11. doi: 10.1016/j.midw.2013.06.009. PMID: 23906878. Exclusion: wrong study design.23906878
94 Claesson IM, Sydsjo G, Brynhildsen J, . Weight after childbirth: a 2-year follow-up of obese women in a weight-gain restriction program. Acta Obstet Gynecol Scand. 2011 Jan;90(1):103–10. doi: 10.1111/j.1600-0412.2010.01016.x. PMID: 21275923. Exclusion: wrong study design.21275923
95 Claesson IM, Sydsjo G, Olhager E, . Effects of a gestational weight gain restriction program for obese pregnant women: children’s weight development during the first five years of life. Child. 2016 Jun;12(3):162–70. doi: 10.1089/chi.2015.0177. PMID: 27007580. Exclusion: wrong outcome.27007580
96 Claesson I-M, Sydsjö G, Brynhildsen J, . Weight gain restriction for obese pregnant women: a case—control intervention study. BJOG. 2008 Jan;115(1):44–50. doi: 10.1111/j.1471-0528.2007.01531.x. PMID: 17970795. Exclusion: wrong study design.17970795
97 Clapp IJF. Diet, exercise, and feto-placental growth. Arch Gynecol Obstet. 1997;260:101–8. Exclusion: wrong study design.
98 Clapp JF, 3rd. The course of labor after endurance exercise during pregnancy. Am J Obstet Gynecol. 1990 Dec;163(6 Pt 1):1799–805. doi: 10.1016/0002-9378(90)90753-T. PMID: 2256485. Exclusion: wrong intervention.2256485
99 Clapp JF, 3rd. Long-term outcome after exercising throughout pregnancy: fitness and cardiovascular risk. Am J Obstet Gynecol. 2008 Nov;199(5):489.e1–6. doi: 10.1016/j.ajog.2008.05.006. PMID: 18667190. Exclusion: wrong outcome.18667190
100 Clapp JF, 3rd, Capeless EL. Neonatal morphometrics after endurance exercise during pregnancy. Am J Obstet Gynecol. 1990a Dec;163(6 Pt 1):1805–11. doi: 10.1016/0002-9378(90)90754-U. PMID: 2256486. Exclusion: wrong intervention.2256486
101 Clapp JF, 3rd, Dickstein S. Endurance exercise and pregnancy outcome. Med Sci Sports Exerc. 1984 Dec;16(6):556–62. PMID: 6513772. Exclusion: wrong intervention.6513772
102 Clapp JF, 3rd, Kim H, Burciu B, . Beginning regular exercise in early pregnancy: effect on fetoplacental growth. Am J Obstet Gynecol. 2000 Dec;183(6):1484–8. doi: 10.1067/mob.2000.107096 PMID: 11120515. Exclusion: wrong intervention.11120515
103 Clapp JF, 3rd, Kim H, Burciu B, . Continuing regular exercise during pregnancy: effect of exercise volume on fetoplacental growth. Am J Obstet Gynecol. 2002 Jan;186(1):142–7. doi: 10.1067/mob.2002.119109. PMID: 11810100. Exclusion: wrong comparator.11810100
104 Clapp JF, 3rd, Little KD. Effect of recreational exercise on pregnancy weight gain and subcutaneous fat deposition. Med Sci Sports Exerc. 1995 Feb;27(2):170–7. PMID: 7723638. Exclusion: wrong intervention.7723638
105 Clark AM, Ledger W, Galletly C, . Weight loss results in significant improvement in pregnancy and ovulation rates in anovulatory obese women. Hum Reprod. 1995 Oct;10(10):2705–12. doi: 10.1093/oxfordjournals.humrep.a135772. PMID: 8567797. Exclusion: wrong population.8567797
106 Clements V, Leung K, Khanal S, . Pragmatic cluster randomised trial of a free telephone-based health coaching program to support women in managing weight gain during pregnancy: the Get Healthy in Pregnancy Trial. BMC Health Serv Res. 2016 Aug 30;16(1):454. doi: 10.1186/s12913-016-1704-z. PMID: 27578294. Exclusion: wrong publication type.27578294
107 Clements V, Raymond J, Nicholl M, . Worth the weight: factors influencing recruitment to the NSW get healthy in pregnancy service trial. J Paediatr Child Health. 2015;51(106). Exclusion: wrong publication type.
108 Clifton RG, Evans M, Cahill AG, . Design of lifestyle intervention trials to prevent excessive gestational weight gain in women with overweight or obesity. Obesity (Silver Spring). 2016 Feb;24(2):305–13. doi: 10.1002/oby.21330. PMID: 26708836. Exclusion: wrong publication type.26708836
109 Coleman-Phox K, Laraia BA, Adler N, . Recruitment and retention of pregnant women for a behavioral intervention: lessons from the Maternal Adiposity, Metabolism, and Stress (MAMAS) study. Prev Chronic Dis. 2013;10doi: 10.5888/pcd10.120096. PMID: 23469765. Exclusion: wrong outcome.23469765
110 Collins TR, DeMellier ST, Leeper JD, . Supplemental food program: effects on health and pregnancy outcome. South Med J. 1985 May;78(5):551–5. doi: 10.1097/00007611-198505000-00014. PMID: 3992303. Exclusion: wrong comparator.3992303
111 Colon-Ramos U, Racette SB, Ganiban J, . Association between dietary patterns during pregnancy and birth size measures in a diverse population in Southern US. Nutrients. 2015 Feb 16;7(2):1318–32. doi: 10.3390/nu7021318. PMID: 25690420. Exclusion: wrong intervention.25690420
112 Cordero Y, Mottola MF, Vargas J, . Exercise is associated with a reduction in gestational diabetes mellitus. Med Sci Sports Exerc. 2015 Jul;47(7):1328–33. doi: 10.1249/MSS.0000000000000547. PMID: 25333246. Exclusion: quality rating is poor.25333246
113 Correia S, Rodrigues T, Barros H. Assessing the effect on outcomes of public or private provision of prenatal care in Portugal. Matern Child Health J. 2015 Jul;19(7):1574–83. doi: 10.1007/s10995-015-1667-4. PMID: 25636645. Exclusion: wrong outcome.25636645
114 Corvalan C, Garmendia ML, Pereira A, . Critical windows for prevention of obesity and associated conditions: the gocs and chimino chilean cohorts. Ann Nutr Metab. 2017;Conference: 21st international congress of nutrition, ICN. 2017. Argentina 71(Supplement 2):231. Exclusion: wrong publication type.
115 Costa BM, Paulinelli RR, Barbosa MA. Association between maternal and fetal weight gain: cohort study. Sao Paulo Med J. 2012;130(4):242–7. doi: 10.1590/S1516-31802012000400007 PMID: 22965365. Exclusion: wrong study design.22965365
116 Crane SS, Wojtowycz MA, Dye TD, . Association between pre-pregnancy obesity and the risk of cesarean delivery. Obstet Gynecol. 1997 Feb;89(2):213–6. doi: 10.1016/S0029-7844(96)00449-8. PMID: 9015022. Exclusion: wrong intervention.9015022
117 Criss S, Oken E, Guthrie L, . A qualitative study of gestational weight gain goal setting. BMC Pregnancy Childbirth. 2016 Oct 20;16(1):317. doi: 10.1186/s12884-016-1118-2 PMID: 27765028. Exclusion: wrong study design.27765028
118 Currie LM, Woolcott CG, Fell DB, . The association between physical activity and maternal and neonatal outcomes: a prospective cohort. Matern Child Health J. 2014 Oct;18(8):1823–30. doi: 10.1007/s10995-013-1426-3. PMID: 24347091. Exclusion: wrong comparator.24347091
119 Currie S, Sinclair M, Murphy MH, . Reducing the decline in physical activity during pregnancy: a systematic review of behaviour change interventions. PLoS ONE. 2013 Jun 14;8(6):e66385. doi: 10.1371/journal.pone.0066385. PMID: 23799096. Exclusion: systematic review or meta-analysis used only as a source document for pearling.23799096
120 da Silva SG, Hallal PC, Domingues MR, . A randomized controlled trial of exercise during pregnancy on maternal and neonatal outcomes: results from the PAMELA study. Int J Behav Nutr Phys Act. 2017 Dec 22;14(175) doi: 10.1186/s12966-017-0632-6. PMID: 29273044. Exclusion: wrong country.29273044
121 da Silva SG, Ricardo LI, Evenson KR, . Leisure-time physical activity in pregnancy and maternal-child health: a systematic review and meta-analysis of randomized controlled trials and cohort studies. Sports Med. 2017a Feb;47(2):295–317. doi: 10.1007/s40279-016-0565-2. PMID: 27282925. Exclusion: systematic review or meta-analysis used only as a source document for pearling.27282925
122 Daemers DOA, Wijnen HAA, van Limbeek EBM, . The effect of gestational weight gain on likelihood of referral to obstetric care for women eligible for primary, midwife-led care after antenatal booking. Midwifery. 2016 Mar;34:123–32. doi: 10.1016/j.midw.2015.12.006. PMID: 26754055. Exclusion: wrong study design.26754055
123 Dahly DL, Li X, Smith HA, . Associations between maternal lifestyle factors and neonatal body composition in the Screening for Pregnancy Endpoints (Cork) cohort study. Int J Epidemiol. 2018 Feb 1;47(1):131–45. doi: 10.1093/ije/dyx221. PMID: 29136159. Exclusion: wrong population.29136159
124 Dalrymple KV, O’Keeffe M, Godfrey KM, . Childhood adiposity and cardiovascular outcomes at 3 years following a randomised controlled trial of a behavioural intervention in obese pregnant women (the upbeat trial). Reprod Sci. 2019;26. Exclusion: wrong publication type.
125 Daly N, Farren M, McKeating A, . Effect of a randomized controlled trial of an intensive medically supervised exercise program designed to improve maternal glucose control on gestational weight gain. Am J Obstet Gynecol. 2017;Conference: 37th annual meeting of the society for maternal-fetal medicine: the pregnancy meeting. United states. Conference start:. 20170123. Conference end: 20170128 216(1 Supplement 1):S24. Exclusion: wrong publication type.
126 D’Angelo-Scott HJ. An investigation of the impact of a multidisciplinary, collaborative maternity care model in Nova Scotia, Canada. Diss Abstr Int: Section B: The Sciences and Engineering. 2013;74(5-B(E)). Exclusion: wrong comparator.
127 Davies DP, Abernethy M. Cigarette smoking in pregnancy: associations with maternal weight gain and fetal growth. Lancet. 1976 Feb 21;1(7956):385–7. doi: 10.1016/S0140-6736(76)90215-4. PMID: 55649. Exclusion: wrong intervention.55649
128 Davies GAL, Maxwell C, McLeod L, . Obesity in pregnancy. J Obstet Gynaecol Can. 2010 Feb;32(2):165–73. doi: 10.1016/S1701-2163(16)34432-2. PMID: 20181319. Exclusion: wrong publication type.20181319
129 Davis D, Davey R, Williams LT, . Optimizing gestational weight gain with the Eating4Two smartphone app: protocol for a randomized controlled trial. JMIR Res Protoc. 2018 May 30;7(5):e146. doi: 10.2196/resprot.9920. PMID: 29848468. Exclusion: wrong publication type.29848468
130 de Alencar Costa LA, Araujo Junior E, de Lucena Feitosa FE, . Maternal and perinatal outcomes after bariatric surgery: a case control study. J Perinat Med. 2016 May 01;44(4):383–8. doi: 10.1515/jpm-2015-0092. PMID: 26352065. Exclusion: wrong intervention.26352065
131 De Frene V, Vansteelandt S, T’Sjoen G, . A retrospective study of the pregnancy, delivery and neonatal outcome in overweight versus normal weight women with polycystic ovary syndrome. Hum Reprod. 2014 Oct 10;29(10):2333–8. doi: 10.1093/humrep/deu154. PMID: 24963163. Exclusion: wrong study design.24963163
132 de Jersey SJ, Mallan KM, Callaway LK, . Prospective relationships between health cognitions and excess gestational weight gain in a cohort of healthy and overweight pregnant women. J Acad Nutr Diet. 2017 Aug;117(8):1198–209. doi: 10.1016/j.jand.2016.12.011. PMID: 28189424. Exclusion: wrong intervention.28189424
133 de Keyser N, Josefsson A, Monfils WG, . Total cost comparison of standard antenatal care with a weight gain restriction programme for obese pregnant women. Public Health. 2011 May;125(5):311–7. doi: 10.1016/j.puhe.2011.02.004. PMID: 21658538. Exclusion: wrong outcome.21658538
134 de Oliveria Melo AS, Silva JL, Tavares JS, . Effect of a physical exercise program during pregnancy on uteroplacental and fetal blood flow and fetal growth: a randomized controlled trial. Obstet Gynecol. 2012 Aug;120(2 Pt 1):302–10. doi: 10.1097/AOG.0b013e31825de592. PMID: 22825089. Exclusion: wrong country.22825089
135 Dean SV, Lassi ZS, Imam AM, . Preconception care: promoting reproductive planning. Reprod Health. 2014 Sep 26;11 Suppl 3:S2. doi: 10.1186/1742-4755-11-S3-S2. PMID: 25415259. Exclusion: wrong population.25415259
136 Deierlein AL, Siega-Riz AM, Herring A. Dietary energy density but not glycemic load is associated with gestational weight gain. Am J Clin Nutr. 2008 Sep 1;88(3):693–9. doi: 10.1093/ajcn/88.3.693. PMID: 18779285. Exclusion: wrong intervention.18779285
137 Dekker Nitert M, Barrett HL, Denny KJ, . Exercise in pregnancy does not alter gestational weight gain, MCP-1 or leptin in obese women. Aust N Z J Obstet Gynaecol. 2015 Feb;55(1):27–33. doi: 10.1111/ajo.12300. PMID: 25688817. Exclusion: inadequate sample size.25688817
138 Dello Russo M, Ahrens W, De Vriendt T, . Gestational weight gain and adiposity, fat distribution, metabolic profile, and blood pressure in offspring: the IDEFICS project. Int J Obes. 2013 Jul;37(7):914–9. doi: 10.1038/ijo.2013.35. PMID: 23567926. Exclusion: wrong study design.23567926
139 Demment MM, Graham ML, Olson CM. How an online intervention to prevent excessive gestational weight gain is used and by whom: a randomized controlled process evaluation. J Med Internet Res. 2014 Aug 20;16(8):e194. doi: 10.2196/jmir.3483. PMID: 25143156. Exclusion: wrong outcome.25143156
140 Deputy NP, Sharma AJ, Kim SY, . Prevalence and characteristics associated with gestational weight gain adequacy. Obstet Gynecol. 2015 Apr;125(4):773–81. doi: 10.1097/AOG.0000000000000739. PMID: 25751216. Exclusion: wrong study design.25751216
141 Desai JR, Taylor G, Benitez GV, . Can financial incentives prevent diabetes in a low-income population? Diabetes. 2016;Conference: 76th scientific sessions of the american diabetes association, ADA. 2016. United states 65(Supplement 1):A71. Exclusion: wrong population.
142 Deveer R, Deveer M, Akbaba E, . The effect of diet on pregnancy outcomes among pregnant with abnormal glucose challenge test. Eur Rev Med Pharmacol Sci. 2013 May;17(9):1258–61. PMID: 23690197. Exclusion: wrong intervention.23690197
143 Di Carlo C, Iannotti G, Sparice S, . The role of a personalized dietary intervention in managing gestational weight gain: a prospective, controlled study in a low-risk antenatal population. Arch Gynecol Obstet. 2014 Apr;289(4):765–70. doi: 10.1007/s00404-013-3054-y. PMID: 24129610. Exclusion: quality rating is poor.24129610
144 Di Mascio D, Magro-Malosso ER, Saccone G, . Exercise during pregnancy in normal-weight women and risk of preterm birth: a systematic review and meta-analysis of randomized controlled trials. Am J Obstet Gynecol. 2016 Nov;215(5):561–71. doi: 10.1016/j.ajog.2016.06.014. PMID: 27319364. Exclusion: systematic review or meta-analysis used only as a source document for pearling.27319364
145 Dieckmann WJ, Turner DF, . Diet regulation and controlled weight in pregnancy. Am J Obstet Gynecol. 1945 Dec;50:701–12. doi: 10.1016/0002-9378(45)90045-7. PMID: 21007069. Exclusion: wrong publication type.21007069
146 Diemert A, Goletzke J, Barkmann C, . Maternal progesterone levels are modulated by maternal BMI and predict birth weight sex-specifically in human pregnancies. J Reprod Immunol. 2017 Jun;121:49–55. doi: 10.1016/j.jri.2017.05.005. PMID: 28641119. Exclusion: wrong intervention.28641119
147 Diemert A, Lezius S, Pagenkemper M, . Maternal nutrition, inadequate gestational weight gain and birth weight: results from a prospective birth cohort. BMC Pregnancy Childbirth. 2016 Aug 15;16(224) doi: 10.1186/s12884-016-1012-y. PMID: 27528213. Exclusion: wrong intervention.27528213
148 Dodd JM. Dietary and lifestyle advice for pregnant women who are overweight or obese: the LIMIT randomized trial. Ann Nutr Metab. 2014;64(3–4):197–202. doi: 10.1159/000365018. PMID: 25300260. Exclusion: wrong publication type.25300260
149 Dodd JM. Pregnancy: managing obesity during pregnancy-what are the options? Nat Rev Endocrinol. 2015 Dec;11(12):691–2. doi: 10.1038/nrendo.2015.141. PMID: 26284450. Exclusion: wrong publication type.26284450
150 Dodd JM, Ahmed S, Karnon J, . The cost-effectiveness of providing antenatal lifestyle advice for women who are overweight or obese: the LIMIT randomised trial. BMC Obes. 2015;2:14. doi: 10.1186/s40608-015-0046-4. PMID: 26217529. Exclusion: companion paper with outdated data, data not used for evidence.26217529
151 Dodd JM, Cramp C, Sui Z, . The effects of antenatal dietary and lifestyle advice for women who are overweight or obese on maternal diet and physical activity: the LIMIT randomised trial. BMC Med. 2014 Oct 13;12:161. doi: 10.1186/s12916-014-0161-y. PMID: 25315237. Exclusion: wrong outcome.25315237
152 Dodd JM, Crowther CA, Robinson JS. Dietary and lifestyle interventions to limit weight gain during pregnancy for obese or overweight women: a systematic review. Acta Obstet Gynecol Scand. 2008;87(7):702–6. doi: 10.1080/00016340802061111. PMID: 18607830. Exclusion: systematic review or meta-analysis used only as a source document for pearling.18607830
153 Dodd JM, Deussen AR, Louise J. Optimising gestational weight gain and improving maternal and infant health outcomes through antenatal dietary, lifestyle and physical activity advice: the OPTIMISE randomised controlled trial protocol. BMJ Open. 2018 Feb 20;8(2):e019583. doi: 10.1136/bmjopen-2017-019583. PMID: 29463591. Exclusion: wrong publication type.29463591
154 Dodd JM, Deussen AR, Mohamad I, . The effect of antenatal lifestyle advice for women who are overweight or obese on secondary measures of neonatal body composition: the LIMIT randomised trial. BJOG. 2016 Jan;123(2):244–53. doi: 10.1111/1471-0528.13796. PMID: 26841217. Exclusion: companion paper with outdated data, data not used for evidence.26841217
155 Dodd JM, Deussen AR, O’Brien CM, . Targeting the postpartum period to promote weight loss: a systematic review and meta-analysis. Nutr Rev. 2018 Aug 01;76(8):639–54. doi: 10.1093/nutrit/nuy024. PMID: 29889259. Exclusion: wrong publication type.29889259
156 Dodd JM, Grivell RM, Crowther CA, . Antenatal interventions for overweight or obese pregnant women: a systematic review of randomised trials. BJOG. 2010 Oct;117(11):1316–26. doi: 10.1111/j.1471-0528.2010.02540.x. PMID: 20353459. Exclusion: systematic review or meta-analysis used only as a source document for pearling.20353459
157 Dodd JM, Grivell RM, Louise J, . The effects of dietary and lifestyle interventions among pregnant women who are overweight or obese on longer-term maternal and early childhood outcomes: protocol for an individual participant data (IPD) meta-analysis. Syst Rev. 2017 Mar 09;6(1):51. doi: 10.1186/s13643-017-0442-6. PMID: 28274270. Exclusion: wrong publication type.28274270
158 Dodd JM, Grivell RM, Owens JA. Antenatal dietary and lifestyle interventions for women who are overweight or obese: outcomes from the LIMIT randomized trial. Curr Nutr Rep. 2014;3(4):392–9. Exclusion: wrong publication type.
159 Dodd JM, Kannieappan LM, Grivell RM, . Effects of an antenatal dietary intervention on maternal anthropometric measures in pregnant women with obesity. Obesity (Silver Spring). 2015 Aug;23(8):1555–62. doi: 10.1002/oby.21145. PMID: 26175260. Exclusion: companion paper with outdated data, data not used for evidence.26175260
160 Dodd JM, Louise J, Cramp C, . Evaluation of a smartphone nutrition and physical activity application to provide lifestyle advice to pregnant women: the SNAPP randomised trial. Matern Child Nutr. 2018 Jan;14(1):01. doi: 10.1111/mcn.12502. PMID: 28836373. Exclusion: wrong outcome.28836373
161 Dodd JM, McPhee AJ, Turnbull D, . The effects of antenatal dietary and lifestyle advice for women who are overweight or obese on neonatal health outcomes: the LIMIT randomised trial. BMC Med. 2014 Oct 13;12:163. doi: 10.1186/s12916-014-0163-9. PMID: 25315325. Exclusion: wrong outcome.25315325
162 Dodd JM, Newman A, Moran LJ, . The effect of antenatal dietary and lifestyle advice for women who are overweight or obese on emotional well-being: the LIMIT randomized trial. Acta Obstet Gynecol Scand. 2016 Mar;95(3):309–18. doi: 10.1111/aogs.12832. PMID: 26618547. Exclusion: companion paper with outdated data, data not used for evidence.26618547
163 Dodd JM, O’Brien CM, Grivell RM. Modifying diet and physical activity to support pregnant women who are overweight or obese. Curr Opin Clin Nutr Metab Care. 2015 May;18(3):318–23. doi: 10.1097/MCO.0000000000000170. PMID: 25807350. Exclusion: wrong publication type.25807350
164 Dodd JM, Turnbull DA, McPhee AJ, . Limiting weight gain in overweight and obese women during pregnancy to improve health outcomes: the LIMIT randomised controlled trial. BMC Pregnancy Childbirth. 2011 Oct 26;11(79) doi: 10.1186/1471-2393-11-79. PMID: 22026403. Exclusion: wrong publication type.22026403
165 Domingues MR, Bassani DG, da Silva SG, . Physical activity during pregnancy and maternal-child health (PAMELA): study protocol for a randomized controlled trial. Trials. 2015 May 24;16(227) doi: 10.1186/s13063-015-0749-3. PMID: 26003406. Exclusion: wrong publication type.26003406
166 Donazar-Ezcurra M, Lopez-Del Burgo C, Bes-Rastrollo M. Primary prevention of gestational diabetes mellitus through nutritional factors: a systematic review. BMC Pregnancy Childbirth. 2017 Jan 13;17(1):30. doi: 10.1186/s12884-016-1205-4. PMID: 28086820. Exclusion: wrong publication type.28086820
167 Donazar-Ezcurra M, Lopez-Del Burgo C, Martinez-Gonzalez MA, . Pre-pregnancy adherences to empirically derived dietary patterns and gestational diabetes risk in a Mediterranean cohort: the Seguimiento Universidad de Navarra (SUN) project. Br J Nutr. 2017 Nov;118(9):715–21. doi: 10.1017/S0007114517002537. PMID: 28974271. Exclusion: wrong intervention.28974271
168 Donnelly JM, Walsh JM, Byrne J, . Impact of maternal diet on neonatal anthropometry: a randomized controlled trial. Pediatr Obes. 2015 Feb;10(1):52–6. doi: 10.1111/j.2047-6310.2013.00216.x. PMID: 24443392. Exclusion: wrong outcome.24443392
169 Dorise B, Byth K, McGee T, . A low intensity dietary intervention for reducing excessive gestational weight gain in an overweight and obese pregnant cohort. Eat Weight Disord. 2018 Aug 28;25(2):257–63. doi: 10.1007/s40519-018-0566-2. PMID: 30155856. Exclusion: wrong study design.30155856
170 Downs DS, Devlin CA, Rhodes RE. The power of believing: salient belief predictors of exercise behavior in normal weight, overweight, and obese pregnant women. J Phys Act Health. 2015 Aug;12(8):1168–76. doi: 10.1123/jpah.2014-0262. PMID: 25409425. Exclusion: wrong study design.25409425
171 Downs DS, Feinberg M, Hillemeier MM, . Design of the Central Pennsylvania Women’s Health Study (CePAWHS) strong healthy women intervention: improving preconceptional health. Matern Child Health J. 2009 Jan;13(1):18–28. doi: 10.1007/s10995-008-0323-7. PMID: 18270808. Exclusion: wrong publication type.18270808
172 Du MC, Ouyang YQ, Nie XF, . Effects of physical exercise during pregnancy on maternal and infant outcomes in overweight and obese pregnant women: a meta-analysis. Birth. 2019 Jun;46(2):211–21. doi: 10.1111/birt.12396. PMID: 30240042. Exclusion: systematic review or meta-analysis used only as a source document for pearling.30240042
173 Dubois L, Girard M. Determinants of birthweight inequalities: population-based study. Pediatr Int. 2006 Oct;48(5):470–8. doi: 10.1111/j.1442-200X.2006.02256.x PMID: 16970785. Exclusion: wrong study design.16970785
174 Dye TD, Knox KL, Artal R, . Physical activity, obesity, and diabetes in pregnancy. Am J Epidemiol. 1997 Dec 1;146(11):961–5. doi: 10.1093/oxfordjournals.aje.a009223. PMID: 9400338. Exclusion: wrong comparator.9400338
175 Egan AM, Simmons D. Lessons learned from lifestyle prevention trials in gestational diabetes mellitus. Diabet Med. 2019 Feb;36(2):142–50. doi: 10.1111/dme.13772. PMID: 29939439. Exclusion: wrong publication type.29939439
176 Einerson BD, Huffman JK, Istwan NB, . New gestational weight gain guidelines: an observational study of pregnancy outcomes in obese women. Obesity (Silver Spring). 2011 Dec;19(12):2361–4. doi: 10.1038/oby.2011.67. PMID: 21455124. Exclusion: wrong study design.21455124
177 Ekstrom S, Magnusson J, Kull I, . Maternal body mass index in early pregnancy and offspring asthma, rhinitis and eczema up to 16 years of age. Clin Exp Allergy. 2015 Jan;45(1):283–91. doi: 10.1111/cea.12340. PMID: 24807420. Exclusion: wrong population.24807420
178 Elliott-Sale KJ, Barnett CT, Sale C. Systematic review of randomised controlled trials on exercise interventions for weight management during pregnancy and up to one year postpartum among normal weight, overweight and obese women. Pregnancy Hypertens. 2014 Jul;4(3):234. doi: 10.1016/j.preghy.2014.03.015. PMID: 26104620. Exclusion: wrong publication type.26104620
179 Elliott-Sale KJ, Barnett CT, Sale C. Exercise interventions for weight management during pregnancy and up to 1 year postpartum among normal weight, overweight and obese women: a systematic review and meta-analysis. Br J Sports Med. 2015 Oct;49(20):1336–42. doi: 10.1136/bjsports-2014-093875. PMID: 25406335. Exclusion: systematic review or meta-analysis used only as a source document for pearling.25406335
180 Emond JA, Karagas MR, Baker ER, . Better diet quality during pregnancy is associated with a reduced likelihood of an infant born small for gestational age: an analysis of the prospective New Hampshire Birth Cohort Study. J Nutr. 2018 Jan 01;148(1):22–30. doi: 10.1093/jn/nxx005. PMID: 29378041. Exclusion: wrong study design.29378041
181 Endres LK, Straub H, McKinney C, . Postpartum weight retention risk factors and relationship to obesity at 1 year. Obstet Gynecol. 2015 Jan;125(1):144–52. doi: 10.1097/AOG.0000000000000565. PMID: 25560116. Exclusion: wrong population.25560116
182 Engberg E, Stach-Lempinen B, Rono K, . A randomized lifestyle intervention preventing gestational diabetes: effects on self-rated health from pregnancy to postpartum. J Psychosom Obstet Gynaecol. 2018 Mar;39(1):1–6. doi: 10.1080/0167482X.2017.1286642. PMID: 28635526. Exclusion: wrong outcome.28635526
183 Ershoff DH, Aaronson NK, Danaher BG, . Behavioral, health, and cost outcomes of an HMO-based prenatal health education program. Public Health Rep. 1983 Nov–Dec;98(6):536–47. PMID: 6419268. Exclusion: wrong outcome.6419268
184 Evenson KR, Moos MK, Carrier K, . Perceived barriers to physical activity among pregnant women. Matern Child Health J. 2009 May;13(3):364–75. doi: 10.1007/s10995-008-0359-8. PMID: 18478322. Exclusion: wrong outcome.18478322
185 Fahey MC, Wayne Talcott G, Cox Bauer CM, . Moms fit 2 fight: rationale, design, and analysis plan of a behavioral weight management intervention for pregnant and postpartum women in the U.S. military. Contemp Clin Trials. 2018 Nov 01;74:46–54. doi: 10.1016/j.cct.2018.09.012. PMID: 30291998 Exclusion: wrong publication type.30291998
186 Faleschini S, Millar L, Rifas-Shiman SL, . Women’s perceived social support: associations with postpartum weight retention, health behaviors and depressive symptoms. BMC Womens Health. 2019 Nov 21;19(1):143. doi: 10.1186/s12905-019-0839-6. PMID: 31752823. Exclusion: wrong population.31752823
187 Faucher MA, Barger MK. Gestational weight gain in obese women by class of obesity and select maternal/newborn outcomes: a systematic review. Women Birth. 2015 Sep;28(3):e70–e9. doi: 10.1016/j.wombi.2015.03.006. PMID: 25866207. Exclusion: systematic review or meta-analysis used only as a source document for pearling.25866207
188 Fealy SM, Taylor RM, Foureur M, . Weighing as a stand-alone intervention does not reduce excessive gestational weight gain compared to routine antenatal care: a systematic review and meta-analysis of randomised controlled trials. BMC Pregnancy Childbirth. 2017 Jan 17;17(1):36. doi: 10.1186/s12884-016-1207-2. PMID: 28095821. Exclusion: systematic review or meta-analysis used only as a source document for pearling.28095821
189 Fernandez ID, Groth SW, Reschke JE, . eMoms: electronically-mediated weight interventions for pregnant and postpartum women. Study design and baseline characteristics. Contemp Clin Trials. 2015 Jul;43:63–74. doi: 10.1016/j.cct.2015.04.013. PMID: 25957183. Exclusion: wrong publication type.25957183
190 Ferrari RM, Siega-Riz AM. Provider advice about pregnancy weight gain and adequacy of weight gain. Matern Child Health J. 2013 Feb;17(2):256–64. doi: 10.1007/s10995-012-0969-z. PMID: 22362261. Exclusion: wrong study design.22362261
191 Fieril DP, Olsen PF, Glantz D, . Experiences of a lifestyle intervention in obese pregnant women - a qualitative study. Midwifery. 2017 Jan;44:1–6. doi: 10.1016/j.midw.2016.10.011. PMID: 27863294. Exclusion: wrong outcome.27863294
192 Flannery C, Fredrix M, Olander EK, . Effectiveness of physical activity interventions for overweight and obesity during pregnancy: a systematic review of the content of behaviour change interventions. Int J Behav Nutr Phys Act. 2019 Nov 01;16(1):97. doi: 10.1186/s12966-019-0859-5. PMID: 31675954. Exclusion: wrong outcome.31675954
193 Flynn A, Poston L, Goff L. The UK Pregnancies Better Eating and Activity Trial (UPBEAT) intervention in women with obesity; nutritional responses according to ethnic and BMI sub-groups. BJOG. Conference: 19th annual conference of the british maternal and fetal medicine society, BMFMS. 2017;124(98). Exclusion: wrong publication type.
194 Flynn AC, Dalrymple K, Barr S, . Dietary interventions in overweight and obese pregnant women: a systematic review of the content, delivery, and outcomes of randomized controlled trials. Nutr Rev. 2016 May;74(5):312–28. doi: 10.1093/nutrit/nuw005. PMID: 27083868. Exclusion: systematic review or meta-analysis used only as a source document for pearling.27083868
195 Flynn AC, Schneeberger C, Seed PT, . The effects of the UK Pregnancies Better Eating and Activity Trial intervention on dietary patterns in obese pregnant women participating in a pilot randomized controlled trial. Nutr Metab Insights. 2015;8:(Suppl 1):79–86. doi: 10.4137/NMI.S29529. PMID: 27385914. Exclusion: companion paper with outdated data, data not used for evidence.27385914
196 Flynn AC, Seed PT, Patel N, . Dietary patterns in obese pregnant women; influence of a behavioral intervention of diet and physical activity in the UPBEAT randomized controlled trial. Int J Behav Nutr Phys Act. 2016 Nov 29;13(1):124. doi: 10.1186/s12966-016-0450-2. PMID: 27894316. Exclusion: companion paper with outdated data, data not used for evidence.27894316
197 Forbes LA, Jones R, Strickland D, . 118: influence of maternal aerobic exercise on fetal right-sided heart function: a randomized controlled trial. Am J Obstet Gynecol. 2019;220(1):S94-. Exclusion: wrong outcome.
198 Forno E, Young OM, Kumar R, . Maternal obesity in pregnancy, gestational weight gain, and risk of childhood asthma. Pediatrics. 2014 Aug;134(2):e535–46. doi: 10.1542/peds.2014-0439. PMID: 25049351. Exclusion: wrong publication type.25049351
199 Forsum E, Brantsaeter AL, Olafsdottir A-S, . Weight loss before conception: a systematic literature review. Food Nutr Res. 2013;57doi: 10.3402/fnr.v57i0.20522. PMID: 23503117. Exclusion: systematic review or meta-analysis used only as a source document for pearling.23503117
200 Gaillard R, Durmus B, Hofman A, . OS021. Risk factors and outcomes of maternal obesity and excessive weight gain during pregnancy. Pregnancy Hypertens. 2012 Jul;2(3):186. doi: 10.1016/j.preghy.2012.04.022. PMID: 26105235. Exclusion: wrong publication type.26105235
201 Gardner B, Wardle J, Poston L, . Changing diet and physical activity to reduce gestational weight gain: a meta-analysis. Obes Rev. 2011 Jul;12(7):e602–20. doi: 10.1111/j.1467-789X.2011.00884.x. PMID: 21521451. Exclusion: systematic review or meta-analysis used only as a source document for pearling.21521451
202 Garmendia ML, Corvalan C, Araya M, . Effectiveness of a normative nutrition intervention (diet, physical activity and breastfeeding) on maternal nutrition and offspring growth: the Chilean Maternal and Infant Nutrition Cohort study (CHiMINCs). BMC Pregnancy Childbirth. 2015 Aug 18;15(175) doi: 10.1186/s12884-015-0605-1. PMID: 26283529. Exclusion: wrong publication type.26283529
203 Garmendia ML, Corvalan C, Casanello P, . Effectiveness on maternal and offspring metabolic control of a home-based dietary counseling intervention and DHA supplementation in obese/overweight pregnant women (MIGHT study): a randomized controlled trial-study protocol. Contemp Clin Trials. 2018 Jul;70:35–40. doi: 10.1016/j.cct.2018.05.007. PMID: 29777864. Exclusion: wrong intervention.29777864
204 Gazquez A, Uhl O, Ruiz-Palacios M, . Placental lipid droplet composition: effect of a lifestyle intervention (UPBEAT) in obese pregnant women. Biochim Biophys Acta. 2018 Sep;1863(9):998–1005. doi: 10.1016/j.bbalip.2018.04.020. PMID: 29702246. Exclusion: wrong outcome.29702246
205 Germeroth LJ, Benno MT, Kolko Conlon RP, . Trial design and methodology for a non-restricted sequential multiple assignment randomized trial to evaluate combinations of perinatal interventions to optimize women’s health. Contemp Clin Trials. 2019 Apr;79:111–21. doi: 10.1016/j.cct.2019.03.002. PMID: 30851434. Exclusion: wrong publication type.30851434
206 Gerome JM, Bucher LKM, Dogbey G. Effects of implementing international association of diabetes and pregnancy study groups gestational diabetes screening on pregnancy outcomes at a small community teaching hospital. Clin Diabetes. 2017 Apr;35(2):84–9. doi: 10.2337/cd16-0031. PMID: 28442822. Exclusion: wrong study design.28442822
207 Godfrey KM, Cutfield W, Chan SY, . Nutritional intervention preconception and during pregnancy to maintain healthy glucose metabolism and offspring health (“NiPPeR”): study protocol for a randomised controlled trial. Trials. 2017 Mar 20;18(1):131. doi: 10.1186/s13063-017-1875-x. PMID: 28320484. Exclusion: wrong intervention.28320484
208 Goletzke J, Buyken AE, Louie JC, . Dietary micronutrient intake during pregnancy is a function of carbohydrate quality. Am J Clin Nutr. 2015 Sep;102(3):626–32. doi: 10.3945/ajcn.114.104836. PMID: 26178724. Exclusion: wrong population.26178724
209 Goodman MH, Thomson JL, Tussing-Humphreys LM. Diet quality of a pregnant primarily African American cohort residing in the mississippi delta: delta healthy sprouts. FASEB J. Conference: experimental biology. 2016;30. Exclusion: wrong outcome.
210 Gosselink CA, Ekwo EE, Woolson RF, . Dietary habits, prepregnancy weight, and weight gain during pregnancy. Risk of pre term rupture of amniotic sac membranes. Acta Obstet Gynecol Scand. 1992 Aug;71(6):425–38. doi: 10.3109/00016349209021091. PMID: 1326841. Exclusion: wrong study design.1326841
211 Graham ML, Strawderman MS, Demment M, . Does usage of an eHealth intervention reduce the risk of excessive gestational weight gain? Secondary analysis from a randomized controlled trial. J Med Internet Res. 2017 Jan 09;19(1):e6. doi: 10.2196/jmir.6644. PMID: 28069560. Exclusion: companion paper with outdated data, data not used for evidence.28069560
212 Graham ML, Uesugi KH, Niederdeppe J, . The theory, development, and implementation of an e-intervention to prevent excessive gestational weight gain: e-Moms Roc. Telemed J E Health. 2014 Dec;20(12):1135–42. doi: 10.1089/tmj.2013.0354. PMID: 25354350. Exclusion: wrong outcome.25354350
213 Greene EM, Ainscough KM, Kennelly MA, . Do pregnant women with overweight and obesity find a nutrition and exercise intervention with smartphone app support acceptable? Findings from the PEARs randomised control trial. BJOG. 2018;Conference: 20th annual conference of the british maternal and fetal medicine society, BMFMS. 2018. United kingdom 125(Supplement 2):74–5. Exclusion: wrong publication type.28678394
214 Gregory EF, Goldshore MA, Henderson JL, . Infant growth following maternal participation in a gestational weight management intervention. Child Obes. 2016 Jun;12(3):219–25. doi: 10.1089/chi.2015.0238. PMID: 27123956. Exclusion: wrong study design.27123956
215 Gregory EF, Goldshore MA, Showell NN, . Parent and clinician perspectives on sustained behavior change after a prenatal obesity program: a qualitative study. Child Obes. 2017 Apr;13(2):85–92. doi: 10.1089/chi.2016.0149. PMID: 27854496. Exclusion: wrong study design.27854496
216 Gresham E, Byles JE, Bisquera A, . Effects of dietary interventions on neonatal and infant outcomes: a systematic review and meta-analysis. Am J Clin Nutr. 2014 Nov;100(5):1298–321. doi: 10.3945/ajcn.113.080655. PMID: 25332328. Exclusion: systematic review or meta-analysis used only as a source document for pearling.25332328
217 Grivell RM, Yelland LN, Deussen A, . Antenatal dietary and lifestyle advice for women who are overweight or obese and the effect on fetal growth and adiposity: the LIMIT randomised trial. BJOG. 2016 Jan;123(2):233–43. doi: 10.1111/1471-0528.13777. PMID: 26841216. Exclusion: wrong outcome.26841216
218 Gross SM, Augustyn M, Henderson JL, . Integrating obstetrical care and WIC nutritional services to address maternal obesity and postpartum weight retention. Maternal and Child Health Journal. 2018 Jun;22(6):794–802. doi: 10.1007/s10995-018-2449-6. PMID: 29417365. Exclusion: wrong population.29417365
219 Gudnadottir TA, Bateman BT, Hernadez-Diaz S, . Body mass index, smoking and hypertensive disorders during pregnancy: a population based case-control study. PLoS ONE. 2016;11(3):e0152187. doi: 10.1371/journal.pone.0152187. PMID: 27010734. Exclusion: wrong intervention.27010734
220 Guelinckx I, Devlieger R, Mullie P, . Effect of lifestyle intervention on dietary habits, physical activity, and gestational weight gain in obese pregnant women: a randomized controlled trial. Am J Clin Nutr. 2010 Feb;91(2):373–80. doi: 10.3945/ajcn.2009.28166. PMID: 19955397. Exclusion: quality rating is poor.19955397
221 Guendelman S, Pearl M, Kosa JL, . Association between preterm delivery and pre-pregnancy body mass (BMI), exercise and sleep during pregnancy among working women in Southern California. Matern Child Health J. 2013 May;17(4):723–31. doi: 10.1007/s10995-012-1052-5. PMID: 22782493. Exclusion: wrong outcome.22782493
222 Guilloty NI, Soto R, Anzalota L, . Diet, pre-pregnancy BMI, and gestational weight gain in Puerto Rican women. Matern Child Health J. 2015 Nov;19(11):2453–61. doi: 10.1007/s10995-015-1764-4. PMID: 26100133. Exclusion: wrong study design.26100133
223 Gunderson EP, Murtaugh MA, Lewis CE, . Excess gains in weight and waist circumference associated with childbearing: the Coronary Artery Risk Development in Young Adults Study (CARDIA). Int J Obes Relat Metab Disord. 2004 Apr;28(4):525–35. doi: 10.1038/sj.ijo.0802551. PMID: 14770188. Exclusion: wrong study design.14770188
224 Gunther J, Hoffmann J, Kunath J, . Effects of a Lifestyle Intervention in Routine Care on Prenatal Dietary Behavior-Findings from the Cluster-Randomized GeliS Trial. J Clin Med. 2019 Jul 02;8(7):02. doi: 10.3390/jcm8070960. PMID: 31269753. Exclusion: wrong outcome.31269753
225 Guo XY, Shu J, Fu XH, . Improving the effectiveness of lifestyle interventions for gestational diabetes prevention: a meta-analysis and meta-regression. BJOG. 2019 Feb;126(3):311–20. doi: 10.1111/1471-0528.15467. PMID: 30216635. Exclusion: systematic review or meta-analysis used only as a source document for pearling.30216635
226 Ha V, Bonner AJ, Jadoo JK, . The effects of various diets on glycemic outcomes during pregnancy: a systematic review and network meta-analysis. PLoS ONE. 2017;12(8):e0182095. doi: 10.1371/journal.pone.0182095. PMID: 28771519. Exclusion: systematic review or meta-analysis used only as a source document for pearling.28771519
227 Haakstad LAH, Kissel I, Bo K. Long-term effects of participation in a prenatal exercise intervention on body weight, body mass index, and physical activity level: a 6-year follow-up study of a randomized controlled trial. J Matern Fetal Neonatal Med. 2019 Jul 21:1–9. doi: 10.1080/14767058.2019.1636028. PMID: 31327292. Exclusion: wrong outcome.31327292
228 Haby K, Berg M, Gyllensten H, . Mighty Mums - a lifestyle intervention at primary care level reduces gestational weight gain in women with obesity. BMC Obes. 2018 Jun 4;5(16) doi: 10.1186/s40608-018-0194-4. PMID: 29881627. Exclusion: quality rating is poor.29881627
229 Haby K, Glantz A, Hanas R, . Mighty Mums - an antenatal health care intervention can reduce gestational weight gain in women with obesity. Midwifery. 2015 Jul;31(7):685–92. doi: 10.1016/j.midw.2015.03.014. PMID: 25912510. Exclusion: companion paper with outdated data, data not used for evidence. - Haby-201825912510
230 Hackley B, Kennedy HP, Berry DC, . A mixed-methods study on factors influencing prenatal weight gain in ethnic-minority women. J Midwifery Womens Health. 2014 Jul–Aug;59(4):388–98. doi: 10.1111/jmwh.12170. PMID: 24986225. Exclusion: wrong study design.24986225
231 Halkjaer SI, Nilas L, Carlsen EM, . Effects of probiotics (Vivomixx) in obese pregnant women and their newborn: study protocol for a randomized controlled trial. Trials. 2016 Oct 11;17(1):491. PMID: 27724923. Exclusion: wrong intervention.27724923
232 Hall DC, Kaufmann DA. Effects of aerobic and strength conditioning on pregnancy outcomes. Am J Obstet Gynecol. 1987 Nov;157(5):1199–203. PMID: 3688075. Exclusion: wrong outcome.3688075
233 Han S, Middleton PF, Crowther CA. 4 month follow-up study of weight and body composition for women after receiving lifestyle advice for treatment of borderline gestational diabetes. J Paediatr Child Health. 2015;51(38). Exclusion: wrong publication type.
234 Han S, Middleton PF, Tran T, . A printed lifestyle intervention tool for women with borderline gestational diabetes: assessing use and achievement of dietary goals set. J Paediatr Child Health. 2015;51(106). Exclusion: wrong intervention.
235 Hannon TS, Carroll AE, Palmer KN, . Rationale and design of a comparative effectiveness trial to prevent type 2 diabetes in mothers and children: the ENCOURAGE healthy families study. Contemp Clin Trials. 2015 Jan;40:105–11. doi: 10.1016/j.cct.2014.11.016. PMID: 25457793. Exclusion: wrong population.25457793
236 Hanson J, Knowlton J, May L. The influence of maternal exercise on fetal growth. Pm R. START: 2014 Nov 13 CONFERENCE END: 2014 Nov 16, 2014 Annual Assembly of the American Academy of Physical Medicine and Rehabilitation San Diego, CA United States;6(9 SUPPL. 1):S188. Exclusion: wrong publication type.
237 Harrison CL, Lombard CB, Gibson-Helm M, . Limiting excess weight gain in high-risk pregnancies: a randomized controlled trial. Endocr Rev. Annual Meeting and Expo of the Endocrine Society, ENDO 2011 Boston, MA United States;32(3 Meeting Abstracts):CONFERENCE START: 2011 Jun 4 CONFERENCE END: Jun 7. Exclusion: wrong publication type.
238 Harrison CL, Teede HJ, Lombard CB. How effective is self-weighing in the setting of a lifestyle intervention to reduce gestational weight gain and postpartum weight retention? Aust N Z J Obstet Gynaecol. 2014 Aug;54(4):382–5. doi: 10.1111/ajo.12207. PMID: 24738837. Exclusion: wrong study design.24738837
239 Haruna M, Shiraishi M, Matsuzaki M, . Effect of tailored dietary guidance for pregnant women on nutritional status: a double-cohort study. Matern Child Nutr. 2017 Oct;13(4) doi: 10.1111/mcn.12391. PMID: 27896937. Exclusion: wrong intervention.27896937
240 Hawkins M, Braun B, Marcus BH, . The impact of an exercise intervention on C - reactive protein during pregnancy: a randomized controlled trial. BMC Pregnancy Childbirth. 2015 Jun 24;15:139. doi: 10.1186/s12884-015-0576-2. PMID: 26104503. Exclusion: wrong outcome.26104503
241 Hayes L, Bell R, Robson S, . Association between physical activity in obese pregnant women and pregnancy outcomes: the UPBEAT pilot study. Ann Nutr Metab. 2014;64(3–4):239–46. doi: 10.1159/000365027. PMID: 25300266. Exclusion: wrong outcome.25300266
242 Hayes L, Bell R, Robson S, . Association between physical activity in obese pregnant women and offspring health. Pregnancy Hypertens. 2014 Jul;4(3):234. doi: 10.1016/j.preghy.2014.03.016. PMID: 26104621. Exclusion: wrong publication type.26104621
243 Hayes L, Kinnunen T, Robson S, . Factors associated with level of physical activity in obese pregnant women participating in the upbeat pilot trial. Arch Dis Child Fetal Neonatal Ed. 2012;97(19). Exclusion: wrong outcome.
244 Hayes L, McParlin C, Kinnunen TI, . Change in level of physical activity during pregnancy in obese women: findings from the UPBEAT pilot trial. BMC Pregnancy Childbirth. 2015 Mar 01;15:52. doi: 10.1186/s12884-015-0479-2. PMID: 25886590. Exclusion: wrong study design.25886590
245 Hayman M, Reaburn P, Browne M, . Feasibility, acceptability and efficacy of a web-based computer-tailored physical activity intervention for pregnant women - the Fit4Two randomised controlled trial. BMC Pregnancy Childbirth. 2017 Mar 23;17(1):96. doi: 10.1186/s12884-017-1277-9. PMID: 28335767. Exclusion: wrong outcome.28335767
246 Henriksson P, Sandborg J, Blomberg M, . A smartphone app to promote healthy weight gain, diet, and physical activity during pregnancy (HealthyMoms): protocol for a randomized controlled trial. JMIR Res Protoc. 2019 Mar 01;8(3):e13011. doi: 10.2196/13011. PMID: 30821695. Exclusion: wrong publication type.30821695
247 Herrera-Perdigon J, Hopkins E, Marcalle M, . Weight gain in high-risk pregnant women: comparison by primary diagnosis and type of care. Clin Excell Nurse Pract. 2005 Dec;9(4):195–201. PMID: 24391405. Exclusion: wrong study design.24391405
248 Herring SJ, Albert JJ, Darden N, . Targeting pregnancy-related weight gain to reduce disparities in obesity: baseline results from the healthy babies trial. Contemp Clin Trials. 2019 Aug 07:105822. doi: 10.1016/j.cct.2019.105822. PMID: 31400513. Exclusion: wrong outcome.31400513
249 Heslehurst N, Crowe L, Robalino S, . Interventions to change maternity healthcare professionals’ behaviours to promote weight-related support for obese pregnant women: a systematic review. Implement Sci. 2014 Aug 5;9(97) doi: 10.1186/s13012-014-0097-9. PMID: 25091032. Exclusion: systematic review or meta-analysis used only as a source document for pearling.25091032
250 Heslehurst N, Rankin J, McParlin C, . GestationaL Obesity Weight management: Implementation of National Guidelines (GLOWING): a pilot cluster randomised controlled trial of a guideline implementation intervention for the management of maternal obesity by midwives. Pilot feasibility stud. 2018;4:47. doi: 10.1186/s40814-018-0241-4. PMID: 29456871. Exclusion: wrong publication type.29456871
251 Hill B, Skouteris H, Fuller-Tyszkiewicz M. Interventions designed to limit gestational weight gain: a systematic review of theory and meta-analysis of intervention components. Obes Rev. 2013 Jun;14(6):435–50. doi: 10.1111/obr.12022. PMID: 23534901. Exclusion: systematic review or meta-analysis used only as a source document for pearling.23534901
252 Hill B, Skouteris H, Fuller-Tyszkiewicz M, . Can a health coaching intervention delivered during pregnancy help prevent excessive gestational weight gain? J Behav Med. 2016 Oct;39(5):793–803. doi: 10.1007/s10865-016-9743-9. PMID: 27108159. Exclusion: wrong study design.27108159
253 Hillesund ER, Bere E, Haugen M, . Development of a New Nordic Diet score and its association with gestational weight gain and fetal growth - a study performed in the Norwegian Mother and Child Cohort Study (MoBa). Public Health Nutr. 2014 Sep;17(9):1909–18. doi: 10.1017/S1368980014000421. PMID: 24685309. Exclusion: wrong outcome.24685309
254 Hillesund ER, Bere E, Sagedal LR, . Pre-pregnancy and early pregnancy dietary behavior in relation to maternal and newborn health in the norwegian fit for delivery study - a post hoc observational analysis. Food Nutr Res. 2018 Aug 08;62doi: 10.29219/fnr.v62.1273. PMID: 30108471. Exclusion: wrong intervention.30108471
255 Hoirisch-Clapauch S, Sant’Anna MCW, Moreira ECC, . A protocol combining daily walking and a lowglycemic index diet increases the rate of take-home babies in women with consecutive first-trimester miscarriages. BJOG. Conference: RCOG World Congress. 2016;123:74–5. Exclusion: wrong publication type.
256 Hopkins SA, Baldi JC, Cutfield WS, . Exercise training in pregnancy reduces offspring size without changes in maternal insulin sensitivity. J Clin Endocrinol Metab. 2010 May;95(5):2080–8. doi: 10.1210/jc.2009-2255. PMID: 20335449. Exclusion: wrong outcome.20335449
257 Hopkins SA, Baldi JC, Cutfield WS, . Effects of exercise training on maternal hormonal changes in pregnancy. Clin Endocrinol (Oxf). 2011 Apr;74(4):495–500. doi: 10.1111/j.1365-2265.2010.03964.x. PMID: 21198740. Exclusion: wrong intervention.21198740
258 Hoppu U, Isolauri E, Koskinen P, . Maternal dietary counseling reduces total and LDL cholesterol postpartum. Nutrition. 2014 Feb;30(2):159–64. doi: 10.1016/j.nut.2013.07.009. PMID: 24176529. Exclusion: wrong outcome.24176529
259 Horan MK, Donnelly JM, McGowan CA, . The association between maternal nutrition and lifestyle during pregnancy and 2-year-old offspring adiposity: analysis from the ROLO study. Journal of Public Health. 2016;24(5):427–36. PMID: 27695668. Exclusion: wrong outcome.27695668
260 Horan MK, McGowan CA, Donnelly J, . Maternal diet and weight at 3 months partum following a pregnancy intervention with a low glycaemic index diet: results from the ROLO randomised control trial. Arch Dis Child Fetal Neonatal Ed. 2014 Jun;99(9). Exclusion: wrong outcome.
261 Horan MK, McGowan CA, Doyle O, . Well-being in pregnancy: an examination of the effect of socioeconomic, dietary and lifestyle factors including impact of a low glycaemic index dietary intervention. Eur J Clin Nutr. 2014 Jan;68(1):19–24. doi: 10.1038/ejcn.2013.212. PMID: 24169456. Exclusion: wrong study design.24169456
262 Horan MK, McGowan CA, Gibney ER, . Maternal nutrition and glycaemic index during pregnancy impacts on offspring adiposity at 6 months of age--analysis from the ROLO randomised controlled trial. Nutrients. 2016 Jan 4;8(1) doi: 10.3390/nu8010007. PMID: 26742066. Exclusion: wrong outcome.26742066
263 Horan MK, McGowan CA, Gibney ER, . Maternal low glycaemic index diet, fat intake and postprandial glucose influences neonatal adiposity--secondary analysis from the ROLO study. Nutr J. 2014 Aug 01;13:78. doi: 10.1186/1475-2891-13-78. PMID: 25084967. Exclusion: wrong outcome.25084967
264 Horan MK, McGowan CA, Gibney ER, . Maternal diet and weight at 3 months postpartum following a pregnancy intervention with a low glycaemic index diet: results from the ROLO randomised control trial. Nutrients. 2014 Jul 23;6(7):2946–55. doi: 10.3390/nu6072946. PMID: 25057103. Exclusion: wrong outcome.25057103
265 Huang R-C, Silva D, Beilin L, . Feasibility of conducting an early pregnancy diet and lifestyle e-health intervention: the Pregnancy Lifestyle Activity Nutrition (PLAN) project. J Dev Orig Health Dis. 2019 Aug 08;11(1):1–13. doi: 10.1017/S2040174419000400. PMID: 31391133. Exclusion: inadequate sample size.31391133
266 Huang TT, Yeh CY, Tsai YC. A diet and physical activity intervention for preventing weight retention among Taiwanese childbearing women: a randomised controlled trial. Midwifery. 2011 Apr;27(2):257–64. doi: 10.1016/j.midw.2009.06.009. PMID: 19775782. Exclusion: wrong country.19775782
267 Hui A, Back L, Ludwig S, . Exercise and dietary intervention increases physical activity, promotes healthy diet and reduces excessive gestational weight gain in pregnant women: a randomized controlled trial in urban community. Diabetes. 2011;60(24). Exclusion: wrong publication type.
268 Hui AL, Back L, Reid A, . Effects of physical activity and dietary intakes on weight gain of pregnant women with normal and above normal prepregnancy weight. Can J Diabetes. START: 2012 Oct 10 CONFERENCE END: 2012 Oct 13, 15th Annual Canadian Diabetes Association/Canadian Society of Endocrinology and Metabolism Professional Conference and Annual Meetings Vancouver, BC Canada;36(5 SUPPL. 1):S8. Exclusion: wrong publication type.
269 Hui AL, Ludwig S, Gardiner P, . Exercise and dietary intervention during pregnancy results in reduced excessive gestational weight gain. 2010. Exclusion: wrong publication type.
270 Hui AL, Ludwig SM, Gardiner P, . Community-based exercise and dietary intervention during pregnancy: a pilot study. Can J Diabetes. 2006;30(2):169–75. doi: 10.1016/S1499-2671(06)02010-7. Exclusion: inadequate sample size.
271 Huvinen H, Koivusalo S, StachLempinen B, . Effects of a lifestyle intervention during pregnancy and 1-year postpartum -results from the RADIEL study. Gynecol Endocrinol. Conference: 17th world congress of gynaecological endocrinology, ISGE. 2016;32(161). Exclusion: wrong publication type.
272 Ickovics JR, Kershaw TS, Westdahl C, . Group prenatal care and perinatal outcomes: a randomized controlled trial.[Erratum appears in Obstet Gynecol. 2007 Oct;110(4):937]. Obstet Gynecol. 2007 Aug;110(2 Pt 1):330–9. PMID: 17666608. Exclusion: wrong intervention.17666608
273 Ilmonen J, Isolauri E, Poussa T, . Impact of dietary counselling and probiotic intervention on maternal anthropometric measurements during and after pregnancy: a randomized placebo-controlled trial. Clin Nutr. 2011 Apr;30(2):156–64. doi: 10.1016/j.clnu.2010.09.009. PMID: 20970896. Exclusion: quality rating is poor.20970896
274 Imdad A, Bhutta ZA. Effect of balanced protein energy supplementation during pregnancy on birth outcomes. BMC Public Health. 2011 Apr 13;11 Suppl 3:S17. doi: 10.1186/1471-2458-11-S3-S17. PMID: 21501434. Exclusion: wrong publication type.21501434
275 Jackson RA, Stotland NE, Caughey AB, . Improving diet and exercise in pregnancy with Video Doctor counseling: a randomized trial. Patient Educ Couns. 2011 May;83(2):203–9. doi: 10.1016/j.pec.2010.05.019. PMID: 21459255. Exclusion: wrong intervention.21459255
276 Jans G, Ameye L, Matthys C, . Does lifestyle coaching affect diet and physical activity stage of change scores in obese pregnant women? Pilot observations from the European DALI project. Obes Facts. 2014;7(132). Exclusion: wrong publication type.
277 Jeffries K, Shub A, Walker SP, . Reducing excessive weight gain in pregnancy: a randomised controlled trial. Med J Aust. 2009;191(8):429–33. PMID: 19835535. Exclusion: wrong intervention.19835535
278 Jelsma JG, van Poppel MN, Galjaard S, . DALI: vitamin D and lifestyle intervention for gestational diabetes mellitus (GDM) prevention: an European multicentre, randomised trial - study protocol. BMC Pregnancy Childbirth. 2013 Jul 05;13:142. doi: 10.1186/1471-2393-13-142. PMID: 23829946. Exclusion: wrong publication type.23829946
279 John E, Cassidy DM, Playle R, . Healthy Eating and Lifestyle in Pregnancy (HELP): a protocol for a cluster randomised trial to evaluate the effectiveness of a weight management intervention in pregnancy. BMC Public Health. 2014 May 10;14:439. doi: 10.1186/1471-2458-14-439. PMID: 24886352. Exclusion: wrong publication type.24886352
280 Johnson M, Campbell F, Messina J, . Weight management during pregnancy: a systematic review of qualitative evidence. Midwifery. 2013 Dec;29(12):1287–96. doi: 10.1016/j.midw.2012.11.016. PMID: 23434033. Exclusion: systematic review or meta-analysis used only as a source document for pearling.23434033
281 Kafatos AG, Vlachonikolis IG, Codrington CA. Nutrition during pregnancy: the effects of an educational intervention program in Greece. Am J Clin Nutr. 1989 Nov;50(5):970–9. doi: 10.1093/ajcn/50.5.970 PMID: 2816804. Exclusion: wrong intervention.2816804
282 Kannieappan LM, Deussen AR, Moran LJ, . The effect of antenatal dietary advice on maternal body composition in women who are overweight or obese - findings from the limit randomised trial. J Paediatr Child Health. 2013;49(94). Exclusion: wrong publication type.
283 Karsten MDA, van Oers AM, Groen H, . Determinants of successful lifestyle change during a 6-month preconception lifestyle intervention in women with obesity and infertility. Eur J Nutr. 2019 Sep;58(6):2463–75. doi: 10.1007/s00394-018-1798-7. PMID: 30076459. Exclusion: wrong population.30076459
284 Kasawara KT, Burgos CSG, do Nascimento SL, . Maternal and perinatal outcomes ofeExercise in pregnant women with chronic hypertension and/or previous preeclampsia: a randomized controlled trial. ISRN Obstet Gynecol. 2013;2013:857047. doi: 10.1155/2013/857047. PMID: 23997960. Exclusion: wrong country.23997960
285 Kasawara KT, Burgos CSG, Nascimento SL, . OS020. Effects of exercise on maternal and neonatal outcomes in pregnantwomen with chronic hypertension and/or previous preecampsia: a randomized clinical trial. Pregnancy Hypertens. 2012 Jul;2(3):185–6. doi: 10.1016/j.preghy.2012.04.021. PMID: 26105234. Exclusion: wrong study design.26105234
286 Kennelly M, Ainscough K, O’Sullivan E, . A randomised controlled trial of an M-health behavioural lifestyle intervention to prevent gestational diabetes in overweight and obese pregnancy: PEARS trial. BJOG. 2017;124(14). Exclusion: wrong publication type. Results not published yet for PEARS trial
287 Kennelly MA, Ainscough K, Lindsay K, . Pregnancy, exercise and nutrition research study with smart phone app support (Pears): study protocol of a randomized controlled trial. Contemp Clin Trials. 2016 Jan;46:92–9. doi: 10.1016/j.cct.2015.11.018. PMID: 26625980. Exclusion: wrong publication type.26625980
288 Kennelly MA, Ainscough K, Lindsay KL, . Pregnancy exercise and nutrition with smartphone application support: a randomized controlled trial. Obstet Gynecol. 2018 May;131(5):818–26. doi: 10.1097/AOG.0000000000002582. PMID: 29630009. Exclusion: wrong intervention.29630009
289 Kennelly MA, Ainscough KM, O’Sullivan EJ, . A randomized controlled trial of an M-health behavioural lifestyle intervention to prevent gestational diabetes in overweight and obese pregnancy: pears. Reprod Sci. 2017;Conference: 64th annual scientific meeting of the society for gynecologic investigation, SGI. 2017. United states 24(1 Supplement 1):83A. Exclusion: wrong publication type.
290 Khoury J, Henriksen T, Christophersen B, . Effect of a cholesterol-lowering diet on maternal, cord, and neonatal lipids, and pregnancy outcome: a randomized clinical trial. Am J Obstet Gynecol. 2005 Oct;193(4):1292–301. PMID: 16202717. Exclusion: wrong intervention.16202717
291 Kim C, Draska M, Hess ML, . A web-based pedometer programme in women with a recent history of gestational diabetes. Diabet Med. 2012 Feb;29(2):278–83. doi: 10.1111/j.1464-5491.2011.03415.x. PMID: 21838764. Exclusion: wrong population.21838764
292 Kinnunen TI, Aittasalo M, Koponen P, . Feasibility of a controlled trial aiming to prevent excessive pregnancy-related weight gain in primary health care. BMC Pregnancy Childbirth. 2008 Aug 11;8:37. doi: 10.1186/1471-2393-8-37. PMID: 18694479. Exclusion: wrong outcome.18694479
293 Kinnunen TI, Pasanen M, Aittasalo M, . Preventing excessive weight gain during pregnancy - a controlled trial in primary health care. Eur J Clin Nutr. 2007 Jul;61(7):884–91. doi: 10.1038/sj.ejcn.1602602. PMID: 17228348. Exclusion: quality rating is poor.17228348
294 Kinnunen TI, Pasanen M, Aittasalo M, . Reducing postpartum weight retention--a pilot trial in primary health care. Nutr J. 2007 Sep 10;6:21. doi: 10.1186/1475-2891-6-21. PMID: 17825113. Exclusion: wrong population.17825113
295 Kitzman H, Olds DL, Henderson CR, Jr., . Effect of prenatal and infancy home visitation by nurses on pregnancy outcomes, childhood injuries, and repeated childbearing. A randomized controlled trial. JAMA. 1997 Aug 27;278(8):644–52. PMID: 9272896. Exclusion: wrong intervention.9272896
296 Kizirian N, Garnett S, Markovic T, . Effects of a low-glycaemic index diet during pregnancy on offspring body composition: a pilot study. Obes Res Clin Pract. 2013;7(17). Exclusion: wrong outcome.
297 Kizirian NV, Kong Y, Muirhead R, . Effects of a low-glycemic index diet during pregnancy on offspring growth, body composition, and vascular health: a pilot randomized controlled trial. Am J Clin Nutr. 2016 Apr;103(4):1073–82. doi: 10.3945/ajcn.115.123695. PMID: 26936333. Exclusion: wrong population.26936333
298 Knuist M, Bonsel GJ, Zondervan HA, . Low sodium diet and pregnancy-induced hypertension: a multi-centre randomised controlled trial. Br J Obstet Gynaecol. 1998 Apr;105(4):430–4. PMID: 9609271. Exclusion: wrong outcome.9609271
299 Kolu P, Raitanen J, Puhkala J, . Effectiveness and cost-effectiveness of a cluster-randomized prenatal lifestyle counseling trial: a seven-year follow-up. PLoS ONE. 2016;11(12):e0167759. doi: 10.1371/journal.pone.0167759. PMID: 27936083. Exclusion: wrong outcome.27936083
300 Kong KL, Campbell C, Wagner K, . Impact of a walking intervention during pregnancy on post-partum weight retention and infant anthropometric outcomes. J Dev Orig Health Dis. 2014 Jun;5(3):259–67. doi: 10.1017/S2040174414000117. PMID: 24901666. Exclusion: wrong intervention.24901666
301 Kong KL, Campbell CG, Foster RC, . A pilot walking program promotes moderate-intensity physical activity during pregnancy. Med Sci Sports Exerc. 2014 Mar;46(3):462–71. doi: 10.1249/MSS.0000000000000141. PMID: 24002348. Exclusion: wrong intervention.24002348
302 Korpi-Hyovalti E, Schwab U, Laaksonen DE, . Effect of intensive counselling on the quality of dietary fats in pregnant women at high risk of gestational diabetes mellitus. Br J Nutr. 2012 Sep;108(5):910–7. doi: 10.1017/S0007114511006118. PMID: 22093485. Exclusion: wrong comparator.22093485
303 Korpi-Hyovalti EA, Laaksonen DE, Schwab US, . Feasibility of a lifestyle intervention in early pregnancy to prevent deterioration of glucose tolerance. BMC Public Health. 2011 Mar 24;11(179) doi: 10.1186/1471-2458-11-179. PMID: 21429234. Exclusion: wrong study design.21429234
304 Kramer MS. Nutritional advice in pregnancy. Cochrane Database Syst Rev. 2000(2):CD000149. doi: 10.1002/14651858.CD000149. PMID: 10796157. Exclusion: wrong publication type.10796157
305 Kramer MS. Energy/protein restriction for high weight-for-height or weight gain during pregnancy. Cochrane Database Syst Rev. 2000(2):CD000080. PMID: 10796119. Exclusion: wrong publication type.10796119
306 Kramer MS. Aerobic exercise for women during pregnancy. Cochrane Database Syst Rev. 2002(2):CD000180. PMID: 12076383. Exclusion: systematic review or meta-analysis used only as a source document for pearling.12076383
307 Kramer MS, McDonald SW. Aerobic exercise for women during pregnancy. Cochrane Database Syst Rev. 2006(3) doi: 10.1002/14651858.CD000180.pub2. PMID: 16855953. Exclusion: systematic review or meta-analysis used only as a source document for pearling.16855953
308 Kuhlmann AK, Dietz PM, Galavotti C, . Weight-management interventions for pregnant or postpartum women. Am J Prev Med. 2008 Jun;34(6):523–8. doi: 10.1016/j.amepre.2008.02.010. PMID: 18471590. Exclusion: systematic review or meta-analysis used only as a source document for pearling.18471590
309 Kurtzhals LL, Norgaard SK, Secher AL, . The impact of restricted gestational weight gain by dietary intervention on fetal growth in women with gestational diabetes mellitus. Diabetol. 2018 Dec;61(12):2528–38. doi: 10.1007/s00125-018-4736-6. PMID: 30255376. Exclusion: wrong population.30255376
310 Laitinen K, Ilmonen J, Isolauri E. Dietary counselling and probiotic intervention during pregnancy modify postpartum adiposity. Ann Nutr Metab. 2011;58(87). Exclusion: wrong intervention.
311 Lakshman R, Whittle F, Hardeman W, . Effectiveness of a behavioural intervention to prevent excessive weight gain during infancy (The Baby Milk Trial): study protocol for a randomised controlled trial. Trials. 2015 Oct 06;16:442. doi: 10.1186/s13063-015-0941-5. PMID: 26445092. Exclusion: wrong population.26445092
312 Lavie M, Lavie I, Maslovitz S. Paleolithic diet during pregnancy-a potential beneficial effect on metabolic indices and birth weight. Eur J Obstet Gynecol Reprod Biol. 2019 Nov;242:7–11. doi: 10.1016/j.ejogrb.2019.08.013. PMID: 31522093. Exclusion: wrong outcome.31522093
313 Lee A, Karpavicius J, Gasparini E, . Implementing a diet and exercise program for limiting maternal weight gain in obese pregnant women: a pilot study. Aust N Z J Obstet Gynaecol. 2012 Oct;52(5):427–32. doi: 10.1111/j.1479-828X.2012.01436.x. PMID: 22510020. Exclusion: wrong outcome.22510020
314 Lee E, Mitchell-Herzfeld SD, Lowenfels AA, . Reducing low birth weight through home visitation: a randomized controlled trial. Am J Prev Med. 2009 Feb;36(2):154–60. doi: 10.1016/j.amepre.2008.09.029. PMID: 19135906. Exclusion: wrong intervention.19135906
315 Lewis BA, Martinson BC, Sherwood NE, . A pilot study evaluating a telephone-based exercise intervention for pregnant and postpartum women. J Midwifery Womens Health. 2011 Mar–Apr;56(2):127–31. doi: 10.1111/j.1542-2011.2010.00016.x. PMID: 21429076. Exclusion: wrong outcome.21429076
316 Li J, Wang Z, Wei D, . Effect of preconceptional orlistat treatment on in-vitro fertilization outcome in overweight/obese women: study protocol for a randomized controlled trial. Trials. 2018 Jul 18;19(1):391. doi: 10.1186/s13063-018-2780-7. PMID: 30021634. Exclusion: wrong publication type.30021634
317 Lim C, McCarthy E, Shub A, . The effect of antenatal interventions on abnormal fetal growth and breastfeeding rates in overweight and obese pregnant women: results from facts, figures and feelings about weight in pregnancy (FFF) randomised controlled trial (RCT) and an updated meta-analysis. Conference: royal Australian and New Zealand College of Obstretricans and Gynaecologists. Aust N Z J Obstet Gynaecol. 2016;56:8–9. Exclusion: wrong publication type.
318 Lindsay KL, Brennan L, Rath A, . Gestational weight gain in obese pregnancy: impact on maternal and foetal metabolic parameters and birthweight. J Obstet Gynaecol. 2018 Jan;38(1):60–5. doi: 10.1080/01443615.2017.1328670. PMID: 28782412. Exclusion: wrong study design.28782412
319 Lindsay KL, Heneghan C, McNulty B, . Lifestyle and dietary habits of an obese pregnant cohort. Matern Child Health J. 2015 Jan;19(1):25–32. doi: 10.1007/s10995-014-1491-2. PMID: 24740724. Exclusion: wrong study design.24740724
320 Liu JH, Mayer-Davis EJ, Pate RR, . Physical activity during pregnancy is associated with reduced fasting insulin--the Pilot Pregnancy and Active Living Study. J Matern Fetal Neonatal Med. 2010 Oct;23(10):1249–52. doi: 10.3109/14767051003677970. PMID: 20230322. Exclusion: wrong study design.20230322
321 Lombard C, Harrison C, Teede H. A randomized controlled trial investigating self-weighing and the prevention of excess weight gain in early pregnancy. Endocr Rev. Annual Meeting and Expo of the Endocrine Society, ENDO 2011 Boston, MA United States;32(3 Meeting Abstracts):CONFERENCE START: 2011 Jun 4 CONFERENCE END: Jun 7. Exclusion: wrong publication type.
322 Luoto RM, Kinnunen TI, Aittasalo M, . Prevention of gestational diabetes: design of a cluster-randomized controlled trial and one-year follow-up. BMC Pregnancy Childbirth. 2010 Aug 03;10:39. doi: 10.1186/1471-2393-10-39. PMID: 20682023. Exclusion: wrong publication type.20682023
323 Ly M, Price S, Ekinci EI. Impact of substantial weight loss on thyroid function in obese women planning pregnancy. Clin Endocrinol. Conference: endocrine society of australia annual scientific meeting. 2016;86:52–3. Exclusion: wrong outcome.
324 Magro-Malosso ER, Saccone G, Di Mascio D, . Exercise during pregnancy and risk of preterm birth in overweight and obese women: a systematic review and meta-analysis of randomized controlled trials. Acta Obstet Gynecol Scand. 2017 Mar;96(3):263–73. doi: 10.1111/aogs.13087. PMID: 28029178. Exclusion: wrong outcome.28029178
325 Maier JT, Schalinski E, Gauger U, . Antenatal body mass index (BMI) and weight gain in pregnancy - its association with pregnancy and birthing complications. J Perinat Med. 2016 May 1;44(4):397–404. doi: 10.1515/jpm-2015-0172. PMID: 26646019. Exclusion: wrong study design.26646019
326 Marcinkevage J, Correa A, Ramakrishnan U, . Reducing sedentary behavior and increasing physical activity during pregnancy: a feasibility study. Diabetes. 2012;61(8). Exclusion: wrong publication type.
327 Marcinkevage J, Narayan KMV, Correa A, . Lifestyle intervention during early pregnancy improves glucose and insulin indices in women at risk for gestational diabetes. Diabetes. 2013;62(21). Exclusion: wrong outcome.
328 Markovic TP, Muirhead R, Overs S, . Randomized controlled trial investigating the effects of a low-glycemic index diet on pregnancy outcomes in women at high risk of gestational diabetes mellitus: the GI Baby 3 study. Diabetes Care. 2016 Jan;39(1):31–8. doi: 10.2337/dc15-0572. PMID: 26185283. Exclusion: wrong population.26185283
329 Martin L, Coughlin JW, Clark JM, . A pilot randomized controlled trial of a remotely-delivered behavioral health coaching program to limit weight gain in pregnancy and reduce postpar-tum weight retention. J Gen Intern Med. 2018;Conference: 41st annual meeting of the society of general internal medicine, SGIM. 2018. United states 33(2 Supplement 1):94–5. Exclusion: wrong publication type.
330 Martinez Galiano JM, Delgado-Rodriguez M. Attendance to a health education program for pregnant women and outcomes of the newborn: health education of pregnant women and newborn. Minerva Pediatr. 2016 Jun;68(3):177–81. PMID: 25358845. Exclusion: wrong study design.25358845
331 Masiero JV, Stone JM, Moore Simas TA, . Accuracy of recalled compared with measured weight for the calculation of prepregnancy body mass index. Obstet Gynecol. 2015;125. Exclusion: wrong publication type.
332 Matsuzaki M, Kusaka M, Sugimoto T, . The effects of a yoga exercise and nutritional guidance program on pregnancy outcomes among healthy pregnant Japanese women: a study protocol for a randomized controlled trial. J Altern Complement Med. 2018 Jun;24(6):603–10. doi: 10.1089/acm.2017.0119. PMID: 29443533. Exclusion: wrong study design.29443533
333 McCarthy EA, co a, Walker SP, . Authors’ reply re: self-weighing and simple dietary advice for overweight and obese pregnant women to reduce obstetric complications without impact on quality of life: a randomised controlled trial. BJOG. 2017 Mar;124(4):698. doi: 10.1111/1471-0528.14428. PMID: 28224750. Exclusion: wrong publication type.28224750
334 McClure CK, Catov JM, Ness R, . Associations between gestational weight gain and BMI, abdominal adiposity, and traditional measures of cardiometabolic risk in mothers 8 y postpartum. Am J Clin Nutr. 2013 Nov;98(5):1218–25. doi: 10.3945/ajcn.112.055772. PMID: 24047920. Exclusion: wrong study design.24047920
335 McDonald SD, Park CK, Pullenayegum E, . Knowledge translation tool to improve pregnant women’s awareness of gestational weight gain goals and risks of gaining outside recommendations: a non-randomized intervention study. BMC Pregnancy Childbirth. 2015 Apr 30;15(105) doi: 10.1186/s12884-015-0534-z. PMID: 25925384. Exclusion: wrong outcome.25925384
336 McDonald SD, Pullenayegum E, Bracken K, . Comparison of midwifery, family medicine, and obstetric patients’ understanding of weight gain during pregnancy: a minority of women report correct counselling. J Obstet Gynaecol Can. 2012 Feb;34(2):129–35. doi: 10.1016/S1701-2163(16)35155-6. PMID: 22340061. Exclusion: wrong outcome.22340061
337 McEachan RRC, Santorelli G, Bryant M, . The HAPPY (Healthy and Active Parenting Programmme for early Years) feasibility randomised control trial: acceptability and feasibility of an intervention to reduce infant obesity. BMC Public Health. 2016 Mar 1;16(211) doi: 10.1186/s12889-016-2861-z. PMID: 26931491. Exclusion: wrong population.26931491
338 McGowan CA, Walsh JM, Byrne J, . The influence of a low glycemic index dietary intervention on maternal dietary intake, glycemic index and gestational weight gain during pregnancy: a randomized controlled trial. Nutr J. 2013 Oct 31;12(140) doi: 10.1186/1475-2891-12-140. PMID: 24175958. Exclusion: wrong intervention.24175958
339 McLaughlin FJ, Altemeier WA, Christensen MJ, . Randomized trial of comprehensive prenatal care for low-income women: effect on infant birth weight. Pediatrics. 1992 Jan;89(1):128–32. PMID: 1727996. Exclusion: wrong intervention.1727996
340 Melzer K, Schutz Y, Soehnchen N, . Effects of recommended levels of physical activity on pregnancy outcomes. Am J Obstet Gynecol. 2010 Mar;202(3):266.e1–.e6. doi: 10.1016/j.ajog.2009.10.876. PMID: 20022583. Exclusion: wrong study design.20022583
341 Michel S, Raab R, Drabsch T, . Do lifestyle interventions during pregnancy have the potential to reduce long-term postpartum weight retention? A systematic review and meta-analysis. Obes Rev. 2019 Apr;20(4):527–42. doi: 10.1111/obr.12809. PMID: 30548769. Exclusion: systematic review or meta-analysis used only as a source document for pearling.30548769
342 Mohd-Shukri NA, Duncan A, Denison FC, . Health behaviours during pregnancy in women with very severe obesity. Nutrients. 2015 Oct 7;7(10):8431–43. doi: 10.3390/nu7105403. PMID: 26457716. Exclusion: wrong study design.26457716
343 Moholdt TT, Salvesen K, Ingul CB, . Exercise Training in Pregnancy for obese women (ETIP): study protocol for a randomised controlled trial. Trials. 2011 Jun 17;12:154. doi: 10.1186/1745-6215-12-154. PMID: 21682869. Exclusion: wrong publication type.21682869
344 Molyneaux E, Begum S, Briley AL, . Do elevated symptoms of depression predict adherence and outcomes in the UPBEAT randomised controlled trial of a lifestyle intervention for obese pregnant women? 11 medical and health sciences 1117 public health and health services. BMC Pregnancy Childbirth. 2018 Sep 18;18(1):378. doi: 10.1186/s12884-018-2004-x. PMID: 30227833 Exclusion: wrong outcome.30227833
345 Monte S, Valenti O, Giorgio E, . Maternal weight gain during pregnancy and neonatal birth weight: a review of the literature. J Prenat Med. 2011 Apr;5(2):27–30. PMID: 22439072. Exclusion: systematic review or meta-analysis used only as a source document for pearling.22439072
346 Monteiro da Silva Mda C, Marlucia Oliveira A, Pereira Magalhaes de Oliveira L, . Determinants of postpartum weight variation in a cohort of adult women; a hierarchical approach. Nutr Hosp. 2013 May–Jun;28(3):660–70. doi: 10.3305/nh.2013.28.3.6391. PMID: 23848086. Exclusion: wrong study design.23848086
347 Moore Simas TA, Doyle Curiale DK, Hardy J, . Efforts needed to provide Institute of Medicine-recommended guidelines for gestational weight gain. Obstet Gynecol. 2010 Apr;115(4):777–83. doi: 10.1097/AOG.0b013e3181d56e12. PMID: 20308839. Exclusion: wrong study design.20308839
348 Moran LJ, Flynn AC, Louise J, . The effect of a lifestyle intervention on pregnancy and postpartum dietary patterns determined by factor analysis. Obesity (Silver Spring). 2017 Jun;25(6):1022–32. doi: 10.1002/oby.21848. PMID: 28452404. Exclusion: wrong outcome.28452404
349 Moses RG, Casey S, Cleary J, . Effect of low glycaemic index dietary advice in normal pregnancy: the PREGGIO study. Obes Res Clin Pract. 2013;7(17). Exclusion: wrong publication type.
350 Moses RG, Casey SA, Quinn EG, . Pregnancy and Glycemic Index Outcomes study: effects of low glycemic index compared with conventional dietary advice on selected pregnancy outcomes. Am J Clin Nutr. 2014 Mar;99(3):517–23. doi: 10.3945/ajcn.113.074138. PMID: 24351875. Exclusion: wrong outcome.24351875
351 Moses RG, Luebcke M, Davis WS, . Effect of a low-glycemic-index diet during pregnancy on obstetric outcomes. Am J Clin Nutr. 2006 Oct;84(4):807–12. doi: 10.1093/ajcn/84.4.807. PMID: 17023707 Exclusion: wrong outcome.17023707
352 Mottola MF. Exercise prescription for overweight and obese women: pregnancy and postpartum. Obstet Gynecol Clin North Am. 2009 Jun;36(2):301–16, viii. doi: 10.1016/j.ogc.2009.03.005. PMID: 19501315. Exclusion: wrong publication type.19501315
353 Mottola MF, Giroux I, Gratton R, . Nutrition and exercise prevent excess weight gain in overweight pregnant women. Med Sci Sports Exerc. 2010 Feb;42(2):265–72. doi: 10.1249/MSS.0b013e3181b5419a. PMID: 20083959. Exclusion: wrong study design.20083959
354 Mourtakos SP, Tambalis KD, Panagiotakos DB, . Association between gestational weight gain and risk of obesity in preadolescence: a longitudinal study (1997-2007) of 5125 children in Greece. J Hum Nutr Diet. 2017 Feb;30(1):51–8. doi: 10.1111/jhn.12398. PMID: 27412890. Exclusion: wrong intervention.27412890
355 Mourtakos SP, Tambalis KD, Panagiotakos DB, . Maternal lifestyle characteristics during pregnancy, and the risk of obesity in the offspring: a study of 5,125 children. BMC Pregnancy Childbirth. 2015 Mar 21;15:66. doi: 10.1186/s12884-015-0498-z. PMID: 25885759. Exclusion: wrong intervention.25885759
356 Moyer C, Livingston J, Fang X, . Influence of exercise mode on pregnancy outcomes: ENHANCED by Mom project. BMC Pregnancy Childbirth. 2015 Jun 09;15:133. doi: 10.1186/s12884-015-0556-6. PMID: 26055756. Exclusion: wrong publication type.26055756
357 Muhajarine N, Ng J, Bowen A, . Understanding the impact of the Canada Prenatal Nutrition Program: a quantitative evaluation. Can J Public Health. 2012 Mar 29;103(7 Suppl 1):eS26–31. PMID: 23618045. Exclusion: wrong study design.23618045
358 Mujsindi W, Habash D, Childs G. Impact of nutrition education on gestational weight gain in obese pregnant women. Am J Obstet Gynecol. START: 2014 Feb 3 CONFERENCE END: 2014 Feb 8, 34th Annual Meeting of the Society for Maternal-Fetal Medicine: The Pregnancy Meeting New Orleans, LA United States;210(1 SUPPL. 1):S188. Exclusion: wrong publication type.
359 Muktabhant B, Lawrie TA, Lumbiganon P, . Diet or exercise, or both, for preventing excessive weight gain in pregnancy. Cochrane Database Syst Rev. 2015 Jun 15(6):CD007145. doi: 10.1002/14651858.CD007145.pub3. PMID: 26068707. Exclusion: companion paper with outdated data, data not used for evidence.26068707
360 Mumford SL, Siega-Riz AM, Herring A, . Dietary restraint and gestational weight gain. J Am Diet Assoc. 2008 Oct;108(10):1646–53. doi: 10.1016/j.jada.2008.07.016. PMID: 18926129. Exclusion: wrong study design.18926129
361 Murtezani A, Pacarada M, Ibraimi Z, . The impact of exercise during pregnancy on neonatal outcomes: a randomized controlled trial. J Sports Med Phys Fitness. 2014 Dec;54(6):802–8. PMID: 25350037. Exclusion: wrong country.25350037
362 Mustila T, Raitanen J, Keskinen P, . Lifestyle counseling during pregnancy and offspring weight development until four years of age: follow-up study of a controlled trial. J Negat Results Biomed. 2012 May 08;11:11. doi: 10.1186/1477-5751-11-11. PMID: 22568871. Exclusion: wrong outcome.22568871
363 Mustila T, Raitanen J, Keskinen P, . Pragmatic controlled trial to prevent childhood obesity in maternity and child health care clinics: pregnancy and infant weight outcomes (the VACOPP Study). BMC Pediatr. 2013 May 20;13:80. doi: 10.1186/1471-2431-13-80. PMID: 23688259. Exclusion: wrong study design.23688259
364 Nagle C, Skouteris H, Hotchin A, . Continuity of midwifery care and gestational weight gain in obese women: a randomised controlled trial. BMC Public Health. 2011 Mar 22;11:174. doi: 10.1186/1471-2458-11-174. PMID: 21426582. Exclusion: wrong publication type.21426582
365 Nagle C, Skouteris H, Morris H, . Primary prevention of gestational diabetes for women who are overweight and obese: a randomised controlled trial. BMC Pregnancy Childbirth. 2013 Mar 13;13:65. doi: 10.1186/1471-2393-13-65. PMID: 23497264. Exclusion: wrong publication type.23497264
366 Nagpal TS, Prapavessis H, Campbell CG, . Sequential introduction of exercise first followed by nutrition improves program adherence during pregnancy: a randomized controlled trial. Int J Behav Med. 2019. doi: 10.1007/s12529-019-09840-0. PMID: 31872340 Exclusion: wrong study design.31872340
367 Narendran S, Nagarathna R, Narendran V, . Efficacy of yoga on pregnancy outcome. J Altern Complement Med. 2005 Apr;11(2):237–44. doi: 10.1089/acm.2005.11.237. PMID: 15865489. Exclusion: wrong country.15865489
368 Nascimento SL, Surita FG, Cecatti JG. Physical exercise during pregnancy: a systematic review. Curr Opin Obstet Gynecol. 2012 Dec;24(6):387–94. doi: 10.1097/GCO.0b013e328359f131. PMID: 23014142. Exclusion: systematic review or meta-analysis used only as a source document for pearling.23014142
369 Nascimento SL, Surita FG, Parpinelli MA, . The effect of an antenatal physical exercise programme on maternal/perinatal outcomes and quality of life in overweight and obese pregnant women: a randomised clinical trial. BJOG. 2011 Nov;118(12):1455–63. doi: 10.1111/j.1471-0528.2011.03084.x. PMID: 21895947. Exclusion: wrong country.21895947
370 Navarro JI, Sigulem DM, Ferraro AA, . The double task of preventing malnutrition and overweight: a quasi-experimental community-based trial. BMC Public Health. 2013 Mar 09;13:212. doi: 10.1186/1471-2458-13-212. PMID: 23496939. Exclusion: wrong country.23496939
371 NCT. Physical activity intervention for gestational diabetes. Https://clinicaltrials.gov/show/nct03664089. 2018. Exclusion: wrong population.
372 NCT. The efficacy of light-to-moderate resistance training in sedentary pregnant women. Https://clinicaltrials.gov/show/nct03705741. 2018. Exclusion: wrong publication type.
373 NCT. Efficacy of an app for monitoring physical activity and weight of obese pregnant women (Pas&Pes). Https://clinicaltrials.gov/show/nct03706872. 2018. Exclusion: wrong publication type.
374 NCT. Partnering with WIC to prevent excessive weight gain in pregnancy. Https://clinicaltrials.gov/show/nct03707834. 2018. Exclusion: wrong publication type.
375 NCT. The healthy moms study: comparison of a post-partum weight loss intervention delivered via Facebook or in-person groups. Https://clinicaltrials.gov/show/nct03700736. 2018. Exclusion: wrong outcome.
376 NCT. Evidence-based educational materials and local resources for improving exercise-related outcomes during pregnancy. Https://clinicaltrials.gov/show/nct03504267. 2018. Exclusion: wrong outcome.
377 NCT. Best start - weight management during pregnancy. Https://clinicaltrials.gov/show/nct03875300. 2019. Exclusion: wrong publication type.
378 NCT. Gestational weight and incentive research study. Https://clinicaltrials.gov/show/nct03834194. 2019. Exclusion: wrong publication type.
379 Nielsen JN, O’Brien KO, Witter FR, . High gestational weight gain does not improve birth weight in a cohort of African American adolescents. Am J Clin Nutr. 2006 Jul;84(1):183–9. PMID: 16825694. Exclusion: wrong study design.16825694
380 Nixon WC. Diet, weight control, and toxaemia in pregnancy. Postgrad Med J. 1955 Jun;31(356):266–71. doi: 10.1136/pgmj.31.356.266. PMID: 14394940. Exclusion: wrong publication type.14394940
381 Nobles C, Marcus B, Stanek E, . Health behaviors of inactive pregnantwomen at high risk for gestational diabetes mellitus. Am J Epidemiol. 2013;177(18). Exclusion: wrong outcome.
382 Nobles C, Marcus BH, Stanek EJ, 3rd, . The effect of an exercise intervention on gestational weight gain: the Behaviors Affecting Baby and You (B.A.B.Y.) study: a randomized controlled trial. Am J Health Promot. 2018 Mar;32(3):736–44. doi: 10.1177/0890117117732409. PMID: 28950725. Exclusion: wrong comparator.28950725
383 Nobles CJ, Marcus BH, Stanek EJ, 3rd, . The health behaviors of ethnically diverse women at increased risk of gestational diabetes: the Behaviors Affecting Baby and You (B.A.B.Y.) study. Matern Child Health J. 2018 May;22(5):735–44. doi: 10.1007/s10995-018-2442-0. PMID: 29335906. Exclusion: wrong study design.29335906
384 Norman JE, Reynolds RM. Prescribing exercise and lifestyle training for high risk women in pregnancy and early post-partum-is it worth it? Plos medicine. 2016 Jul;13(7):e1002093. doi: 10.1371/journal.pmed.1002093. PMID: 27459631. Exclusion: wrong publication type.27459631
385 O’Brien EC. Educated women respond to dietary intervention regardless of neighborhood deprivation-secondary analysis from the ROLO study. Am J Obstet Gynecol. 2017;Conference: 37th annual meeting of the society for maternal-fetal medicine: the pregnancy meeting. United states. Conference start:. 20170123. Conference end: 20170128 216(1 Supplement 1):S287–S8. Exclusion: wrong publication type.
386 O’Brien EC, Alberdi G, Geraghty AA, . Lower education predicts poor response to dietary intervention in pregnancy, regardless of neighbourhood affluence: secondary analysis from the ROLO randomised control trial. Public Health Nutr. 2017 Nov;20(16):2959–69. doi: 10.1017/S1368980017001951. PMID: 28807059. Exclusion: companion paper with outdated data, data not used for evidence.28807059
387 O’Brien OA, McCarthy M, Gibney ER, . Technology-supported dietary and lifestyle interventions in healthy pregnant women: a systematic review. Eur J Clin Nutr. 2014 Jul;68(7):760–6. doi: 10.1038/ejcn.2014.59. PMID: 24781682. Exclusion: systematic review or meta-analysis used only as a source document for pearling.24781682
388 Ockenden H, Gunnell K, Giles A, . Development and preliminary validation of a comprehensive questionnaire to assess women’s knowledge and perception of the current weight gain guidelines during pregnancy. Int J Environ Res Public Health. 2016 Nov 30;13(12):1187. doi: 10.3390/ijerph13121187 PMID: 27916921. Exclusion: wrong outcome.27916921
389 O’Connor E, Senger CA, Henninger M, . Interventions to prevent perinatal depression: a systematic evidence review for the U.S. Preventive Services Task Force. AHRQ. 2019 Feb(18-05243-EF-1) PMID: 3080706030807060. Exclusion: systematic review or meta-analysis used only as a source document for pearling.
390 Okesene-Gafa K, Li M, Taylor RS, . A randomised controlled demonstration trial of multifaceted nutritional intervention and or probiotics: the Healthy Mums and Babies (HUMBA) trial.[Erratum appears in BMC Pregnancy Childbirth. 2018 May 4;18(1):130; PMID: 29728087]. BMC Pregnancy Childbirth. 2016 Nov 24;16(1):373. doi: 10.1186/s12884-016-1149-8. PMID: 27884128. Exclusion: wrong publication type.27884128
391 Okesene-Gafa K, McKinlay CJD, Li M, . Dietary intervention and/or probiotic capsules in obese pregnant women-effect on gestational weight gain and infant birthweight: Healthy Mums and Babies (HUMBA) trial. J Paediatr Child Health. 2018;Conference: 22nd annual congress of the perinatal society of australia and new zealand, PSANZ. 2018. New zealand 54(Supplement 1):4–5. Exclusion: wrong publication type.
392 Olander EK, Berg M, McCourt C, . Person-centred care in interventions to limit weight gain in pregnant women with obesity - a systematic review. BMC Pregnancy Childbirth. 2015 Feb 27;15(50) doi: 10.1186/s12884-015-0463-x. PMID: 25885178. Exclusion: wrong comparator.25885178
393 Olayiwola JN, Irizarry OC, O’Connell K, . Living smart, living fit: a patient-centered program to improve perinatal outcomes in a community health center population. Journal of Primary Care & Community Health. 2013 Jan;4(1):31–5. doi: 10.1177/2150131912461148. PMID: 23799687. Exclusion: wrong comparator.23799687
394 Olds DL. Home visitation for pregnant women and parents of young children. Am J Dis Child. 1992 Jun;146(6):704–8. doi: 10.1001/archpedi.1992.02160180062018. PMID: 1375807. Exclusion: wrong publication type.1375807
395 Olds DL, Kitzman H. Review of research on home visiting for pregnant women and parents of young children. Future Child. 1993 Win;3(3):53–92. Exclusion: wrong publication type.
396 Olson CM, Strawderman MS. Modifiable behavioral factors in a biopsychosocial model predict inadequate and excessive gestational weight gain. J Am Diet Assoc. 2003 Jan;103(1):48–54. doi: 10.1053/jada.2003.50001. PMID: 12525793. Exclusion: wrong study design.12525793
397 Olson CM, Strawderman MS, Graham ML. Association between consistent weight gain tracking and gestational weight gain: Secondary analysis of a randomized trial. Obesity (Silver Spring). 2017 Jul;25(7):1217–27. doi: 10.1002/oby.21873. PMID: 28573669. Exclusion: wrong study design.28573669
398 Olson CM, Strawderman MS, Hinton PS, . Gestational weight gain and postpartum behaviors associated with weight change from early pregnancy to 1 y postpartum. Int J Obes Relat Metab Disord. 2003 Jan;27(1):117–27. doi: 10.1038/sj.ijo.0802156. PMID: 12532163. Exclusion: wrong study design.12532163
399 Olson CM, Strawderman MS, Reed RG. Efficacy of an intervention to prevent excessive gestational weight gain. Am J Obstet Gynecol. 2004 Aug;191(2):530–6. doi: 10.1016/j.ajog.2004.01.027. PMID: 15343232. Exclusion: wrong comparator.15343232
400 Ong MJ, Guelfi KJ, Hunter T, . Supervised home-based exercise may attenuate the decline of glucose tolerance in obese pregnant women. Diabetes Metab. 2009 Nov;35(5):418–21. doi: 10.1016/j.diabet.2009.04.008. PMID: 19747869. Exclusion: wrong outcome.19747869
401 Oostdam N, van Poppel MN, Eekhoff EM, . Design of FitFor2 study: the effects of an exercise program on insulin sensitivity and plasma glucose levels in pregnant women at high risk for gestational diabetes. BMC Pregnancy Childbirth. 2009 Jan 05;9:1. doi: 10.1186/1471-2393-9-1. PMID: 19123930. Exclusion: wrong publication type.19123930
402 Oostdam N, van Poppel MN, Wouters MG, . No effect of the FitFor2 exercise programme on blood glucose, insulin sensitivity, and birthweight in pregnant women who were overweight and at risk for gestational diabetes: results of a randomised controlled trial. BJOG. 2012 Aug;119(9):1098–107. doi: 10.1111/j.1471-0528.2012.03366.x. PMID: 22616913. Exclusion: wrong outcome.22616913
403 Opie RS, Neff M, Tierney AC. A behavioural nutrition intervention for obese pregnant women: Effects on diet quality, weight gain and the incidence of gestational diabetes. Aust N Z J Obstet Gynaecol. 2016 Aug;56(4):364–73. doi: 10.1111/ajo.12474. PMID: 27170563. Exclusion: wrong comparator.27170563
404 Opray N, Grivell RM, Deussen AR, . Directed preconception health programs and interventions for improving pregnancy outcomes for women who are overweight or obese. Cochrane Database Syst Rev. 2015 Jul 14(7):CD010932. doi: 10.1002/14651858.CD010932.pub2. PMID: 26171908. Exclusion: systematic review or meta-analysis used only as a source document for pearling.26171908
405 Ornaghi S, Algeri P, Todyrenchuk L, . Impact of excessive pre-pregnancy body mass index and abnormal gestational weight gain on pregnancy outcomes in women with chronic hypertension. Pregnancy Hypertension. 2018 Apr;12:90–5. doi: 10.1016/j.preghy.2018.04.005. PMID: 29674207. Exclusion: wrong population.29674207
406 Orr ST, James SA, Garry J, . Exercise and pregnancy outcome among urban, low-income, black women. Ethn Dis. 2006;16(4):933–7. PMID: 17061749. Exclusion: wrong study design.17061749
407 Ota E, Tobe-Gai R, Mori R, . Antenatal dietary advice and supplementation to increase energy and protein intake. Cochrane Database Syst Rev. 2012 Sep 12(9):CD000032. doi: 10.1002/14651858.CD000032.pub2. PMID: 22972038. Exclusion: wrong publication type.22972038
408 Oteng-Ntim E, Varma R, Croker H, . Lifestyle interventions for overweight and obese pregnant women to improve pregnancy outcome: systematic review and meta-analysis. BMC Med. 2012 May 10;10(47) doi: 10.1186/1741-7015-10-47. PMID: 22574949. Exclusion: systematic review or meta-analysis used only as a source document for pearling.22574949
409 Overby NC, Hillesund ER, Sagedal LR, . The Fit for Delivery study: rationale for the recommendations and test-retest reliability of a dietary score measuring adherence to 10 specific recommendations for prevention of excessive weight gain during pregnancy. Matern Child Nutr. 2015 Jan;11(1):20–32. doi: 10.1111/mcn.12026. PMID: 23241065. Exclusion: wrong intervention.23241065
410 P. DN, J. SA, Y. KS, . Achieving appropriate gestational weight gain: the role of healthcare provider advice. J Womens Health (Larchmt). 2018 May 27(5):552–60. doi: 10.1089/jwh.2017.6514. PMID: 29319394. Exclusion: wrong intervention.29319394
411 Parker JD, Abrams B. Prenatal weight gain advice: an examination of the recent prenatal weight gain recommendations of the Institute of Medicine. Obstet Gynecol. 1992 May;79(5 (Pt 1)):664–9. PMID: 1565346. Exclusion: wrong study design.1565346
412 Parlapani E, Agakidis C, Karagiozoglou-Lampoudi T, . The Mediterranean diet adherence by pregnant women delivering prematurely: association with size at birth and complications of prematurity. J Matern Fetal Neonatal Med. 2019 Apr;32(7):1084–91. doi: 10.1080/14767058.2017.1399120. PMID: 29082786. Exclusion: wrong outcome.29082786
413 Patel N, Godfrey KM, Pasupathy D, . Infant adiposity following a randomised controlled trial of a behavioural intervention in obese pregnancy. Int J Obes (Lond). 2017 Jul;41(7):1018–26. doi: 10.1038/ijo.2017.44. PMID: 28216644. Exclusion: wrong outcome.28216644
414 Paterson H, Treharne GJ, Horwath C, . Intuitive eating and gestational weight gain. Eat. 2019 Aug;34:101311. doi: 10.1016/j.eatbeh.2019.101311. PMID: 31330479 Exclusion: wrong outcome.31330479
415 Paul KH, Olson CM. Moving beyond quantity of participation in process evaluation of an intervention to prevent excessive pregnancy weight gain. Int J Behav Nutr Phys Act. 2013 Feb 13;10(23) doi: 10.1186/1479-5868-10-23. PMID: 23406294. Exclusion: wrong study design.23406294
416 Pawalia A, Kulandaivelan S, Savant S, . Exercise in pregnancy: effect on obesity parameters in indian women - a randomized controlled trial. Rom J Diabetes Nutr Metab Dis. 2017;24(4):315–23. Exclusion: wrong country.
417 Peaceman AM, Kwasny MJ, Gernhofer N, . MOMFIT: a randomized clinical trial of an intervention to prevent excess gestational weight gain in overweight and obese women. Am J Obstet Gynecol. 2017;Conference: 37th annual meeting of the society for maternal-fetal medicine: the pregnancy meeting. United states. Conference start:. 20170123. Conference end: 20170128 216(1 Supplement 1):S2–S3. Exclusion: wrong publication type.
418 Perreault M, Atkinson SA, Mottola MF, . Structured diet and exercise guidance in pregnancy to improve health in women and their offspring: study protocol for the Be Healthy in Pregnancy (BHIP) randomized controlled trial. Trials. 2018 Dec 19;19(1):691. doi: 10.1186/s13063-018-3065-x. PMID: 30567604. Exclusion: wrong publication type.30567604
419 Petrella E, Bruno R, Pedrielli G, . A customized low glycaemic-index (GI) diet prevents both the gestational diabetes mellitus (GDM) and the large for gestational age (LGA) babies in overweight/obese pregnant women. Am J Obstet Gynecol. 2016 START: 2016 Feb 1 CONFERENCE END: 2016 Feb 6, 36th Annual Meeting of the Society for Maternal-Fetal Medicine: The Pregnancy Meeting Atlanta, GA United States;214(1 SUPPL. 1):S159. Exclusion: wrong publication type.
420 Petrella E, Facchinetti F, Bertarini V, . Occurrence of pregnancy complications in women with BMI >25 submitted to a healthy lifestyle and eating habits program. Am J Obstet Gynecol. 2013 START: 2013 Feb 11 CONFERENCE END: 2013 Feb 16, 33rd Annual Meeting of the Society for Maternal-Fetal Medicine: The Pregnancy Meeting San Francisco, CA United States;208(1 SUPPL.1):S33–S4. Exclusion: wrong publication type.
421 Petrella E, Tamborrino V, Di Cerbo L, . An early, customized low-glycemic-index diet prevents adverse pregnancy outcomes in overweight/obese women. Minerva Ginecol. 2018 Jun;70(3):254–60. doi: 10.23736/S0026-4784.17.04156-9. PMID: 29083138. Exclusion: wrong study design.29083138
422 Petrov Fieril K, Glantz A, Fagevik Olsen M. The efficacy of moderate-to-vigorous resistance exercise during pregnancy: a randomized controlled trial. Acta Obstet Gynecol Scand. 2015 Jan;94(1):35–42. doi: 10.1111/aogs.12525. PMID: 25287282. Exclusion: wrong comparator.25287282
423 Phelan S. Windows of opportunity for lifestyle interventions to prevent gestational diabetes mellitus. Am J Perinatol. 2016 Nov;33(13):1291–9. doi: 10.1055/s-0036-1586504. PMID: 27487229. Exclusion: wrong publication type.27487229
424 Phelan S, Hagobian TA, Ventura A, . ‘Ripple’ effect on infant zBMI trajectory of an internet-based weight loss program for low-income postpartum women. Pediatr Obes. 2019 Sep 17;14(1) doi: 10.1111/ijpo.12456. PMID: 30225981 Exclusion: wrong population.30225981
425 Phelan S, Jankovitz K, Hagobian T, . Reducing excessive gestational weight gain: lessons from the weight control literature and avenues for future research. Womens Health. 2011 Nov;7(6):641–61. doi: 10.2217/whe.11.70. PMID: 22040207. Exclusion: wrong publication type.22040207
426 Phelan S, Phipps MG, Abrams B, . Practitioner advice and gestational weight gain. J Womens Health. 2011a Apr;20(4):585–91. doi: 10.1089/jwh.2010.2316. PMID: 21413898. Exclusion: wrong study design.21413898
427 Phelan S, Phipps MG, Abrams B, . Factors associated with success in the “fit for delivery” intervention to reduce excessive gestational weight gain. Obesity (Silver Spring). 2011c;19(1). Exclusion: wrong publication type.
428 Pigeyre M, Lelorain S, Couturier E, . Electronic-Personalized Program for Obesity during Pregnancy (ePPOP). Obes Rev. 2016;17:175–6. Exclusion: wrong publication type.
429 Pihet S, Mellier D, Bullinger A, . Behavioral responses of preterm newborns to odors: preliminary study. Enfance. 1997;1:33–46. Exclusion: foreign language.
430 Pinto AM, Gokee-Larose J, Wing RR. Behavioral approaches to weight control: a review of current research. Womens Health. 2007 May;3(3):341–53. doi: 10.2217/17455057.3.3.341. PMID: 19803993. Exclusion: wrong publication type.19803993
431 Polley BA, Wing RR. Diabetes: the challenge of maintaining glycemic control. Health care for women: Psychological, social, and behavioral influences. Washington, DC: American Psychological Association; US; 1997:349–63. Exclusion: wrong population.
432 Poobalan AS, Aucott LS, Precious E, . Weight loss interventions in young people (18 to 25 year olds): a systematic review. Obes Rev. 2010 Aug;11(8):580–92. doi: 10.1111/j.1467-789X.2009.00673.x. PMID: 19874531. Exclusion: wrong publication type.19874531
433 Poon AK, Yeung E, Boghossian N, . Maternal dietary patterns during third trimester in association with birthweight characteristics and early infant growth. Scientifica (Cairo). 2013 Dec;2013(786409) doi: 10.1155/2013/786409. PMID: 24490111. Exclusion: wrong study design.24490111
434 Poorman E, Gazmararian J, Parker RM, . Use of text messaging for maternal and infant health: a systematic review of the literature. Matern Child Health J. 2015 May;19(5):969–89. doi: 10.1007/s10995-014-1595-8. PMID: 25081242. Exclusion: wrong publication type.25081242
435 Poston L. Obesity in pregnancy: could lifestyle interventions work? BMC Med. 2014 Oct 13;12:201. doi: 10.1186/s12916-014-0201-7. PMID: 25318013. Exclusion: wrong publication type.25318013
436 Poston L. Obesity in pregnancy; the role of nutrition in the health of mother and child. Ann Nutr Metab. 2015;67(26). Exclusion: wrong publication type.
437 Poston L, Bell R, Croker H, . Effect of a behavioural intervention in obese pregnant women (the UPBEAT study): a multicentre, randomised controlled trial. Lancet Diabetes Endocrinol. 2015 Oct;3(10):767–77. doi: 10.1016/S2213-8587(15)00227-2. PMID: 26165396. Exclusion: wrong outcome.26165396
438 Poston L, Harthoorn LF, Van Der Beek EM, . Obesity in pregnancy: implications for the mother and lifelong health of the child. A consensus statement. Pediatr Res. 2011 Feb;69(2):175–80. doi: 10.1203/PDR.0b013e3182055ede. PMID: 21076366. Exclusion: wrong publication type.21076366
439 Power ML, Cogswell ME, Schulkin J. Obesity prevention and treatment practices of U.S. obstetrician-gynecologists. Obstet Gynecol. 2006 Oct;108(4):961–8. doi: 10.1097/01.AOG.0000233171.20484.db. PMID: 17012460. Exclusion: wrong study design.17012460
440 Poyatos-Leon R, Sanabria-Martinez G, Garcia-Prieto JC, . A follow-up study to assess the determinants and consequences of physical activity in pregnant women of Cuenca, Spain. BMC Public Health. 2016 May 25;16:437. doi: 10.1186/s12889-016-3130-x. PMID: 27411389. Exclusion: wrong publication type.27411389
441 Price BB, Amini SB, Kappeler K. Exercise in pregnancy: effect on fitness and obstetric outcomes-a randomized trial. Med Sci Sports Exerc. 2012 Dec;44(12):2263–9. doi: 10.1249/MSS.0b013e318267ad67. PMID: 22843114. Exclusion: wrong outcome.22843114
442 Price S, Nankervis A, Permezel M, . Health consequences for mother and baby of substantial pre-conception weight loss in obese women: study protocol for a randomized controlled trial. Trials. 2018 Apr 24;19(1):248. doi: 10.1186/s13063-018-2615-6. PMID: 29690917. Exclusion: wrong publication type.29690917
443 Quack Loetscher KC, Selvin S, Zimmermann R, . Ethnic-cultural background, maternal body size and pregnancy outcomes in a diverse Swiss cohort. Women Health. 2007 Oct 10;45(2):25–40. doi: 10.1300/J013v45n02_02. PMID: 18019284. Exclusion: wrong study design.18019284
444 Quansah DY, Gross J, Gilbert L, . Intuitive eating is associated with weight and glucose control during pregnancy and in the early postpartum period in women with gestational diabetes mellitus (GDM): a clinical cohort study. Eat Behav. 2019 Aug;34:101304. doi: 10.1016/j.eatbeh.2019.101304. PMID: 31154153. Exclusion: wrong population.31154153
445 Quinlivan JA, Julania S, Lam L. Antenatal dietary interventions in obese pregnant women to restrict gestational weight gain to Institute of Medicine recommendations: a meta-analysis. Obstet Gynecol. 2011 Dec;118(6):1395–401. doi: 10.1097/AOG.0b013e3182396bc6. PMID: 22105270. Exclusion: systematic review or meta-analysis used only as a source document for pearling.22105270
446 Quinlivan JA, Lam LT, Fisher J. A randomised trial of a four-step multidisciplinary approach to the antenatal care of obese pregnant women. Aust N Z J Obstet Gynaecol. 2011 Apr;51(2):141–6. doi: 10.1111/j.1479-828X.2010.01268.x. PMID: 21466516. Exclusion: wrong outcome.21466516
447 Radwan H, Hashim M, Shaker Obaid R, . The Mother-Infant Study Cohort (MISC): methodology, challenges, and baseline characteristics. PLoS ONE. 2018 May 31;13(5):e0198278. doi: 10.1371/journal.pone.0198278. PMID: 29851999. Exclusion: wrong study design.29851999
448 Raghavan R, Dreibelbis C, Kingshipp BL, . Dietary patterns before and during pregnancy and birth outcomes: a systematic review. Am J Clin Nutr. 2019 Mar 01;109(Supplement 7):729S–56S. doi: 10.1093/ajcn/nqy353. PMID: 30982873. Exclusion: systematic review or meta-analysis used only as a source document for pearling.30982873
449 Raisler J, Kennedy H. Midwifery care of poor and vulnerable women, 1925-2003. J Midwifery Womens Health. 2005 Mar–Apr;50(2):113–21. doi: 10.1016/j.jmwh.2004.12.010. PMID: 15749297. Exclusion: wrong publication type.15749297
450 Ramirez-Velez R. A 12-week exercise program performed during the second trimester does not prevent gestational diabetes in healthy pregnant women. J Physiother. 2012;58(3):198. doi: 10.1016/S1836-9553(12)70112-1. PMID: 22884188. Exclusion: wrong publication type.22884188
451 Ramirez-Velez R. Combined aerobic and resistance exercise on metabolic and body composition outcomes in primigravid Latina women. Obes Rev. 2014;15:201–2. Exclusion: wrong outcome.
452 Rauh K, Kunath J, Rosenfeld E, . Healthy living in pregnancy: a cluster-randomized controlled trial to prevent excessive gestational weight gain - rationale and design of the GeliS study. BMC Pregnancy Childbirth. 2014 Mar 28;14:119. doi: 10.1186/1471-2393-14-119. PMID: 24678761. Exclusion: wrong publication type.24678761
453 Reiss K, Breckenkamp J, Borde T, . The association of pre-pregnancy overweight and obesity with delivery outcomes: a comparison of immigrant and non-immigrant women in Berlin, Germany. Int J Public Health. 2016 May;61(4):455–63. doi: 10.1007/s00038-016-0825-9. PMID: 27165864. Exclusion: wrong study design.27165864
454 Renault KM, Carlsen EM, Norgaard K, . Intake of sweets, snacks and soft drinks predicts weight gain in obese pregnant women: detailed analysis of the results of a randomised controlled trial. PLoS ONE. 2015;10(7):e0133041. doi: 10.1371/journal.pone.0133041. PMID: 26192183. Exclusion: companion paper with outdated data, data not used for evidence.26192183
455 Restall A, Taylor RS, Thompson JM, . Risk factors for excessive gestational weight gain in a healthy, nulliparous cohort. J Obes. 2014 Jun 3;2014(148391) doi: 10.1155/2014/148391. PMID: 24995130. Exclusion: wrong study design.24995130
456 Reyes NR, Klotz AA, Herring SJ. A qualitative study of motivators and barriers to healthy eating in pregnancy for low-income, overweight, African-American mothers. J Acad Nutr Diet. 2013 Sep;113(9):1175–81. doi: 10.1016/j.jand.2013.05.014. PMID: 23871106. Exclusion: wrong study design.23871106
457 Rhodes ET, Pawlak DB, Takoudes TC, . Effects of a low-glycemic load diet in overweight and obese pregnant women: a pilot randomized controlled trial. Am J Clin Nutr. 2010 Dec;92(6):1306–15. doi: 10.3945/ajcn.2010.30130. PMID: 20962162. Exclusion: wrong outcome.20962162
458 Rissel C, Raymond J, Taylor K, . Get Healthy in Pregnancy - evaluation and outcomes report: a cluster randomised trial to evaluate the effectiveness of a telephone based coaching program in reducing excessive gestational weight gain amongst pregnant women NSW Ministry of Health. North Sydney: 2016. http://www.preventivehealth.net.au/uploads/2/3/5/3/23537344/ghip-outcomes_and_evaluation_report_final_updated_18_jan_2017.pdf. Exclusion: wrong publication type.
459 Robbins CL, D’Angelo D, Zapata L, . Preconception health indicators for public health surveillance. J Womens Health. 2018 Apr;27(4):430–43. doi: 10.1089/jwh.2017.6531. PMID: 29323604. Exclusion: wrong publication type.29323604
460 Robbins CL, Zapata LB, Farr SL, . Core state preconception health indicators - pregnancy risk assessment monitoring system and behavioral risk factor surveillance system, 2009. Morb Mortal Wkly Rep Surveill Summ. 2014 Apr 25;63(3):1–62. PMID: 24759729. Exclusion: wrong publication type.24759729
461 Robinson M, Zubrick SR, Pennell CE, . Pre-pregnancy maternal overweight and obesity increase the risk for affective disorders in offspring. J Dev Orig Health Dis. 2013 Feb;4(1):42–8. doi: 10.1017/S2040174412000578. PMID: 25080181. Exclusion: wrong study design.25080181
462 Rode L, Kjaergaard H, Ottesen B, . Association between gestational weight gain according to body mass index and postpartum weight in a large cohort of danish women. Matern Child Health J. 2012 Feb;16(2):406–13. doi: 10.1007/s10995-011-0775-z. PMID: 21431860 Exclusion: wrong study design.21431860
463 Rodriguez-Blanque R, Sanchez-Garcia JC, Manuel Sanchez-Lopez A, . Randomized clinical trial of an aquatic physical exercise program during pregnancy. J Obstet Gynecol Neonatal Nurs. 2019 May;48(3):321–31. doi: 10.1016/j.jogn.2019.02.003. PMID: 30953605. Exclusion: wrong outcome.30953605
464 Rogozinska E, Marlin N, Jackson L, . Effects of antenatal diet and physical activity on maternal and fetal outcomes: individual patient data meta-analysis and health economic evaluation. Health Technol Assess. 2017 Aug;21(41):1–158. doi: 10.3310/hta21410. PMID: 28795682. Exclusion: systematic review or meta-analysis used only as a source document for pearling.28795682
465 Ronnberg A, Hanson U, Ostlund I, . Effects on postpartum weight retention after antenatal lifestyle intervention - a secondary analysis of a randomized controlled trial. Acta Obstet Gynecol Scand. 2016 Sep;95(9):999–1007. doi: 10.1111/aogs.12910. PMID: 27100375. Exclusion: wrong study design.27100375
466 Ronnberg AK, Nilsson K. Interventions during pregnancy to reduce excessive gestational weight gain: a systematic review assessing current clinical evidence using the Grading of Recommendations, Assessment, Development and Evaluation (GRADE) system. BJOG. 2010 Oct;117(11):1327–34. doi: 10.1111/j.1471-0528.2010.02619.x. PMID: 20840691. Exclusion: systematic review or meta-analysis used only as a source document for pearling.20840691
467 Rono K, Stach-Lempinen B, Klemetti MM, . Prevention of gestational diabetes through lifestyle intervention: study design and methods of a Finnish randomized controlled multicenter trial (RADIEL). BMC Pregnancy Childbirth. 2014 Feb 14;14:70. doi: 10.1186/1471-2393-14-70. PMID: 24524674. Exclusion: wrong publication type.24524674
468 Rosenberg TJ, Garbers S, Lipkind H, . Maternal obesity and diabetes as risk factors for adverse pregnancy outcomes: differences among 4 racial/ethnic groups. Am J Public Health. 2005 Sep;95(9):1545–51. doi: 10.2105/AJPH.2005.065680. PMID: 16118366. Exclusion: wrong study design.16118366
469 Rosenbloom L, Buchert E, Vasiloff R, . Preventing excessive weight gain among publicly insured pregnant women. J Community Health. 2012 Oct;37(5):1066–70. doi: 10.1007/s10900-011-9539-3. PMID: 22227775. Exclusion: wrong study design.22227775
470 Rotheram-Fuller EJ, Swendeman D, Becker KD, . Replicating evidence-based practices with flexibility for perinatal home visiting by paraprofessionals. Matern Child Health J. 2017 Dec;21(12):2209–18. doi: 10.1007/s10995-017-2342-8. PMID: 28755042. Exclusion: wrong outcome.28755042
471 Ruchat SM, Davenport MH, Giroux I, . Nutrition and exercise reduce excessive weight gain in normal-weight pregnant women. Med Sci Sports Exerc. 2012 Aug;44(8):1419–26. doi: 10.1249/MSS.0b013e31825365f1. PMID: 22453250. Exclusion: wrong study design.22453250
472 Ruifrok AE, Althuizen E, Oostdam N, . The relationship of objectively measured physical activity and sedentary behaviour with gestational weight gain and birth weight. J Pregnancy. 2014 Sep;2014:567379. doi: 10.1155/2014/567379. PMID: 25309754. Exclusion: wrong study design.25309754
473 Ruifrok AE, Rogozinska E, van Poppel MN, . Study protocol: differential effects of diet and physical activity based interventions in pregnancy on maternal and fetal outcomes--individual patient data (IPD) meta-analysis and health economic evaluation. Syst Rev. 2014 Nov 04;3:131. doi: 10.1186/2046-4053-3-131. PMID: 25370505. Exclusion: wrong publication type.25370505
474 Ruifrok AE, van Poppel MN, van Wely M, . Association between weight gain during pregnancy and pregnancy outcomes after dietary and lifestyle interventions: a meta-analysis. Am J Perinatol. 2014 May;31(5):353–64. doi: 10.1055/s-0033-1352484. PMID: 23918523. Exclusion: systematic review or meta-analysis used only as a source document for pearling.23918523
475 Sanabria-Martinez G, Garcia-Hermoso A, Poyatos-Leon R, . Effectiveness of physical activity interventions on preventing gestational diabetes mellitus and excessive maternal weight gain: a meta-analysis. BJOG. 2015 Aug;122(9):1167–74. doi: 10.1111/1471-0528.13429. PMID: 26036300. Exclusion: systematic review or meta-analysis used only as a source document for pearling.26036300
476 Sanabria-Martinez G, Garcia-Hermoso A, Poyatos-Leon R, . Effects of exercise-based interventions on neonatal outcomes: a meta-analysis of randomized controlled trials. Am J Health Promot. 2016 Mar;30(4):214–23. doi: 10.1177/0890117116639569. PMID: 27404056. Exclusion: wrong publication type.27404056
477 Santos P, Hefele JG, Ritter G, . Population-based risk factors for shoulder dystocia. J Obstet Gynecol Neonatal Nurs. 2018 Jan;47(1):32–42. doi: 10.1016/j.jogn.2017.11.011. PMID: 29221671. Exclusion: wrong study design.29221671
478 Santos-Rocha R, Portela C, Santos T. Active pregnancy: effects of a physical exercise and nutritional counselling program on pregnant women’ lifestyle and new-born’s health (pilot study). J Perinat Med. World Congress of Perinatal Medicine 2015 Madrid Spain;43.:CONFERENCE START: 2015 Nov 3 CONFERENCE END: Nov 6. Exclusion: wrong publication type.
479 Sarwer DB, Allison KC, Gibbons LM, . Pregnancy and obesity: a review and agenda for future research. J Womens Health 2006 Jul–Aug;15(6):720–33. doi: 10.1089/jwh.2006.15.720. PMID: 16910904. Exclusion: wrong publication type.16910904
480 Savage JS, Downs DS, Dong Y, . Control systems engineering for optimizing a prenatal weight gain intervention to regulate infant birth weight. Am J Public Health. 2014 Jul;104(7):1247–54. doi: 10.2105/AJPH.2014.301959. PMID: 24832411. Exclusion: wrong study design.24832411
481 Savitsky LM, Valent A, Burwick R, . Cost-effectiveness of exercise for the prevention of preeclampsia and gestational diabetes in normal weight women. Am J Obstet Gynecol. 2017;Conference: 37th annual meeting of the society for maternal-fetal medicine: the pregnancy meeting. United states. Conference start:. 20170123. Conference end: 20170128 216(1 Supplement 1):S486. Exclusion: wrong publication type.
482 Schmidt MD, Pekow P, Freedson PS, . Physical activity patterns during pregnancy in a diverse population of women. J Womens Health. 2006 Oct;15(8):909–18. doi: 10.1089/jwh.2006.15.909. PMID: 17087614. Exclusion: wrong study design.17087614
483 Schmitt NM, Nicholson WK, Schmitt J. The association of pregnancy and the development of obesity - results of a systematic review and meta-analysis on the natural history of postpartum weight retention. Int J Obes 2007 Nov;31(11):1642–51. doi: 10.1038/sj.ijo.0803655. PMID: 17607325. Exclusion: wrong publication type.17607325
484 Schummers L, Hutcheon JA, Bodnar LM, . Risk of adverse pregnancy outcomes by prepregnancy body mass index: a population-based study to inform prepregnancy weight loss counseling. Obstet Gynecol. 2015 Jan;125(1):133–43. doi: 10.1097/AOG.0000000000000591. PMID: 25560115. Exclusion: wrong study design.25560115
485 Scott C, Andersen CT, Valdez N, . No global consensus: a cross-sectional survey of maternal weight policies. BMC Pregnancy Childbirth. 2014 May 15;14:167. doi: 10.1186/1471-2393-14-167. PMID: 24884985. Exclusion: wrong study design.24884985
486 Sebire NJ, Jolly M, Harris JP, . Maternal obesity and pregnancy outcome: a study of 287,213 pregnancies in London. Int J Obes. 2001 Aug;25(8):1175–82. doi: 10.1038/sj.ijo.0801670. PMID: 11477502. Exclusion: wrong study design.11477502
487 Seneviratne SN, Jiang Y, McCowan LM, . The improve randomised controlled trial: non-weight bearing antenatal exercise in overweight and obese women increases neonatal adiposity. Endocrine reviews. Conference: 97th annual meeting and expo of the endocrine society, ENDO. 2015;36. Exclusion: wrong publication type.
488 Shahnazi H, Abdolalian N, Kazemi A, . Designing an educational intervention to prevent excessive gestational weight gain: a protocol for a randomized controlled trial. Reprod Health. 2019 Mar 12;16(1):31. doi: 10.1186/s12978-019-0696-7. PMID: 30866980. Exclusion: wrong country.30866980
489 Sharma SV, Chuang R-J, Byrd-Williams C, . Pilot evaluation of HEAL - a natural experiment to promote obesity prevention behaviors among low-income pregnant women. Prev Med Rep. 2018 Jun;10:254–62. doi: 10.1016/j.pmedr.2018.04.005. PMID: 29868377. Exclusion: wrong study design.29868377
490 Shepherd E, Gomersall JC, Tieu J, . Combined diet and exercise interventions for preventing gestational diabetes mellitus. Cochrane Database Syst Rev. 2017 Nov 13;11:CD010443. doi: 10.1002/14651858.CD010443.pub3. PMID: 29129039. Exclusion: systematic review or meta-analysis used only as a source document for pearling.29129039
491 Sherifali D, Nerenberg KA, Wilson S, . The effectiveness of eHealth technologies on weight management in pregnant and postpartum women: systematic review and meta-analysis. J Med Internet Res. 2017 Oct 13;19(10):e337. doi: 10.2196/jmir.8006. PMID: 29030327. Exclusion: systematic review or meta-analysis used only as a source document for pearling.29030327
492 Shieh C, Cullen DL, Pike C, . Intervention strategies for preventing excessive gestational weight gain: systematic review and meta-analysis. Obes Rev. 2018 Aug;19(8):1093–109. doi: 10.1111/obr.12691. PMID: 29806187. Exclusion: systematic review or meta-analysis used only as a source document for pearling.29806187
493 Shieh C, Draucker CB. Self-monitoring lifestyle behavior in overweight and obese pregnant women: qualitative findings. Clin Nurse Spec. 2018 Mar/Apr;32(2):81–9. doi: 10.1097/NUR.0000000000000355. PMID: 29419580. Exclusion: wrong study design.29419580
494 Shieh C, Yang Z, Haas DM, . Feasibility and potential benefits of a self-monitoring enhanced lifestyle intervention to prevent excessive gestational weight gain in women who are overweight or obese. J Obstet Gynecol Neonatal Nurs. 2017 Mar – Apr;46(2):182–96. doi: 10.1016/j.jogn.2016.09.006. PMID: 28063804. Exclusion: wrong study design.28063804
495 Shirazian T, Faris BS, Fox NS, . The lifestyle modification project: limiting pregnancy weight gain in obese women. J Matern Fetal Neonatal Med. 2016 Dec 16;29(1):80–4. doi: 10.3109/14767058.2014.987118. PMID: 25394608. Exclusion: wrong study design.25394608
496 Shirazian T, Monteith S, Friedman F, . Lifestyle modification program decreases pregnancy weight gain in obese women. Am J Perinatol. 2010 May;27(5):411–4. doi: 10.1055/s-0029-1243368. PMID: 20013602. Exclusion: quality rating is poor.20013602
497 Sim KA, Dezarnaulds GM, Denyer GS, . Weight loss improves reproductive outcomes in obese women undergoing fertility treatment: a randomized controlled trial. Clin Obes. 2014 Apr;4(2):61–8. doi: 10.1111/cob.12048. PMID: 25826729. Exclusion: wrong population.25826729
498 Sim KA, Partridge SR, Sainsbury A. Does weight loss in overweight or obese women improve fertility treatment outcomes? A systematic review. Obes Rev. 2014 Oct;15(10):839–50. doi: 10.1111/obr.12217. PMID: 25132280. Exclusion: systematic review or meta-analysis used only as a source document for pearling.25132280
499 Simas TA, Liao X, Garrison A, . Impact of updated Institute of Medicine guidelines on prepregnancy body mass index categorization, gestational weight gain recommendations, and needed counseling. J Womens Health. 2011 Jun;20(6):837–44. doi: 10.1089/jwh.2010.2429. PMID: 21510805. Exclusion: wrong study design.21510805
500 Simmons D. Prevention of gestational diabetes mellitus: where are we now? Diabetes Obes Metab. 2015 Sep;17(9):824–34. doi: 10.1111/dom.12495. PMID: 25974384. Exclusion: wrong publication type.25974384
501 Simmons D, Devlieger R, van Assche A, . Association between gestational weight gain, gestational diabetes risk, and obstetric outcomes: a randomized controlled trial post hoc analysis. Nutrients. 2018 Oct 23;10(11):pii: E1568. doi: 10.3390/nu10111568. PMID: 30360536. Exclusion: wrong study design.30360536
502 Simmons D, Jelmsa J, Galjaard S, . Results from a European multicentre, randomised trial of physical activity and/or healthy eating to reduce the risk of gestational diabetes mellitus (GDM): the DALI pilot study. Diabetes. 2015;64(5). Exclusion: companion paper with outdated data, data not used for evidence.
503 Simmons D, Jelsma JG, Galjaard S, . Results from a European multicenter randomized trial of physical activity and/or healthy eating to reduce the risk of gestational diabetes mellitus: the DALI lifestyle pilot. Diabetes Care. 2015 Sep;38(9):1650–6. doi: 10.2337/dc15-0360. PMID: 26112044. Exclusion: companion paper with outdated data, data not used for evidence.26112044
504 Skau JK, Nordin AB, Cheah JC, . A complex behavioural change intervention to reduce the risk of diabetes and prediabetes in the pre-conception period in Malaysia: study protocol for a randomised controlled trial. Trials. 2016 Apr 27;17(1):215. doi: 10.1186/s13063-016-1345-x. PMID: 27117703. Exclusion: wrong publication type.27117703
505 Skouteris H, McCabe M, Milgrom J, . Protocol for a randomized controlled trial of a specialized health coaching intervention to prevent excessive gestational weight gain and postpartum weight retention in women: the HIPP study. BMC Public Health. 2012 Jan 25;12(78) doi: 10.1186/1471-2458-12-78. PMID: 22272935. Exclusion: wrong publication type.22272935
506 Skouteris H, Morris H, Nagle C, . Behavior modification techniques used to prevent gestational diabetes: a systematic review of the literature. Curr Diab Rep. 2014 Apr;14(4):480. doi: 10.1007/s11892-014-0480-6. PMID: 24554382. Exclusion: systematic review or meta-analysis used only as a source document for pearling.24554382
507 SMA. SMA statement the benefits and risks of exercise during pregnancy. Sport Medicine Australia. J Sci Med Sport. 2002 Mar;5(1):11–9. PMID: 12054382. Exclusion: wrong publication type.12054382
508 Song C, Li J, Leng J, . Lifestyle intervention can reduce the risk of gestational diabetes: a meta-analysis of randomized controlled trials. Obes Rev. 2016 Oct;17(10):960–9. doi: 10.1111/obr.12442. PMID: 27417680. Exclusion: wrong publication type.27417680
509 Spencer L, Rollo M, Hauck Y, . The effect of weight management interventions that include a diet component on weight-related outcomes in pregnant and postpartum women: a systematic review protocol. JBI Database System Rev Implement Rep. 2015 Jan;13(1):88–98. doi: 10.11124/jbisrir-2015-1812. PMID: 26447010. Exclusion: wrong publication type.26447010
510 Stafne SN, Salvesen KA, Romundstad PR, . Regular exercise during pregnancy to prevent gestational diabetes: a randomized controlled trial. Obstet Gynecol. 2012 Jan;119(1):29–36. doi: 10.1097/AOG.0b013e3182393f86. PMID: 22183208. Exclusion: wrong outcome.22183208
511 Steegers EA, Van Lakwijk HP, Jongsma HW, . (Patho)physiological implications of chronic dietary sodium restriction during pregnancy; a longitudinal prospective randomized study. Br J Obstet Gynaecol. 1991 Oct;98(10):980–7. PMID: 1751444. Exclusion: wrong intervention.1751444
512 Sternfeld B, Quesenberry CP, Jr., Eskenazi B, . Exercise during pregnancy and pregnancy outcome. Med Sci Sports Exerc. 1995 May;27(5):634–40. PMID: 7674866. Exclusion: wrong study design.7674866
513 Su T, Lu J, Ma H. Lifestyle intervention prevents pregnant woman from gestational diabetes mellitus: a Chinese randomized controlled trial. Int J Clin Exp Med. 2016;9(12):23584–90. Exclusion: wrong population.
514 Sui Z, Grivell RM, Dodd JM. Antenatal exercise to improve outcomes in overweight or obese women: a systematic review. Acta Obstet Gynecol Scand. 2012 May;91(5):538–45. doi: 10.1111/j.1600-0412.2012.01357.x. PMID: 22229625. Exclusion: systematic review or meta-analysis used only as a source document for pearling.22229625
515 Sun Y, Zhao H. The effectiveness of lifestyle intervention in early pregnancy to prevent gestational diabetes mellitus in Chinese overweight and obese women: a quasi-experimental study. Appl Nurs Res. 2016 May;30:125–30. doi: 10.1016/j.apnr.2015.10.006. PMID: 27091266. Exclusion: wrong country.27091266
516 Sydsjo G, Monfils WG, de Keyser N, . Effects of a weight-gain restriction programme for obese pregnant women on sickness absence and pregnancy benefits. Scand J Prim Health Care. 2013 Jun;31(2):106–10. doi: 10.3109/02813432.2012.754091. PMID: 23301596. Exclusion: wrong outcome.23301596
517 Symons Downs D, Savage JS, Rivera DE, . Individually tailored, adaptive intervention to manage gestational weight gain: protocol for a randomized controlled trial in women with overweight and obesity. JMIR Res Protoc. 2018 Jun 08;7(6):e150. doi: 10.2196/resprot.9220. PMID: 29884603. Exclusion: wrong publication type.29884603
518 Syngelaki A, Nicolaides KH, Balani J, . Metformin versus placebo in obese pregnant women without diabetes mellitus. N Engl J Med. 2016 Feb 4;374(5):434–43. doi: 10.1056/NEJMoa1509819. PMID: 26840133. Exclusion: wrong intervention.26840133
519 Szmeja MA, Cramp C, Grivell RM, . Use of a DVD to provide dietary and lifestyle information to pregnant women who are overweight or obese: a nested randomised trial. BMC Pregnancy Childbirth. 2014 Dec 12;14(409) doi: 10.1186/s12884-014-0409-8. PMID: 25495459. Exclusion: wrong comparator.25495459
520 Tanentsapf I, Heitmann BL, Adegboye AR. Systematic review of clinical trials on dietary interventions to prevent excessive weight gain during pregnancy among normal weight, overweight and obese women. BMC Pregnancy Childbirth. 2011 Oct 26;11(81) doi: 10.1186/1471-2393-11-81. PMID: 22029725. Exclusion: systematic review or meta-analysis used only as a source document for pearling.22029725
521 Taylor BJ, Gray AR, Galland BC, . Targeting sleep, food, and activity in infants for obesity prevention: an RCT. Pediatrics. 2017 Mar;139(3) doi: 10.1542/peds.2016-2037. PMID: 28242860. Exclusion: wrong intervention.28242860
522 Taylor BJ, Heath AL, Galland BC, . Prevention of Overweight in Infancy (POI.nz) study: a randomised controlled trial of sleep, food and activity interventions for preventing overweight from birth. BMC Public Health. 2011 Dec 19;11(942) doi: 10.1186/1471-2458-11-942. PMID: 22182309. Exclusion: wrong intervention.22182309
523 Teede HJ, Harrison CL, Gibson-Helm M, . Improving physical activity in high-risk pregnancies: a randomized controlled trial. Endocr Rev. Annual Meeting and Expo of the Endocrine Society, ENDO 2011 Boston, MA United States;32(3 Meeting Abstracts):CONFERENCE START: 2011 Jun 4 CONFERENCE END: Jun 7. Exclusion: wrong publication type.
524 Teede HJ, Lombard C, Harrison C. Optimising healthy gestational weight gain in women at high risk of gestational diabetes: a randomised controlled trial. Endocr Rev. Annual Meeting and Expo of the Endocrine Society, ENDO 2012 Houston, TX United States;33(3 MeetingAbstracts):CONFERENCE START: 2012 Jun 23 CONFERENCE END: Jun 26. Exclusion: wrong publication type.
525 Thangaratinam S, Marlin N, Dodds J, . Effects of diet and physical activity-based interventions on maternal and fetal outcomes in pregnancy-an individual patient data (IPD) meta-analysis of randomised trials. Am J Obstet Gynecol. 2017;Conference: 37th annual meeting of the society for maternal-fetal medicine: the pregnancy meeting. United states. Conference start:. 20170123. Conference end: 20170128 216(1 Supplement 1):S352–S3. Exclusion: wrong publication type.
526 Thangaratinam S, Rogozinska E, Jolly K, . Interventions to reduce or prevent obesity in pregnant women: a systematic review. Health Technol Assess. 2012 Jul;16(31):iii–iv, 1–191. doi: 10.3310/hta16310. PMID: 22814301. Exclusion: systematic review or meta-analysis used only as a source document for pearling.22814301
527 Thangaratinam S, Rogozinska E, Jolly K, . Effects of interventions in pregnancy on maternal weight and obstetric outcomes: meta-analysis of randomised evidence. Bmj. 2012 May 16;344:e2088. doi: 10.1136/bmj.e2088. PMID: 22596383. Exclusion: systematic review or meta-analysis used only as a source document for pearling.22596383
528 Thomson JL, Tussing-Humphreys LM, Goodman MH. Delta Healthy Sprouts: a randomized comparative effectiveness trial to promote maternal weight control and reduce childhood obesity in the Mississippi Delta. Contemp Clin Trials. 2014 May;38(1):82–91. doi: 10.1016/j.cct.2014.03.004. PMID: 24685997. Exclusion: wrong publication type.24685997
529 Thornton YS. Preventing excessive weight gain during pregnancy through dietary and lifestyle counseling: a randomized controlled trial. Obstet Gynecol. 2009 Jul;114(1):173; author reply -4. doi: 10.1097/AOG.0b013e3181ac3aa9. PMID: 19546789. Exclusion: wrong publication type.19546789
530 Tieu J, Coat S, Hague W, . Oral anti-diabetic agents for women with established diabetes/impaired glucose tolerance or previous gestational diabetes planning pregnancy, or pregnant women with pre-existing diabetes. Cochrane Database Syst Rev. 2017 Oct 18;10:CD007724. doi: 10.1002/14651858.CD007724.pub3. PMID: 29045765. Exclusion: wrong publication type.29045765
531 Tieu J, Shepherd E, Middleton P, . Interconception care for women with a history of gestational diabetes for improving maternal and infant outcomes. Cochrane Database Syst Rev. 2017 Aug 24;8:CD010211. doi: 10.1002/14651858.CD010211.pub3. PMID: 28836274. Exclusion: wrong publication type.28836274
532 Tieu J, Shepherd E, Middleton P, . Dietary advice interventions in pregnancy for preventing gestational diabetes mellitus. Cochrane Database Syst Rev. 2017 Jan 3;1(CD006674) doi: 10.1002/14651858.CD006674.pub3. PMID: 28046205. Exclusion: systematic review or meta-analysis used only as a source document for pearling.28046205
533 Timmermans Yeg VDKKDGRDKLMPDEKBWZLJIS-T. Towards Prepared mums (TOP-mums) for a healthy start, a lifestyle intervention for women with overweight and a child wish: study protocol for a randomised controlled trial in the Netherlands. BMJ Open. 2019;9(11) doi: 10.1136/bmjopen-2019-030236. PMID: 31748290. Exclusion: wrong publication type.31748290
534 Tobias DK, Stuart JJ, Li S, . Association of history of gestational diabetes with long-term cardiovascular disease risk in a large prospective cohort of US women. JAMA Intern Med. 2017 Dec 1;177(12):1735–42. doi: 10.1001/jamainternmed.2017.2790. PMID: 29049820. Exclusion: wrong study design.29049820
535 Trak-Fellermeier MA, Campos M, Meléndez M, . PEARLS randomized lifestyle trial in pregnant Hispanic women with overweight/obesity: gestational weight gain and offspring birthweight. Diabetes Metab Syndr Obes. 2019 Feb;12:225–38. doi: 10.2147/DMSO.S179009. PMID: 30858715. Exclusion: inadequate sample size.30858715
536 Tundidor D, Zawiejska A, Mathiesen E, . DALI lifestyle intervention in pregnant women with BMI >29 kg/m. Continuous glucose monitoring substudy. Diabetologia. 2016;Conference: 52nd annual meeting of the european association for the study of diabetes, EASD. 2016. Germany. Conference start: 20160912. Conference end: 20160916 59(1 Supplement 1):S449. Exclusion: wrong publication type.
537 Upadhyaya NB, Bryant SB, Heidel RE, . Early diagnosis of gestational diabetes mellitus in patients with elevated body mass index. Obstet Gynecol. 2015;125. Exclusion: wrong publication type.
538 Vahamiko S, Isolauri E, Laitinen K. Weight status and dietary intake determine serum leptin concentrations in pregnant and lactating women and their infants. Br J Nutr. 2013 Sep 28;110(6):1098–106. doi: 10.1017/S0007114513000214. PMID: 23432806. Exclusion: wrong outcome.23432806
539 Valkama A, Koivusalo S, Lindstrom J, . The effect of dietary counselling on diet in pregnant women at risk for gestational diabetes. Conference: 12th european nutrition conference, FENS. Ann Nutr Metab. 2015;67(138). Exclusion: wrong outcome.
540 Valkama A, Koivusalo S, Lindstrom J, . The effect of dietary counselling on food intakes in pregnant women at risk for gestational diabetes: a secondary analysis of a randomised controlled trial RADIEL. Eur J Clin Nutr. 2016 Aug;70(8):912–7. doi: 10.1038/ejcn.2015.205. PMID: 26669570. Exclusion: wrong outcome.26669570
541 Valkama AJ, Meinila J, Koivusalo S, . The effect of pre-pregnancy lifestyle counselling on food intakes and association between food intakes and gestational diabetes in high-risk women: results from a randomised controlled trial. J Hum Nutr Diet. 2018 Jun;31(3):301–5. doi: 10.1111/jhn.12547. PMID: 29468749. Exclusion: wrong outcome.29468749
542 Van Buul BJA, Steegers EAP, Van der Maten GD, . Dietary sodium restriction does not prevent gestational hypertension: a dutch two-center randomized trial. Hypertens. 1997 Jul 7;16(3):335–46. doi: 10.3109/10641959709031642 Exclusion: wrong intervention.
543 van der Maten GD. Low sodium diet in pregnancy: effects on maternal nutritional status. Eur J Obstet Gynecol Reprod Biol. 1995 Jul;61(1):63–4. doi: 10.1016/0028-2243(95)02154-K. PMID: 8549849. Exclusion: wrong publication type.8549849
544 van der Maten GD, van Raaij JM, Visman L, . Low-sodium diet in pregnancy: effects on blood pressure and maternal nutritional status. Br J Nutr. 1997 May;77(5):703–20. doi: 10.1079/BJN19970069. PMID: 9175991. Exclusion: wrong intervention.9175991
545 van Elten TM, van de Beek C, Geelen A, . Preconception lifestyle and cardiovascular health in the offspring of overweight and obese women. Nutrients. 2019 Oct 14;11(10):14. doi: 10.3390/nu11102446. PMID: 31615021. Exclusion: wrong outcome.31615021
546 Van Poppel M, Oostdam N, Wouters M, . FitFor2: effects of an exercise training program on the incidence of gestational diabetes. J Sci Med Sport. 2012;15(31). Exclusion: wrong outcome.
547 Van Poppel MN, Oostdam N, Wouters MG, . A training program for women at risk for gestational diabetes. Diabetes. 2011;60(24). Exclusion: wrong outcome.
548 van Zutphen M, Milder IE, Bemelmans WJ. Usage of an online healthy lifestyle program by pregnant women attending midwifery practices in Amsterdam. Prev Med. 2008 Jun 01;46(6):552–7. doi: 10.1016/j.ypmed.2008.01.003. PMID: 18302971 Exclusion: wrong outcome.18302971
549 Vanstone M, Kandasamy S, Giacomini M, . Pregnant women’s perceptions of gestational weight gain: a systematic review and meta-synthesis of qualitative research. Matern Child Nutr. 2017 Oct;13(4) doi: 10.1111/mcn.12374. PMID: 27873484. Exclusion: wrong publication type.27873484
550 Vesco K, Leo M, Gillman M, . Impact of a weight management intervention on pregnancy outcomes among obese women: the Healthy Moms Trial. Am J Obstet Gynecol. START: 2013 Feb 11 CONFERENCE END: 2013 Feb 16, 33rd Annual Meeting of the Society for Maternal-Fetal Medicine: The Pregnancy Meeting San Francisco, CA United States;208(1 SUPPL.1):S352. Exclusion: wrong publication type.
551 Vesco KK, Karanja N, King JC, . Healthy Moms, a randomized trial to promote and evaluate weight maintenance among obese pregnant women: study design and rationale. Contemp Clin Trials. 2012 Jul;33(4):777–85. doi: 10.1016/j.cct.2012.03.006. PMID: 22465256. Exclusion: wrong publication type.22465256
552 Vinter CA, Jensen DM, Ovesen PG, . Lifestyle and Pregnancy (LIP) study: the clinical effect of lifestyle intervention during pregnancy in obese women. Diabetes. 2011;60(24). Exclusion: wrong publication type.
553 Vinter CA, Jorgensen JS, Ovesen P, . Metabolic effects of lifestyle intervention in obese pregnant women. Results from the randomized controlled trial ‘Lifestyle in Pregnancy’ (LiP). Diabet Med. 2014 Nov;31(11):1323–30. doi: 10.1111/dme.12548. PMID: 24989831. Exclusion: wrong outcome.24989831
554 Vinter CA, Tanvig MH, Christensen MH, . Lifestyle intervention in Danish obese pregnant women with early gestational diabetes mellitus according to WHO 2013 criteria does not change pregnancy outcomes: results from the LiP (Lifestyle in Pregnancy) study. Diabetes Care. 2018 Oct;41(10):2079–85. doi: 10.2337/dc18-0808. PMID: 30061318. Exclusion: wrong population.30061318
555 Walker Lo KSSSB. Weight-loss resilience among low-income postpartum women: association with health habits effect of a low glycaemic index diet during pregnancy on maternal and cord blood metabolomic profiles: results from the ROLO randomized controlled trial. West J Nurs Res. 2019 Dec;41(12):1709–23. doi: 10.1177/0193945918824598. PMID: 30658560. Exclusion: wrong population.30658560
556 Walsh J, Mahony R, Foley M, . A randomised control trial of low glycaemic index carbohydrate diet versus no dietary intervention in the prevention of recurrence of macrosomia. BMC Pregnancy Childbirth. 2010 Apr 23;10(16) doi: 10.1186/1471-2393-10-16. PMID: 20416041. Exclusion: wrong publication type.20416041
557 Walsh J, McGowan C, Byrne J, . The influence of a low glycaemic index dietary intervention on maternal glycaemic index, dietary intake and gestational weight gain. Am J Obstet Gynecol. START: 2013 Feb 11 CONFERENCE END: 2013 Feb 16, 33rd Annual Meeting of the Society for Maternal-Fetal Medicine: The Pregnancy Meeting San Francisco, CA United States;208(1 SUPPL.1):S33. Exclusion: wrong publication type.
558 Walsh JM, Mahony RM, Canty G, . Identification of those most likely to benefit from a low-glycaemic index dietary intervention in pregnancy. Br J Nutr. 2014 Aug 28;112(4):583–9. doi: 10.1017/S000711451400110X. PMID: 24896237. Exclusion: wrong intervention.24896237
559 Walsh JM, McGowan CA, Mahony R, . Low glycaemic index diet in pregnancy to prevent macrosomia (ROLO study): randomised control trial. Bmj. 2012 Aug 30;345(e5605) doi: 10.1136/bmj.e5605. PMID: 22936795. Exclusion: wrong outcome.22936795
560 Wang C, Wei Y, Zhang X, . Effect of regular exercise commenced in early pregnancy on the incidence of gestational diabetes mellitus in overweight and obese pregnant women: a randomized controlled trial. Diabetes Care. 2016 Oct;39(10):e163–4. doi: 10.2337/dc16-1320. PMID: 27660125. Exclusion: wrong country.27660125
561 Wang C, Wei Y, Zhang X, . A randomized clinical trial of exercise during pregnancy to prevent gestational diabetes mellitus and improve pregnancy outcome in overweight and obese pregnant women. Am J Obstet Gynecol. 2017 Apr;216(4):340–51. doi: 10.1016/j.ajog.2017.01.037. PMID: 28161306. Exclusion: wrong country.28161306
562 Wang S, Ma J-M, Yang H-X. Lifestyle intervention for gestational diabetes mellitus prevention: a cluster-randomized controlled study. Chronic Dis Transl Med. 2015 Oct 21;1(3):169–74. doi: 10.1016/j.cdtm.2015.09.001. PMID: 29063004. Exclusion: wrong country.29063004
563 Washington Cole KO, Gudzune KA, Bleich SN, . Influence of the 5A’s counseling strategy on weight gain during pregnancy: an observational study. J Womens Health. 2017 Oct;26(10):1123–30. doi: 10.1089/jwh.2016.6115. PMID: 28525296. Exclusion: wrong study design.28525296
564 Webb JB, Siega-Riz AM, Dole N. Psychosocial determinants of adequacy of gestational weight gain. Obesity (Silver Spring). 2009 Feb;17(2):300–9. doi: 10.1038/oby.2008.490. PMID: 19008871. Exclusion: wrong study design.19008871
565 Weisman CS, Hillemeier MM, Downs DS, . Preconception predictors of weight gain during pregnancy: prospective findings from the Central Pennsylvania Women’s Health Study. Womens Health Issues. 2010 Mar–Apr;20(2):126–32. doi: 10.1016/j.whi.2009.12.002. PMID: 20133152. Exclusion: wrong study design.20133152
566 Weisman CS, Hillemeier MM, Downs DS, . Improving women’s preconceptional health: long-term effects of the Strong Healthy Women behavior change intervention in the central Pennsylvania Women’s Health Study. Womens Health Issues. 2011 July–Aug;21(4):265–71. doi: 10.1016/j.whi.2011.03.007. PMID: 21536455. Exclusion: wrong population.21536455
567 Weisman CS, Misra DP, Hillemeier MM, . Preconception predictors of birth outcomes: prospective findings from the central Pennsylvania Women’s Health Study. Matern Child Health J. 2011 Oct;15(7):829–35. doi: 10.1007/s10995-009-0473-2. PMID: 19472041. Exclusion: wrong study design.19472041
568 Wekker V, Van Dammen L, Van Oers AM, . Effect of a lifestyle intervention in obese infertile women on cardiometabolic health and quality of life: results of a randomised controlled trial. Hum Reprod. Conference: 33rd annual meeting of the european society of human reproduction and embryology. Switzerland. 2017;32:i28–i9. Exclusion: wrong population.
569 Wells CS, Schwalberg R, Noonan G, . Factors influencing inadequate and excessive weight gain in pregnancy: Colorado, 2000-2002. Matern Child Health J. 2006 Jan;10(1):55–62. doi: 10.1007/s10995-005-0034-2 PMID: 16496222. Exclusion: wrong study design.16496222
570 Whitaker KM. Patient and provider perceptions of weight gain, physical activity, and nutrition in pregnancy. Diss Abstr Int. 2016;76(10-B(E)). Exclusion: wrong study design.
571 Whitaker KM, Wilcox S, Liu J, . Patient and provider perceptions of weight gain, physical activity and nutrition counseling during pregnancy: a qualitative study. Womens Health Issues. 2016 Jan–Feb 11/24;26(1):116–22. doi: 10.1016/j.whi.2015.10.007. PMID: 26621605 Exclusion: wrong study design.26621605
572 Wilcox S, Liu J, Addy CL, . A randomized controlled trial to prevent excessive gestational weight gain and promote postpartum weight loss in overweight and obese women: Health In Pregnancy and Postpartum (HIPP). Contemp Clin Trials. 2018 Mar;66:51–63. doi: 10.1016/j.cct.2018.01.008. PMID: 29371061. Exclusion: wrong study design.29371061
573 Wilkinson SA, McIntyre HD. Evaluation of the ‘healthy start to pregnancy’ early antenatal health promotion workshop: a randomized controlled trial. BMC Pregnancy Childbirth. 2012 Nov 19;12(131) doi: 10.1186/1471-2393-12-131. PMID: 23157894. Exclusion: wrong outcome.23157894
574 Willcox JC, Campbell KJ, McCarthy EA, . Testing the feasibility of a mobile technology intervention promoting healthy gestational weight gain in pregnant women (txt4two) - study protocol for a randomised controlled trial. Trials. 2015 May 7;16(209) doi: 10.1186/s13063-015-0730-1. PMID: 25947578. Exclusion: wrong publication type.25947578
575 Yeo S, Walker JS, Caughey MC, . What characteristics of nutrition and physical activity interventions are key to effectively reducing weight gain in obese or overweight pregnant women? A systematic review and meta-analysis. Obes Rev. 2017 Apr;18(4):385–99. doi: 10.1111/obr.12511. PMID: 28177566. Exclusion: systematic review or meta-analysis used only as a source document for pearling.28177566
576 Zeron HM, Flores AP, Chavez AA, . Pregnancy weight gain limitation by a supervised nutritional program influences placental NF-kappaB/IKK complex expression and oxidative stress. Oman med. 2013 May;28(3):167–72. doi: 10.5001/omj.2013.48. PMID: 23772281. Exclusion: wrong outcome.23772281

## Appendix A6 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized Controlled Trials (RCTs) and Cohort Studies

Criteria:

- Initial assembly of comparable groups:
  - For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  - For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs

Definition of ratings based on above criteria:

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.

Poor: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Source: Procedure Manual. U.S. Preventive Services Task Force.

https://www.uspreventiveservicestaskforce.org/Page/Name/appendix-vi-criteria-for-assessing-internal-validity-of-individual-studies Accessed on 4/12/19.

## Appendix A7 Expert Reviewers of the Draft Report

❖ Patrick Catalano MD, Vice Chair of Obstetrics & Gynecology Research; Professor, Tufts University School of Medicine
❖ Rebecca Clifton PhD, Associate Research Professor, Milken Institute School of Public Health, George Washington University; Co-Investigator, Maternal Fetal Medicine Units Network, NICHD
❖ Alan Peaceman MD, Chief of Maternal Fetal Medicine, Professor, Department of Obstetrics and Gynecology, Northwestern University
❖ Scott K. Winiecki MD, Director, Safe Use Initiative, Professional Affairs and Stakeholder Engagement Staff, Center for Drug Evaluation and Research, U.S. Food and Drug Administration
❖ Brandy Peaker MD, MPH, Medical Advisor, Office of Public Health Scientific Services, Division of Public Health Information Dissemination, CDC
❖ Gretchen Buckler MD, MPH, CDR, USPHS Commissioned Corps Medical Officer, Clinical Research Office of Research on Women’s Health (ORWH)
❖ Elena Gorodetsky MD, PhD, Health Scientist Administrator/Research Program Officer, Office of Research on Women’s Health (ORWH)