# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Tina Fan, MD, MPH, Tracy Wolff, MD, MPH, and Quyen Ngo-Metzger, MD, MPH, of AHRQ; members of the U.S. Preventive Services Task Force who contributed to the decision analysis work plan; Douglas Corley, MD, PhD, MPH (Kaiser Permanente), Jennifer Croswell, MD, MPH (National Cancer Institute), and Jason A. Dominitz, MD, MHS (Veterans Affairs Puget Sound Health Care System and University of Washington), for their content expertise and review of the draft report; Deborah Schrag, MD, MPH (Dana-Farber Cancer Institute) for assistance with histology codes for colorectal cancer; the Multi-Society Task Force on Colorectal Cancer for sharing surveillance recommendations; Caitlin Senger, MPH (Kaiser Permanente EPC) for assistance and guidance; and John Clarke, MS, Zachary Dodge, MS, and Lon Sherritt, MPH (Cornerstone Systems Northwest) for development of interactive versions of many figures included in this report. The figures are available at https://resources.cisnet.cancer.gov/projects/#crcr/uspstf2021/explorer.