# Navigation

The text includes a large number of in-line references to Tables, Figures, Appendixes, and specific sections of the report.

Mac users can navigate directly to the referenced item by clicking on the name of the item.

PC users can navigate directly to the item by clicking on the name of the item while pressing the “control” key. To return to the original place in the text, click the back arrow key while pressing the “alt” key.