# Authors’ Contributions

Drs. Zauber, Kuntz, and Lansdorp-Vogelaar contributed equally to this report.