# Chapter 4 Discussion

The goal of this decision analysis was to estimate how the benefits, burden, and harms of screening average-risk, asymptomatic adults for colorectal cancer vary by class of screening modality, screening interval, age to begin screening, and age to end screening. The decision analysis examined a large number of screening strategies, with 8 screening modalities, 3 ages to begin screening, 4 ages to end screening, and multiple screening intervals. Analyses were also carried out under 3 assumptions about population risk of colorectal cancer, and they examined the sensitivity of results to reductions in the sensitivity of colonoscopy and the potential for targeted screening strategies based on race and sex.

This analysis is not intended for individual-level decision-making, which would consider information about personal risk and patient preferences that would likely affect screening behavior. Previous model-based analyses have evaluated screening strategies tailored to individuals at increased risk due to family history,^106^ genetics,^107^ and other reasons,^108^ comorbidity status,^109^ and screening history.^110^

## Summary of Findings

Compared to no screening, all of the colorectal cancer screening strategies evaluated by the models were estimated to yield substantial increases in both life expectancy (171 to 381 LYG per 1000 40-year-olds) and quality-adjusted life expectancy (144 to 358 QALYG per 1000) and substantial reductions in the estimated lifetime number of colorectal cancer cases (16 to 74 cases averted per 1000) and colorectal cancer deaths (15 to 32 deaths averted per 1000).^‡‡^ In consultation with USPSTF members, this report focuses on the estimated number of LYG as the primary measure of the benefit of screening, although numbers of other events are also provided. Across screening strategies estimated LYG from screening were lowest with FIT 55-70, 3 and highest with COL 45-85, 5. The estimated number of colonoscopies needed to achieve these benefits was generally lowest for FIT and highest for colonoscopy, and strategies with fewer colonoscopies also resulted in fewer harms from screening. Although non-colonoscopy screening modalities do not require screening colonoscopies, they still require colonoscopies for follow-up of positive tests, for surveillance, and for detection of colorectal cancer by symptoms. The estimated number of such colonoscopies varied by modality and ranged from 0.6 to 2.0 per person with FIT, 1.1 to 2.9 per person with sDNA-FIT, 0.9 to 2.2 per person with sigmoidoscopy, and 0.9 to 1.9 per person with CTC.

Efficient screening strategies within a class of screening modality are those that best balance the burden and benefits of screening, with burdens measured in terms of the estimated number of colonoscopies. This decision analysis focused on describing screening strategies that were efficient based on estimated LYG, and not on identifying a best set of strategies. Efficiency ratios were only used to compare strategies within a class of screening modality. Many screening strategies were efficient across classes of screening modalities, and with some exceptions, results were similar across models. Across three scenarios for increasing population risk of colorectal cancer, most of the strategies that were efficient across all 3 models specified screening beginning at age 45.

Table 15 summarizes the strategies that were efficient across all 3 models with estimated LYG as the measure of the benefit of screening and IRR of 1.19. [Efficient strategies with estimated QALYG as the measure of benefit were nearly identical to those identified based on estimated LYG, and findings were generally robust across the 3 scenarios of population risk of colorectal cancer.] Table 15 also includes the strategies highlighted by the USPSTF in 2016, for comparison. Summarizing across the 57 efficient strategies is challenging, but we offer some observations below.

Table 15 Estimated Outcomes for Strategies That Were Efficient With SimCRC, CRC-SPIN, and MISCAN With Estimated Life-Years Gained as the Measure of Screening Benefit

Class of modality | Unique strategies simulated, N | Efficient strategies with all models^†^ | | Range of outcomes per 1000 across models | | | | | | | DLG | Efficiency ratio (Δ COL / Δ LYG)^§^ | Alternative ratio (Δ DLG / Δ COL)^§^
Class of modality | Unique strategies simulated, N | N | Strategy | COLs | Non-COL tests^‡^ | Compli-cations | CRC cases | CRC deaths | LYG | QALYG | DLG | Efficiency ratio (Δ COL / Δ LYG)^§^ | Alternative ratio (Δ DLG / Δ COL)^§^
Colonoscopy | 26 | 11 | COL 55-70, 15 | 2532-2630 | 0 | 13-14 | 21-40 | 7-11 | 250-285 | 223-265 | 91-104 | -- | --
Colonoscopy | 26 | 11 | COL 50-70, 15 | 2734-2868 | 0 | 11-13 | 18-40 | 6-11 | 264-318 | 237-298 | 96-116 | 6^*^-18 | 21-61^*^
Colonoscopy | 26 | 11 | COL 45-70, 15 | 2829-3006 | 0 | 10-12 | 18-41 | 6-12 | 265-336 | 240-316 | 97-123 | 6-85^*^ | 4^*^-63
Colonoscopy | 26 | 11 | COL 45-75, 15 | 3463-3558 | 0 | 15-16 | 14-37 | 4-10 | 281-352 | 253-331 | 103-129 | 38^*^-59^*^ | 6^*^-10^*^
Colonoscopy | 26 | 11 | COL 45-70, 10 | 3679-3782 | 0 | 12-14 | 13-37 | 4-10 | 292-361 | 265-340 | 107-132 | 34-45 | 8-11
Colonoscopy | 26 | 11 | COL 45-75, 10 | 4212-4300 | 0 | 15-17 | 12-34 | 3-8 | 301-369 | 272-347 | 110-135 | 52-112 | 3-7
Colonoscopy | 26 | 11 | COL 45-85, 10 | 4449-4566 | 0 | 17-19 | 11-34 | 3-8 | 302-370 | 273-347 | 110-135 | 227^*^-828^*^ | 0^*^-2^*^
Colonoscopy | 26 | 11 | COL 45-70, 5 | 5626-5789 | 0 | 15-17 | 10-32 | 3-8 | 318-377 | 288-355 | 116-138 | 84-180^*^ | 2^*^-4
Colonoscopy | 26 | 11 | COL 45-75, 5 | 6016-6235 | 0 | 17-19 | 10-31 | 3-7 | 321-380 | 291-357 | 117-139 | 116-344 | 1-3
Colonoscopy | 26 | 11 | COL 45-80, 5 | 6320-6581 | 0 | 19-20 | 9-30 | 2-7 | 323-381 | 293-358 | 118-139 | 169-736 | 0-2
Colonoscopy | 26 | 11 | COL 45-85, 5 | 6516-6817 | 0 | 20-22 | 9-30 | 2-7 | 323-381 | 293-358 | 118-139 | 926-2190 | 0-0
COL strategy highlighted in 2016 | | | COL 50-75, 10 | 3414-3500 | 0 | 13-15 | 15-36 | 5-9 | 286-335 | 257-314 | 104-122 | D, D, 28 | D, D, 13
FIT or sDNA-FIT | 72 | 16 | FIT 55-70, 3 | 624-754 | 4637-4710 | 5-7 | 47-65 | 17-20 | 171-203 | 144-181 | 63-74 | -- | --
FIT or sDNA-FIT | 72 | 16 | FIT 50-70, 3 | 691-858 | 5663-5757 | 5-7 | 43-64 | 15-20 | 184-231 | 156-208 | 67-84 | 2-6^*^ | 65^*^-155
FIT or sDNA-FIT | 72 | 16 | FIT 45-70, 3 | 810-1007 | 7299-7435 | 6-8 | 38-62 | 13-18 | 205-266 | 175-241 | 75-97 | 3-6^*^ | 59^*^-106
FIT or sDNA-FIT | 72 | 16 | FIT 45-75, 3 | 917-1110 | 8300-8475 | 7-9 | 36-60 | 11-16 | 226-286 | 192-258 | 82-104 | 5-7^*^ | 49^*^-68
FIT or sDNA-FIT | 72 | 16 | FIT 45-80, 3 | 971-1163 | 8866-9043 | 8-10 | 35-60 | 10-14 | 233-293 | 198-264 | 85-107 | 6-8^*^ | 44^*^-59
FIT or sDNA-FIT | 72 | 16 | FIT 45-75, 2 | 1147-1361 | 11420-11731 | 8-11 | 29-55 | 9-13 | 256-318 | 221-289 | 93-116 | 7-9 | 39-50
FIT or sDNA-FIT | 72 | 16 | FIT 45-80, 2 | 1220-1426 | 12249-12576 | 9-12 | 28-54 | 7-12 | 264-325 | 227-295 | 96-119 | 8-12 | 29-47
FIT or sDNA-FIT | 72 | 16 | FIT 45-85, 2 | 1288-1492 | 13160-13487 | 10-13 | 27-54 | 6-11 | 269-329 | 231-298 | 98-120 | 12-25^*^ | 14^*^-31
FIT or sDNA-FIT | 72 | 16 | FIT 45-75, 1 | 1602-1824 | 18950-19680 | 10-13 | 20-46 | 6-10 | 291-348 | 256-321 | 106-127 | 15^*^-16 | 22-25^*^
FIT or sDNA-FIT | 72 | 16 | FIT 45-80, 1 | 1710-1923 | 20622-21368 | 11-14 | 19-45 | 5-9 | 300-355 | 263-326 | 110-129 | 14-27 | 13-27
FIT or sDNA-FIT | 72 | 16 | FIT 45-85, 1 | 1769-1990 | 21850-22567 | 12-15 | 19-44 | 4-8 | 303-356 | 266-328 | 111-130 | 19-43 | 8-19
FIT or sDNA-FIT | 72 | 16 | sDNA-FIT 45-80, 2 | 2012-2181 | 9928-10167 | 11-14 | 18-43 | 5-9 | 298-356 | 262-329 | 109-130 | 26^*^-176^*^ | 2^*^-14^*^
FIT or sDNA-FIT | 72 | 16 | sDNA-FIT 45-85, 2 | 2114-2275 | 10620-10828 | 13-15 | 17-42 | 4-8 | 301-358 | 265-330 | 110-131 | 69^*^-375^*^ | 1^*^-5^*^
FIT or sDNA-FIT | 72 | 16 | sDNA-FIT 45-75, 1 | 2462-2617 | 13494-13888 | 12-14 | 15-38 | 4-9 | 306-363 | 272-337 | 112-133 | 53-251^*^ | 1^*^-7
FIT or sDNA-FIT | 72 | 16 | sDNA-FIT 45-80, 1 | 2614-2758 | 14608-14966 | 13-15 | 14-37 | 4-8 | 311-367 | 277-340 | 114-134 | 62-104^*^ | 4^*^-6
FIT or sDNA-FIT | 72 | 16 | sDNA-FIT 45-85, 1 | 2713-2856 | 15424-15721 | 14-16 | 14-36 | 3-8 | 313-368 | 278-341 | 114-134 | 94-111 | 3-4
FIT and sDNA-FIT strategies highlighted in 2016 | | | sDNA-FIT 50-75, 3 | 1405-1576 | 5939-6074 | 9-12 | 26-50 | 8-12 | 257-304 | 223-278 | 94-111 | D, D, D | D, D, D
FIT and sDNA-FIT strategies highlighted in 2016 | | | FIT 50-75, 1 | 1423-1619 | 15562-16160 | 9-12 | 23-47 | 7-11 | 274-316 | 240-289 | 100-115 | D, D, 29^*^ | D, D, 13^*^
FIT and sDNA-FIT strategies highlighted in 2016 | | | sDNA-FIT 50-75, 1 | 2156-2295 | 11132-11463 | 11-14 | 18-39 | 6-9 | 290-330 | 257-305 | 106-121 | D, D, D | D, D, D
SIG | 20 | 7 | SIG 55-70, 10 | 907-1340 | 1623-1708 | 7-10 | 35-48 | 13-16 | 204-210 | 182-197 | 74-77 | -- | --
SIG | 20 | 7 | SIG 45-70, 10 | 1155-1635 | 2480-2622 | 7-10 | 29-45 | 11-14 | 234-262 | 210-246 | 85-96 | 4-73^*^ | 5^*^-86
SIG | 20 | 7 | SIG 45-75, 10 | 1360-1800 | 2946-3173 | 9-12 | 26-43 | 9-12 | 245-278 | 220-260 | 90-101 | 13^*^-18 | 21-27^*^
SIG | 20 | 7 | SIG 45-70, 5 | 1586-2020 | 4013-4446 | 9-11 | 25-40 | 9-12 | 263-302 | 237-284 | 96-110 | 11-20 | 18-34
SIG | 20 | 7 | SIG 45-75, 5 | 1680-2119 | 4389-4935 | 10-12 | 24-39 | 8-11 | 269-309 | 241-289 | 98-113 | 19-27 | 13-19
SIG | 20 | 7 | SIG 45-80, 5 | 1749-2196 | 4681-5326 | 11-13 | 23-38 | 7-10 | 271-311 | 244-291 | 99-114 | 29-49 | 7-12
SIG | 20 | 7 | SIG 45-85, 5 | 1793-2235 | 4877-5602 | 12-13 | 23-38 | 7-10 | 272-312 | 244-292 | 99-114 | 78-98 | 4-5
SIG strategy highlighted in 2016 | | | SIG 50-75, 5 | 1510-1927 | 3646-4134 | 10-12 | 26-40 | 9-11 | 256-279 | 229-260 | 93-102 | D, D, 19^*^ | D, D, 19^*^
SIG+FIT | 24 | 10 | SIG+FIT 55-70, 10_2 | 1230-1547 | 6084-6685 | 8-11 | 27-45 | 9-13 | 241-266 | 213-245 | 88-97 | -- | --
SIG+FIT | 24 | 10 | SIG+FIT 50-70, 10_2 | 1512-1835 | 8519-9277 | 9-12 | 22-42 | 7-11 | 274-314 | 243-291 | 100-115 | 6^*^-9 | 42-63^*^
SIG+FIT | 24 | 10 | SIG+FIT 45-70, 10_2 | 1617-1947 | 10174-11005 | 9-12 | 20-42 | 7-11 | 280-340 | 250-316 | 102-124 | 5-24^*^ | 15^*^-70
SIG+FIT | 24 | 10 | SIG+FIT 45-75, 10_2 | 1835-2130 | 11710-12693 | 11-13 | 18-39 | 5-9 | 294-354 | 262-329 | 108-129 | 15-22 | 17-24
SIG+FIT | 24 | 10 | SIG+FIT 45-80, 10_2 | 1889-2154 | 12266-13375 | 11-14 | 17-39 | 4-9 | 296-357 | 264-331 | 108-130 | 15-25 | 15-24
SIG+FIT | 24 | 10 | SIG+FIT 45-70, 10_1 | 1903-2148 | 15867-17141 | 10-13 | 17-40 | 6-10 | 292-353 | 261-329 | 107-129 | 19^*^-88^*^ | 4^*^-20^*^
SIG+FIT | 24 | 10 | SIG+FIT 45-85, 10_2 | 1988-2235 | 13131-14286 | 13-15 | 17-39 | 4-8 | 298-358 | 265-332 | 109-131 | 38^*^-78^*^ | 5^*^-10^*^
SIG+FIT | 24 | 10 | SIG+FIT 45-75, 10_1 | 2102-2331 | 17858-19217 | 11-14 | 15-37 | 4-9 | 304-363 | 272-338 | 111-133 | 22^*^-34 | 11-17^*^
SIG+FIT | 24 | 10 | SIG+FIT 45-80, 10_1 | 2203-2379 | 19076-20649 | 12-15 | 15-37 | 4-8 | 307-366 | 274-340 | 112-134 | 21-53 | 7-17
SIG+FIT | 24 | 10 | SIG+FIT 45-85, 10_1 | 2293-2463 | 20204-21763 | 14-16 | 14-37 | 3-8 | 309-367 | 275-341 | 113-134 | 46-81 | 5-8
SIG+FIT strategy highlighted in 2016 | | | SIG+FIT 50-75, 10_1 | 1840-2048 | 14257-15636 | 11-13 | 18-39 | 6-10 | 287-330 | 255-306 | 105-121 | D, D, 18^*^ | D, D, 21^*^
CTC | 20 | 5 | CTC 55-70, 10 | 939-1029 | 1695-1705 | 7-9 | 32-57 | 12-19 | 181-245 | 159-227 | 66-90 | -- | --
CTC | 20 | 5 | CTC 45-70, 5 | 1569-1677 | 4372-4436 | 9-11 | 20-45 | 6-12 | 271-348 | 241-326 | 99-127 | 11-21^*^ | 17^*^-33
CTC | 20 | 5 | CTC 45-75, 5 | 1672-1791 | 4804-4893 | 10-13 | 18-42 | 5-11 | 283-355 | 251-332 | 103-130 | 11-21 | 17-33
CTC | 20 | 5 | CTC 45-80, 5 | 1744-1882 | 5131-5254 | 11-14 | 17-40 | 4-9 | 288-358 | 256-335 | 105-131 | 13-38 | 10-28
CTC | 20 | 5 | CTC 45-85, 5 | 1790-1939 | 5348-5504 | 12-15 | 17-40 | 4-9 | 290-359 | 257-335 | 106-131 | 32-104 | 4-12
CTC strategy highlighted in 2016 | | | CTC 50-75, 5 | 1519-1626 | 4006-4088 | 10-12 | 20-43 | 6-11 | 268-325 | 238-302 | 98-119 | D, D, 9 | D, D, 41
Total | 162 | 49

COL – colonoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – range across models of days of life gained per person, compared with no screening; D – dominated; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

† For comparison purposes, the strategies highlighted by the USPSTF in 2016) are included even though they are not efficient in all 3 models.

‡ For SIG+FIT, this is the sum of the 2 tests. Numbers of each test can be found in Appendix Table 9.5.

§ The strategies highlighted by the USPSTF in 2016 were not efficient in all 3 models. For these strategies, the efficiency ratio and alternative ratio columns indicate whether the 2016 highlighted strategy was dominated and not near efficient (D) or if efficient, the efficiency ratio (or alternative ratio) in the SimCRC, CRC-SPIN, and MISCAN models, respectively. For all other strategies, these columns indicate the range of efficiency ratios/alternative ratios across the 3 models.

Note: For comparison purposes, the strategies highlighted in the 2016 USPSTF recommendations are included (in gray) even though they are not efficient in all 3 models. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

The estimated numbers of colonoscopies and colonoscopy complications were highest with colonoscopy screening alone (as many as 6.5 to 6.8 lifetime colonoscopies per person). They were generally lowest with FIT (at most 1.8 to 2.0 colonoscopies per person), followed by CTC and sigmoidoscopy (at most 1.8 to 1.9 and 1.8 to 2.2 lifetime colonoscopies per person, respectively). Among the stool-based options, the estimated number of colonoscopies was higher with sDNA-FIT compared with FIT alone (at most 2.7 to 2.9 vs 1.8 to 2.0 colonoscopies per person). The risk of serious complications was generally low (at most 22 per 1000 with COL 45-85, 5). Even the most intensive sigmoidoscopy -alone strategy (SIG 45-85, 5) generally had lower estimated LYG and more estimated colorectal cancer deaths than efficient strategies with other classes of modalities. Estimated LYG and colorectal cancer deaths with SIG 45-85, 5 were comparable to those estimated for biennial FIT from age 45 to age 75, 80, or 85.

With the exception of colonoscopy strategies with a 5-year screening interval, for each colonoscopy screening strategy that was efficient with all 3 models there is generally a strategy from each class of modality (potentially with the exception of sigmoidoscopy alone) that yields similar estimated LYG, colorectal cancer deaths, and/or number of complications. For example, strategies with similar estimated LYG and colorectal cancer deaths per 1000 as COL 45-70, 10 (292 to 361 LYG; 4-10 colorectal cancer deaths) include:

- FIT 45-75, 1 (291 to 348 LYG; 6-10 colorectal cancer deaths);
- FIT 45-80, 1 (300 to 355 LYG; 5-9 colorectal cancer deaths);
- SIG+FIT 45-75, 10_2 (294 to 354 LYG; 5 to 9 colorectal cancer deaths);
- SIG+FIT 45-80, 10_2 (296 to 357 LYG; 4 to 9 colorectal cancer deaths);
- SIG+FIT 45-85, 10_2 (298 to 358 LYG; 4 to 8 colorectal cancer deaths);
- SIG+FIT 45-75, 10_1 (304 to 363 LYG; 4 to 9 colorectal cancer deaths);
- CTC 45-80, 5 (288 to 358 LYG; 4 to 9 colorectal cancer deaths);
- CTC 45-85, 5 (290 to 359 LYG; 4 to 9 colorectal cancer deaths).

A similar exercise can be undertaken for other strategies that are of particular interest.

Finally, the majority of efficient strategies with all 3 models were those with screening starting at age 45 (41/49). With the exception of the efficient FIT strategies, the efficiency ratio generally increased sharply among strategies in which screening continues beyond age 75 (assuming full adherence with prior screening), indicating an increasing number of colonoscopies is needed for a limited increase in LYG. For colonoscopy, there is a sharp increase in efficiency ratio with strategies involving 5-yearly screening, while with stool-based screening the efficiency ratio almost quadruples for strategies involving sDNA-FIT. An alternative way to present the results is in terms of the additional days of life gained per additional colonoscopy performed. Compared to the next-best option, an estimated 8 to 11 additional days of life are gained per additional colonoscopy performed with COL 45-70, 10, and an estimated 3 to 7 days are gained per additional colonoscopy performed with COL 45-75, 10. The estimated number of additional days gained per additional colonoscopy approaches 0 with COL 45-85, 10, or when the colonoscopy screening interval is every 5 years.

Scenario analyses examined whether the balance of colonoscopy burden and LYG from screening differed by race and sex. As noted in Analyses by Race and Sex, the analyses were limited to Black and White race and assumed racial differences in only all-cause mortality^53^ and in survival from colorectal cancer following diagnosis.^48^ Despite the assumption that the risk of developing adenomas and their progression to colorectal cancer in the absence of screening was the same among Black adults and White adults, the models did not estimate the same lifetime risk of colorectal cancer diagnosis by race. Due to higher age-specific rates of death among Black adults compared to White adults,^53^ the models estimated that a smaller proportion of an initial cohort of 40-year-old Black adults would be alive at older ages where the risk of colorectal cancer diagnosis is highest, and therefore the estimated lifetime risk of colorectal cancer diagnosis was lower among a cohort of Black adults compared to a cohort of White adults by sex (Table 10). Among Black males, this lower estimated lifetime incidence of colorectal cancer compared to White males also resulted in a lower estimated lifetime risk of colorectal cancer death, despite the higher risk of dying from colorectal cancer among Black colorectal cancer patients compared to White colorectal cancer patients.^48^ Among Black females, the lower estimated lifetime incidence of colorectal cancer was offset by the higher risk of colorectal cancer death among Black colorectal cancer patients compared with White colorectal cancer patients, resulting in a slightly higher estimated lifetime risk of colorectal cancer death among a cohort of Black females compared to a cohort of White females.

Despite these differences in the absence of screening, the models estimated that there was little advantage to customizing screening by race and sex; while the estimated LYG from screening were lower for Black males compared with White males (but similar for Black females and White females), efficient strategies identified for each race-sex group were generally the same as those for the population as a whole (Appendix Figures 11.1 and 11.2), and efficiency ratios were similar by race for each sex (Tables 11–12). As noted in Analyses by Race and Sex, while access to screening is thought to be the largest driver of Black-White differences in colorectal cancer incidence, differences in biology^111,112^ and/or risk factors^113,114^ may also contribute. In that event, it is possible that efficient strategies and their efficiency ratios would vary by race.

The model finding that, in the absence of screening, the incidence of colorectal cancer is lower in Black adults than in White adults may appear to be inconsistent with SEER data that show higher incidence of colorectal cancer among Black adults.^115^ However, SEER data are in the presence of screening, while the model estimates are in the absence of screening. It is important to consider historical disadvantages of Black adults especially as it relates to receipt of medical care. Black adults are less likely to be up-to-date with colorectal cancer screening recommendations, to undergo follow-up colonoscopy after a positive non-colonoscopy screening test, and to be screened by endoscopists with higher adenoma detection rates.^74^

Similar to the finding that efficient strategies were similar by race and sex, scenario analyses demonstrated that efficient strategies were similar across 3 scenarios for population risk of colorectal cancer, including one in which the assumed risk increase is less conservative than the assumption for the base-case analysis. However, at the highest level of risk increase evaluated (IRR of 1.52), efficiency ratios were generally lower than for the base-case analysis, indicating that at this rate of risk increase, more intensive strategies could result in a similar balance between colonoscopy burden and LYG as less intensive strategies in the base-case.

Based on sensitivity analysis, we did not find evidence that reduced sensitivity of colonoscopy would result in different efficient colonoscopy and FIT strategies.

Across the 3 models, the estimated benefits and colonoscopy burden of screening were generally highest with SimCRC and lowest with MISCAN, with results from CRC-SPIN falling in between. The SimCRC and CRC-SPIN models estimated that most (and often, nearly all) of the efficient strategies would begin at age 45. While the strategies starting at age 45 that were efficient with SimCRC and CRC-SPIN were generally also efficient with MISCAN, MISCAN found strategies with screening beginning at age 50 or even at age 55 were also efficient. Based on prior extensive work to understand the differences in the models,^76,77^ we believe that differences in outcomes across models are primarily attributable to differences in adenoma dwell times. As explained in the section “Natural History Component”, MISCAN simulates a shorter adenoma dwell time than the SimCRC and CRC-SPIN models (Table 2), which arises from the assumption that some adenomas are non-progressive. The probability that an adenoma in MISCAN is progressive increases with the age at adenoma initiation (see Progression to Preclinical Colorectal Cancer). CRC-SPIN also allows the risk of adenoma progression to be a function of the age at adenoma initiation, but all adenomas in CRC-SPIN have the potential to progress. In SimCRC, the risk of progression is based on the current age, not the age at adenoma initiation, and as with CRC-SPIN, all adenomas have the potential to progress. We suspect that the smaller incremental estimated benefit from a first screen with adenoma removal at age 45 compared to a first screen with adenoma removal at age 50 in MISCAN compared to the other 2 models is attributable to MISCAN’s assumption that an adenoma that forms between ages 45 and 50 is more likely to be progressive and has a higher risk of progression than an adenoma that forms before age 45.

Unlike the age to begin screening, there were no consistent patterns across models in the age to end screening. For colonoscopy screening, efficiency ratios were relatively high when screening was extended to age 80 or 85 (>169 additional colonoscopies per LYG; Table 15), assuming full adherence with prior screening; efficiency ratios were considerably lower for the efficient FIT strategies with all 3 models with screening to age 85 (< 43 additional colonoscopies per LYG). With sigmoidoscopy and CTC strategies, the efficiency ratio increased substantially when an additional screening colonoscopy was performed at age 85 (Table 15).

Two models (SimCRC and CRC-SPIN) found that the screening strategies highlighted by the USPSTF in 2016 were not among the efficient options at any IRR^§§^ (see Table 9 for IRR = 1.19; the efficiency of these strategies with IRR = 1 and IRR = 1.52 can be gleaned from Appendix Tables 14.1–14.7). With MISCAN, all strategies highlighted by the USPSTF in 2016 were efficient options in this analysis with IRR = 1 and IRR = 1.19, with the exception of the 2 highlighted sDNA-FIT strategies; these strategies were not efficient at any of the 3 IRRs with any model. Additionally, at IRR = 1.52, FIT 50-75, 1 was no longer an efficient option with MISCAN. As summarized in Table 15, in the current analysis, many strategies within each class of screening modality were efficient with all 3 models; across classes of modalities, 49 strategies were efficient with all 3 models. [Note that the strategies highlighted by the USPSTF in 2016 were generally only efficient in the 2016 analysis when strategies with screening beginning at age 45 were removed from consideration – see Knudsen et al.^16^ for details. Even then, the USPSTF-highlighted strategy of sDNA-FIT every 3 years was not efficient with any of the models.]

Estimation of the tradeoffs involved with starting screening at age 45 vs age 50 is challenging because multiple strategies with screening starting at age 45 are efficient (Table 15). Figure 27 and Tables 16–22 show the changes in model-estimated outcomes for the strategies highlighted by the USPSTF in 2016 if screening were to begin at age 45 instead of age 50, and Tables 16–22 compare these changes with those from the 2016 decision analysis. Despite different assumptions about colorectal cancer risk (IRR = 1.19 vs IRR = 1), and the use of different all-cause mortality rates, different surveillance intervals, and a different version of CRC-SPIN model, the changes in model-estimated outcomes between screening at age 45 vs age 50 were similar in the current and the 2016 decision analyses. The outcomes for each screening strategy highlighted by the USPSTF in 2016 are summarized below. All outcomes are expressed per 1000 40-year-olds.

Figure 27 Estimated Benefits, Harms and Burden of Colorectal Cancer Screening Strategies Highlighted by the USPSTF in 2016 (With Screening From Ages 50 to 75 Years) and the Change in Outcomes When Screening Is Started at Age 45 Instead of At Age 50

FIT indicates fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; HSgFOBT, high sensitivity guaiac-based fecal occult blood test; sDNA-FIT, multitarget stool DNA test (stool DNA test with a fecal immunochemical test); CTC, computed tomographic colonography; SIG, flexible sigmoidoscopy; CRC, colorectal cancer.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

† Due to imprecision in sensitivity and specificity, there is considerable uncertainty in model outcomes for HSgFOBT strategies. See Appendix 4 for details.

‡ Compared to other options for stool-based screening, these strategies do not provide an efficient balance of the burden (i.e., lifetime number of colonoscopies) vs the benefit (life-years gained) of screening.

[A] Benefit: Life-years gained per 1000 individuals screened^*^ * Outcomes are expressed per 1000 40-year-olds who start screening at age 45 or at age 50.

Estimated life-years gained for screening strategies highlighted by the USPSTF in 2016 with screening from ages 50-75 and additional life-years gained if screening is started at age 45.

[B] Benefit: CRC cases averted per 1000 individuals screened^*^

Estimated colorectal cancer cases averted for screening strategies highlighted by the USPSTF in 2016 with screening from ages 50-75 and additional cases averted if screening is started at age 45.

[C] Benefit: CRC deaths averted per 1000 individuals screened^*^

Estimated colorectal cancer deaths averted for screening strategies highlighted by the USPSTF in 2016 with screening from ages 50-75 and additional deaths averted if screening is started at age 45.

[D] Harms: Complications (gastrointestinal and cardiovascular) of CRC screening and follow-up procedures per 1000 individuals screened^*^

Estimated number of complications from screening strategies highlighted by the USPSTF in 2016 with screening from ages 50-75 and additional complications if screening is started at age 45.

[E] Burden: Lifetime number of colonoscopies per 1000 individuals screened^*^

Estimated number of colonoscopies with screening strategies highlighted by the USPSTF in 2016 with screening from ages 50-75 and additional colonoscopies if screening is started at age 45.

[F] Burden: Lifetime number of other (non-colonoscopy) tests^§^ § Other (non-colonoscopy) tests include FIT, HSgFOBT, sDNA-FIT, CTC, SIG. per 1000 individuals screened^*^

Estimated number of non-colonoscopy tests with screening strategies highlighted by the USPSTF in 2016 with screening from ages 50-75 and additional non-colonoscopy tests if screening is started at age 45.

### Colonoscopy Every 10 Years to Age 75

For colonoscopy every 10 years to age 75, lowering the age to begin screening from 50 to 45 was estimated to prevent 2 to 4 diagnosed cases of colorectal cancer and 1 to 2 colorectal cancer deaths and yield 16 to 34 additional LYG. However, it is also estimated to require 756 to 800 additional colonoscopies and result in 2 additional complications (Table 16).

Table 16 Estimated Outcomes From the Current Analysis and From the 2016 Analysis^*^ for the Colonoscopy Screening Strategy Highlighted by the USPSTF in 2016 and for the Same Strategy But With Screening Beginning at Age 45 Instead of Age 50

Strategy by model | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | DLG
Strategy by model | Stool tests | SIGs | CTCs | COLs | Compli-cations | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
Colonoscopy every 10 years to age 75 – current analysis
SimCRC
COL 50-75, 10 | 0 | 0 | 0 | 3414 | 13 | 18 | 5 | 335 | 314 | 122
COL 45-75, 10 | 0 | 0 | 0 | 4212 | 16 | 14 | 3 | 369 | 347 | 135
Difference^‡^ | 0 | 0 | 0 | +798 | +2 | -4 | -2 | +34 | +33 | +12
CRC-SPIN
COL 50-75, 10 | 0 | 0 | 0 | 3500 | 15 | 15 | 5 | 308 | 291 | 112
COL 45-75, 10 | 0 | 0 | 0 | 4300 | 17 | 12 | 4 | 340 | 321 | 124
Difference^‡^ | 0 | 0 | 0 | +800 | +2 | -3 | -1 | +32 | +30 | +12
MISCAN
COL 50-75, 10 | 0 | 0 | 0 | 3476 | 14 | 36 | 9 | 286 | 257 | 104
COL 45-75, 10 | 0 | 0 | 0 | 4232 | 15 | 34 | 8 | 301 | 272 | 110
Difference^‡^ | 0 | 0 | 0 | +756 | +2 | -2 | -1 | +16 | +15 | +6
Colonoscopy every 10 years to age 75 – 2016 analysis
SimCRC
COL 50-70, 10 | 0 | 0 | 0 | 4007 | 14 | 13 | 4 | 275 | 255 | 100
COL 45-75, 10 | 0 | 0 | 0 | 4853 | 16 | 9 | 2 | 303 | 281 | 110
Difference^‡^ | 0 | 0 | 0 | +846 | +2 | -4 | -1 | +28 | +26 | +10
CRC-SPIN
COL 50-70, 10 | 0 | 0 | 0 | 4049 | 15 | 9 | 3 | 270 | 257 | 98
COL 45-75, 10 | 0 | 0 | 0 | 4906 | 17 | 6 | 2 | 289 | 276 | 106
Difference^‡^ | 0 | 0 | 0 | +856 | +2 | -3 | -1 | +19 | +18 | +7
MISCAN
COL 50-70, 10 | 0 | 0 | 0 | 4101 | 15 | 25 | 6 | 248 | 222 | 90
COL 45-75, 10 | 0 | 0 | 0 | 4928 | 16 | 23 | 5 | 262 | 236 | 96
Difference^‡^ | 0 | 0 | 0 | +827 | +1 | -2 | -0.8 | +15 | +14 | +5

SIG = sigmoidoscopy; CTC – computed tomographic colonography; COL – colonoscopy; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening.

* The current and 2016 decision analyses make different assumptions about CRC risk (IRR 1.19 vs 1) and use different all-cause mortality rates, different surveillance intervals, and a different version of CRC-SPIN model.

† Includes deaths from complications of screening.

‡ Due to rounding, reported difference may not match calculated difference.

### Annual FIT to Age 75

Screening with annual FIT from ages 45 to 75 instead of from ages 50 to 75 was estimated to prevent 1 to 4 cases of diagnosed colorectal cancer and approximately 1 colorectal cancer death, and yield 17 to 33 additional LYG. It was also estimated to require 3387 to 3520 additional FITs and 175 to 205 additional colonoscopies and result in <1 additional complication (Table 17).

Table 17 Estimated Outcomes From the Current Analysis and From the 2016 Analysis^*^ for the FIT Screening Strategy Highlighted by the USPSTF in 2016 and for the Same Strategy But With Screening Beginning at Age 45 Instead of Age 50

Strategy by model | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | DLG
Strategy by model | Stool tests | SIGs | CTCs | COLs | Compli-cations | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
Annual fecal immunochemical testing to age 75 – current analysis
SimCRC
FIT 50-75, 1 | 16160 | 0 | 0 | 1423 | 9 | 30 | 7 | 316 | 289 | 115
FIT 45-75, 1 | 19680 | 0 | 0 | 1602 | 10 | 26 | 6 | 348 | 321 | 127
Difference^‡^ | +3520 | 0 | 0 | +179 | +0.2 | -4 | -1 | +33 | +32 | +12
CRC-SPIN
FIT 50-75, 1 | 15562 | 0 | 0 | 1619 | 12 | 23 | 7 | 285 | 266 | 104
FIT 45-75, 1 | 18950 | 0 | 0 | 1824 | 13 | 20 | 6 | 314 | 293 | 115
Difference^‡^ | +3387 | 0 | 0 | +205 | +0.4 | -3 | -1 | +29 | +28 | +11
MISCAN
FIT 50-75, 1 | 16097 | 0 | 0 | 1445 | 10 | 47 | 11 | 274 | 240 | 100
FIT 45-75, 1 | 19607 | 0 | 0 | 1620 | 10 | 46 | 10 | 291 | 256 | 106
Difference^‡^ | +3510 | 0 | 0 | +175 | +0.2 | -1 | -0.6 | +17 | +16 | +6
Annual fecal immunochemical testing to age 75 – 2016 analysis
SimCRC
FIT 50-75, 1 | 15778 | 0 | 0 | 1739 | 10 | 23 | 5 | 260 | 240 | 95
FIT 45-75, 1 | 19196 | 0 | 0 | 1979 | 10 | 20 | 4 | 287 | 267 | 105
Difference^‡^ | +3418 | 0 | 0 | +239 | +0.2 | -3 | -1 | +27 | +27 | +10
CRC-SPIN
FIT 50-75, 1 | 15444 | 0 | 0 | 1899 | 11 | 20 | 5 | 244 | 231 | 89
FIT 45-75, 1 | 18733 | 0 | 0 | 2163 | 11 | 17 | 4 | 263 | 250 | 96
Difference^‡^ | +3289 | 0 | 0 | +263 | +0.2 | -3 | -0.8 | +19 | +19 | +7
MISCAN
FIT 50-75, 1 | 15843 | 0 | 0 | 1757 | 10 | 35 | 8 | 231 | 205 | 84
FIT 45-75, 1 | 19256 | 0 | 0 | 1995 | 10 | 34 | 7 | 247 | 221 | 90
Difference^‡^ | +3413 | 0 | 0 | +238 | +0.2 | -2 | -0.7 | +16 | +16 | +6

FIT – fecal immunochemical testing with a cutoff for positivity of 20 μg of hemoglobin per g of feces; SIG = sigmoidoscopy; CTC – computed tomographic colonography; COL – colonoscopy; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening.

* The current and 2016 decision analyses make different assumptions about CRC risk (IRR 1.19 vs 1) and use different all-cause mortality rates, different surveillance intervals, and a different version of CRC-SPIN model.

† Includes deaths from complications of screening.

‡ Due to rounding, reported difference may not match calculated difference.

### Annual sDNA-FIT to Age 75

For annual sDNA-FIT to age 75, lowering the age to begin screening from 50 to 45 was estimated to prevent 1 to 4 diagnosed cases of colorectal cancer and approximately 1 colorectal cancer death. It was estimated to result in 16 to 33 additional LYG. The estimated number of additional tests were as follows: 2361 to 2425 additional sDNA-FITs and 305 to 322 additional colonoscopies. It was estimated to result in <1 additional complication (Table 18).

Table 18 Estimated Outcomes From the Current Analysis and From the 2016 Analysis^*^ for the Annual sDNA-FIT Screening Strategy Highlighted by the USPSTF in 2016 and for the Same Strategy But With Screening Beginning at Age 45 Instead of Age 50

Strategy by model | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | DLG
Strategy by model | Stool tests | SIGs | CTCs | COLs | Compli-cations | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
Annual multitarget stool DNA testing to age 75 – current analysis
SimCRC
sDNA-FIT 50-75, 1 | 11463 | 0 | 0 | 2156 | 11 | 22 | 6 | 330 | 305 | 121
sDNA-FIT 45-75, 1 | 13888 | 0 | 0 | 2462 | 12 | 19 | 4 | 363 | 337 | 133
Difference^‡^ | +2425 | 0 | 0 | +305 | +0.2 | -4 | -1 | +33 | +32 | +12
CRC-SPIN
sDNA-FIT 50-75, 1 | 11132 | 0 | 0 | 2295 | 14 | 18 | 6 | 301 | 281 | 110
sDNA-FIT 45-75, 1 | 13494 | 0 | 0 | 2617 | 14 | 15 | 5 | 331 | 309 | 121
Difference^‡^ | +2361 | 0 | 0 | +322 | +0.4 | -3 | -1 | +30 | +28 | +11
MISCAN
sDNA-FIT 50-75, 1 | 11315 | 0 | 0 | 2211 | 12 | 39 | 9 | 290 | 257 | 106
sDNA-FIT 45-75, 1 | 13698 | 0 | 0 | 2515 | 12 | 38 | 9 | 306 | 272 | 112
Difference^‡^ | +2383 | 0 | 0 | +305 | +0.2 | -1 | -0.6 | +16 | +15 | +6
Annual multitarget stool DNA testing to age 75 – 2016 analysis
SimCRC
sDNA-FIT 50-75, 1 | 11041 | 0 | 0 | 2601 | 12 | 17 | 4 | 271 | 252 | 99
sDNA-FIT 45-75, 1 | 13372 | 0 | 0 | 2978 | 12 | 14 | 3 | 298 | 278 | 109
Difference^‡^ | +2331 | 0 | 0 | +378 | +0.2 | -3 | -1 | +26 | +26 | +10
CRC-SPIN
sDNA-FIT 50-75, 1 | 10745 | 0 | 0 | 2729 | 13 | 13 | 4 | 261 | 249 | 95
sDNA-FIT 45-75, 1 | 12989 | 0 | 0 | 3122 | 13 | 11 | 3 | 279 | 267 | 102
Difference^‡^ | +2244 | 0 | 0 | +393 | +0.2 | -2 | -0.7 | +18 | +18 | +7
MISCAN
sDNA-FIT 50-75, 1 | 11025 | 0 | 0 | 2662 | 12 | 28 | 6 | 246 | 222 | 90
sDNA-FIT 45-75, 1 | 13328 | 0 | 0 | 3044 | 12 | 27 | 6 | 261 | 236 | 95
Difference^‡^ | +2303 | 0 | 0 | +382 | +0.2 | -1 | -0.6 | +15 | +14 | +5

sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); SIG = sigmoidoscopy; CTC – computed tomographic colonography; COL – colonoscopy; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening.

* The current and 2016 decision analyses make different assumptions about CRC risk (IRR 1.19 vs 1) and use different all-cause mortality rates, different surveillance intervals, and a different version of CRC-SPIN model.

† Includes deaths from complications of screening.

‡ Due to rounding, reported difference may not match calculated difference.

### Triennial sDNA-FIT to Age 75

For sDNA-FIT every 3 years to age 75, lowering the age to begin screening from 50 to 45 was estimated to prevent 1 to 4 diagnosed cases of colorectal cancer and approximately 1 colorectal cancer death, and to yield 16 to 31 additional LYG. It was estimated to require 1166 to 1201 additional sDNA-FITs and 177 to 196 additional colonoscopies and result in <1 additional complication (Table 19).

Table 19 Estimated Outcomes From the Current Analysis and From the 2016 Analysis^*^ for the Triennial sDNA-FIT Screening Strategy Highlighted by the USPSTF in 2016 and for the Same Strategy But With Screening Beginning at Age 45 Instead of Age 50

Strategy by model | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | DLG
Strategy by model | Stool tests | SIGs | CTCs | COLs | Compli-cations | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
Triennial multitarget stool DNA testing to age 75 – current analysis
SimCRC
sDNA-FIT 50-75, 3 | 6074 | 0 | 0 | 1405 | 9 | 34 | 8 | 304 | 278 | 111
sDNA-FIT 45-75, 3 | 7274 | 0 | 0 | 1582 | 9 | 30 | 7 | 335 | 308 | 122
Difference^‡^ | +1201 | 0 | 0 | +177 | +0.2 | -4 | -1 | +31 | +30 | +11
CRC-SPIN
sDNA-FIT 50-75, 3 | 5939 | 0 | 0 | 1576 | 12 | 26 | 8 | 271 | 253 | 99
sDNA-FIT 45-75, 3 | 7105 | 0 | 0 | 1772 | 12 | 23 | 7 | 301 | 281 | 110
Difference^‡^ | +1166 | 0 | 0 | +196 | +0.4 | -3 | -1 | +30 | +28 | +11
MISCAN
sDNA-FIT 50-75, 3 | 6006 | 0 | 0 | 1449 | 9 | 50 | 12 | 257 | 223 | 94
sDNA-FIT 45-75, 3 | 7204 | 0 | 0 | 1629 | 10 | 49 | 12 | 273 | 239 | 100
Difference^‡^ | +1199 | 0 | 0 | +179 | +0.2 | -1 | -0.6 | +16 | +15 | +6
Triennial multitarget stool DNA testing to age 75 – 2016 analysis
SimCRC
sDNA-FIT 50-75, 3 | 5990 | 0 | 0 | 1701 | 9 | 26 | 6 | 250 | 229 | 91
sDNA-FIT 45-75, 3 | 7158 | 0 | 0 | 1928 | 9 | 23 | 5 | 274 | 254 | 100
Difference^‡^ | +1168 | 0 | 0 | +226 | +0.2 | -3 | -1 | +25 | +24 | +9
CRC-SPIN
sDNA-FIT 50-75, 3 | 5927 | 0 | 0 | 1827 | 10 | 23 | 7 | 226 | 215 | 83
sDNA-FIT 45-75, 3 | 7061 | 0 | 0 | 2073 | 10 | 20 | 6 | 244 | 232 | 89
Difference^‡^ | +1134 | 0 | 0 | +245 | +0.2 | -3 | -0.8 | +18 | +18 | +6
MISCAN
sDNA-FIT 50-75, 3 | 5779 | 0 | 0 | 1714 | 9 | 38 | 9 | 215 | 190 | 79
sDNA-FIT 45-75, 3 | 7086 | 0 | 0 | 1965 | 10 | 36 | 8 | 231 | 205 | 84
Difference^‡^ | +1308 | 0 | 0 | +251 | +0.4 | -2 | -0.9 | +16 | +15 | +6

sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); SIG = sigmoidoscopy; CTC – computed tomographic colonography; COL – colonoscopy; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening.

* The current and 2016 decision analyses make different assumptions about CRC risk (IRR 1.19 vs 1) and use different all-cause mortality rates, different surveillance intervals, and a different version of CRC-SPIN model.

† Includes deaths from complications of screening.

‡ Due to rounding, reported difference may not match calculated difference.

### Sigmoidoscopy Every 5 Years to Age 75

Lowering the age to begin 5-yearly FIT screening from age 50 to age 45 (with screening ending at age 75) was estimated to result in 1 to 3 fewer cases of diagnosed colorectal cancer, approximately 1 fewer colorectal cancer death, and 13 to 30 additional LYG. It was estimated to require 743 to 801 additional sigmoidoscopies and 170 to 192 additional colonoscopies, and result in <1 additional complication (Table 20).

Table 20 Estimated Outcomes From the Current Analysis and From the 2016 Analysis^*^ for the SIG Screening Strategy Highlighted by the USPSTF in 2016 and for the Same Strategy But With Screening Beginning at Age 45 Instead of Age 50

Strategy by model | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | DLG
Strategy by model | Stool tests | SIGs | CTCs | COLs | Compli-cations | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
Sigmoidoscopy every 5 years to age 75 – current analysis
SimCRC
SIG 50-75, 5 | 0 | 4058 | 0 | 1544 | 10 | 29 | 9 | 279 | 260 | 102
SIG 45-75, 5 | 0 | 4846 | 0 | 1720 | 10 | 25 | 8 | 309 | 289 | 113
Difference^‡^ | 0 | +788 | 0 | +176 | +0.1 | -3 | -1 | +30 | +29 | +11
CRC-SPIN
SIG 50-75, 5 | 0 | 4134 | 0 | 1510 | 11 | 26 | 9 | 256 | 241 | 94
SIG 45-75, 5 | 0 | 4935 | 0 | 1680 | 12 | 24 | 9 | 280 | 264 | 102
Difference^‡^ | 0 | +801 | 0 | +170 | +0.2 | -2 | -0.9 | +24 | +22 | +9
MISCAN
SIG 50-75, 5 | 0 | 3646 | 0 | 1927 | 12 | 40 | 11 | 256 | 229 | 93
SIG 45-75, 5 | 0 | 4389 | 0 | 2119 | 12 | 39 | 11 | 269 | 241 | 98
Difference^‡^ | 0 | +743 | 0 | +192 | 0 | -1 | -0.4 | +13 | +12 | +5
Sigmoidoscopy every 5 years to age 75 – 2016 analysis
SimCRC
SIG 50-75, 5 | 0 | 4111 | 0 | 1820 | 10 | 23 | 7 | 227 | 207 | 83
SIG 45-75, 5 | 0 | 4912 | 0 | 2039 | 11 | 20 | 6 | 251 | 230 | 91
Difference^‡^ | 0 | +800 | 0 | +219 | +0.2 | -3 | -1 | +24 | +23 | +9
CRC-SPIN
SIG 50-75, 5 | 0 | 4298 | 0 | 1493 | 9 | 30 | 10 | 181 | 169 | 66
SIG 45-75, 5 | 0 | 5128 | 0 | 1669 | 9 | 28 | 10 | 193 | 180 | 70
Difference^‡^ | 0 | +830 | 0 | +176 | +0.1 | -1 | -0.4 | +12 | +11 | +4
MISCAN
SIG 50-75, 5 | 0 | 3807 | 0 | 2287 | 12 | 29 | 8 | 221 | 196 | 81
SIG 45-75, 5 | 0 | 4572 | 0 | 2533 | 12 | 28 | 7 | 234 | 207 | 85
Difference^‡^ | 0 | +765 | 0 | +246 | +0.2 | -1 | -0.5 | +12 | +11 | +5

SIG - sigmoidoscopy; CTC – computed tomographic colonography; COL – colonoscopy; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening.

* The current and 2016 decision analyses make different assumptions about CRC risk (IRR 1.19 vs 1) and use different all-cause mortality rates, different surveillance intervals, and a different version of CRC-SPIN model.

† Includes deaths from complications of screening.

‡ Due to rounding, reported difference may not match calculated difference.

### Sigmoidoscopy Every 10 Years With Annual FIT to Age 75

For the USPSTF-highlighted strategy combining sigmoidoscopy every 10 years and annual FIT to age 75, the estimated benefits of lowering the age to begin screening from age 50 to age 45 were as follows: 2 to 4 fewer diagnosed cases of colorectal cancer; about 1 fewer colorectal cancer death; and 17 to 33 additional LYG. The estimated burdens and harms associated with this change were: 458 to 493 additional sigmoidoscopies; 3018 to 3112 additional FITs; 263 to 284 additional colonoscopies; and <1 additional complication (Table 21).

Table 21 Estimated Outcomes From the Current Analysis and From the 2016 Analysis^*^ for the SIG+FIT Screening Strategy Highlighted by the USPSTF in 2016 and for the Same Strategy But With Screening Beginning at Age 45 Instead of Age 50

Strategy by model | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | DLG
Strategy by model | Stool tests | SIGs | CTCs | COLs | Compli-cations | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
Sigmoidoscopy every 10 years with annual fecal immunochemical testing to age 75 – current analysis
SimCRC
SIG+FIT 50-75, 10_1 | 13537 | 2099 | 0 | 1840 | 11 | 22 | 6 | 330 | 306 | 121
SIG+FIT 45-75, 10_1 | 16648 | 2568 | 0 | 2102 | 11 | 18 | 4 | 363 | 338 | 133
Difference^‡^ | +3112 | +469 | 0 | +263 | +0.6 | -4 | -1 | +33 | +32 | +12
CRC-SPIN
SIG+FIT 50-75, 10_1 | 13305 | 2067 | 0 | 1973 | 13 | 18 | 6 | 301 | 282 | 110
SIG+FIT 45-75, 10_1 | 16322 | 2525 | 0 | 2237 | 14 | 15 | 5 | 330 | 309 | 120
Difference^‡^ | +3018 | +458 | 0 | +265 | +0.5 | -3 | -1 | +29 | +27 | +11
MISCAN
SIG+FIT 50-75, 10_1 | 12357 | 1900 | 0 | 2048 | 12 | 39 | 10 | 287 | 255 | 105
SIG+FIT 45-75, 10_1 | 15466 | 2393 | 0 | 2331 | 13 | 37 | 9 | 304 | 272 | 111
Difference^‡^ | +3109 | +493 | 0 | +284 | +0.8 | -2 | -0.9 | +17 | +17 | +6
Sigmoidoscopy every 10 years with annual fecal immunochemical testing to age 75 – 2016 analysis
SimCRC
SIG+FIT 50-75, 10_1 | 13393 | 2097 | 0 | 2248 | 11 | 17 | 4 | 270 | 250 | 99
SIG+FIT 45-75, 10_1 | 16427 | 2553 | 0 | 2560 | 12 | 13 | 3 | 298 | 276 | 109
Difference^‡^ | +3034 | +456 | 0 | +312 | +0.4 | -3 | -1 | +28 | +27 | +10
CRC-SPIN
SIG+FIT 50-75, 10_1 | 13404 | 2079 | 0 | 2289 | 12 | 15 | 4 | 256 | 242 | 93
SIG+FIT 45-75, 10_1 | 16356 | 2523 | 0 | 2606 | 12 | 12 | 3 | 274 | 260 | 100
Difference^‡^ | +2952 | +444 | 0 | +317 | +0.3 | -3 | -0.8 | +18 | +18 | +7
MISCAN
SIG+FIT 50-75, 10_1 | 12642 | 1903 | 0 | 2490 | 12 | 28 | 6 | 246 | 220 | 90
SIG+FIT 45-75, 10_1 | 15711 | 2397 | 0 | 2826 | 13 | 26 | 5 | 262 | 235 | 96
Difference^‡^ | +3069 | +494 | 0 | +336 | +0.6 | -2 | -0.8 | +16 | +15 | +6

SIG = sigmoidoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; CTC – computed tomographic colonography; COL – colonoscopy; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening.

* The current and 2016 decision analyses make different assumptions about CRC risk (IRR 1.19 vs 1) and use different all-cause mortality rates, different surveillance intervals, and a different version of CRC-SPIN model.

† Includes deaths from complications of screening.

‡ Due to rounding, reported difference may not match calculated difference.

### CTC Every 5 Years to Age 75

For CTC every 5 years to age 75, lowering the ages to begin screening from age 50 to age 45 was estimated to avert 1 to 3 diagnosed colorectal cancer cases and about 1 colorectal cancer death, yielding an estimated 14 to 31 additional LYG. It was estimated to require 798 to 806 additional CTCs and 153 to 165 additional colonoscopies and result in approximately 1 additional complication (Table 22).

Table 22.

Estimated Outcomes From the Current Analysis and From the 2016 Analysis for the CTC Screening Strategy Highlighted by the USPSTF in 2016 and for the Same Strategy But With Screening Beginning at Age 45 Instead of Age 50

| | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer
Strategy by model | | Stool; tests | SIGs | CTCs | COLs | Compli-cations | CRC; cases | CRC deaths^†^ | LYG | QALYG | DLG
Computed tomographic colonography every 5 years to age 75 – current analysis
SimCRC
| CTC 50-75, 5 | 0 | 0 | 4006 | 1624 | 11 | 21 | 6 | 325 | 302 | 119
| CTC 45-75, 5 | 0 | 0 | 4804 | 1788 | 11 | 18 | 5 | 355 | 332 | 130
| Difference ^‡^ | 0 | 0 | +798 | +164 | +0.1 | -3 | -1 | +31 | +30 | +11
CRC-SPIN
| CTC 50-75, 5 | 0 | 0 | 4088 | 1626 | 12 | 20 | 7 | 287 | 270 | 105
| CTC 45-75, 5 | 0 | 0 | 4893 | 1791 | 13 | 18 | 6 | 313 | 294 | 114
| Difference ^‡^ | 0 | 0 | +805 | +165 | +0.2 | -2 | -1 | +26 | +24 | +9
MISCAN
| CTC 50-75, 5 | 0 | 0 | 4075 | 1519 | 10 | 43 | 11 | 268 | 238 | 98
| CTC 45-75, 5 | 0 | 0 | 4881 | 1672 | 10 | 42 | 11 | 283 | 251 | 103
| Difference ^‡^ | 0 | 0 | +806 | +153 | +0.1 | -1 | -0.5 | +14 | +14 | +5
Computed tomographic colonography every 5 years to age 75 – 2016 analysis
SimCRC
| CTC 50-75, 5 | 0 | 0 | 4069 | 1927 | 11 | 16 | 4 | 265 | 241 | 97
| CTC 45-75, 5 | 0 | 0 | 4879 | 2133 | 11 | 13 | 3 | 290 | 265 | 106
| Difference ^‡^ | 0 | 0 | +811 | +206 | +0.2 | -3 | -1 | +25 | +24 | +9
CRC-SPIN
| CTC 50-75, 5 | 0 | 0 | 4254 | 1654 | 10 | 16 | 5 | 248 | 232 | 91
| CTC 45-75, 5 | 0 | 0 | 5106 | 1807 | 10 | 14 | 4 | 264 | 246 | 96
| Difference ^‡^ | 0 | 0 | +852 | +153 | +0.1 | -2 | -0.5 | +15 | +14 | +6
MISCAN
| CTC 50-75, 5 | 0 | 0 | 4171 | 1743 | 10 | 33 | 8 | 226 | 196 | 82
| CTC 45-75, 5 | 0 | 0 | 4990 | 1933 | 10 | 32 | 7 | 239 | 207 | 87
| Difference ^‡^ | 0 | 0 | +819 | +190 | +0.2 | -1 | -0.5 | +14 | +12 | +5

CTC – computed tomographic colonography; SIG = sigmoidoscopy; COL – colonoscopy; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening.

* The current and 2016 decision analyses make different assumptions about CRC risk (IRR 1.19 vs 1) and use different all-cause mortality rates, different surveillance intervals, and a different version of CRC-SPIN model.

† Includes deaths from complications of screening.

‡ Due to rounding, reported difference may not match calculated difference.

## Caution Regarding the Interpretation of Findings

It is important to remember that, with the exception of colonoscopy, all screening modalities involve additional screening procedures, some of which result in the referral to colonoscopy. These additional non-colonoscopy screening procedures represent a screening burden and are not accounted for in the assessment of efficiency, which measures burden only in terms of the estimated number of colonoscopies. When comparing efficiency ratios across classes of modalities, it would not be appropriate to assume a colonoscopy strategy and a non-colonoscopy strategy with the same efficiency ratios are equivalent. An equivalent non-colonoscopy strategy would have a lower efficiency ratio (i.e., to account for the increased burden). How much lower is a matter of judgement.

## Comparison With the 2016 Decision Analysis

A key change from the 2016 decision analysis of colorectal cancer screening for the USPSTF to the current decision analysis is the assumption of increasing population risk of colorectal cancer in the current base-case analysis (IRR of 1.19) vs stable population risk in the 2016 analysis (IRR of 1). However, as shown in Figures 22–26, efficient strategies were similar across risk scenarios, as were efficiency ratios (Appendix Tables 14.1–14.7). The systematic evidence review found few new studies informing test performance characteristics,^17^ so inputs for test sensitivity and specificity were similar to those in the prior analysis. It is therefore not surprising that the findings from this decision analyses are similar to those of the 2016 decision analysis for the USPSTF. In both the current and the 2016 decision analyses, all 3 models found that when the estimated number of LYG is used as the measure of screening benefit (estimated number of LYG was the only measure of benefit used in the 2016 analysis), efficient strategies were primarily those with screening beginning at age 45. In 2016, there was limited evidence to support screening before age 50. While data on the yield of screening among asymptomatic adults aged 45 to 49 remain sparse,^116–118^ there is now clearer evidence that colorectal cancer incidence in the US is increasing before age 50,^18,65–71^ and that this increase is likely a cohort effect that will be carried forward with each generation as they age.^18^

As in 2016, the models continue to differ in terms of the magnitude of the estimated benefit from starting screening at age 45 instead of at age 50; estimated benefits from starting at age 45 are greater with SimCRC and CRC-SPIN than with MISCAN. In 2016 we used an algorithm to select sets of recommendable strategies from the efficient options for each class of screening modality. Doing so made it relatively easy to identify and quantify the differences in estimated outcomes across strategies with different ages to begin and end screening. Because recommending strategies is the role of the USPSTF, current analyses identify the efficient options with each class of modality but do not include further analyses to identify “model-recommendable” strategies. In addition, the current analysis compares a much larger number of strategies than the 2016 report, and each can be evaluated on several dimensions (i.e., estimated life expectancy, colorectal cancer deaths averted, numbers of colonoscopies and harms). This makes it difficult to identify and communicate key differences between strategies.

As in 2016, we found that efficient stool testing strategies are generally those that involve FIT (11/16 efficient stool-based strategies across all three models, Table 15). While annual sDNA-FIT (referred to as “FIT-DNA” in the 2016 analyses) strategies are also among the efficient strategies, the estimated efficiency ratios for those strategies are high compared to those of FIT. The sensitivity of sDNA-FIT for adenomas by size and for colorectal cancer is higher than that of FIT (Table 7). As a result, annual sDNA-FIT is estimated to yield more LYG and to prevent more colorectal cancer deaths than annual FIT. However, sDNA-FIT has lower specificity than FIT, so the additional estimated LYG with sDNA-FIT come with more colonoscopies − colonoscopies for follow-up of true-positive and of false-positive sDNA-FITs, and colonoscopies for surveillance of persons with detected adenomas. The high efficiency ratios for sDNA-FIT strategies imply that the estimated LYG from the superior sensitivity of sDNA-FIT are small relative to the large increase in the estimated colonoscopies due to the lower specificity. sDNA-FIT strategies with a 3-year interval are not efficient; this finding indicates that repeated FIT screening may be more effective than 3-yearly sDNA-FIT while requiring fewer colonoscopies. This finding is the same as in the 2016 decision analysis.

In both the current and the 2016 decision analyses, we found that older ages to end screening could be supported for stool tests. For example, in the current analyses, efficiency ratios for annual FIT strategies with screening from age 45 increased slowly as the age to end screening was extended from age 75 to age 80 and to age 85 (efficiency ratios 15-16, 14-27, and 19-43 additional colonoscopies per LYG, respectively, Appendix Table 10.2); for comparison, efficiency ratios for 10-yearly colonoscopy strategies with screening from age 45 often more than doubled as the age of the last scheduled screening colonoscopy increased from 65, to 75, to 85 (efficiency ratios 34-45, 52-112, and 227-828 additional colonoscopies per LYG, respectively, Appendix Table 10.1). Note that strategies with annual FIT from ages 50 to 80 or 85 were dominated with SimCRC and CRC-SPIN but not with MISCAN, and with colonoscopy, strategies with 10-yearly screening from age 50 to age 80, which is the same as to age 85, were also dominated with SimCRC and CRC-SPIN but not with MISCAN. It is important to remember that the FIT strategies require FITs that are not accounted for in the efficiency assessment.

As in the 2016 decision analysis, estimated outcomes from the SimCRC and CRC-SPIN models were very similar. All 3 models estimated similar relative performance across screening strategies. In some cases, findings differed for the MISCAN model, which posits a shorter adenoma dwell time (Table 2).

The models continued to differ regarding COL 45-75, 15. A key finding from the 2016 decision analysis was that with 2 models (SimCRC and CRC-SPIN) COL 45-75, 15 was an efficient screening strategy that had estimated LYG slightly higher than the estimated LYG with COL 50-75, 10, while with MISCAN, COL 45-75, 15 was strongly dominated by COL 50-75, 10, that is, it was estimated to provide fewer LYG and require more colonoscopies (see Figure 10 for an example). This finding is the same in the current decision analysis (Figure 12). However, in the current decision analysis, both strongly- and weakly-dominated strategies may be deemed near efficient, provided they meet the benefit criterion (e.g., within 3 days of life gained per person of the efficient frontier); with MISCAN, the COL 45-75, 15 is strongly dominated and has estimated LYG within 3 days per person of the efficient frontier, so is near efficient. In the 2016 analysis, only weakly dominated strategies were eligible for near-efficient status and as a result, COL 45-75, 15 was not included as a near-efficient option with MISCAN.

Finally, in both analyses, we found that efficiency ratios for strategies with colonoscopy screening every 5 years were generally high (≥84 additional colonoscopies per LYG, Appendix Table 10.1), as were efficiency ratios for strategies with annual sDNA-FIT, relative to screening with annual FIT (Appendix Table 10.2).

For outcomes assessed in both the 2016 and the current decision analysis, there were no major differences in findings.

## Comparison With Decision Analysis for the ACS

The ACS requested 2 decision analyses from CISNET to evaluate the age to begin colorectal cancer screening for their 2018 colorectal cancer screening guidelines. These analyses focused on the rising colorectal cancer incidence observed in recent birth cohorts (performed by MISCAN)^22^ and on analyses by race and sex (performed by MISCAN and SimCRC).^22,23^ Citing the studies by Siegel et al.^18,119^ and the CISNET decision analyses,^22,23^ the ACS gave a qualified recommendation that average-risk adults, regardless of sex or race, begin screening for colorectal cancer at age 45 years.^120^ The current analysis, based on all 3 CISNET models, similarly finds that beginning screening at age 45 years provides an efficient balance of the estimated colonoscopies required (a measure of the burden of screening that correlates with harms) and LYG, for the asymptomatic average-risk population as a whole and by race and sex.

While analyses reached similar conclusions, there are several noteworthy differences (summarized in Appendix 17). First, there is uncertainty about how much risk has increased, and the ACS and USPSTF analyses made different assumptions that were incorporated into model calibration to colorectal cancer incidence. Due to differences in SEER case selection (i.e., exclusions or inclusion of carcinoid tumors and others that are not the primary target of colorectal cancer screening) and in methods for estimating the increase in risk (see Appendix 1), the USPSTF analyses use a lower elevation in risk (IRR of 1.19 in base-case analyses, vs 1.59 in the ACS analyses), and this resulted in a lower estimated absolute benefit of screening. However, the strategies with screening beginning at age 45 were predominant among the efficient strategies in both the current USPSTF and the ACS analyses. Additionally, in sensitivity analyses we found that efficient screening strategies and efficiency ratios were robust to a wide range of assumptions about the magnitude of the increase in colorectal cancer risk. For example, 10-yearly colonoscopy screening from ages 45 to 75 years (COL 45-75, 10), compared to 10-yearly colonoscopy from ages 50 to 75 years (COL 50-70, 1), was estimated to result in 34, 32 and 16 additional LYG and 798, 800 and 756 additional colonoscopies per 1000 unscreened 40-year-olds for SimCRC, CRC-SPIN and MISCAN, respectively. In the analysis for the ACS,^22^ MISCAN estimated a difference of 25 LYG and 810 colonoscopies, resulting in a slightly more favorable balance between the burden and benefits of screening initiation at age 45 years than MISCAN’s current estimate. However, the current analysis demonstrates that MISCAN is the most conservative model when estimating the burden-to-benefit ratio of screening initiation at age 45 years (Tables 16–22).

Second, the differences in outcomes by race and sex in this analysis were smaller than in the ACS analysis.^2^ These differences can be explained by the assumptions about the underlying risk of colorectal cancer by race across the two analyses. While both the ACS and USPSTF analyses incorporated sex- and race-specific estimates of relative survival after diagnosis with colorectal cancer^48^ and sex- and race-specific all-cause mortality rates,^53^ only the analyses for the ACS allowed for a difference by race in the underlying risk of developing colorectal cancer. As noted in the section Analyses by Race and Sex, we reviewed the literature on race and colorectal cancer immediately prior to performing this analysis for the USPSTF. We concluded that the primary driver of differences in colorectal cancer incidence and mortality by race is access to screening and subsequent care, rather than biological differences in natural history,^74^ and therefore did not allow for differential risk of adenoma onset or colorectal cancer incidence by race in the USPSTF analyses. The model-estimated outcomes from the USPSTF analysis likely better reflect the benefits, harms, and burden of colorectal cancer screening by race and sex. Still findings are in line, because the race-specific analysis for ACS incorporating the increase in CRC risk also showed that efficient screening recommendations were similar for different races and hence the ACS did not issue differential screening recommendations by race.^120^

Third, more screening strategies were evaluated in the USPSTF analysis; the hybrid strategies (screen first with FIT, then change to COL, and vice-versa), once-only strategies, and strategies that end screening at age 70 years were not included in the analyses for the ACS. Furthermore, the USPSTF analysis included strategies with screening starting at ages 45, 50, and 55 years, whereas the comparable analysis for the ACS evaluated start ages of 40, 45, and 50 years.^22^ The set of strategies considered affects estimated efficiency ratios for a given modality, and several of the strategies included in the USPSTF, but not ACS analyses were efficient options. For example, a strategy included in the USPSTF analysis that was found to be efficient with all 3 models is colonoscopy screening at ages 45, 55 and 65 years (COL 45-70, 10). This strategy was not included in the ACS analysis. As a result, the efficiency ratios for 10-yearly colonoscopy screening from ages 45 to 75 years (COL 45-75, 10) were higher in the current analysis, as the estimated LYG and number of colonoscopies were being compared to a different strategy (10-yearly colonoscopy screening from ages 45 to 70 years in current analysis vs 10-yearly colonoscopy screening from ages 50 to 75 years in ACS analysis).

## Strengths of the Modeling

Although randomized controlled trials are the gold standard for determining the effectiveness of screening, they have their limitations. They are expensive and time consuming and therefore limited in the number of strategies that can be evaluated. Decision models provide a useful tool to extrapolate evidence from randomized trials and project outcomes of screening strategies that vary by age to begin, age to end and interval of screening, as well as explore new evidence on the natural history such as the increase in cancers observed among recent birth cohorts. The microsimulation models synthesize available evidence about the natural history of developing adenomas and subsequent progression to colorectal cancer and incorporate the evidence available from randomized trials to determine the effect of alternative screening strategies on colorectal cancer incidence and mortality.

We used 3 distinct simulation models to estimate benefits, burden, and harms of alternative screening strategies. Each model is based on different assumptions about the adenoma-carcinoma sequence, though all are calibrated to similar data on adenoma prevalence and cancer incidence,^76^ with the latter excluding carcinoid tumors and others in the colon and rectum that are not the primary target of colorectal cancer screening. The models have a range of differences (e.g., in dwell times, size and location of adenomas, progressive vs non-progressive adenomas, continuous vs categorical adenoma size), which provide a range of estimated outcomes that reflect a sensitivity analysis of the different underlying model assumptions. The similar relative estimated outcomes across classes of screening modalities and similar rankings of strategies within classes of screening modalities across the 3 models demonstrate the robustness of the findings. Differences in relative estimations of screening effectiveness are most influenced by the dwell times associated with each model. Longer dwell times correspond to longer periods of time during which screening can identify and remove preclinical lesions (adenomas and preclinical colorectal cancer). Differences in the estimated distribution of adenomas by location (Figure 3) have the biggest effect on the model-estimated effectiveness of strategies involving sigmoidoscopy alone. For example, with MISCAN, 63% of adenomas are estimated to be within reach of the sigmoidoscope, and the sigmoidoscopy strategy highlighted by the USPSTF in 2016 (Table 20) is estimated to yield 90% of the estimated LYG from the USPSTF-highlighted colonoscopy strategy (Table 14). The estimated proportion of adenomas within reach of the sigmoidoscope is lower with SimCRC and CRC-SPIN (38% and 45%, respectively), as are the relative estimated LYG of the highlighted sigmoidoscopy strategy compared to the highlighted colonoscopy strategy in 2016 (83% for both models).

## Limitations of the Modeling

Despite the strengths of modeling, some limitations are noteworthy.

We did not include some tests that have been used for colorectal cancer screening. One such test is the low-sensitivity fecal occult blood test, Hemoccult II^®^ (Beckman Coulter; Brea, CA), which, in consultation with USPSTF members, we excluded due to the availability of similar tests with better sensitivity. [Hemoccult II was also excluded from the 2016 decision analysis.] For HSgFOBT (a similar test with better sensitivity) we only present results in Appendix 4 due to the high degree of uncertainty in its test characteristics and the fact that FIT is easier to administer and has better test characteristics.^17^ In addition, we did not evaluate the blood-based methylated septin 9 DNA test, which has only been FDA-approved for individuals not willing to do any of the USPSTF-recommended CRC screening tests, or tests with very limited evidence among screening populations (i.e., magnetic resonance colonography and capsule colonoscopy). For tests that we did simulate, we did not carry out a complete examination of the variability and uncertainty in test characteristics, though the accompanying systematic review indicated that there was little to no evidence about the ability of screening tests to detect small (<6 mm) adenomas), and limited information about the sensitivity of tests to detect preclinical colorectal cancers.^17^ If the findings for the sensitivity analysis on colonoscopy test characteristics hold for other classes of screening modalities, then the effect of uncertainty in test characteristics on model results is likely to be modest.

Although the modeled results provide a lifetime framework for evaluating benefits, burden, and harms from a program of screening, much of the empiric data on sensitivity and specificity of screening tests are based on a single round of screening with relatively short periods of follow-up. Currently, there only is long-term evidence for Hemoccult II and sigmoidoscopy, which the models have shown to successfully reproduce.^60,78,79^ However, outcomes for repeat rounds of FIT and HSgFOBT have only been reported in a few small studies; these studies suggest that test performance in repeat screening is not independent as assumed in the current analysis.^121,122^ Future larger studies are needed to confirm these findings so they can be used to inform model assumptions and inputs. An analysis using the MISCAN model previously showed that the effect of assuming correlation of outcomes in repeat screening rounds is likely to be modest.^121^

The models simulate the adenoma-carcinoma sequence using the size of adenomas as an indicator for advanced adenomas. The models do not explicitly simulate adenoma histology. Given the high correlation between adenoma size and histology,^123,124^ the effect of this assumption is likely small. Additionally, the models do not simulate the serrated polyp pathway,^34,35^ in part due to insufficient evidence on the prevalence of serrated polyps by age and location, their malignant potential, and the ability of screening tests to detect them. A modeling study by Greuter et al.^125^ assessed the effect of the serrated polyp pathway on screening effectiveness and found very little difference in results between a model assuming 0% vs 30% of cancers arise from this pathway. Analyses with an expanded version of the MISCAN model that included a first exploratory serrated polyp pathway also showed that inclusion of the serrated pathway had limited effect on the optimal screening strategies.^106^ More information is needed to fully incorporate this pathway into the models.

We assumed that the current generation of 40-year-olds will carry forward the same elevated disease risk as they age, and that the increase in colorectal cancer incidence is caused by an increase in adenoma risk. Although the increasing background risk is likely a cohort effect that will be carried forward with this generation as they age,^18^ it is unlikely that it will be observed in colorectal cancer incidence data, especially at ages ≥55 years, because it is counteracted by the increased uptake of screening. Furthermore, it is not known whether the increase in colorectal cancer incidence is caused by an increase in adenoma risk, a faster adenoma progression to malignancy, or some combination of the two. The effects of each of these assumptions were evaluated in MISCAN’s analysis for the ACS;^22^ the model recommendation of screening initiation at age 45 years was robust. Future research is needed to determine the cause and carcinogenic pathway of the increase in colorectal cancer incidence.

In analyses by race and sex we assumed that the natural history of colorectal cancer does not vary by race. This assumption was based on a comprehensive review of the literature that found that the primary driver of differential risks by race is access to care, not biological differences in natural history.^74^ This assumption is also supported by the recently-published findings from the Southern Community Cohort Study^75^ (see the section Analyses by Race and Sex for more details on the findings of these studies). While differences in biology^111,112^ and/or risk factors^113,114^ may also contribute to Black-White differences in colorectal cancer incidence and mortality rates, mounting evidence suggests that the magnitude is likely small relative to the role of access to screening^126–128^ and treatment.^129,130^

We expressed results using 3 different metrics of efficiency, differing with respect to the measure of benefit. When the estimated number of LYG (or QALYG) is used as a measure of benefit, screening strategies beginning at age 45 years mostly dominate the efficient frontiers, whereas when using the estimated number of deaths averted, strategies that begin screening at ages 50 or 55 years are also efficient. The advantage of using the estimated number of deaths averted as the measure of benefit is that patients and clinicians find it easier to interpret.^131^ However, this measure does not tell us how premature the avoided death would have been.^132^ Using estimated LYG as a measure of benefit accounts for a larger gain in life expectancy from, for example, preventing a colorectal cancer death in a 45-year-old individual compared to a 75-year-old individual. To provide guidance with interpretation, we also expressed the LYG from each screening strategy in terms of the estimated number of days of life gained per person.

We did not perform analyses to identify the optimal ages to begin and end screening among all possible ages to begin and end. In consultation with Task Force members, analyses were limited to 3 ages to being screening (45, 50, and 55) and 4 ages to end screening (70, 75, 80, and 85). It is possible that strategies with screening starting prior to age 45 would also be efficient options. Analysis performed by MISCAN for the 2018 ACS colorectal cancer screening recommendations included strategies with screening beginning at age 40, 45, and 50.^22^ Although screening strategies starting at age 40 were efficient, there were diminishing returns from lowering the age to begin screening, and the estimated benefits of starting at age 40 rather than at age 45 were small. For example, for colonoscopy strategies that involve 4 screening colonoscopies at 10-year intervals (i.e., COL 40-70, 10; COL 45-75, 10, and COL 50-80, 10), starting at age 45 rather than at age 50 were estimated to increase LYG by 5%, whereas starting at age 40 instead of at age 45 was estimated to increase LYG by 2%.

We did not perform a comprehensive analysis directly comparing all available screening strategies. Cost-effectiveness analysis would be a way to perform such a comprehensive analysis, however cost analysis is not part of the USPSTF evaluation. As there is no consensus on the appropriate metric to assess efficiency when costs are not considered, we used the estimated number of required colonoscopies as a proxy for harms and burden of screening. Because of the required cathartic preparation and its invasive nature, colonoscopy is likely to contribute most to the burden and harms of screening. However, not all components of screening burden and/or harm are captured this way. For example, many patients may also consider collecting feces for stool testing or undergoing a sigmoidoscopy to be burdensome. Furthermore, CTC, like colonoscopy, generally requires cathartic bowel preparation and is associated with radiation exposure. Because of this, we estimated the relative efficiency of strategies within a class of screening modalities; we did not estimate relative efficiency across classes of modalities. A comprehensive analysis comparing all tests based on the estimated number of required colonoscopies would penalize colonoscopy strategies compared to strategies with other screening modalities. Future measures need to be developed that can provide a common denominator for resources other than costs that would make comparison of screening strategies across tests more informative.

Additionally, as alluded to in the limitations described above, there is uncertainty in many model inputs and assumptions, from natural history and changes in colorectal cancer risk over time to test characteristics and their correlation. Additional uncertainty not focused on here surrounds assumptions for risks of fatal and non-fatal complications, endoscopy reach, surveillance intervals (the MSTF provides ranges, rather than a single interval), and utility weights for health states. Furthermore, we did not account for increasing colonoscopy quality over time, via increasing emphasis among the gastrointestinal endoscopy community on improving adenoma detection rates,^133–139^ which have been shown to inversely correlate with both interval colorectal cancer cases^133–135,137,140^ and interval colorectal cancer deaths.^134,137^ Similarly, we were unable to account for possible improvements in relative survival following colorectal cancer diagnosis after 2003, due to changes in the staging algorithm used by the SEER Program^49^ and in the use of neoadjuvant chemotherapy over time.^50–52^ We also did not perform a probabilistic sensitivity analysis (PSA) to characterize the simultaneous effect of all uncertain model parameters on the findings; high-performance computing resources would be required to perform a PSA for models of this level of complexity and an analysis of this magnitude. Instead, the effect of uncertainty in model structure and natural history parameters are explored through the use of 3 independently-developed models, and sensitivity analysis on other key assumptions and parameters (IRR, colonoscopy sensitivity) are explored in sensitivity analysis.

Finally, it is important to remember that models only approximate reality. The models used in this report have been extensively calibrated and validated and are able to approximate observed outcomes. However, as mentioned above, there remains uncertainty about the accuracy of screening tests, which use colonoscopy as the reference standard, and the true natural history of colorectal cancer, which cannot be directly observed. In addition, simulations evaluate screening regimens that patients are unlikely to follow exactly (e.g., most patients opting for annual FIT will not be screened at exact one-year intervals). The intent of these analyses was to compare the estimated benefits (i.e., efficacy), harms, burden, and efficiency of different screening regimens, it was not to estimate the effectiveness of regimens in real-world settings. These model-based estimates are important because they provide patients and their clinicians with information they can use to make decisions about when and how to screen for colorectal cancer, decisions that would otherwise be left to individual judgement, as that information cannot feasibly be obtained from clinical studies. Modeling studies are no substitute for empirical evidence. Instead they synthesize, build from, and extend empirical evidence to provide insights into questions about screening practices.

## Conclusion

This decision analysis suggests that colorectal cancer screening may lead to sizable reductions in the lifetime risks of developing and dying from the disease and may increase population life expectancy. The models suggest that many screening strategies may provide an efficient balance of the burden and benefits of screening; these strategies encompass a range of screening modalities, intervals, and ages. However, when the benefits of screening are measured by the estimated number of LYG, most of the efficient screening strategies identified by all 3 models specified screening starting at age 45. Starting screening at age 45 was generally estimated to result in more LYG and QALYG and fewer colorectal cancer cases and deaths than similar strategies with screening starting at age 50 or age 55, albeit with a higher burden of both colonoscopy and non-colonoscopy testing and slightly higher risks of complications.

‡‡ Ranges exclude HSgFOBT, once-only colonoscopy, once-only sigmoidoscopy, and colonoscopy preceded by and followed by annual FIT; estimated outcomes for these strategies are presented in Appendixes 4–8, respectively.

§§ These strategies were not efficient with SimCRC or CRC-SPIN in 2016 when strategies with screening beginning at age 45 were included in the analysis; with the exception of sDNA-FIT 50-75, 3, all recommended strategies in 2016 were efficient in all 3 models when strategies starting at age 45 were eliminated from the analysis.