# Chapter 3 Results

## Benefits, Burden, and Harms of Screening

As noted in the Methods, primary analyses are based on models calibrated to reflect the increasing population risk of colorectal cancer (see Appendix 1 for details). Screening strategies are referred to by modality age to begin-age to end, interval. For example, annual FIT from ages 55 to 70 is FIT 55-70, 1. The strategy combining sigmoidoscopy every 10 years with annual fecal immunochemical testing from ages 50 to 80 is SIG+FIT 50-80, 10_1.

### Findings in the Absence of Screening

In the absence of screening, the models simulated identical life expectancy among 40-year-olds with no prior diagnosis of colorectal cancer: 40.2 years. Models estimated that out of 1000 40-years-olds, 77 to 85 would be diagnosed with colorectal cancer in their lifetimes and 32 to 34 would die from the disease (Figure 11).

Figure 11 Estimated Cumulative Number of Colorectal Cancer Cases and of Colorectal Cancer Deaths per 1,000 Persons From Age 40 to Age 95 in the Absence of Screening, by Model

Model-estimated cumulative risk of colorectal cancer diagnosis and of colorectal cancer death by age in the absence of screening (incidence rate ratio = 1.19).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

### General Findings in the Presence of Screening

Model-estimated outcomes for HSgFOBT strategies, once-only colonoscopy strategies, once-only sigmoidoscopy strategies, and strategies with colonoscopy preceded by or followed by annual FIT are presented in Appendix 4–8; outcomes with these strategies are not discussed. Outcomes with all other screening strategies are shown in Appendix 9. Although the absolute estimates of the benefits, colonoscopy burden and harms of screening differed across models, relative estimates and rankings of screening strategies within each screening modality were consistent across models. Compared to no screening, all colorectal cancer screening strategies were estimated to yield substantial increases in life expectancy and substantial reductions in the lifetime number of colorectal cancer cases and deaths. Estimated LYG from screening ranged from 171 to 381 per 1000 40-year-olds (63 to 139 days of life gained per person); within each model, LYG were lowest with FIT 55-70, 3 and highest with COL 45-85, 5.

With screening, the estimated lifetime number of colorectal cancer cases diagnosed ranged from 9 to 65 per 1000 40-year-olds, and the estimated lifetime number of colorectal cancer deaths ranged from 2 to 20 per 1000, depending upon the screening strategy and model. Within each model, the estimated numbers of cases diagnosed and colorectal cancer deaths were generally lowest with COL 45-85, 5 and highest with FIT 55-70, 3. The estimated benefits of screening were generally highest with SimCRC and lowest with MISCAN, with results from CRC-SPIN falling in between.

The estimated lifetime number of colonoscopies – the primary measure of the burden of screening – ranged from 624 to 6817 per 1000 40-year-olds (<1 to nearly 7 per person) and were lowest with FIT 55-70, 3 and highest with COL 45-85, 5 across models. Harms from screening – the estimated number of colonoscopy complications – ranged from 5 to 22 per 1000 40-year-olds (Appendix 9). Fatal complications were rare, ranging from 4.2 to 23.1 per million 40-year-olds; the years of life lost from these deaths were accounted for in the estimation of the LYG from screening. The strategies with the lowest and highest estimated number of total complications and of fatal complications generally tracked with the strategies with the lowest and highest estimated number of lifetime colonoscopies.

## Efficient Strategies Within Each Class of Screening Modality

Efficiency ratios for the screening strategies highlighted by the USPSTF in 2016 are in Table 9. As a reminder, a strategy is efficient if no other strategy or combination of strategies within the class of screening modality is estimated to provide more life-years with the same (or fewer) number of colonoscopies. Efficiency ratios are calculated within a class of screening modality and can be interpreted as the number of additional colonoscopies required to achieve an additional LYG.

Table 9 Efficient Frontier Status and Efficiency Ratios (i.e., Number of Additional Colonoscopies per Additional Life-Year Gained) for Colorectal Cancer Screening Strategies Highlighted by the USPSTF in 2016, by Model

Strategy | Efficient frontier status (efficiency ratio^*^), by model
Strategy | SimCRC | CRC-SPIN | MISCAN
COL 50-75, 10 | Dominated | Dominated | Efficient (ER = 28)
SIG 50-75, 5 | Dominated | Dominated | Near efficient^‡^ (ER = 19)
SIG+FIT 50-75, 10_1 | Dominated | Dominated | Near efficient^‡^ (ER = 18)
CTC 50-75, 5 | Dominated | Dominated | Efficient (ER = 9)
FIT 50-75, 1^†^ | Dominated | Dominated | Near efficient^‡^ (ER = 29)
sDNA-FIT 50-75, 1^†^ | Dominated | Dominated | Dominated
sDNA-FIT 50-75, 3^†^ | Dominated | Dominated | Dominated

COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); ER = efficiency ratio.^*^

* Expressed as the number of additional colonoscopies per additional life-year gained.

† For FIT and sDNA-FIT, efficient frontier status and efficiency ratio did not change with inclusion of HSgFOBT. HSgFOBT was highlighted by the USPSTF in 2016 but is not included in this table.

‡ Dominated strategy with ≤3 days of life gained per person of the efficient frontier.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

### Colonoscopy

Of the 26 unique colonoscopy strategies, 11 were efficient with SimCRC, 12 with CRC-SPIN, and 17 with MISCAN (Appendix Table 10.1). Eleven strategies were efficient with all 3 models; 9 of the 11 were strategies with screening beginning at age 45. The MISCAN model estimated that several strategies with screening starting at age 50 or age 55 would also be efficient options (Figure 12). No single age to end screening or screening interval was predominant among efficient strategies. Among strategies that were efficient with all 3 models, strategies with screening ending at age 80 or 85 had efficiency ratios of ≥169 additional colonoscopies per LYG, and strategies with a 5-year interval had efficiency ratios ranging from 84 to >2000 (Appendix Table 10.1). Across the 3 models, estimated LYG per 1000 were lowest for COL 55-70, 15 (250 to 285 across models) and highest for COL 45-85, 5 (323 to 381 across models, Figure 12); the estimated number of complications for these strategies ranged from 13 to 14 per 1000 and from 20 to 22 per 1000, respectively (Appendix Table 9.1).

Figure 12 Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for Colonoscopy Screening Strategies, by Model

Estimated colonoscopies vs life-years gained for colonoscopy screening strategies.

Note: Here, color indicates modality; screening interval (1, 2, or 3y) is noted on each symbol. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

### Stool Tests (FIT and sDNA-FIT)

Seventy-two strategies used stool testing (FIT or sDNA-FIT) alone. Of these, 21 were efficient with SimCRC, 21 with CRC-SPIN, and 32 with MISCAN; 16 strategies were efficient with all 3 models (Appendix Table 10.2). Efficient strategies with all 3 models were primarily those with screening beginning at age 45 (14 of 16 strategies) The MISCAN model again included several (17 out of 32) strategies with screening starting at age 50 or age 55 as efficient options (Figure 13).

Figure 13 Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for FIT and sDNA-FIT Screening Strategies, by Model

Estimated colonoscopies vs life-years gained for FIT and sDNA-FIT screening strategies.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

With all 3 models, efficient stool testing strategies were primarily those with FIT as the stool test (Figure 13) (14 of 21 with SimCRC, 13 of 21 with CRC-SPIN; 27 of 32 with MISCAN); efficiency ratios were ≤43 additional colonoscopies per LYG across models for the efficient FIT strategies with all 3 models (Appendix Table 10.2). Annual and biennial sDNA-FIT strategies (with screening starting at age 45) were also efficient with all 3 models with efficiency ratios ranging from 26 to 375 additional colonoscopies per LYG. sDNA-FIT strategies with a 3-year interval were not efficient with any model.

Efficiency ratios for the subset of efficient FIT strategies with all 3 models with screening ending at age 85 ranged from 12 to 43 additional colonoscopies per LYG (Appendix Table 10.2). Across models, FIT 55-70, 3 yielded the fewest LYG (171 to 203 per 1000), and sDNA-FIT 45-85, 1 provided the most LYG (313 to 368 per 1000, Figure 13). The estimated number of complications for these strategies ranged from 5 to 7 per 1000 for FIT 55-70, 3 and from 14 to 16 per 1000 for sDNA-FIT 45-85, 1 (Appendix Tables 9.2 and 9.3).

Model findings for stool-based screening modalities including HSgFOBT are in Appendix 4.

### Sigmoidoscopy

Of the 20 unique sigmoidoscopy strategies, 7 were efficient with SimCRC, 8 with CRC-SPIN, and 15 with MISCAN (Appendix Table 10.3). Seven strategies were efficient with all 3 models, and in all but 1 strategy screening began at age 45. With MISCAN, strategies with screening starting at age 50 were also efficient (Figure 14). All 4 ages to end screening and both screening intervals were included among the strategies that were efficient across all 3 models; efficiency ratios with screening to age 85 ranged from 78 to 98 additional colonoscopies per LYG and efficiency ratios for strategies with a 5-year screening interval ranged from 11 to 98 additional colonoscopies per LYG (Appendix Table 10.3). Across models, estimated LYG were lowest for SIG 55-70, 10 (range 204 to 210 per 1000) and highest with SIG 45-85, 5 (272 to 312 per 1000, Figure 14); the estimated number of complications for these 2 strategies ranged from 7 to 10 per 1000 and from 12 to 13 per 1000, respectively (Appendix Table 9.4).

Figure 14 Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for Sigmoidoscopy Screening Strategies, by Model

Estimated colonoscopies vs life-years gained for sigmoidoscopy screening strategies.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

### SIG+FIT

Of the 24 SIG+FIT strategies evaluated, the number that were efficient was 10, 10, and 20 for the SimCRC, CRC-SPIN, and MISCAN models, respectively (Appendix Table 10.4). Ten strategies were efficient with all 3 models, and strategies with screening beginning at age 45 were predominant among them (8 of 10 strategies). As with other modalities, with MISCAN, strategies with screening starting at age 50 or 55 were also among those that were efficient (Figure 15, Appendix Table 10.4). Among strategies that were efficient with all 3 models, no single age to end screening or interval for FIT was predominant. Across the 3 models, SIG+FIT 55-70, 10_2 provided the fewest estimated LYG (241 to 266 per 1000) and SIG+FIT 45-85, 10_1 provided the most (309 to 367 per 1000, Figure 15); the estimated number of complications for these strategies ranged from 8 to 11 per 1000 and from 14 to 16 per 1000, respectively (Appendix Table 9.5).^††^

Figure 15 Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for 10-Yearly Sigmoidoscopy Plus Interval FIT Screening Strategies, by Model

Estimated colonoscopies vs life-years gained for 10-yearly sigmoidoscopy plus interval FIT screening strategies.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

### CTC

Findings with CTC were similar to those with sigmoidoscopy: of the 20 unique CTC strategies, 7 were efficient with SimCRC, 8 with CRC-SPIN, and 14 with MISCAN (Appendix Table 10.5). Five strategies were efficient with all 3 models, and all but 1 had screening beginning at age 45. The MISCAN model estimated that strategies with screening beginning at age 50 and 55 would also be efficient (Figure 16). Among strategies that were efficient with all 3 models, no 1 age to end screening emerged as efficient, but efficient strategies were generally those with a 5-year interval. Across models, CTC 55-70, 10 yielded the fewest estimated LYG (181 to 245 per 1000) and CTC 45-85, 5 provided the most (290 to 359 per 1000, Figure 16); the estimated number of complications for these strategies ranged from 7 to 9 per 1000 and from 12 to 15 per 1000, respectively (Appendix Table 9.6).

Figure 16 Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for Computed Tomographic Colonography Screening Strategies, by Model

Estimated colonoscopies vs life-years gained for computed tomographic colonography screening strategies.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

## Scenario and Sensitivity Analyses

### Findings by Race and Sex

As explained in Analyses by Race and Sex, the modeling analyses assumed no differences by race in the development of clinically-detected colorectal cancer in the absence of screening. This assumption was based on our review of the literature on race and colorectal cancer.^74^ While the development of adenomas and their progression to colorectal cancer was not allowed to vary by race, the models incorporated Black-White differences in all-cause mortality^53^ and in relative survival from colorectal cancer following diagnosis.^48^

Before presenting the detailed findings, we briefly describe the general implications of the assumption and inputs described above. All else being equal, higher all-cause mortality rates among simulated Black adults vs White adults results in a smaller proportion of an initial cohort of Black adults being alive at older ages when the risk of colorectal cancer diagnosis is highest (Figure 5). Accordingly, in the absence of screening, the models would estimate both a lower life expectancy and a lower lifetime risk of being diagnosed with colorectal cancer among an initial cohort of cancer-free Black adults than among an initial cohort of cancer-free White adults. In addition, the lower stage-specific colorectal cancer relative survival probabilities among Black adults vs White adults would result in a larger proportion of Black colorectal cancer patients dying from their cancer than White colorectal cancer patients. Whether the model-estimated lifetime number of colorectal cancer deaths is higher among an initial cohort of cancer-free Black adults than White adults depends only on whether the lower lifetime risk of colorectal cancer diagnosis among Black adults is offset by this group’s worse survival following colorectal cancer diagnosis. Detailed model-estimated outcomes for each race and sex group compared with those estimated for the total population are described below.

Compared to the total population (model-estimated life expectancy 40.2 years), model-estimated life expectancy among unscreened 40-year-olds with no prior CRC diagnosis was 2 years higher for White females (42.2 years), similar for Black females (40.1 years), 2 years lower for White males (38.4 years), and 5 years lower for Black males (35.2 years). In the absence of screening, the model-estimated lifetime number of diagnosed colorectal cancer cases was higher for White males compared to the total population (86 vs 81 cases per 1000, respectively; estimates are the mean across the 3 models) and lower than the total population for the other groups (77, 73, and 70 cases per 1000 White females, Black males, and Black females, respectively, Table 10). For both sexes, model-estimated lifetime risk of colorectal cancer diagnosis was lower among Black vs White adults (73 vs 86 per 1000 males by race; 70 vs 77 per 1000 females by race).

Table 10 Model-Estimated Lifetime Outcomes for a Cohort of 40-Year-Olds in the Absence of Colorectal Cancer Screening

Population | Life Expectancy (y) | | | | Colorectal Cancer Cases per 1000 | | | | Colorectal Cancer Deaths per 1000
Population | SimCRC | CRC-SPIN | MISCAN | Mean^*^ | SimCRC | CRC-SPIN | MISCAN | Mean^*^ | SimCRC | CRC-SPIN | MISCAN | Mean^*^
Total population | 40.2 | 40.2 | 40.2 | 40.2 | 85 | 77 | 81 | 81 | 34 | 32 | 34 | 33
White males | 38.4 | 38.4 | 38.4 | 38.4 | 92 | 80 | 87 | 86 | 37 | 33 | 36 | 35
Black males | 35.2 | 35.2 | 35.2 | 35.2 | 78 | 68 | 74 | 73 | 35 | 31 | 34 | 33
White females | 42.2 | 42.2 | 42.2 | 42.2 | 78 | 74 | 77 | 77 | 31 | 30 | 32 | 31
Black females | 40.1 | 40.1 | 40.1 | 40.1 | 72 | 68 | 71 | 70 | 32 | 31 | 33 | 32

* Mean outcome across the SimCRC, CRC-SPIN, and MISCAN models.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

The models estimated that the lower lifetime risk of colorectal cancer diagnosis among Black males vs White males in the absence of screening also led to a lower lifetime risk of colorectal cancer death (33 vs 35 per 1000, Table 10), despite the worse relative survival following CRC diagnosis in Black patients compared to White patients. The pattern was reversed for females by race: Black females were estimated to have lower lifetime risk of colorectal cancer diagnosis in the absence of screening but higher lifetime risk of colorectal cancer death (32 vs 31 per 1000). This implies that the lower estimated lifetime incidence in Black females vs White females was offset by the worse relative survival following colorectal cancer diagnosis in Black patients vs White patients. Compared to the total population, the lifetime risk of colorectal cancer death was estimated to be higher for White males than for the total population (35 vs 33 deaths per 1000), the same as the total population for Black males (33 per 1000), and lower than the total population for Black females and White females (32 and 31 per 1000, respectively).

Due to these differences in estimated lifetime risk of colorectal cancer death among Black adults vs White adults by sex in the absence of screening, estimated LYG from both colonoscopy and FIT were generally lower for Black males vs White males and generally similar for Black females vs White females (Appendix Figures 11.1 and 11.2). However, efficient strategies by race and sex were generally the same, and efficiency ratios were similar by race among each sex (Tables 11 and 12; Appendix Tables 11.1 and 11.2), suggesting that with equal access to quality care, the relative balance of the colonoscopy burden and the LYG from screening differs by sex but not by race. For example, across models, efficiency ratios for 10-yearly colonoscopy from age 45 to 75 ranged from 48 to 143 for White males, 46 to 142 for Black males, 57 to 100 for White females, and 51 to 93 for Black females. Among all 4 race-sex groups, efficient screening options for all 3 models were predominantly those beginning at age 45. Results for colonoscopy are described in more detail below, followed by those for FIT.

Table 11 Estimated Range of Outcomes Over the Lifetime of a Cohort of 40-Year-Olds Across the SimCRC, CRC-SPIN, and MISCAN Models With No Screening and With Efficient Colonoscopy Screening Strategies Among the Total Population and by Race and Sex

Strategy | Range of outcomes across models, by population group
Strategy | Colonoscopies per 1000 | | | | | Colorectal cancer cases per 1000 | | | | | Colorectal cancer deaths per 1000 | | | | | Days of life gained per person | | | | | Efficiency ratio (Δ COL / Δ LYG)
Strategy | TP | WM | BM | WF | BF | TP | WM | BM | WF | BF | TP | WM | BM | WF | BF | TP | WM | BM | WF | BF | TP | WM | BM | WF | BF
No screening | 77-85 | 80-92 | 68-78 | 74-78 | 68-72 | 77-85 | 80-92 | 68-78 | 74-78 | 68-72 | 32-34 | 33-37 | 31-35 | 30-32 | 31-33 | 0 | 0 | 0 | 0 | 0
COL 55-70, 15 | 2532-2630 | 2560-2658 | 2320-2411 | 2522-2647 | 2387-2503 | 21-40 | 21-44 | 19-39 | 21-38 | 19-35 | 7-11 | 7-12 | 8-12 | 7-10 | 7-11 | 91-104 | 92-106 | 81-96 | 89-98 | 88-99 | -- | -- | -- | -- | --
COL 50-70, 15 | 2734-2868 | 2788-2929 | 2575-2704 | 2695-2855 | 2580-2728 | 18-40 | 17-44 | 15-38 | 19-38 | 17-35 | 6-11 | 6-12 | 6-12 | 6-10 | 7-11 | 96-116 | 98-119 | 87-108 | 94-110 | 93-111 | 6^*^-18 | 7-17 | 8-18 | 5^*^-17 | 6^*^-18
COL 45-70, 15 | 2829-3006 | 2903-3104 | 2732-2916 | 2768-2966 | 2678-2862 | 18-41 | 16-45 | 14-39 | 19-39 | 18-36 | 6-12 | 6-13 | 5-13 | 6-11 | 7-12 | 97-123 | 99-125 | 89-115 | 93-116 | 93-118 | 6-85^*^ | 7-52^*^ | 8-45^*^ | 5-26^*^ | 5-280^*^
COL 45-75, 15 | 3463-3558 | 3475-3620 | 3199-3340 | 3472-3567 | 3311-3404 | 14-37 | 13-41 | 12-36 | 15-35 | 14-33 | 4-10 | 4-10 | 4-11 | 4-9 | 4-10 | 103-129 | 104-131 | 93-120 | 99-122 | 99-124 | 38^*^-59^*^ | 35^*^-70^*^ | 33^*^-72^*^ | 44^*^-55^*^ | 40^*^-50^*^
COL 45-70, 10 | 3679-3782 | 3714-3865 | 3483-3623 | 3661-3788 | 3532-3650 | 13-37 | 12-40 | 11-35 | 15-35 | 14-32 | 4-10 | 4-10 | 4-10 | 4-9 | 5-10 | 107-132 | 109-134 | 98-123 | 103-125 | 103-127 | 34-45 | 33-49 | 32-49 | 38-55 | 35-50
COL 45-75, 10 | 4212-4300 | 4180-4306 | 3865-3988 | 4268-4318 | 4080-4129 | 12-34 | 11-38 | 10-33 | 12-32 | 11-30 | 3-8 | 4-9 | 4-9 | 3-8 | 3-8 | 110-135 | 112-137 | 100-126 | 106-128 | 106-130 | 52-112 | 48-143 | 46-142 | 57-100 | 51-93
COL 45-85, 10 | 4449-4566 | 4341-4504 | 3994-4136 | 4572-4653 | 4343-4419 | 11-34 | 11-38 | 10-33 | 12-32 | 11-30 | 3-8 | 3-9 | 3-9 | 2-7 | 3-8 | 110-135 | 112-137 | 100-126 | 107-128 | 107-130 | 227^*^-828^*^ | 228^*^-870^*^ | 187^*^-395^*^ | 270^*^-574^*^ | 219^*^-416^*^
COL 45-70, 5 | 5626-5789 | 5456-5689 | 5129-5347 | 5802-5917 | 5596-5710 | 10-32 | 10-35 | 9-30 | 11-30 | 10-28 | 3-8 | 3-8 | 3-8 | 2-7 | 3-8 | 116-138 | 118-140 | 106-129 | 112-130 | 112-133 | 84-180^*^ | 74-187 | 74-203 | 95-206 | 92-185^*^
COL 45-75, 5 | 6016-6235 | 5764-6060 | 5384-5653 | 6270-6444 | 6020-6186 | 10-31 | 9-34 | 8-30 | 9-29 | 9-27 | 3-7 | 3-8 | 3-8 | 2-7 | 2-7 | 117-139 | 119-141 | 107-130 | 113-131 | 113-134 | 116-344 | 110-450 | 103-414 | 129-322 | 115-299
COL 45-80, 5 | 6320-6581 | 5989-6333 | 5560-5867 | 6649-6866 | 6354-6558 | 9-30 | 9-33 | 8-29 | 9-28 | 8-26 | 2-7 | 3-7 | 3-8 | 2-6 | 2-7 | 118-139 | 119-141 | 108-130 | 114-131 | 114-134 | 169-736 | 163-1030 | 145-843 | 210-680 | 175-605
COL 45-85, 5 | 6516-6817 | 6122-6506 | 5660-5997 | 6909-7167 | 6579-6819 | 9-30 | 9-33 | 8-29 | 9-28 | 8-26 | 2-7 | 3-7 | 3-8 | 2-6 | 2-7 | 118-139 | 119-141 | 108-130 | 114-132 | 114-134 | 926-2190 | 934-8876 | 724-4827 | 1100-3557 | 863-1813

TP – total population; WM – White males; BM – Black males; WF – White females; BF – Black females; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Table 12 Estimated Range of Outcomes Over the Lifetime of a Cohort of 40-Year-Olds Across the SimCRC, CRC-SPIN, and MISCAN Models With No Screening and With Efficient FIT Strategies Among the Total Population and by Race and Sex

Strategy | Range of outcomes across models, by population group
Strategy | Colonoscopies per 1000 | | | | | Colorectal cancer cases per 1000 | | | | | Colorectal cancer deaths per 1000 | | | | | Days of life gained per person | | | | | Efficiency ratio (Δ COL / Δ LYG)
Strategy | TP | WM | BM | WF | BF | TP | WM | BM | WF | BF | TP | WM | BM | WF | BF | TP | WM | BM | WF | BF | TP | WM | BM | WF | BF
No screening | 77-85 | 80-92 | 68-78 | 74-78 | 68-72 | 77-85 | 80-92 | 68-78 | 74-78 | 68-72 | 32-34 | 33-37 | 31-35 | 30-32 | 31-33 | 0 | 0 | 0 | 0 | 0
FIT 55-70, 3 | 624-754 | 687-845 | 607-747 | 566-668 | 529-624 | 47-65 | 47-70 | 42-61 | 46-62 | 43-57 | 17-20 | 17-20 | 16-20 | 15-18 | 17-19 | 63-74 | 64-77 | 55-67 | 61-70 | 59-67 | -- | -- | -- | -- | --
FIT 50-70, 3 | 691-858 | 760-968 | 682-869 | 627-754 | 591-708 | 43-64 | 43-69 | 37-60 | 43-61 | 40-56 | 15-20 | 15-20 | 15-20 | 14-18 | 16-19 | 67-84 | 69-88 | 60-77 | 66-80 | 63-78 | 2-6^*^ | 3-10^*^ | 3-7^*^ | 2-6^*^ | 2-6^*^
FIT 45-70, 3 | 810-1007 | 886-1137 | 801-1027 | 739-883 | 699-834 | 38-62 | 38-67 | 33-58 | 39-59 | 36-55 | 13-18 | 13-19 | 12-19 | 13-17 | 14-18 | 75-97 | 77-100 | 67-90 | 73-92 | 70-90 | 3-6^*^ | 4-6^*^ | 4-6^*^ | 3-7^*^ | 3-7^*^
FIT 45-75, 3 | 917-1110 | 1000-1243 | 894-1114 | 842-984 | 793-926 | 36-60 | 35-65 | 31-57 | 36-57 | 34-53 | 11-16 | 11-16 | 11-16 | 10-14 | 11-16 | 82-104 | 84-108 | 73-96 | 80-99 | 78-97 | 5-7^*^ | 6-9^*^ | 6-9^*^ | 5-9^*^ | 5-10^*^
FIT 45-80, 3 | 971-1163 | 1054-1294 | 937-1154 | 896-1039 | 840-974 | 35-60 | 34-65 | 30-57 | 35-56 | 33-52 | 10-14 | 10-15 | 11-15 | 9-13 | 10-14 | 85-107 | 87-110 | 75-98 | 83-102 | 80-99 | 6-8^*^ | 6-10^*^ | 6-10^*^ | 7-7 | 7-7^*^
FIT 45-75, 2 | 1147-1361 | 1239-1512 | 1113-1360 | 1063-1219 | 1001-1149 | 29-55 | 28-60 | 25-52 | 30-52 | 28-48 | 9-13 | 8-13 | 8-14 | 8-12 | 9-13 | 93-116 | 96-119 | 84-107 | 91-109 | 88-108 | 7-9 | 7-11 | 7-11 | 8-8 | 7-10^*^
FIT 45-80, 2 | 1220-1426 | 1307-1574 | 1170-1409 | 1138-1289 | 1068-1211 | 28-54 | 27-59 | 24-52 | 28-51 | 26-47 | 7-12 | 7-12 | 8-13 | 6-11 | 8-12 | 96-119 | 98-122 | 86-109 | 94-112 | 91-111 | 8-12 | 8-19^*^ | 8-16^*^ | 8-13 | 8-14^*^
FIT 45-85, 2 | 1288-1492 | 1358-1632 | 1209-1453 | 1218-1363 | 1138-1275 | 27-54 | 26-59 | 24-52 | 28-51 | 26-47 | 6-11 | 6-11 | 7-12 | 5-10 | 7-11 | 98-120 | 100-123 | 87-110 | 96-114 | 93-112 | 12-25^*^ | 13-22^*^ | 11-19^*^ | 12-21^*^ | 11-17^*^
FIT 45-75, 1 | 1602-1824 | 1702-1990 | 1540-1805 | 1513-1670 | 1431-1581 | 20-46 | 19-50 | 17-44 | 21-44 | 20-40 | 6-10 | 6-11 | 6-11 | 5-10 | 6-11 | 106-127 | 109-131 | 97-119 | 103-120 | 101-120 | 15^*^-16 | 14^*^-20 | 13^*^-22 | 15-17 | 14-15
FIT 45-80, 1 | 1710-1923 | 1791-2080 | 1614-1876 | 1633-1780 | 1538-1678 | 19-45 | 18-49 | 16-43 | 20-42 | 19-39 | 5-9 | 5-9 | 5-10 | 4-8 | 5-9 | 110-129 | 112-133 | 99-120 | 106-122 | 105-123 | 14-27 | 14-32 | 13-28 | 15-23 | 13-21
FIT 45-85, 1 | 1769-1990 | 1841-2136 | 1652-1919 | 1717-1859 | 1611-1747 | 19-44 | 18-49 | 16-43 | 19-41 | 18-38 | 4-8 | 4-9 | 5-9 | 3-7 | 4-8 | 111-130 | 113-133 | 100-121 | 108-123 | 106-123 | 19-43 | 20-63 | 17-52 | 20-42 | 17-35

TP – total population; WM – White males; BM – Black males; WF – White females; BF – Black females; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

For colonoscopy screening, the SimCRC and CRC-SPIN models found that for each of the 4 race-sex groups, efficient strategies were the same as those for the population as a whole (Appendix Tables 11.1a and 11.1b). With MISCAN, differences in conclusions about efficiency only occurred for COL 55-85, 15, which was efficient among Black males and dominated in all other groups, including the total population (Appendix Table 11.1c). With SimCRC and MISCAN, efficiency ratios for a given colonoscopy strategy were generally lower for males than for females, while the opposite was true with CRC-SPIN. Across all 3 models, efficiency ratios were slightly lower for a given colonoscopy strategy for Black adults vs White adults by sex. For example, the efficiency ratio for COL 45-75, 10 was 52 vs 56 additional colonoscopies per LYG for Black vs White males and 66 vs 76 for Black vs White females (reported ratios are from SimCRC, Appendix Table 11.1a).

For FIT screening, efficient strategies with SimCRC were the same as those for the population as a whole (Appendix Table 11.2a). With CRC-SPIN and MISCAN, differences in efficiency across populations occurred almost exclusively in strategies with biennial and triennial screening (Appendix Tables 11.2b and 11.2c). With CRC-SPIN, strategies that were dominated among the total population and among White and Black males were efficient among White and Black females. No clear patterns were observed for changes in efficiency by race and sex with MISCAN. As with colonoscopy screening strategies, efficiency ratios for a given FIT strategy were generally the same as or lower for males than for females in SimCRC and MISCAN, while the opposite was true with CRC-SPIN. Across all 3 models, efficiency ratios for a given FIT strategy were generally equal to or slightly lower for Black adults vs White adults by sex. For example, the efficiency ratio for FIT 45-80, 1 was 28 vs 32 additional colonoscopies per LYG for Black males vs White males and 21 vs 23 for Black females vs White females (reported ratios are from CRC-SPIN, Appendix Tables 11.2b).

### Measure of the Benefit of Screening

#### QALYG

Estimated QALYG from screening ranged from 144 to 358 per 1000 40-year-olds, which is lower than the range for estimated LYG (171 to 381 per 1000, Appendix Tables 9.1–9.8). In general, we found a larger effect of quality-adjustment of LYG for strategies and models that estimated more colorectal cancer cases (i.e., stool-based strategies, compared with direct-visualization tests (colonoscopy, CTC, and sigmoidoscopy), and MISCAN, compared with SimCRC and CRC-SPIN), due to the relatively large decrement in quality of life associated with colorectal cancer (Appendix Table 3.4 vs Appendix Tables 3.2 and 3.3).

Efficient strategies within each class of screening modality with estimated QALYG as the measure of benefit were nearly identical to those with estimated LYG (Appendix Tables 12.1–12.5; Appendix Figures 12.1–12.5). Estimated QALYG with a given screening strategy were lower than the estimated LYG, shifting the efficient frontier down. For each class of screening modality, efficient screening strategies continued to be primarily those with screening starting at age 45; MISCAN continued to find additional strategies with screening starting at age 50 or 55 to be efficient. Across classes of screening modalities and models, efficiency ratios were generally the same or higher with estimated QALYG vs estimated LYG as the measure of screening benefit, though the differences in efficiency ratios were small for most strategies (Appendix Tables 12.1–12.5). For example, with SIG 45-75, 5 efficiency ratios with LYG and QALYG were 20 and 23 with SimCRC, 27 and 31 with CRC-SPIN, and 19 and 23 with MISCAN (Appendix Table 12.3).

#### Colorectal Cancer Deaths Averted

The estimated number of colorectal cancer deaths averted ranged from 15 to 32 per 1000 (Appendix Tables 9.1–9.8). Within each class of screening modality, the ranking of strategies by the estimated number of colorectal cancer deaths averted differed from the ranking by the estimated number of LYG. As a result, the strategies deemed efficient changed when the estimated number of colorectal cancer deaths averted was used as the measure of the benefit of screening, instead of the estimated LYG (Appendix Tables 13.1–13.5; Figures 17–21). Efficient strategies included those with all 3 ages to begin screening, all 4 ages to end screening, and all simulated screening intervals. Incremental numbers of colonoscopies required to prevent an additional colorectal cancer death are presented in Appendix Tables 13.6–13.10.

##### Colonoscopy Strategies

The colonoscopy screening strategy with the fewest estimated colorectal cancer deaths averted varied across models (Figure 17): COL 55-70, 10 with SimCRC (27 estimated colorectal cancer deaths averted per 1000 40-year-olds); COL 55-70, 15 with CRC-SPIN (24 estimated colorectal cancer deaths averted per 1000); and COL 45-70, 15 with MISCAN (22 estimated colorectal cancer deaths averted per 1000). The estimated number of colorectal cancer deaths averted was highest with COL 45-85, 5 with all 3 models (28 to 32 per 1000, Appendix Table 9.1). The number of efficient colonoscopy screening strategies was 16 with SimCRC, 15 with CRC-SPIN, and 23 with MISCAN; 13 strategies were efficient with all 3 models (Appendix Table 13.6). Compared to COL 55-70, 15, COL 50-70, 10 required 380 to 712 additional colonoscopies per additional colorectal cancer death averted. This number increased to over 3000 colonoscopies per additional colorectal cancer death averted for COL 45-85, 5 vs COL 45-80, 5.

Figure 17 Estimated Colonoscopies and Colorectal Cancer Deaths Averted for a Cohort of 40-Year-Olds for Colonoscopy Screening Strategies, by Model

Estimated colonoscopies vs colorectal cancer deaths averted for colonoscopy screening strategies.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

##### Stool Tests

With SimCRC and CRC-SPIN, FIT 55-70, 3 was estimated to prevent the fewest colorectal cancer deaths (15 to 17 per 1000), while with MISCAN FIT 50-70, 3 was estimated to prevent the fewest (15 per 1000) (Figure 18). With all 3 models, sDNA-FIT 45-85, 1 was estimated to prevent the most colorectal cancer deaths (27 to 31 per 1000). The number of efficient stool test strategies was 24 with SimCRC, 40 with CRC-SPIN, and 23 with MISCAN; 18 strategies were efficient with all 3 models. For these strategies, the estimated number of additional colonoscopies per colorectal cancer death averted were 35 to 54 with FIT 55-75, 3; 317 to 531 with FIT 50-80, 1; and 783 to over 1200 with sDNA-FIT 45-85, 1 (Appendix Table 13.7). Efficient strategies with all 3 models included all ages to begin and end screening and screening intervals, but were primarily those with FIT, as opposed to sDNA-FIT. sDNA-FIT strategies with a 3-year interval were not efficient with 2 models and were efficient with CRC-SPIN (>300 additional colonoscopies per colorectal cancer death averted).

Figure 18 Estimated Colonoscopies and Colorectal Cancer Deaths Averted for a Cohort of 40-Year-Olds for FIT and sDNA-FIT Screening Strategies, by Model

Estimated colonoscopies vs colorectal cancer deaths averted for FIT and sDNA-FIT screening strategies.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

##### Other Modalities

For all but 1 other screening modality, the strategies estimated to yield the fewest and most colorectal cancer deaths averted did not vary across models. For sigmoidoscopy and CTC, screening from ages 55 to 70 every 10 years (SIG or CTC 55-70, 10) was estimated to yield the fewest colorectal cancer deaths averted (18 to 19 per 1000 with sigmoidoscopy (Figure 19); 16 to 22 with CTC (Figure 21)), and screening from ages 45 to 85 every 5 years (45-85, 5) was estimated to yield the most colorectal cancer deaths averted (23 to 27 with sigmoidoscopy; 25 to 31 with CTC). For SIG+FIT, screening from ages 55 to 70 with sigmoidoscopy every 10 years and biennial FIT (SIG+FIT 55-70, 10_2) was estimated to yield the fewest colorectal cancer deaths averted (22 to 24 per 1000 (Figure 20)) and screening from ages 45 to 85 with sigmoidoscopy every 10 years and annual FIT (SIG+FIT 45-85, 10_1) was estimated to yield the most (27 to 31 per 1000).

Figure 19 Estimated Colonoscopies and Colorectal Cancer Deaths Averted for a Cohort of 40-Year-Olds for Sigmoidoscopy Screening Strategies, by Model

Estimated colonoscopies vs colorectal cancer deaths averted for sigmoidoscopy screening strategies.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Figure 20 Estimated Colonoscopies and Colorectal Cancer Deaths Averted for a Cohort of 40-Year-Olds for 10-Yearly Sigmoidoscopy Plus Interval FIT Screening Strategies, by Model

Estimated colonoscopies vs colorectal cancer deaths averted for 10-yearly sigmoidoscopy plus interval FIT screening strategies.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Figure 21 Estimated Colonoscopies and Colorectal Cancer Deaths Averted for a Cohort of 40-Year-Olds for Computed Tomographic Colonography Screening Strategies, by Model

Estimated colonoscopies vs colorectal cancer deaths averted for computed tomographic colonography screening strategies.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Efficient sigmoidoscopy (Appendix Table 13.8) and CTC (Appendix Table 13.10) strategies with all 3 models included all 3 ages to begin screening, all 4 ages to end screening, and both screening intervals. With SIG+FIT, no ages to begin or end screening or FIT interval were predominant among the efficient strategies with all 3 models (Appendix Table 13.9).

### Population-Level Risk (IRR)

Estimated adenoma prevalence and colorectal cancer incidence when models were calibrated to achieve an IRR of 1.52 are presented in Appendix 14. Estimated adenoma prevalence and colorectal cancer incidence were fairly similar with SimCRC and MISCAN: prevalence increased to a maximum of 63% to 65% by approximately age 85 (Appendix Figure 14.6) and the lifetime incidence of colorectal cancer was estimated at 103 to 105 cases per 1000 (Appendix Figure 14.9). With CRC-SPIN smaller changes in adenoma onset were needed to achieve an IRR of 1.52; estimated adenoma prevalence was at most 47% by age 79, and lifetime incidence of colorectal cancer was 91 cases per 1000. For all models, estimated adenoma prevalence was still within the range observed in autopsy studies.

Within each class of screening modality, efficient strategies, based on estimated life-years gained, were nearly identical across the 3 scenarios for colorectal cancer risk (Appendix Tables 14.1–14.7, Figures 22–26). Across all models, efficient strategies were generally those with screening beginning at age 45. Efficiency ratios generally decreased as risk increased. Changes for specific classes of modalities are highlighted below.

#### Colonoscopy

With SimCRC and CRC-SPIN the efficient colonoscopy screening strategies did not change across scenarios of population colorectal cancer risk (Appendix Tables 14.1a, 14.1b; Figures 22a, 22b). With MISCAN, COL 50-75, 5 was not efficient at the highest assumed increase in population risk (IRR = 1.52); it was dominated by COL 45-70, 5 but was efficient at lower risk (Appendix Table 14.1c; Figure 22c). As noted above, efficiency ratios generally fell as risk increased. For example, the efficiency ratio for COL 45-70, 10 fell from 39 to 58 across models with IRR = 1, to 34 to 45 across models with IRR = 1.19, and to 29 to 40 across models with IRR = 1.52, respectively.

Figure 22a Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for Colonoscopy Screening Strategies, by Risk Scenario: SimCRC

Estimated colonoscopies vs life-years gained for colonoscopy screening strategies by risk scenario (SimCRC).

Figure 22b Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for Colonoscopy Screening Strategies, by Risk Scenario: CRC-SPIN

Estimated colonoscopies vs life-years gained for colonoscopy screening strategies by risk scenario (CRC-SPIN).

Figure 22c Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for Colonoscopy Screening Strategies, by Risk Scenario: MISCAN

Estimated colonoscopies vs life-years gained for colonoscopy screening strategies by risk scenario (MISCAN).

#### Stool Tests

With all models, efficient stool strategies changed across scenarios of population colorectal cancer risk. For SimCRC, FIT 50-75, 3 was only efficient at IRR = 1, and sDNA-FIT 45-70, 1 was not efficient at IRR = 1.52 (Appendix Table 14.2a; Figure 23a). For CRC-SPIN, 4 strategies (FIT 55-75, 3; FIT 55-70, 2; FIT 50-75, 3; and FIT 50-70, 2) were only efficient at IRR = 1 (no increase in risk from 1975-1979 levels) (Appendix Table 14.2b; Figure 23b). For MISCAN, 3 FIT strategies that were efficient at IRR = 1 were not efficient at higher levels of colorectal cancer risk and an additional 5 strategies were efficient at only the two lower levels of risk (IRR = 1 and IRR = 1.19), including the 2016 USPSTF-highlighted FIT strategy (FIT 50-75, 1) (Appendix Table 14.2c; Figure 23c). The efficiency ratio for FIT 45-75, 1, for example, fell as risk increased: the range across models was 16 to 18 with IRR = 1, 15 to 16 with IRR = 1.19, and 13 to 15 with IRR = 1.52.

Figure 23a Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for FIT and sDNA-FIT Screening Strategies, by Risk Scenario: SimCRC

Estimated colonoscopies vs life-years gained for FIT and sDNA-FIT screening strategies by risk scenario (SimCRC)

Figure 23b Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for FIT and sDNA-FIT Screening Strategies, by Risk Scenario: CRC-SPIN

Estimated colonoscopies vs life-years gained for FIT and sDNA-FIT screening strategies by risk scenario (CRC-SPIN)

Figure 23c Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for FIT and sDNA-FIT Screening Strategies, by Risk Scenario: MISCAN

Estimated colonoscopies vs life-years gained for FIT and sDNA-FIT screening strategies by risk scenario (MISCAN)

#### Sigmoidoscopy

With CRC-SPIN, efficient sigmoidoscopy strategies did not change across scenarios of population colorectal cancer risk (Appendix Table 14.3b; Figure 24b). With SimCRC, SIG 45-85, 10 was only efficient at IRR = 1 (Appendix Table 14.3a; Figure 24a). Similarly, with MISCAN, SIG 55-75, 10 and SIG 55-75, 5 were only efficient at IRR = 1 (Appendix Table 14.3c; Figure 24c), and SIG 45-85, 10 was only efficient with IRR = 1 and IRR = 1.19 but not IRR = 1.52. The efficiency ratio for SIG 45-75, 5, for example, fell as risk increased: the range across models was 22 to 29 with IRR = 1, 19 to 27 with IRR = 1.19, and 16 to 24 with IRR = 1.52.

Figure 24a Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for Sigmoidoscopy Screening Strategies, by Risk Scenario: SimCRC

Estimated colonoscopies vs life-years gained for sigmoidoscopy screening strategies by risk scenario (SimCRC)

Figure 24b Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for Sigmoidoscopy Screening Strategies, by Risk Scenario: CRC-SPIN

Estimated colonoscopies vs life-years gained for sigmoidoscopy screening strategies by risk scenario (CRC-SPIN)

Figure 24c Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for Sigmoidoscopy Screening Strategies, by Risk Scenario: MISCAN

Estimated colonoscopies vs life-years gained for sigmoidoscopy screening strategies by risk scenario (MISCAN)

#### SIG+FIT

With SimCRC and CRC-SPIN, efficient SIG+FIT strategies did not change across scenarios of population colorectal cancer risk (Appendix Tables 14.4a, 14.4b; Figures 25a, 25b). With MISCAN, 2 strategies (SIG+FIT 55-75, 10_2 and SIG+FIT 55-80, 10_2) were not efficient at IRR = 1.52 (Appendix Table 14.4c; Figure 25c).

Figure 25a Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for 10-Yearly Sigmoidoscopy Plus Interval FIT Screening Strategies, by Risk Scenario: SimCRC

Estimated colonoscopies vs life-years gained for 10-yearly sigmoidoscopy plus interval FIT screening strategies by risk scenario (SimCRC)

Figure 25b Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for 10-Yearly Sigmoidoscopy Plus Interval FIT Screening Strategies, by Risk Scenario: CRC-SPIN

Estimated colonoscopies vs life-years gained for 10-yearly sigmoidoscopy plus interval FIT screening strategies by risk scenario (CRC-SPIN)

Figure 25c Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for 10-Yearly Sigmoidoscopy Plus Interval FIT Screening Strategies, by Risk Scenario: MISCAN

Estimated colonoscopies vs life-years gained for 10-yearly sigmoidoscopy plus interval FIT screening strategies by risk scenario (MISCAN)

#### CTC

As with sigmoidoscopy strategies, efficient CTC strategies with CRC-SPIN did not change across scenarios of population colorectal cancer risk (Appendix Table 14.5b; Figure 26b). With SimCRC, CTC 45-85, 10 was only efficient at IRR = 1 (Appendix Table 14.5a; Figure 26a). With MISCAN, both CTC 55-75, 10 and CTC 45-75, 10 were only efficient at IRR = 1 (Appendix Table 14.5c; Figure 26c), and CTC 55-80, 5 was not efficient at IRR = 1.52. The efficiency ratio for CTC 45-75, 5, for example, fell as risk increased; the range across models was 12 to 22 with IRR = 1, 11 to 21 with IRR = 1.19, and 8 to 19 with IRR = 1.52.

Figure 26a Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for Computed Tomographic Colonography Screening Strategies, by Risk Scenario: SimCRC

Estimated colonoscopies vs life-years gained for computed tomographic colonography screening strategies by risk scenario (SimCRC)

Figure 26b Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for Computed Tomographic Colonography Screening Strategies, by Risk Scenario: CRC-SPIN

Estimated colonoscopies vs life-years gained for computed tomographic colonography screening strategies by risk scenario (CRC-SPIN)

Figure 26c Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for Computed Tomographic Colonography Screening Strategies, by Risk Scenario: MISCAN

Estimated colonoscopies vs life-years gained for computed tomographic colonography screening strategies by risk scenario (MISCAN)

### Colonoscopy Sensitivity

Sensitivity analyses on colonoscopy sensitivity were performed only for colonoscopy modalities alone and FIT modalities alone. For colonoscopy strategies (Appendix Table 15.1), efficient strategies were unchanged across all models when alternative (lower) values for the sensitivity of colonoscopy (Table 7) were used. For efficient colonoscopy strategies with a 10- or 15-year screening interval, changes in efficiency ratios were small. For FIT (Appendix Table 15.2), efficient strategies were nearly identical with use of the alternative values for colonoscopy sensitivity; the exception was that with CRC-SPIN 1 additional strategy (FIT 55-75, 3) was included as efficient (Appendix Table 15.2b). All changes in efficiency ratios were small. Efficiency ratios generally decreased from the base-case estimates.

### Potential Implications of Adherence

Because this analysis is meant to inform population guidelines, the analyses assumed perfect adherence to screening strategies, including receipt of all screening, follow-up (i.e., for abnormal non-colonoscopy screening tests), and surveillance tests in order to predict the maximum achievable benefit for each strategy. In practice, such high adherence is not observed.^17^ Because of the complexities and uncertainties of long-term adherence rates, we did not simulate scenarios of imperfect adherence. Instead, we highlight the potential implications of non-adherence.

There are at least 3 different types of non-adherence associated with colorectal cancer screening: initial screening, repeat screening, and follow-up colonoscopy. Below, we discuss evidence available related to each type of screening failure, and plausible ways to consider the effect of non-adherence on outcomes.

#### Screening Initiation

Adherence to initial screening, also referred to as screening uptake, is arguably the most important type of adherence in terms of its effect on health benefits. Not initiating screening is equivalent to remaining unscreened, and results in no “screening” benefit. The effect of screening uptake on outcomes can be compared by taking a weighted average of estimated outcomes with a given screening strategy and with no screening.

The effect of delayed uptake (e.g., a person who is recommended to start screening at age 50 doesn’t get her first screen until the age of 53 years) can be gleaned from the differences in estimated outcomes based on different start ages. For example, with annual FIT to age 75, delaying the start age from age 50 to age 55 could result in 3 to 6 additional diagnosed cases of colorectal cancer per 1000, 1 to 2 additional colorectal cancer deaths per 1000, and a loss of 28 to 41 LYG per 1000 (Table 13). Changes in outcomes with delayed screening uptake may be similar with colonoscopy screening every 10 years to age 75: a 5-year delay (i.e., starting at age 55 instead of 50) could result in 1 to 4 additional cases per 1000, 0.1 to 0.4 additional colorectal cancer deaths per 1000, and a loss of 22 to 38 LYG per 1000. Changes in outcomes associated with 5- and 10-year delays in screening initiation relative to colorectal cancer screening starting at age 45 are presented in Appendix Table 16.1.

Table 13 Illustration of the Estimated Changes in Outcomes From Adherence to Screening Initiation for Sample Strategies With Screening Beginning at Age 50, by Model^*^

Strategy by model | Outcomes and change in outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | DLG
Strategy by model | Stool tests | SIGs | CTCs | COLs | Compli-cations | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
Colonoscopy (COL)
SimCRC
COL 50-75, 10 | 0 | 0 | 0 | 3414 | 13 | 18 | 5 | 335 | 314 | 122
Delay start by 5y | 0 | 0 | 0 | −262 | +2 | +4 | +1 | −38 | −38 | −14
CRC-SPIN
COL 50-75, 10 | 0 | 0 | 0 | 3500 | 15 | 15 | 5 | 308 | 291 | 112
Delay start by 5y | 0 | 0 | 0 | −285 | +1 | +3 | +1 | −30 | −30 | −11
MISCAN
COL 50-75, 10 | 0 | 0 | 0 | 3476 | 14 | 36 | 9 | 286 | 257 | 104
Delay start by 5y | 0 | 0 | 0 | −296 | +1 | +1 | +0.4 | −22 | −21 | −8
Sigmoidoscopy (SIG)
SimCRC
SIG 50-75, 5 | 0 | 4058 | 0 | 1544 | 10 | 29 | 9 | 279 | 260 | 102
Delay start by 5y | 0 | −755 | 0 | −187 | −0.2 | +5 | +2 | −37 | −36 | −14
CRC-SPIN
SIG 50-75, 5 | 0 | 4134 | 0 | 1510 | 11 | 26 | 9 | 256 | 241 | 94
Delay start by 5y | 0 | −770 | 0 | −185 | −0.4 | +4 | +1 | −27 | −27 | −10
MISCAN
SIG 50-75, 5 | 0 | 3646 | 0 | 1927 | 12 | 40 | 11 | 256 | 229 | 93
Delay start by 5y | 0 | −686 | 0 | −215 | −0.1 | +2 | +0.9 | −22 | −21 | −8
Sigmoidoscopy plus interval fecal immunochemical testing (SIG+FIT)
SimCRC
SIG+FIT 50-75, 10_1 | 13537 | 2099 | 0 | 1840 | 11 | 22 | 6 | 330 | 306 | 121
Delay start by 5y | −2885 | −269 | 0 | −190 | +0.4 | +5 | +2 | −40 | −39 | −15
CRC-SPIN
SIG+FIT 50-75, 10_1 | 13305 | 2067 | 0 | 1973 | 13 | 18 | 6 | 301 | 282 | 110
Delay start by 5y | −2828 | −257 | 0 | −232 | −0.2 | +4 | +1 | −31 | −31 | −12
MISCAN
SIG+FIT 50-75, 10_1 | 12357 | 1900 | 0 | 2048 | 12 | 39 | 10 | 287 | 255 | 105
Delay start by 5y | −2732 | −169 | 0 | −177 | +0.6 | +1 | +0.6 | −24 | −22 | −9
Computed tomographic colonography (CTC)
SimCRC
CTC 50-75, 5 | 0 | 0 | 4006 | 1624 | 11 | 21 | 6 | 325 | 302 | 119
Delay start by 5y | 0 | 0 | −760 | −177 | −0.2 | +5 | +2 | −41 | −40 | −15
CRC-SPIN
CTC 50-75, 5 | 0 | 0 | 4088 | 1626 | 12 | 20 | 7 | 287 | 270 | 105
Delay start by 5y | 0 | 0 | −768 | −186 | −0.4 | +4 | +1 | −30 | −30 | −11
MISCAN
CTC 50-75, 5 | 0 | 0 | 4075 | 1519 | 10 | 43 | 11 | 268 | 238 | 98
Delay start by 5y | 0 | 0 | −766 | −169 | −0.2 | +2 | +1 | −24 | −23 | −9
Fecal immunochemical testing (FIT)
SimCRC
FIT 50-75, 1 | 16160 | 0 | 0 | 1423 | 9 | 30 | 7 | 316 | 289 | 115
Delay start by 5y | −3370 | 0 | 0 | −191 | −0.3 | +6 | +2 | −41 | −40 | −15
CRC-SPIN
FIT 50-75, 1 | 15562 | 0 | 0 | 1619 | 12 | 23 | 7 | 285 | 266 | 104
Delay start by 5y | −3221 | 0 | 0 | −225 | −0.6 | +5 | +2 | −35 | −34 | −13
MISCAN
FIT 50-75, 1 | 16097 | 0 | 0 | 1445 | 10 | 47 | 11 | 274 | 240 | 100
Delay start by 5y | −3340 | 0 | 0 | −193 | −0.3 | +3 | +1 | −28 | −26 | −10
Multitarget stool DNA test (sDNA-FIT), 1-year interval
SimCRC
sDNA-FIT 50-75, 1 | 11463 | 0 | 0 | 2156 | 11 | 22 | 6 | 330 | 305 | 121
Delay start by 5y | −2291 | 0 | 0 | −307 | −0.2 | +5 | +2 | −41 | −40 | −15
CRC-SPIN
sDNA-FIT 50-75, 1 | 11132 | 0 | 0 | 2295 | 14 | 18 | 6 | 301 | 281 | 110
Delay start by 5y | −2222 | 0 | 0 | −331 | −0.5 | +5 | +2 | −33 | −33 | −12
MISCAN
sDNA-FIT 50-75, 1 | 11315 | 0 | 0 | 2211 | 12 | 39 | 9 | 290 | 257 | 106
Delay start by 5y | −2225 | 0 | 0 | −314 | −0.2 | +2 | +1 | −27 | −25 | −10
Multitarget stool DNA test (sDNA-FIT), 3-year interval
SimCRC
sDNA-FIT 50-75, 3 | 6074 | 0 | 0 | 1405 | 9 | 34 | 8 | 304 | 278 | 111
Delay start by 5y | −1344 | 0 | 0 | −218 | −0.5 | +6 | +2 | −43 | −41 | −16
CRC-SPIN
sDNA-FIT 50-75, 3 | 5939 | 0 | 0 | 1576 | 12 | 26 | 8 | 271 | 253 | 99
Delay start by 5y | −1306 | 0 | 0 | −244 | −0.8 | +5 | +2 | −35 | −34 | −13
MISCAN
sDNA-FIT 50-75, 3 | 6006 | 0 | 0 | 1449 | 9 | 50 | 12 | 257 | 223 | 94
Delay start by 5y | −1321 | 0 | 0 | −218 | −0.5 | +3 | +1 | −28 | −26 | −10

CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening.

* These strategies were selected for illustration purposes. Inclusion in this table should not be interpreted as endorsement of these strategies.

† Includes deaths from complications of screening.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix G of the systematic evidence review reports wide ranges of the adherence to initial screening based on both US and non-US studies performed over the past 3 decades.^17^ A population-based estimate from the Behavioral Risk Factor Surveillance System survey shows that 26% of the US population of screening age have never been screened, indicating an uptake of 74%.^99^ For those who do initiate screening, the benefit depends on the adherence with repeat screening and follow-up colonoscopy (if applicable).

#### Repeat Screening

Once a first test is done, adherence to the recommended tests at each interval is necessary to achieve the full benefit of the screening strategy. The first screening test provides the greatest benefit compared with the magnitude of the benefit associated with subsequent screening (i.e., the estimated LYG moving from no screening to once-only colonoscopy is about 3 to 6 times greater than moving from once-only screening to twice-in-a-lifetime colonoscopy). If people do not get screened at the recommended interval but instead undergo delayed screening, the estimated benefit of that non-adherent schedule would be similar to a strategy with the same test but with a longer interval between tests. For example, it has been estimated that if, on average, 60% to 70% of people adhere with repeat screening tests, then the benefit would be similar to a doubling of the screening interval.^100,101^

We found that, for example, extending the interval for FIT 50-75 from 1 to 2 years could result in 9 to 11 additional diagnosed cases of colorectal cancer per 1000, 3 additional colorectal cancer deaths per 1000, and a loss of 33 to 37 LYG per 1000 (Table 14). When the interval is extended from 1 to 3 years, there could be as many as 14 to 19 additional diagnosed cases of colorectal cancer per 1000, 5 to 6 additional colorectal cancer deaths per 1000, and a loss of 60 to 65 LYG per 1000. For colonoscopy screening from ages 50 to 75, extending the interval from 10 to 15 years could result in 3 to 5 additional diagnosed cases of colorectal cancer per 1000, 1 to 2 additional colorectal cancer deaths per 1000, and a loss of 12 to 22 LYG per 1000. If the interval is extended such that only 1 colonoscopy is performed, the changes could be considerably larger: 15 to 22 additional diagnosed cases of colorectal cancer per 1000, 6 to 9 additional colorectal cancer deaths per 1000, and a loss of 53 to 87 LYG per 1000. Changes in outcomes associated with extending the screening interval for strategies with screening beginning at age 45 are presented in Appendix Table 16.2.

Table 14 Illustration of the Estimated Changes in Outcomes From Adherence to Repeat Screening for Sample Strategies With Screening Beginning at Age 50, by Model^*^

Strategy by model | Outcomes and change in outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | DLG
Strategy by model | Stool tests | SIGs | CTCs | COLs | Compli-cations | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
Colonoscopy (COL)
SimCRC
COL 50-75, 10 | 0 | 0 | 0 | 3414 | 13 | 18 | 5 | 335 | 314 | 122
Increase interval to 15y | 0 | 0 | 0 | −680 | −2 | +5 | +2 | −17 | −16 | −6
Once-only | 0 | 0 | 0 | −1695 | −6 | +22 | +9 | −79 | −73 | −29
CRC-SPIN
COL 50-75, 10 | 0 | 0 | 0 | 3500 | 15 | 15 | 5 | 308 | 291 | 112
Increase interval to 15y | 0 | 0 | 0 | −676 | −2 | +3 | +1 | −12 | −11 | −4
Once-only | 0 | 0 | 0 | −1621 | −6 | +15 | +6 | −53 | −50 | −20
MISCAN
COL 50-75, 10 | 0 | 0 | 0 | 3476 | 14 | 36 | 9 | 286 | 257 | 104
Increase interval to 15y | 0 | 0 | 0 | −608 | −1 | +4 | +2 | −22 | −20 | −8
Once-only | 0 | 0 | 0 | −1535 | −5 | +16 | +9 | −87 | −77 | −32
Sigmoidoscopy (SIG)
SimCRC
SIG 50-75, 5 | 0 | 4058 | 0 | 1544 | 10 | 29 | 9 | 279 | 260 | 102
Increase interval to 10y | 0 | −1593 | 0 | −407 | −2 | +8 | +3 | −32 | −30 | −12
Once-only | 0 | −3087 | 0 | −1001 | −6 | +32 | +14 | −129 | −120 | −47
CRC-SPIN
SIG 50-75, 5 | 0 | 4134 | 0 | 1510 | 11 | 26 | 9 | 256 | 241 | 94
Increase interval to 10y | 0 | −1680 | 0 | −294 | −1 | +4 | +2 | −16 | −15 | −6
Once-only | 0 | −3162 | 0 | −816 | −5 | +21 | +9 | −83 | −77 | −30
MISCAN
SIG 50-75, 5 | 0 | 3646 | 0 | 1927 | 12 | 40 | 11 | 256 | 229 | 93
Increase interval to 10y | 0 | −1349 | 0 | −346 | −1 | +4 | +2 | −23 | −21 | −8
Once-only | 0 | −2675 | 0 | −1030 | −6 | +21 | +12 | −119 | −105 | −43
Sigmoidoscopy plus interval fecal immunochemical testing (SIG+FIT)
SimCRC
SIG+FIT 50-75, 10_1 | 13537 | 2099 | 0 | 1840 | 11 | 22 | 6 | 330 | 306 | 121
Increase FIT interval to 2y | −5605 | +97 | 0 | −261 | −1 | +4 | +1 | −11 | −11 | −4
CRC-SPIN
SIG+FIT 50-75, 10_1 | 13305 | 2067 | 0 | 1973 | 13 | 18 | 6 | 301 | 282 | 110
Increase FIT interval to 2y | −5462 | +96 | 0 | −265 | −0.9 | +3 | +1 | −10 | −9 | −4
MISCAN
SIG+FIT 50-75, 10_1 | 12357 | 1900 | 0 | 2048 | 12 | 39 | 10 | 287 | 255 | 105
Increase FIT interval to 2y | −5180 | +138 | 0 | −181 | −0.5 | +2 | +0.7 | −10 | −10 | −4
Computed tomographic colonography (CTC)
SimCRC
CTC 50-75, 5 | 0 | 0 | 4006 | 1624 | 11 | 21 | 6 | 325 | 302 | 119
Increase interval to 10y | 0 | 0 | −1566 | −396 | −2 | +8 | +3 | −30 | −28 | −11
CRC-SPIN
CTC 50-75, 5 | 0 | 0 | 4088 | 1626 | 12 | 20 | 7 | 287 | 270 | 105
Increase interval to 10y | 0 | 0 | −1626 | −366 | −2 | +6 | +3 | −28 | −25 | −10
MISCAN
CTC 50-75, 5 | 0 | 0 | 4075 | 1519 | 10 | 43 | 11 | 268 | 238 | 98
Increase interval to 10y | 0 | 0 | −1622 | −382 | −2 | +9 | +4 | −49 | −46 | −18
Fecal immunochemical testing (FIT)
SimCRC
FIT 50-75, 1 | 16160 | 0 | 0 | 1423 | 9 | 30 | 7 | 316 | 289 | 115
Increase interval to 2y | −6714 | 0 | 0 | −417 | −2 | +11 | +3 | −33 | −33 | −12
Increase interval to 3y | −9215 | 0 | 0 | −609 | −3 | +19 | +6 | −60 | −60 | −22
CRC-SPIN
FIT 50-75, 1 | 15562 | 0 | 0 | 1619 | 12 | 23 | 7 | 285 | 266 | 104
Increase interval to 2y | −6357 | 0 | 0 | −426 | −2 | +9 | +3 | −37 | −35 | −13
Increase interval to 3y | −8745 | 0 | 0 | −638 | −3 | +16 | +6 | −65 | −62 | −24
MISCAN
FIT 50-75, 1 | 16097 | 0 | 0 | 1445 | 10 | 47 | 11 | 274 | 240 | 100
Increase interval to 2y | −6703 | 0 | 0 | −407 | −2 | +9 | +3 | −37 | −36 | −13
Increase interval to 3y | −9192 | 0 | 0 | −598 | −3 | +14 | +5 | −65 | −63 | −24
Multitarget stool DNA testing (sDNA-FIT)
SimCRC
sDNA-FIT 50-75, 1 | 11463 | 0 | 0 | 2156 | 11 | 22 | 6 | 330 | 305 | 121
Increase interval to 2y | −3735 | 0 | 0 | −498 | −2 | +6 | +1 | −13 | −13 | −5
Increase interval to 3y | −5389 | 0 | 0 | −752 | −2 | +11 | +3 | −26 | −27 | −10
CRC-SPIN
sDNA-FIT 50-75, 1 | 11132 | 0 | 0 | 2295 | 14 | 18 | 6 | 301 | 281 | 110
Increase interval to 2y | −3607 | 0 | 0 | −474 | −1 | +4 | +1 | −14 | −14 | −5
Increase interval to 3y | −5194 | 0 | 0 | −720 | −2 | +8 | +3 | −30 | −28 | −11
MISCAN
sDNA-FIT 50-75, 1 | 11315 | 0 | 0 | 2211 | 12 | 39 | 9 | 290 | 257 | 106
Increase interval to 2y | −3672 | 0 | 0 | −502 | −2 | +6 | +1 | −16 | −16 | −6
Increase interval to 3y | −5309 | 0 | 0 | −761 | −3 | +11 | +3 | −33 | −34 | −12

CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening.

* These strategies were selected for illustration purposes. Inclusion in this table should not be interpreted as endorsement of these strategies.

† Includes deaths from complications of screening.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix G of the systematic evidence review reports limited data on adherence with repeated tests in the short term.^17^ One study found adherence over the subsequent 3 years after the initial FIT to be as high as 75.3% to 86.1%.^102^

#### Follow-Up Colonoscopy

Most tests other than colonoscopy require adherence with a colonoscopy following a positive screen in order for that screen to have any benefit. If a test is done that requires follow-up colonoscopy and the follow-up test is never done, then it is equivalent, benefit-wise, to the screening test not being done in the first place. This type of adherence impacts non-colonoscopy test strategies. Alternatively, the follow-up could just be delayed. For example, a delay of 1 year in getting a follow-up colonoscopy after a positive FIT is estimated to reduce life years gained by 2.0% to 9.5%.^103,104^

A recent systematic review reported adherence to follow-up colonoscopy of 80.4%.^105^

Much of the evidence on adherence assesses whether the test recommended at a particular time was performed at or near that time. If it was not performed at or near that time, then the alternative is either that the test was never performed again or that it was just delayed, which would have different implications. Very little information is available about screening behaviors needed for models to simulate the impact of these behaviors on efficacy. This information includes whether screening delays are clustered within individuals and how delays vary across screening tests.

†† As a reminder, the intervals noted in the reference to the SIG+FIT strategies, 10_1 and 10_2, refer to the interval for SIG (10 years) and for FIT (either 1 or 2 years).