# Chapter 2 Methods

## Scope and Purpose

The USPSTF will use this decision analysis in conjunction with a systematic evidence review from the Kaiser Permanente Evidence-based Practice Center (EPC), to update its 2016 recommendation statement on colorectal cancer screening.^14^ This decision analysis updates the prior analysis^16^ of how the benefits, burden, and harms of colorectal cancer screening might vary by screening modality, screening interval, age to begin screening, and age to end screening. It incorporates recent evidence reporting increasing rates of colorectal cancer among recent birth cohorts^18^ and evaluates whether the benefits, burden, and harms of screening might vary by race and sex.

## Key Questions

The CISNET Colorectal Cancer Working Group, USPSTF members, EPC evidence review team, and Agency for Healthcare Research and Quality (AHRQ) Medical Officer defined the scope and key questions for the decision analysis. The key questions were:

1. How do the benefits, burden, and harms of screening average-risk, asymptomatic adults for colorectal cancer vary by screening modality, screening interval, age to begin screening, and age to end screening?
2. Which screening strategies are efficient in terms of the additional number of colonoscopies per life-year gained? Do the efficient strategies vary by race and sex?
3. Do the answers to key questions 1 and 2 change when efficiency is measured as the additional number of colonoscopies per quality-adjusted life-year gained? As the additional number of colonoscopies per colorectal cancer death averted?
4. Do the answers to key questions 1 and 2 change according to assumptions about the underlying risk of colorectal cancer?

In addition to analyses to address the key questions above, we performed sensitivity analysis to assess the effect of uncertainty in test characteristics. We also provide plausible ways to consider different types of non-adherence with the screening process (i.e., non-adherence with screening initiation, repeat screening, and follow-up of a positive non-colonoscopy screening test).

## Overview of the Analysis

We used 3 independently-developed microsimulation models of colorectal cancer that are funded by the National Cancer Institute’s CISNET consortium – Simulation Model of Colorectal Cancer (SimCRC), Colorectal Cancer Simulated Population model for Incidence and Natural history (CRC-SPIN), and Microsimulation Screening Analysis (MISCAN) for Colorectal Cancer – to estimate life-years gained, colorectal cancer incidence and mortality, number of screening tests required, and complications of screening for 239 (221 unique) colorectal cancer screening strategies that vary by screening modality, age to begin screening, age to end screening and screening interval. Each of these strategies is simulated for 3 scenarios of population-level colorectal cancer risk.

## Models

The microsimulation models used for this analysis have a long history of use in collaborative modeling analyses, including analyses to inform colorectal cancer screening National Coverage Determinations for the Centers for Medicare and Medicaid Services,^19–21^ to inform screening recommendations by the American Cancer Society (ACS)^22,23^ and the USPSTF,^15,16^ as well as to guide screening programs in South Carolina.^24^ Each model consists of a natural history component and a screening component. These components were described in detail in the 2016 report^25^ and are briefly summarized below. Changes to the CRC-SPIN model are highlighted because that model has been revised since 2016.^26^

SimCRC was programmed in C++, CRC-SPIN in R, and MISCAN in Delphi.

### Natural History Component

The 3 CISNET microsimulation^*^ models describe the natural history of colorectal cancer in an unscreened population, based on the adenoma-carcinoma sequence.^27–29^ Simulated persons begin in a disease-free “no lesion” state and may progress to an adenoma state, a preclinical colorectal cancer state, and a clinically detected colorectal cancer state, from which they may die from colorectal cancer (Figure 1). Persons may die from other causes at any time.

Figure 1 Graphical Representation of the Natural History of Colorectal Cancer and the Effects of Screening as Simulated by SimCRC, CRC-SPIN, and MISCAN

Note: The opportunity to intervene in the natural history through screening (adenoma detection and removal, and early detection) is noted by the dotted lines. Screening can either remove a precancerous lesion (i.e., adenoma), thus moving a person to the “No lesion” state, or diagnose a preclinical cancer, which, if detected at an earlier stage, may be more amenable to treatment.

Flowchart showing how the models simulate the natural history of colorectal cancer and the effects of screening.

While the models have a similar natural history framework, they differ in the implementation of the framework. Table 1 provides a brief comparison of the structure of the natural history components of the 3 models.

Table 1 Comparison of Natural History Model Structures

Property | SimCRC | CRC-SPIN | MISCAN
Adenoma risk
Mechanism | Logistic function | Poisson process | Poisson process
Risk varies:
Randomly across individuals | Yes | Yes | Yes
Systematically with age and sex | Yes | Yes | Yes
Adenoma growth
Mechanism | Time in each size category | Growth curve | Time in each size category
Size modeled as continuous | No | Yes | No
Risk varies:
Randomly across individuals | Yes | Yes | Yes
Systematically with location | Yes^*^ | Yes^*^ | No
Transition times correlated across size categories | No | Yes | Yes
Transition to preclinical CRC
Mechanism | Logistic function | Adenoma size at transition | Overall transition probability
Risk varies:
Randomly across adenomas by size within individuals | Yes | Yes | No^†^
Systematically with:
Sex | Yes | Yes | No
Age | Yes | Yes^‖^ | Yes^‡^
Adenoma size | No | Yes | Yes
Location | Yes^*^ | Yes^*^ | No
Transition times correlated across preclinical stages | No | Not applicable | Yes
Transition to clinical CRC
Mechanism | Time to transition | Time to transition | Time to transition
Transition times:
Vary randomly across CRCs within individuals | Yes | Yes | Yes
Vary systematically with:
Sex | No | No | Yes
Location | Yes^§^ | Yes^§^ | Yes^§^
Correlated with duration of preclinical CRC | No | No | Yes

* Varies by proximal colon, distal colon, and rectum for SimCRC and by colon and rectum for CRC-SPIN.

† The probability of transition is 0 for all non-progressive adenomas and for adenomas <6 mm, 0.3 for progressive adenomas 6 to <10 mm, and 1 for progressive adenomas ≥10 mm.

‡ The probability that an adenoma is progressive depends on age at adenoma initiation.

‖ Depends on age at adenoma initiation.

§ Varies by proximal colon, distal colon, and rectum for SimCRC and MISCAN and by colon and rectum for CRC-SPIN.

A key change from the 2016 decision analysis is that the code for the CRC-SPIN model has been rewritten, after which the model was recalibrated.^26^ Compared with the previous version, the current version of CRC-SPIN (CRC-SPIN 2.0) simulates a longer sojourn time of preclinical colorectal cancer, more in line with the other 2 models, as described later in this report. CRC-SPIN was also revised to more accurately simulate the stage at clinical detection. No changes have been made to the SimCRC and MISCAN models since the 2016 report.

#### Adenoma Risk

In all 3 models, adenoma risk varies stochastically across individuals and by age and sex. All models allow multiple adenomas within individuals and none allow detectable adenomas in individuals <20 years of age. The risk of having an adenoma is derived to match the prevalence of adenomas by age from autopsy studies (Figure 2). None of the models allow regression of adenomas,^30–33^ nor do they simulate the serrated polyp pathway to colorectal cancer.^34,35^

Figure 2 Prevalence of Adenomas by Age From Autopsy Studies and as Estimated by the Original Models Calibrated to (Among Others) Colorectal Cancer Incidence Data From the Surveillance, Epidemiology, and End Results Program for 1975-1979

Adenoma prevalence by age as estimated by the models and as reported in autopsy studies.

#### Distribution of Adenomas in the Colon and Rectum

All models assign adenomas a location in the large intestine based on a multinomial distribution. SimCRC and CRC-SPIN inform these distributions using data on the location of adenomas from autopsy studies;^36–45^ MISCAN assumes that the distribution of adenomas in the colon and rectum is the same as the distribution of clinically-detected colorectal cancer.^46^ Consequently, the models differ in the estimated distribution of adenomas by location within the colon and rectum (Figure 3).

Figure 3 Model-Estimated Distribution of Adenomas by Location (Including Proportion in the Distal Colon or Rectum) Among Persons Aged 40 and Older

Model-estimated distribution of adenomas by location in the large intestine.

#### Adenoma Growth

All models allow adenoma growth to vary stochastically across individuals, and across adenomas within individuals. SimCRC and MISCAN define adenoma size categorically (1 to <6 mm, 6 to <10 mm, ≥10 mm) and do not explicitly specify a maximum size. CRC-SPIN simulates continuous adenoma size using a Richard’s growth curve model,^47^ with a minimum detectable size of 1 mm and maximum size of 50 mm. The models also differ in the estimated distribution of the size of the most advanced adenoma (Figure 4). For all models the estimated percentage of adenomas that are ≥10 mm increases with age.

Figure 4 Model-Estimated Distribution of Adenomas by Size of the Most Advanced Adenoma Among Persons Aged 40 and Older, by Age

Note: Distributions are from the original models calibrated to (among others) colorectal cancer incidence data from the Surveillance, Epidemiology, and End Results Program for 1975-1979.

Model-estimated distribution of adenomas by size of the most advanced adenoma.

#### Progression to Preclinical Colorectal Cancer

All models allow multiple preclinical cancers within individuals and allow the time from adenoma onset to progression to preclinical disease to vary stochastically across individuals and across adenomas within individuals. MISCAN and SimCRC do not allow progression to preclinical cancer in adenomas that are <6 mm. CRC-SPIN simulates progression rates that are a function of continuous size, with a very small (non-zero) probability of progression to preclinical cancer in adenomas <6 mm.

MISCAN specifies 2 types of adenomas: non-progressive adenomas, which have no potential of becoming cancerous, and progressive adenomas, which have this potential; the risk that an adenoma is progressive increases with age at initiation. The SimCRC and CRC-SPIN models do not explicitly model non-progressive adenomas; in these models, all adenomas have the potential to progress although most will not within a simulated individual’s lifetime.

#### Progression to Clinically Detected Colorectal Cancer (Sojourn Time)

All models allow sojourn time (i.e., the time from preclinical cancer onset to cancer detection in the absence of screening) to vary stochastically across individuals. Mean sojourn time (for cancers that are ultimately diagnosed) ranges from 3.6 to 4.7 years across the 3 models (Table 2). All models assume that when 1 preclinical cancer is detected (either by symptoms or by screening), all are detected. Currently, none of the models explicitly simulate metachronous primary colorectal cancer after colorectal cancer detection. The impact of metachronous primary colorectal cancer is incorporated in rates of colorectal cancer relative survival after diagnosis.

Table 2 Estimated Dwell Times Among Colorectal Cancer Cases: Mean (Interquartile Ranges) in Years Across Simulated Individuals, by Model

Dwell time component | SimCRC | CRC-SPIN | MISCAN
Adenoma onset to preclinical colorectal cancer onset; (adenoma dwell time) | 21.2 (12-29) | 25.4 (16-33) | 12.5 (4-18)
Preclinical colorectal cancer onset to colorectal cancer diagnosis; (sojourn time) | 4.0 (2-5) | 3.6 (2-5) | 4.7 (1-7)
Adenoma onset to colorectal cancer diagnosis; (total dwell time) | 25.2 (15-33) | 29.0 (20-37) | 17.2 (9-24)

Note: Dwell time is calculated for diagnosed colorectal cancers and is defined as the time from adenoma onset to symptom-detection of colorectal cancer in the absence of screening.

Prior to age 75, the models reproduce age-specific colorectal cancer incidence rates (excluding carcinoid tumors and others that are not the primary target of colorectal cancer screening) from the Surveillance, Epidemiology, and End Results Program (SEER) from 1975-1979^46^ – a period with little to no colorectal cancer screening (Figure 5). At older ages SimCRC predicts incidence rates that are higher than those observed in SEER.

Figure 5 Estimated Colorectal Cancer Cases per 100,000 Persons by Age and Model for Models Calibrated to Incidence Rates From the Surveillance, Epidemiology, and End Results (SEER) Program for 1975-1979^*^ * This period was chosen because incidence rates at that time are likely to reflect those among a largely unscreened population. Note that open symbols indicate incidence rates for the 85+ age group (plotted at age 87 for convenience).

Colorectal cancer incidence rate per 100,000 by age as estimated by the models and as estimated from SEER data for 1975-1979.

The models are calibrated to and generally replicate the stage distribution observed in SEER among a largely unscreened population (Figure 6).

Figure 6 Model-Estimated Distribution of the Stage of Colorectal Cancer at Diagnosis Among Persons Aged 40 and Older^*^ * Distributions may not sum to 100% due to rounding.

Note: Stage distributions are from the original models calibrated to (among others) colorectal cancer incidence data from the Surveillance, Epidemiology and End Results Program for 1975-1979.

Distribution of colorectal cancers by stage at diagnosis as estimated by the models and as estimated from SEER data for 1975-1979.

#### Colorectal Cancer Death

For each simulated individual who is diagnosed with colorectal cancer, the models stochastically assign the age of colorectal cancer death using survival probabilities based on Cox proportional hazards models for relative (i.e., cause-specific) survival applied to SEER survival data for cases diagnosed from 1/1/1975 to 12/31/2003 with follow-up through 12/31/2010.^48^ Time from colorectal cancer diagnosis to colorectal cancer death depends on year of diagnosis, stage, location (colon or rectum), age at diagnosis, sex, and (optionally) race. Rather than project continued improvements in relative survival for persons diagnosed after 2003 (the last diagnosis year included in the statistical analysis, due to a change in the cancer staging algorithm in 2004^49^ and the dissemination of neoadjuvant chemotherapy for rectal cancer^50–52^), we fixed survival at rates estimated for cases diagnosed in 2003. None of the models allow colorectal cancer death during the lead time (i.e., the time between a screen-detected cancer and the time that the person would have been clinically detected). The age-specific colorectal cancer mortality rates estimated by the models are presented in Figure 7.

Figure 7 Estimated Colorectal Cancer Deaths per 100,000 Persons by Age for Models Calibrated to Colorectal Cancer Incidence Rates From the Surveillance, Epidemiology, and End Results Program for 1975-1979

Colorectal cancer deaths per 100,000 by age as estimated by the models.

#### Non-Colorectal Cancer Death

All models stochastically assign each simulated individual’s age of non-colorectal cancer death using all-cause mortality rates reported in the 2017 US life tables from the National Center for Health Statistics.^53^ In the absence of screening, life expectancy at age 40 ranged from 40.2 to 40.3 years across models (when calibrated to colorectal cancer incidence rates from SEER for 1975-1979^46^), which is slightly less than the 40.7-year life expectancy from the 2017 US life table for the total population. This difference is expected, because colorectal cancer deaths were not removed from the all-cause mortality rates (i.e., the models treat all-cause mortality rates as non-colorectal cancer death rates).

### Screening Component

All models have a screening component that allows the adenoma-carcinoma sequence to be interrupted through detection and removal of preclinical lesions. The screening components also allow for detection of preclinical cancer, potentially at an earlier stage. Each individual’s life history is simulated in the absence of screening and in the presence of screening, such that the effect of a given screening strategy on each simulated individual’s outcomes are known. The effectiveness of a screening strategy is simulated through a test’s ability to detect lesions (that is, adenomas or preclinical colorectal cancer) (Figure 1). Once screening is introduced, a simulated person who has an underlying lesion has a chance of having it detected during a screening round depending on the sensitivity of the test for that lesion and, for endoscopic tests, whether the lesion is within the reach of the scope.

The models assume that all simulated people with an abnormal non-colonoscopy screening test undergo a follow-up colonoscopy; the person may be found to have 1 or more adenomas, which would be removed via polypectomy, or colorectal cancer. Screened persons without an underlying lesion can have a false-positive test result and undergo an unnecessary follow-up colonoscopy. Non-adenomatous polyps are not simulated explicitly, but their detection is reflected in false-positive rates of the direct visualization tests (colonoscopy, sigmoidoscopy, and CTC). Patient management following cancer detection is not explicitly simulated. Patients with a history of adenomas of any size are assumed to undergo surveillance with colonoscopy. The time to the next surveillance colonoscopy is simulated based on past findings. The models incorporate the risk of fatal and non-fatal complications from colonoscopy.

## Model Calibration

Because the natural history of colorectal cancer is largely unobserved, there are limited data to directly inform the parameters of the natural history components of the models. Model parameter values for the natural history components were derived by calibration. Calibration is the process of selecting parameters so that model estimates closely match data from observational studies (“calibration data”).^54^

All 3 natural history models are calibrated to SEER colorectal cancer incidence rates (excluding carcinoid tumors and others that are not the primary target of colorectal cancer screening) in 1975-1979^46^ because this period represents colorectal cancer incidence in the US when there was little or no screening for the disease. All models incorporate information about adenoma prevalence from autopsy studies.^36–45^ The SimCRC and MISCAN models are calibrated using findings from each study. The CRC-SPIN model incorporates this information by specifying prior distributions for adenoma risk parameters that are based on a meta-analysis of autopsy studies.^55^

Each model includes additional calibration data. SimCRC was calibrated to outcomes from autopsy studies that report the size distribution of adenomas^37–45^ and the prevalence of preclinical colorectal cancer^38–45,56^ (by age group and sex, when reported). MISCAN was calibrated to adenoma size distributions from colonoscopy studies,^57–59^ stage-specific screen-detected and interval cancers from 3 large randomized FOBT trials,^60^ and incidence reduction from the United Kingdom Flexible Sigmoidoscopy Screening (UKFSS) Trial.^7^ CRC-SPIN was calibrated to adenoma prevalence by age and sex,^61^ adenoma size,^58,62^ and prevalence of preclinical colorectal cancer^57,63^ reported in screening studies, and the proportion of adenomas that included colorectal cancer from a clinical series that reported adenoma-level data drawn from pathology records.^64^

## Changes From the 2016 Decision Analysis

### Increasing Population Risk of Colorectal Cancer

Since the mid-1990s, there have been steady increases in colorectal cancer incidence before age 50,^18,65–71^ the age of screening initiation recommended by the USPSTF in 2016. Age-period-cohort modeling^18^ suggests that the increase in colorectal cancer incidence in young adults is primarily driven by a cohort effect, implying that increased risk observed before age 50 is carried forward as individuals age. Presumably this increase is not observed in colorectal cancer incidence rates among people aged ≥50 years because of the dissemination of screening.^72,73^

To estimate the effectiveness of screening in the context of increasing population risk, we modified the models to incorporate an increase in background risk. This increase in risk was estimated by the incidence rate ratio (IRR), which reflects the ratio of colorectal cancer incidence in among 20- to 44-year-olds in 2012-2016 (the most recent 5 years of data available from SEER) relative to colorectal cancer incidence among 20- to 44-year-olds in 1975-1979 (the years of SEER data used for model calibration). [Analyses of SEER data excluded carcinoid tumors and other cancers in the colon and rectum that are not the primary target of colorectal cancer screening; see Appendix 1 for included histology codes.] While there is certainty that colorectal cancer incidence is higher among adults aged <50 years today vs 40 years ago (i.e., IRR>1), the extent of the increase is uncertain. The CISNET modeling group collaborated with USPSTF members and a leading expert on trends in cancer risk to obtain estimates of the magnitude of increasing risk for use in simulation models (see Appendix 1 and Table 3).

Table 3 Age-Adjusted Rates of Colorectal Cancer Among 20- to 44-Year-Olds by Period of Diagnosis (1975-1979 and 2012-2016) From the Surveillance, Epidemiology, and End Results Program, With and Without Adjustment for Delays in Reporting

Delay-adjustment status/Period of diagnosis | Cases per 100,000 (95% CI) | Incidence rate ratio (95% CI)
With delay adjustment
1975-1979 | 4.92 (4.74, 5.12) | --
2012-2016 | 6.15 (5.98, 6.32) | 1.25 (1.19, 1.31)
Without delay adjustment
1975-1979 | 4.94 (4.68, 5.21) | --
2012-2016 | 6.06 (5.84, 6.29) | 1.23 (1.15, 1.31)

In consultation with USPSTF members, we decided that base-case simulations used for the decision analysis would assume an IRR of 1.19 for increasing population risk models, and that this increase would be simulated as a cohort effect,^18^ so that the relative increase in risk, which we assume is driven by an increase in adenoma risk, is applied throughout each simulated individuals’ lifespan. Sensitivity analyses assume an IRR of 1.52 (the approximate upper bound of the 95% CI for the IRR estimated from age-period-cohort modeling of SEER incidence rates) and of 1 (no increase from the pre-screening era). These analyses were selected to capture the likely range of risk elevation.

### Analyses by Race and Sex

An important addition to the current analysis compared with the 2016 analysis is the inclusion of analyses by race and sex. These analyses allow assessment of whether model results would potentially support differential screening recommendations by race and sex.

Prior to performing these analyses, we conducted a comprehensive review of the literature on race and colorectal cancer.^74^ We concluded that the primary driver of differences in colorectal cancer incidence by race is access to screening and subsequent care, rather than biological differences in adenoma risk and progression to colorectal cancer. This research found that Black-White differences in colorectal cancer incidence began only after the dissemination of screening, that there is strong evidence that Black adults are less likely to be screened for colorectal cancer than White adults, and that there is limited evidence for Black-White differences in findings at screening, including detection of adenomas, advanced adenomas, and cancer.^74^ A recent study by Warren Andersen and colleagues^75^ reporting the findings of over 47,000 individuals in the Southern Community Cohort Study (68% African American; 55% with household income <$15,000) found that the effect of screening on colorectal cancer incidence did not vary by race or household income, concluding that addressing the gap in screening use may reduce disparities in colorectal cancer outcomes.

Based on these studies, we assumed no Black-White differences in the risk of developing colorectal cancer, but we incorporated Black-White differences in all-cause mortality^53^ and in stage-specific relative survival after diagnosis.^48^ [For details on these data sources, see Non-Colorectal Cancer Death and Colorectal Cancer Death, respectively].

With respect to differences by sex, SimCRC has separately calibrated natural history models for men and women, based on sex-specific calibration targets for adenoma prevalence and size (when available)^36–45^ and colorectal cancer incidence.^46^ The CRC-SPIN model allows adenoma incidence and the probability of transition to preclinical cancer to vary by sex. The MISCAN model simulates sex differences in adenoma risk. All models incorporate race- and sex-specific all-cause mortality rates^53^ and relative survival probabilities^48^ after colorectal cancer diagnosis. In race- and sex-specific analyses, colorectal cancer incidence was simulated under the increasing population risk scenario (IRR = 1.19). We did not simulate race- and sex-specific increases in colorectal cancer incidence over time due to the wide and largely overlapping confidence intervals (CIs) for race- and sex-specific IRRs.

## Model Validation

We have conducted a series of model comparisons (cross-validation) to better understand differences in outcomes across models.^76,77^ As mentioned above, the models estimate similar adenoma prevalence (Figure 2), cancer incidence (Figure 5), and stage distribution (Figure 6). However, among colorectal cancer cases diagnosed in the absence of screening, the models estimate different mean times between adenoma formation and clinical colorectal cancer detection for adenomas that progress to diagnosed colorectal cancer (“dwell time,” Table 2). Dwell time is unobservable and is an important driver of the simulated effectiveness of screening tests. The total time from adenoma formation to clinical cancer detection can be divided into 2 parts: the time from adenoma formation to onset of preclinical cancer (“adenoma dwell time”), and the time from preclinical cancer onset to clinical detection (“sojourn time”). While the models estimate similar mean sojourn time (3.6-4.7 years), they estimate different adenoma dwell times (12-25 years) and therefore different total dwell times (17-29 years). Estimated dwell times are shorter with MISCAN, due to the assumption that some adenomas are non-progressive (see Progression to Preclinical Colorectal Cancer).

External validation offers an opportunity to evaluate these dwell time assumptions. We externally validated all 3 models,^78^ comparing their estimates to published 10-year results from the UKFSS Trial, a randomized controlled trial of 1-time sigmoidoscopy screening to reduce colorectal cancer mortality.^7^ The MISCAN modeling group subsequently used these data for calibration and afterwards revalidated their model to the Norwegian Colorectal Cancer Prevention sigmoidoscopy study.^79^ All models recently updated their validation against the 17-year outcomes of the UKFSS.^80^ Validation focused on longer-term primary study outcomes: estimated hazard ratios of colorectal cancer incidence and mortality 17 years after screening in intervention versus control participants.^81^ We also examined the ability of the models to estimate adenoma detection rates by location in the colon and rectum.^78^ Point predictions were based on the mean across 2,000 simulated trials. We also compared the estimated and observed variability of outcomes based on 95% intervals estimated by the 2.5th and 97.5th percentiles across 2,000 simulated trials. We found that the 95% credible intervals from model estimates were similar in width to reported 95% CIs and largely overlapped (Figure 8); this suggests that the models show a reasonable estimation of the effect of the intervention on CRC-specific incidence and mortality. Estimated adenoma detection rates at baseline sigmoidoscopy (UKFSS: 12.1%, 95% CI 11.8%-12.4%) were too low for SimCRC (8.8%, 95% credible interval 8.5%-9.0%) and too high for CRC-SPIN and MISCAN (13.3%, 95% credible interval 13.0%-13.6% and 27.7%, 95% credible interval 27.2%-28.2%, respectively). The CRC-SPIN modeling group subsequently incorporated UKFSS screen detection rates^63^ into model calibration.

Figure 8 Model Validation Based on Estimated Hazard Ratios for Colorectal Cancer Incidence and Mortality After 17 Years of Follow-up Among the Intervention Group Compared With the Control Group of the UK Flexible Sigmoidoscopy Screening Trial (UKFSS)

* Hazard ratios and confidence intervals are from the per-protocol analysis.^81^

Model-estimated hazard ratios for colorectal cancer incidence and mortality after once-only flexible sigmoidoscopy screening. Hazard ratios from the UK Flexible Sigmoidoscopy Screening Trial are also shown.

## Colorectal Cancer Screening Strategies

In consultation with the USPSTF, we included the following screening modalities: HSgFOBT (i.e., Hemoccult SENSA (Beckman Coulter; Brea, CA)); a FIT representative of the OC-Sensor family of tests (Polymedco; Cortlandt, NY), with a cutoff of 20 µg of hemoglobin per g of feces; a stool DNA test with a FIT assay (sDNA-FIT), marketed as Cologuard (Exact Sciences Corporation; Madison, WI); sigmoidoscopy (without biopsy); SIG+FIT; colonoscopy; CTC; strategies with once-only colonoscopy then annual FIT; and strategies with annual FIT then 10-yearly colonoscopy (Table 4).

Table 4 Screening Strategies Evaluated by the Models

Modality | Age to begin screening, y | Age to end screening^*^, y | Screening interval, y | Number of (unique) runs
Strategies with once-only screening^†^
COL | 45, 50, 55, 60, 65 | -- | Once only | 5 (5)
SIG | 45, 50, 55, 60, 65 | -- | Once only | 5 (5)
Strategies with repeated screening using the same modality/modalities
COL | 45, 50, 55 | 70, 75, 80, 85 | 5, 10, 15 | 36 (26)
CTC | 45, 50, 55 | 70, 75, 80, 85 | 5, 10 | 24 (20)
SIG | 45, 50, 55 | 70, 75, 80, 85 | 5, 10 | 24 (20)
FIT | 45, 50, 55 | 70, 75, 80, 85 | 1, 2, 3 | 36 (36)
HSgFOBT^†^ | 45, 50, 55 | 70, 75, 80, 85 | 1, 2, 3 | 36 (36)
sDNA-FIT | 45, 50, 55 | 70, 75, 80, 85 | 1, 2, 3 | 36 (36)
SIG + FIT^‡^ | 45, 50, 55 | 70, 75, 80, 85 | 10 (SIG) + 1 (FIT), 10 (SIG) + 2 (FIT), | 24 (24)
Strategies with screening using different modalities by age^†^
Annual FIT 45-49y then COL | 50 (COL) | 70, 80 (COL) | 10 (COL) | 2 (2)
Annual FIT 50-54y then COL | 55 (COL) | 75, 85 (COL) | 10 (COL) | 2 (2)
COL at 45y then FIT | 55 (FIT) | 70, 75, 80, 85 (FIT) | 1 (FIT) | 4 (4)
COL at 50y then FIT | 60 (FIT) | 70, 75, 80, 85 (FIT) | 1 (FIT) | 4 (4)
Additional strategy
No screening | -- | -- | -- | 1 (1)
TOTAL NUMBER OF STRATEGIES FOR BASE-CASE ANALYSIS | | | | 239 (221)

FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; HSgFOBT – high sensitivity guaiac-based fecal occult blood test (i.e., Hemoccult SENSA); sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test, i.e., Cologuard); SIG – sigmoidoscopy without biopsy; CTC – computed tomographic colonography; COL – colonoscopy.

* Age to end screening is the last age at which screening happens; screening may happen during this age but no later.

† Outcomes are included in Appendix 4 (HSgFOBT), Appendix 5 (once-only colonoscopy), Appendix 6 (once-only sigmoidoscopy), Appendix 7 (annual FIT then 10-yearly COL), and Appendix 8 (once-only COL, then annual FIT).

‡ If performed at the same time, assume FIT is performed first, and SIG is only performed if FIT is negative. If FIT is positive, skip the SIG and go directly to colonoscopy.

For each modality, we evaluated multiple screening intervals, referring to the time between subsequent screening tests for persons with a normal test result. Intervals were 1, 2, and 3 years for stool tests; 5 and 10 years for sigmoidoscopy and for CTC; and 5, 10, and 15 years for colonoscopy. For SIG+FIT, we simulated sigmoidoscopy at a 10-year interval with FIT at intervals of 1 or 2 years. We also simulated 1-time screens for sigmoidoscopy and colonoscopy.

For each combination of screening modality and interval, we evaluated ages to begin screening of 45, 50, and 55 and ages to end screening of 70, 75, 80, and 85. These ages were chosen to provide ranges around the recommended ages to begin (age 50) and end (age 75) screening from the 2016 USPSTF recommendations. The age at the last screening test for a particular strategy is not necessarily equal to the age to end screening, but rather it is a function of the age to begin and the screening interval. For example, colonoscopy every 10 years for age to begin 50 and age to end 75 results in 3 screening colonoscopies at ages 50, 60, and 70. We assume no screening occurs after the stopping age, but that colonoscopy surveillance of persons with a history of adenoma(s) is continued through at least age 85 (see Surveillance subsection below for more details).

In all, we evaluated 221 unique screening strategies (Table 4). Including duplicate strategies, the total number was 239. Table 5 lists the non-unique strategies, that is, strategies with screening at the same ages despite different ages to end screening (e.g., “COL 50-80, 10” and “COL 50-85, 10”, both of which have screening colonoscopies at ages 50, 60, 70, and 80).

Table 5 Strategies With Screening at the Same Ages Despite Different Ages to End Screening

Modality/screening ages (y) | Age to begin-age to end, interval (y)
Modality/screening ages (y) | Strategy | Equivalent strategy 1 | Equivalent strategy 2
Colonoscopy/sigmoidoscopy/CT colonography
45, 55, 65, 75 | 45-75, 10 | 45-80, 10 | --
50, 60, 70 | 50-70, 10 | 50-75, 10 | --
50, 60, 70, 80 | 50-80, 10 | 50-85, 10 | --
55, 65, 75 | 55-75, 10 | 55-80, 10 | --
Colonoscopy
45, 60, 75 | 45-75, 15 | 45-80, 15 | 45-85, 15
50, 65 | 50-70, 15 | 50-75, 15 | --
50, 65, 80 | 50-80, 15 | 50-85, 15 | --
55, 70 | 55-70, 15 | 55-75, 15 | 55-80, 15

Note: Table 4 notes that there are 239 screening strategies but only 221 unique strategies, therefore 18 strategies are effectively equivalent to another strategy with a different age to end screening. These equivalent strategies are listed here. For example, colonoscopy from ages 50-75 every 10 years and from 50-70 every 10 years both involved colonoscopy screening at ages 50, 60, and 70.

A comparison of the 2021 and 2016 CISNET colorectal cancer screening analyses is presented in Table 6.

Table 6 Comparison of the 2021 and 2016 CISNET CRC Screening Analyses for the USPSTF

Characteristic | 2021 analysis | 2016 analysis
Simulation models | SimCRC, CRC-SPIN, MISCAN | SimCRC, CRC-SPIN, MISCAN
Cohort of interest | US average-risk 40-year-olds^*^ | US average-risk 40-year-olds^*^
US life table (for other-cause mortality rates) | 2017 | 2009
CRC incidence | Models calibrated to incidence rate ratio from SEER for 20- to 44-year-olds in 2012-2016 vs 1975-1979 | Models calibrated to rates from 1975-1979 SEER data
CRC relative survival | SEER (1975-2003)^†^ | SEER (1975-2003)^†^
Age to begin screening (y) | 45, 50, 55 | 45, 50, 55
Age to end screening (y) | 70, 75, 80, 85 | 75, 80, 85
Stool based screening modalities (intervals (y)) | HSgFOBT (1, 2, 3)^‡^ | HSgFOBT (1, 2, 3)
Stool based screening modalities (intervals (y)) | FIT (1, 2, 3) | FIT (1, 2, 3)
Stool based screening modalities (intervals (y)) | sDNA-FIT (1, 2, 3) | sDNA-FIT (1, 3, 5)
Other screening modalities (intervals (y)) | COL (5, 10, 15) | COL (5, 10, 15)
Other screening modalities (intervals (y)) | SIG (5, 10) | SIG (5, 10)
Other screening modalities (intervals (y)) | SIG + FIT (10_1, 10_2) | SIG + FIT (5_2, 5_3, 10_1, 10_2)
Other screening modalities (intervals (y)) | Not simulated | SIG + HSgFOBT (5_2, 5_3, 10_1, 10_2)
Other screening modalities (intervals (y)) | CTC (5, 10) | CTC (5, 10)
Other screening modalities (intervals (y)) | Once-only COL to FIT (1) | Not simulated
Other screening modalities (intervals (y)) | Five years of FIT (1) to COL (10) | Not simulated
Management of persons with a false-positive non-colonoscopy test^§^ | Resume screening with original modality and schedule 10 years after the false-positive test | Resume screening with original modality and schedule 10 years after the false-positive test
Age to end surveillance | 85, assuming the last surveillance colonoscopy detected no adenomas | 85, assuming the last surveillance colonoscopy detected no adenomas
Adherence with all procedures | 100% | 100%

COL – colonoscopy; CRC – colorectal cancer; CTC – computed tomographic colonography; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); HSgFOBT – high sensitivity guaiac-based fecal occult blood test; SEER – Surveillance, Epidemiology and End Results Program; SIG – sigmoidoscopy.

* Previously unscreened for colorectal cancer and free of diagnosed colorectal cancer.

† CRC relative survival estimates from models fit to SEER data from 1975-2003 that predict stage-specific survival as a function of age at diagnosis, time since diagnosis, diagnosis year, sex, and (optionally) race.^48^ Rather than project continued improvements in relative survival for persons diagnosed after 2003 (the last year of diagnosis included in the statistical analysis), we fixed survival at rates predicted for cases diagnosed in 2003.

‡ Due to uncertainty in the test performance characteristics of HSgFOBT, outcomes with this modality are included in Appendix 4.

§ A positive non-colonoscopy test but no adenomas or CRC detected at follow-up colonoscopy.

## Model Input Parameters

### Operating Characteristics of Screening Tests

Test characteristics are based primarily on estimates from a systematic evidence review conducted by Lin et al.^17^ for the USPSTF.

The sensitivity for direct visualization tests (colonoscopy, sigmoidoscopy, and CTC) is often reported on both a per-lesion and a per-person basis, whereas sensitivity estimates for stool-based tests are always per person. All 3 models specify lesion-level sensitivity for direct visualization tests so that simulated persons with multiple adenomas have a greater likelihood of an abnormal test than simulated persons with only 1 adenoma. For stool tests, CRC-SPIN specifies person-level sensitivity. SimCRC and MISCAN specify lesion-specific sensitivity values that are calibrated so that sensitivity estimates on a person-level match those observed in the selected studies. See Appendix 2 for more information.

For all tests other than CTC, specificity in the models is defined as the probability of a normal test result among persons who do not have any adenomas or colorectal cancer. For CTC, we use a different definition for specificity to match the purpose of CTC for detecting adenomas ≥6 mm (see below for details). The lack of specificity with endoscopy reflects the detection of non-adenomatous lesions, which, in the case of sigmoidoscopy, leads to referral to colonoscopy.

Model inputs for sensitivity and specificity for each test are provided in Table 7. Additional information on the assumptions and sources for test characteristics is provided in Appendix 2.

Table 7 Screening Test Characteristics Used in the Analysis Benefits

Test characteristic | Base-case value | Source | Value in sensitivity analysis | Source
HSgFOBT (per person) | | Lin, 2021^17^ | Not varied | Not applicable
Specificity | 0.97
Sensitivity for adenomas 1 to <6 mm | 0.05^*^
Sensitivity for adenomas 6 to <10 mm
Sensitivity for adenomas ≥10 mm | 0.11^†^
Sensitivity for colorectal cancer | 0.68
FIT (per person) | | Lin, 2021^17^ | Not varied | Not applicable
Specificity | 0.97
Sensitivity for adenomas 1 to <6 mm | 0.07^*^
Sensitivity for adenomas 6 to <10 mm
Sensitivity for adenomas ≥10 mm | 0.22^†^
Sensitivity for colorectal cancer | 0.74
sDNA-FIT (per person) | | Lin, 2021^17^ | Not varied | Not applicable
Specificity | 0.91
Sensitivity for adenomas 1 to <6 mm | 0.15^*^
Sensitivity for adenomas 6 to <10 mm
Sensitivity for adenomas ≥10 mm | 0.42^†^
Sensitivity for colorectal cancer | 0.94
Colonoscopy (within reach, per lesion) ^‡^
Specificity | 0.86^§^ | Schroy, 2013^141^ | Not varied | Not applicable
Sensitivity for adenomas 1 to <6 mm | 0.75 | van Rijn, 2006^142^ | 0.69 | Zhao, 2019^98^
Sensitivity for adenomas 6 to <10 mm | 0.85 | van Rijn, 2006^142^ | 0.81 | Zhao, 2019^98^
Sensitivity for adenomas ≥10 mm | 0.95 | van Rijn, 2006^142^ | 0.91 | Zhao, 2019^98^
Sensitivity for colorectal cancer | 0.95 | By assumption^‖^ | Not varied | Not applicable
SIG (within reach, per lesion) | | | Not varied | Not applicable
Specificity | 0.87^§^ | Weissfeld, 2005^143^
Sensitivity for adenomas 1 to <6 mm | 0.75 | By assumption^¶^
Sensitivity for adenomas 6 to <10 mm | 0.85 | By assumption^¶^
Sensitivity for adenomas ≥10 mm | 0.95 | By assumption^¶^
Sensitivity for colorectal cancer | 0.95 | By assumption^¶^
CTC (per lesion) | | Johnson, 2008^144^ | Not varied | Not applicable
Specificity | 0.88^**^
Sensitivity for adenomas 1 to <6 mm | --
Sensitivity for adenomas 6 to <10 mm | 0.57
Sensitivity for adenomas ≥10 mm | 0.84
Sensitivity for colorectal cancer | 0.84^‖^

CTC – computed tomographic colonography; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); HSgFOBT – high sensitivity guaiac-based fecal occult blood test; SIG – sigmoidoscopy; -- indicates sensitivity is not provided because adenoma size is smaller than the referral threshold for a colonoscopy of 6 mm.

Note: For all tests other than CTC, specificity is defined as the probability of a normal test result among persons who do not have any adenomas or colorectal cancer. The specificity of CTC is explained below.

* Sensitivity for persons with non-advanced adenomas. For persons with 1 to <6 mm adenomas, sensitivity is assumed to equal to the positivity rate in persons without adenomas. The sensitivity for persons with 6 to <10 mm adenomas was chosen such that the weighted-average sensitivity for persons with 1 to < 6 mm and with 6 to <10 mm adenoma(s) is equal to the sensitivity for non-advanced adenomas.

† Sensitivity for persons with advanced adenomas (i.e., adenomas ≥10 mm and/or adenomas with advanced histology); the studies cited did not provide sensitivity for ≥10 mm adenomas separately from advanced adenomas.

‡ The same test characteristics were assumed to apply to all colonoscopies, regardless of indication. No correlation in findings between CTC or SIG and follow-up colonoscopy was assumed.

§ The lack of specificity with endoscopy reflects the detection of nonadenomatous polyps, which, in the case of sigmoidoscopy, may lead to unnecessary follow-up colonoscopy, and in the case of colonoscopy, leads to unnecessary polypectomy, which is associated with an increased risk of complications.

‖ Sensitivity for cancer was assumed to be the same as the sensitivity for adenomas ≥10 mm due to the small number of cancers detected in screening studies.

¶ Sensitivity for sigmoidoscopy was assumed to equal that of colonoscopy within reach of the sigmoidoscope and 0 for lesions beyond reach of the scope.

** The lack of specificity with CTC reflects the detection of ≥6 mm nonadenomatous lesions, artifacts, stool, and adenomas smaller than the 6 mm threshold for referral to colonoscopy that are measured as ≥6 mm.

It is important to note the findings of the systematic review for HSgFOBT. The EPC pooled the diagnostic accuracy from 2 studies^82,83^ of the HSgFOBT Hemoccult SENSA. Both used colonoscopy as the reference standard and were deemed ‘fair quality’. The 95% CIs for point estimates of the pooled sensitivity for advanced adenomas and for colorectal cancer were wide (0.01 to 0.22 and 0.46 to 0.90, respectively) and only 1 study^83^ provided information on sensitivity for non-advanced adenomas and on test specificity using the definition required by the models (i.e., the probability of a normal test result among persons who do not have any adenomas or colorectal cancer). Given the uncertainty in the test performance characteristics, there is considerable uncertainty in model outcomes for HSgFOBT. As a result, decisions about this test should not be informed by the models. We include model findings for HSgFOBT strategies in Appendix 4, rather than with the main results.

### Endoscopy Reach

We assume that 5% of persons undergoing colonoscopy have poor bowel preparation^84^ and require 2 procedures to achieve complete visualization, and that the cecum is ultimately visualized in 95% of patients.^85^ Reach of sigmoidoscopy was based on the UKFSS Trial,^63^ with 76-88% of procedures reaching the junction of the sigmoid and descending colon.

### Complications of Screening

Colonoscopy is the main source of reported harms (complications) from colorectal cancer screening. Harms could be from a screening or surveillance colonoscopy, or from a follow-up colonoscopy to evaluate a patient after an abnormal finding on another screening test. Fatal complications are extremely rare and affect life-years gained from screening. Non-fatal complications are more common, and affect quality of life (and costs, which are [underlined: not] explored in the decision analysis).

#### Colonoscopy

As noted by Lin et al.,^17^ serious adverse events from colonoscopy in asymptomatic persons are relatively uncommon. In a population undergoing colonoscopy for screening, the risks of perforation and major bleeding were 3.3 per 10,000 (95% CI 2.2 to 4.3) and 14.9 per 10,000 (95% CI 9.0 to 20.8), respectively. Complication rates were higher in a population undergoing colonoscopy for either screening or diagnostic follow-up, with 4.8 (95% CI 3.8 to 5.7) perforations and 16.7 (95% CI 12.0 to 21.5) major bleeds per 10,000.

The risks of colonoscopy complications increase with age.^17^ Age-specific estimates of the risk of non-fatal complications from colonoscopy used in the analysis are based on results from a study of adverse events (serious gastrointestinal events, other gastrointestinal events, and cardiovascular events) by age among Medicare beneficiaries undergoing outpatient colonoscopy (with or without polypectomy) relative to matched controls.^86^ This study found no evidence of excess risk for complications when colonoscopies did not include polypectomy, and that the risks in therapeutic colonoscopies (i.e., those with polypectomy) increased exponentially with age (Figure 9). We assumed 2 fatal complications per 100,000 colonoscopies with polypectomy, based on the risk of perforation at age 65 and the risk of dying of a perforation reported by Gatto et al.^87^

Figure 9 Age-Specific Excess Risks of Complications From Colonoscopy With Polypectomy Relative to Colonoscopies Without Polypectomy as Estimated by Van Hees et al^73^

Note: Complications include serious gastrointestinal events, other gastrointestinal events, and cardiovascular events.

* Perforations, gastrointestinal bleeding, or transfusions. Excess risk per colonoscopy with polypectomy = 1/[exp(9.27953 − 0.06105 × Age) + 1] − 1/[exp(10.78719 − 0.06105 × Age) + 1].

† Paralytic ileus, nausea and vomiting, dehydration, abdominal pain. Excess risk per colonoscopy with polypectomy = 1/[exp(8.81404 − 0.05903 × Age) + 1] − 1/[exp(9.61197 − 0.05903 × Age) + 1].

‡ Myocardial infarction or angina, arrhythmias, congestive heart failure, cardiac or respiratory arrest, syncope, hypotension, or shock. Excess risk per colonoscopy with polypectomy = 1/[exp(9.09053 − 0.07056 × Age) + 1] − 1/[exp(9.38297 − 0.07056 × Age) + 1]

Model inputs for the age-specific risk of serious gastrointestinal complications, other gastrointestinal complications, and cardiovascular complications from colonoscopy with polypectomy by age.

#### Sigmoidoscopy

Lin et al.^17^ identified several studies reporting the harms of sigmoidoscopy among the general population. However, none evaluated excess risks relative to a comparison group. As with colonoscopy, we assume risks of complications are conditional on polypectomy. Because we assume that polyps detected at sigmoidoscopy are not removed or biopsied during the procedure, we assumed that there is no risk of complications due to sigmoidoscopy, though complications could occur during colonoscopic follow-up of an abnormal sigmoidoscopy exam.

#### CTC

Lin et al.^17^ found that perforation from CTC itself was rare, with 95% CIs of 0 to 2.9 per 10,000 procedures. Furthermore, these perforations were detected radiologically, so are not on par with serious harms of perforation with colonoscopy. We therefore assumed no complications from CTC, though complications could occur during colonoscopic follow-up of an abnormal CTC exam.

Because CTC is a radiologic procedure, it may increase the risk of radiation-induced cancers. The models do not account for these risks, although their risks have been estimated to be small relative to the potential reduction in colorectal cancer risk from CTC screening.^88^

CTC often leads to the detection of suspicious findings outside of the colon.^17^ The models do not include the potential benefits or harms associated with the work-up and possible treatment of these extracolonic findings.

#### Stool Tests

Given their non-invasive nature, we assumed no direct harms from stool tests. We assumed complications could arise from colonoscopic follow-up of an abnormal stool test.

### Surveillance

Simulated persons who have an abnormal screening test but have no adenomas or cancer at the follow-up colonoscopy return to their original screening modality and schedule 10 years after the normal follow-up colonoscopy. Simulated persons with adenomas detected at a screening or a follow-up colonoscopy are assumed to undergo surveillance with colonoscopy. The time to the next surveillance colonoscopy is simulated based on findings at prior colonoscopies, in accordance with the 2020 recommendations of the Multi-Society Task Force on Colorectal Cancer (MSTF).^89^ These recommendations provide intervals for surveillance based on baseline findings and findings at the first surveillance colonoscopy. We assume the intervals provided by the MSTF can be more generally expressed as the intervals based on the most recent colonoscopy (“first-most-recent colonoscopy”) and the colonoscopy prior to that (“second-most-recent colonoscopy”) (Table 8). In situations where the MSTF provided a range rather than a single interval, we assumed that the shortest interval would be used in routine practice. Surveillance colonoscopy is assumed to continue through age 85, provided no adenomas or colorectal cancer are detected at the last surveillance colonoscopy (either at or before age 85). Otherwise surveillance was continued according to the clinical findings at the last colonoscopy until no adenomas are detected. For example, if a simulated person has no adenomas detected at a surveillance colonoscopy at age 83, they would stop surveillance because they would be >85-years-old at the next surveillance colonoscopy. However, if an adenoma ≥10 mm is detected at the surveillance colonoscopy at age 83, another surveillance colonoscopy would be performed at age 86, because the surveillance colonoscopy at or just prior to age 85 was abnormal; if the colonoscopy at age 86 is normal, then surveillance ends.

Table 8 Surveillance Intervals Used in the Analysis

Finding at second-most recent colonoscopy^*^,^†^ | Finding at first-most recent colonoscopy^*^,^†^ | Interval^‡^ to next colonoscopy, y
No prior colonoscopy | Normal colonoscopy | See note below^§^
No prior colonoscopy | 1-2 adenomas <10 mm | 7
No prior colonoscopy | 3-4 adenomas <10 mm | 3
No prior colonoscopy | 5-10 adenomas <10 mm or any adenoma ≥10 mm | 3
No prior colonoscopy | > 10 adenomas | 1
Normal colonoscopy | Normal colonoscopy | 10
Normal colonoscopy | 1-2 adenomas <10 mm | 7
Normal colonoscopy | 3-4 adenomas <10 mm | 3
Normal colonoscopy | 5-10 adenomas <10 mm or any adenoma ≥10 mm | 3
Normal colonoscopy | > 10 adenomas | 1
1-2 adenomas <10 mm | Normal colonoscopy | 10
1-2 adenomas <10 mm | 1-2 adenomas <10 mm | 7
1-2 adenomas <10 mm | 3-4 adenomas <10 mm | 3
1-2 adenomas <10 mm | 5-10 adenomas <10 mm or any adenoma ≥10 mm | 3
1-2 adenomas <10 mm | > 10 adenomas | 1
3-4 adenomas <10 mm | Normal colonoscopy | 10
3-4 adenomas <10 mm | 1-2 adenomas <10 mm | 7
3-4 adenomas <10 mm | 3-4 adenomas <10 mm | 3
3-4 adenomas <10 mm | 5-10 adenomas <10 mm or any adenoma ≥10 mm | 3
3-4 adenomas <10 mm | > 10 adenomas | 1
5-10 adenomas <10 mm; or; any adenoma ≥10 mm | Normal colonoscopy | 5
5-10 adenomas <10 mm; or; any adenoma ≥10 mm | 1-2 adenomas <10 mm | 5
5-10 adenomas <10 mm; or; any adenoma ≥10 mm | 3-4 adenomas <10 mm | 3
5-10 adenomas <10 mm; or; any adenoma ≥10 mm | 5-10 adenomas <10 mm or any adenoma ≥10 mm | 3
5-10 adenomas <10 mm; or; any adenoma ≥10 mm | > 10 adenomas | 1
> 10 adenomas of any size | Normal colonoscopy | 5
> 10 adenomas of any size | 1-2 adenomas <10 mm | 5
> 10 adenomas of any size | 3-4 adenomas <10 mm | 3
> 10 adenomas of any size | 5-10 adenomas <10 mm or any adenoma ≥10 mm | 3
> 10 adenomas of any size | >10 adenomas | 1

* A normal colonoscopy is one in which no adenomas, sessile-serrated polyps (not currently simulated), or colorectal cancer is detected.

† This table omits the case where colorectal cancer is detected at a screening, follow-up, or surveillance colonoscopy because the CISNET colorectal cancer models do not simulate detailed events following colorectal cancer diagnosis.

‡ The Multi-Society Task Force provides a range for some intervals (e.g., the interval for 3-4 adenomas <10 mm is 3-5 years). In such cases, we selected the shortest interval provided.

§ A person whose first screening or follow-up colonoscopy is normal does not enter surveillance but instead resumes screening with the original modality 10 years after the normal colonoscopy. The exception to the 10-year waiting period is when the first colonoscopy is a screening colonoscopy with an x-year interval, where x >10. In that case, the next colonoscopy is in x years.

Note: Intervals are based on surveillance recommendations for individuals with a personal history of adenomas from the Multi-Society Task Force on Colorectal Cancer.^89^

### Adherence

In base-case analyses, we assumed perfect adherence to the screening process, including all screening, follow-up, and surveillance procedures, reflecting the goal of estimating the effect of screening among average-risk persons with full willingness to be screened for colorectal cancer.

Lin et al.^17^ performed a robust review of the literature on adherence. None of the identified studies provide information on long-term adherence patterns required by the models. Given the limited evidence to inform long-term adherence patterns and the variability in estimates of short-term adherence rates, simulating the effect of imperfect adherence requires numerous assumptions. As a result, uncertainty surrounding model outcomes with imperfect adherence would be high. We therefore did not perform a formal sensitivity analysis on adherence rates, but instead discuss the potential effect of delayed screening initiation, repeat screening less frequently than recommended, delayed or lack of follow-up colonoscopy, and earlier screening cessation than recommended by comparing outcomes across scenarios with perfect adherence but with screening at different ages and intervals. For example, if people start colonoscopy late and only do 1, then the estimated effect on outcomes can be seen through comparison of once-only colonoscopy at age 55 with the recommended colonoscopy strategy. Similarly, if people are non-adherent with annual FIT, the estimated effect can be seen by comparing outcomes with annual FIT vs with FIT every 2 or 3 years.

### Quality of Life Assumptions

When calculating quality-adjusted life-years (QALYs), we accounted for preferences for a year of life varying by age, as well as utility losses associated with specific events (e.g., colonoscopy) or health states (e.g., time with CRC). The approach we used is similar to that used by the CISNET breast cancer group in their 2016 analysis for the USPSTF.^90^

Estimates of how preferences for a year of life vary according to age were obtained from the age-related utility weights from Hanmer et al.^91^ We assumed no disutility from performing stool tests themselves, but for all tests, we accounted for the disutility associated with waiting for test results. Disutilities for colonoscopy were based on a study by Swan et al.^92^ and were applied for a duration of 36 hours, based on a study by Jonas et al.^93^ We assumed the same disutility for sigmoidoscopy and CTC as for colonoscopy, but for shorter time periods because the lack of sedation reduces the time to resolution of normal activities. See Appendix 3 for more details on the inputs for QALY calculation.

## Outcomes

The models estimated a number of outcomes for each screening strategy to capture the potential health effects and harms over a lifetime. Outcomes included the estimated numbers of stool tests, sigmoidoscopies, CTCs, colonoscopies by type (screening, follow-up, surveillance, or symptom diagnosis), normal and abnormal test results, complications, colorectal cancer cases, colorectal cancer deaths, complication-related deaths, overall life-years, and life-years with colorectal cancer by stage at diagnosis. To keep the tables of outputs manageable, not all outcomes are included in the summary tables provided in this report (e.g., colonoscopies were reported as screening vs other colonoscopies).

All model-estimated outcomes are presented for a cohort of average-risk US adults who are unscreened and free of diagnosed colorectal cancer at age 40.^†^ Outcomes are tallied from age 40 to death and expressed per 1,000 persons at age 40. To facilitate interpretation of LYG, they are also expressed in terms of days of life gained per person.

### Benefit

We considered estimated life-years gained (LYG) compared with no screening^‡^ as the primary outcome for benefits of screening. A small fraction of those who are screened may experience a loss of life-years as a result of fatal complications; these losses are accounted for in the LYG for a given screening strategy.

### Harms

We used the model-estimated lifetime number of required colonoscopies to represent the primary harms and burden of colorectal cancer screening. This metric includes colonoscopies for screening, follow-up, and surveillance, as well as colonoscopies for the diagnosis of symptomatic cancers (i.e., cancers detected outside of screening or surveillance). Because the number of colonoscopies does not fully capture the burden of colorectal cancer screening, we also report the number of screening tests by type and the number of complications.

### Ratio of Harms (Burden) to Benefit

Ideally, all colorectal cancer screening strategies would be evaluated together in one comprehensive analysis comparing the model-estimated harms and benefits of screening. However, an analysis such as this would provide an incomplete picture of the tradeoffs across different screening modalities due to large differences in the number of non-colonoscopy tests (i.e., stool tests, sigmoidoscopies, and CTCs) across modalities. We therefore did not perform a comprehensive analysis of all strategies. Instead, we performed separate analyses by screening modality, as described in the sections that follow. Briefly, we first grouped together screening modalities with comparable non-colonoscopy burden to create “classes” of screening modalities. We then identified the subset of efficient screening strategies within each class, as described below.

#### Classes of Comparable Screening Modalities

We grouped FIT and sDNA-FIT together as exclusively stool-based screening modalities with comparable burden. (Model-estimated outcomes for stool-based modalities including HSgFOBT are included in Appendix 4.) The remaining modalities – SIG+FIT, sigmoidoscopy alone, CTC, and colonoscopy – each remained a unique screening class due to differences in bowel preparation, invasiveness, the need for sedation, and in the need for, type of, and number of non-colonoscopy tests. After this grouping, we were left with seven classes of screening modalities: stool-based modalities, SIG+FIT, sigmoidoscopy alone, CTC, colonoscopy alone, and strategies involving colonoscopy either preceded by or followed by annual FIT.

#### Efficient Strategies Within a Class of Screening Modality

Our goal was not to identify a “best” test or set of tests, but, as noted in Key Question 2, to identify efficient screening strategies within each class of screening modality. A strategy is efficient if no other strategy or combination of strategies within the class is estimated to provide more LYG with the same (or fewer) estimated number of colonoscopies. We first identified screening strategies that were estimated to require more colonoscopies and provide lower LYG than another strategy within the class; these strategies are strongly dominated and were deemed inefficient (Figure 10). For each of the remaining strategies within a class of screening modality we calculated the incremental number of lifetime colonoscopies (ΔCOL) and the incremental LYG (ΔLYG), relative to the next least effective strategy. We then calculated an “efficiency ratio,” defined as the incremental number of colonoscopies required to achieve an additional LYG (ΔCOL/ΔLYG). In an approach that mirrors that of incremental cost-effectiveness analysis, strategies that were estimated to provide lower LYG than another and had a higher efficiency ratio were weakly dominated and deemed inefficient.

Figure 10 Illustration of Efficient, Strongly Dominated and Weakly Dominated Strategies

Note: Strategies A, B, C, and D are efficient. The line connecting the efficient strategies is the efficient frontier. The inverse of the slope of the efficient frontier between 2 adjacent efficient strategies is the efficiency ratio. A steep efficient frontier implies a big increase in LYG from the additional colonoscopies (i.e., a low efficiency ratio); a flat efficient frontier implies a small increase in LYG from the additional colonoscopies (i.e., a high efficiency ratio).

Chart illustrating efficient, strongly dominated, and weakly dominated strategies and the efficient frontier.

We then derived an “efficient frontier” for each class of screening modality, which is the line connecting efficient strategies when the strategies are plotted with the estimated number of colonoscopies on the horizontal axis and the estimated number of LYG on the vertical axis. The inverse of the slope of the efficient frontier between adjacent strategies is the efficiency ratio. It represents the number of additional colonoscopies required to increase LYG by 1. This ratio is akin to the incremental cost-effectiveness ratio in a cost-effectiveness analysis. As the efficient frontier gets flatter, the efficiency ratio increases, indicating diminishing returns from each additional colonoscopy performed.

There is no standard for determining the optimal point on the efficient frontier. In cost-effectiveness analysis, decision makers typically refer to estimates of the willingness to pay for a year of (quality-adjusted) life gained as a benchmark for deciding which of the efficient strategies provide good vs poor value.^94–96^ There is no comparable metric in this setting, where efficiency is expressed as the number of additional colonoscopies per LYG. To aid in the interpretation of the tradeoff between life expectancy gains and colonoscopies across strategies within a class of screening modality, we also present the results as the number of additional days of life gained per additional colonoscopy performed (ΔDLG/ΔCOL) in a summary table provided in the Discussion. This metric is equivalent to the slope of the efficient frontier, but with the benefit of screening expressed in terms of days of life gained instead of years of life gained. It conveys the “bang” (additional days of life gained) for each additional colonoscopy “buck.”

Lastly, because an inefficient strategy providing outcomes that are very similar to an efficient strategy may be a reasonable option for another reason^97^ (e.g., for consistency of starting and stopping ages across screening modalities), we also identified “near-efficient” strategies, which we defined as a strategy within 3 days of life gained per person of the efficient frontier. There is no standard for what constitutes a reasonable number of days from the frontier for a strategy to be near efficient. We chose an absolute distance of 3 days per person, which, for the strategies highlighted by the USPSTF in 2016, is largely consistent with the relative measure that we used in the 2016 decision analysis, namely LYG within 2% of the efficient frontier. Hereafter, we refer to efficient and near-efficient strategies as “efficient”.

## Scenario and Sensitivity Analyses

Many of the sensitivity and scenario analyses have been described above, although not in those terms. Through the use of 3 independently-developed models, the primary analysis includes a sensitivity analysis on model structure. We also evaluated outcomes for 2 scenarios of colorectal cancer risk (IRR of 1.52, and 1, see Increasing Population Risk of Colorectal Cancer), in addition to the scenario for the base-case analysis (IRR = 1.19). Additional analyses were stratified by race and sex (see Analyses by Race and Sex).

Two additional sensitivity analyses were performed. First, because there are multiple ways to express the benefit of screening, we presented results using 3 metrics: LYG (the metric for base-case analyses); quality-adjusted life-years gained (QALYG);^§^ and colorectal cancer deaths averted.^**^ Additional information on the calculation of quality-adjusted life-years is provided in Appendix 3. We assumed that a strategy within 3 quality-adjusted days of life gained per person of the efficient frontier is near efficient, which is similar to the approach used for LYG (i.e., within 3 days of life gained per person of the efficient frontier is near efficient). With the estimated number of colorectal cancer deaths averted as the measure of benefit, we assumed a dominated strategy within 0.75 deaths averted per 1,000 of the efficient frontier is near efficient.

Second, we performed a sensitivity analysis to evaluate the effect of uncertainty in the sensitivity of colonoscopy for detecting adenomas by size. Values for colonoscopy sensitivity (Table 7) were based on a 2019 systematic review and meta-analysis of tandem colonoscopy studies by Zhao et al.^98^

To keep the number of model simulations at a manageable number, in consultation with USPSTF members, analyses by race and sex and sensitivity analyses of colonoscopy sensitivity were limited to 1 risk scenario (IRR=1.19) and 2 screening modalities (colonoscopy and FIT). Even so, these additional analyses required 355 additional simulations for each model.

While not technically a sensitivity or scenario analysis, we also provided plausible ways to consider different types of non-adherence with the screening process. For example, estimated outcomes accounting for non-adherence with screening initiation can be calculated by a weighted average of estimated outcomes with a given screening strategy and with no screening. The effect of delayed screening initiation can be estimated by comparing output across strategies with different ages to begin screening. Similarly, the effect of non-adherence with repeat screening can be estimated by comparison of strategies with different screening intervals.

## Expert Review and Public Comments

A draft version of this report was reviewed by content experts, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report when appropriate. Additionally, a draft of this report was posted for public comment on the USPSTF website from October 27, 2020, through November 23, 2020. Few comments were received during this public comment period; minor clarifications and editorial changes were made to the report based on these comments. While no changes were made to the model findings or to the conclusions, tables and figures were added to simplify comparison of outcomes by race and sex.

* Microsimulation means that the models simulate outcomes for individual agents (i.e., individual hypothetical people).

† We chose a 40-year-old cohort to maintain consistency with the 2008 and 2016 decision analyses for colorectal cancer screening for the USPSTF. The initial decision to simulate a cohort of 40-year-olds was based on the fact that the 2008 decision analysis included strategies with screening starting at age 40.

‡ The number of life-years gained with a given strategy was calculated as the difference in model-estimated life expectancy between the strategy of interest and the no screening strategy.

§ The number of quality-adjusted life-years gained with a given strategy was calculated as the difference in model-estimated quality-adjusted life expectancy between the strategy of interest and the no screening strategy.

** The estimated number of colorectal cancer deaths averted with a given strategy was calculated as the difference in the model-estimated number of colorectal cancer deaths with the no screening strategy and the strategy of interest.