# Chapter 1 Introduction

Although colorectal cancer mortality rates have declined 51 percent from 1975 to 2016,^1^ colorectal cancer remains the second most common cause of cancer death in the United States (US) with 52,980 deaths expected in 2021.^2^ Randomized trials have shown that screening reduces colorectal cancer incidence and mortality.^3–10^ While these trials provide the highest quality evidence of screening effectiveness, it is not feasible for trials to examine the full range of potential screening programs. In this context, microsimulation modeling can be used to synthesize available information about screening to provide estimates of the risks, benefits, and burden of different screening strategies to reduce colorectal cancer incidence and mortality.

The US Preventive Services Task Force (USPSTF) first recommended colorectal cancer screening in 1996^11^ with updated recommendations reported in 2002,^12^ 2008,^13^ and 2016.^14^ The latter 2 updates considered outcomes of decision analyses conducted using colorectal cancer models funded by the Cancer Intervention and Surveillance Modeling Network (CISNET) to inform the ages to begin and end screening, intervals of screening, and screening modality.^15,16^ Modeling input was most informative regarding the age to end routine colorectal cancer screening and the screening interval for recommended tests. In 2016 the USPSTF recommended that average-risk adults undergo screening for colorectal cancer from ages 50 to 75.^14^ Screening strategies highlighted by the USPSTF included colonoscopy every 10 years, flexible sigmoidoscopy alone every 5 years, sigmoidoscopy every 10 years with annual fecal immunochemical testing (SIG+FIT), computed tomographic colonography (CTC) every 5 years, annual high-sensitivity guaiac-based fecal occult blood testing (HSgFOBT, i.e., Hemoccult SENSA^®^ (Beckman Coulter; Brea, CA)), annual fecal immunochemical testing (FIT), or multitarget stool DNA testing (sDNA-FIT, i.e., Cologuard^®^ (Exact Sciences Corporation; Madison, WI)) either annually or every 3 years.^14^

This decision analysis, with an accompanying systematic evidence review,^17^ will be used by the USPSTF to update its 2016 colorectal cancer screening recommendations.^14^