# Appendix 9 Model-Estimated Outcomes for Each Strategy Within a Screening Modality

Appendix Table 9.1a Estimated Outcomes for Colonoscopy Screening Strategies: SimCRC

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 85 | 85 | 2 | 85 | 34 | 0 | 0 | 0
COL 45-70, 5 | 0 | 0 | 0 | 4436 | 1282 | 5718 | 15 | 12 | 3 | 377 | 355 | 138
COL 45-70, 10 | 0 | 0 | 0 | 2537 | 1142 | 3679 | 12 | 17 | 5 | 361 | 340 | 132
COL 45-70, 15 | 0 | 0 | 0 | 1846 | 983 | 2829 | 10 | 24 | 7 | 336 | 316 | 123
COL 45-75, 5 | 0 | 0 | 0 | 4826 | 1319 | 6145 | 17 | 11 | 3 | 380 | 357 | 139
COL 45-75, 10 | 0 | 0 | 0 | 2987 | 1225 | 4212 | 16 | 14 | 3 | 369 | 347 | 135
COL 45-75, 15 | 0 | 0 | 0 | 2351 | 1112 | 3463 | 15 | 18 | 4 | 352 | 331 | 129
COL 45-80, 5 | 0 | 0 | 0 | 5115 | 1339 | 6454 | 19 | 11 | 2 | 381 | 358 | 139
COL 45-80, 10 | 0 | 0 | 0 | 2987 | 1225 | 4212 | 16 | 14 | 3 | 369 | 347 | 135
COL 45-80, 15 | 0 | 0 | 0 | 2351 | 1112 | 3463 | 15 | 18 | 4 | 352 | 331 | 129
COL 45-85, 5 | 0 | 0 | 0 | 5304 | 1347 | 6652 | 21 | 10 | 2 | 381 | 358 | 139
COL 45-85, 10 | 0 | 0 | 0 | 3205 | 1244 | 4449 | 18 | 14 | 3 | 370 | 347 | 135
COL 45-85, 15 | 0 | 0 | 0 | 2351 | 1112 | 3463 | 15 | 18 | 4 | 352 | 331 | 129
COL 50-70, 5 | 0 | 0 | 0 | 3583 | 1179 | 4762 | 15 | 16 | 4 | 345 | 323 | 126
COL 50-70, 10 | 0 | 0 | 0 | 2343 | 1072 | 3414 | 13 | 18 | 5 | 335 | 314 | 122
COL 50-70, 15 | 0 | 0 | 0 | 1742 | 992 | 2734 | 11 | 23 | 7 | 318 | 298 | 116
COL 50-75, 5 | 0 | 0 | 0 | 3973 | 1216 | 5189 | 17 | 15 | 4 | 348 | 326 | 127
COL 50-75, 10 | 0 | 0 | 0 | 2343 | 1072 | 3414 | 13 | 18 | 5 | 335 | 314 | 122
COL 50-75, 15 | 0 | 0 | 0 | 1742 | 992 | 2734 | 11 | 23 | 7 | 318 | 298 | 116
COL 50-80, 5 | 0 | 0 | 0 | 4262 | 1236 | 5498 | 19 | 14 | 4 | 348 | 326 | 127
COL 50-80, 10 | 0 | 0 | 0 | 2676 | 1116 | 3792 | 16 | 17 | 4 | 338 | 316 | 123
COL 50-80, 15 | 0 | 0 | 0 | 2123 | 1064 | 3186 | 16 | 21 | 5 | 324 | 303 | 118
COL 50-85, 5 | 0 | 0 | 0 | 4451 | 1244 | 5696 | 20 | 14 | 3 | 348 | 326 | 127
COL 50-85, 10 | 0 | 0 | 0 | 2676 | 1116 | 3792 | 16 | 17 | 4 | 338 | 316 | 123
COL 50-85, 15 | 0 | 0 | 0 | 2123 | 1064 | 3186 | 16 | 21 | 5 | 324 | 303 | 118
COL 55-70, 5 | 0 | 0 | 0 | 2792 | 1059 | 3851 | 14 | 21 | 6 | 302 | 282 | 110
COL 55-70, 10 | 0 | 0 | 0 | 1666 | 949 | 2615 | 12 | 26 | 8 | 288 | 269 | 105
COL 55-70, 15 | 0 | 0 | 0 | 1617 | 915 | 2532 | 13 | 26 | 8 | 285 | 265 | 104
COL 55-75, 5 | 0 | 0 | 0 | 3182 | 1096 | 4279 | 16 | 20 | 5 | 305 | 284 | 111
COL 55-75, 10 | 0 | 0 | 0 | 2118 | 1034 | 3152 | 15 | 22 | 6 | 297 | 276 | 108
COL 55-75, 15 | 0 | 0 | 0 | 1617 | 915 | 2532 | 13 | 26 | 8 | 285 | 265 | 104
COL 55-80, 5 | 0 | 0 | 0 | 3471 | 1116 | 4587 | 18 | 19 | 5 | 306 | 284 | 112
COL 55-80, 10 | 0 | 0 | 0 | 2118 | 1034 | 3152 | 15 | 22 | 6 | 297 | 276 | 108
COL 55-80, 15 | 0 | 0 | 0 | 1617 | 915 | 2532 | 13 | 26 | 8 | 285 | 265 | 104
COL 55-85, 5 | 0 | 0 | 0 | 3661 | 1124 | 4785 | 20 | 19 | 5 | 306 | 284 | 112
COL 55-85, 10 | 0 | 0 | 0 | 2337 | 1053 | 3389 | 18 | 22 | 6 | 297 | 277 | 109
COL 55-85, 15 | 0 | 0 | 0 | 1866 | 947 | 2812 | 16 | 25 | 7 | 286 | 266 | 104

COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.1b Estimated Outcomes for Colonoscopy Screening Strategies: CRC-SPIN

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 77 | 77 | 2 | 77 | 32 | 0 | 0 | 0
COL 45-70, 5 | 0 | 0 | 0 | 4379 | 1410 | 5789 | 17 | 10 | 3 | 348 | 328 | 127
COL 45-70, 10 | 0 | 0 | 0 | 2506 | 1276 | 3782 | 14 | 13 | 4 | 335 | 317 | 122
COL 45-70, 15 | 0 | 0 | 0 | 1827 | 1138 | 2965 | 12 | 18 | 6 | 317 | 300 | 116
COL 45-75, 5 | 0 | 0 | 0 | 4804 | 1431 | 6235 | 19 | 10 | 3 | 349 | 329 | 128
COL 45-75, 10 | 0 | 0 | 0 | 2976 | 1324 | 4300 | 17 | 12 | 4 | 340 | 321 | 124
COL 45-75, 15 | 0 | 0 | 0 | 2339 | 1218 | 3558 | 16 | 14 | 5 | 327 | 309 | 119
COL 45-80, 5 | 0 | 0 | 0 | 5138 | 1443 | 6581 | 20 | 9 | 3 | 350 | 330 | 128
COL 45-80, 10 | 0 | 0 | 0 | 2976 | 1324 | 4300 | 17 | 12 | 4 | 340 | 321 | 124
COL 45-80, 15 | 0 | 0 | 0 | 2339 | 1218 | 3558 | 16 | 14 | 5 | 327 | 309 | 119
COL 45-85, 5 | 0 | 0 | 0 | 5369 | 1448 | 6817 | 22 | 9 | 3 | 350 | 330 | 128
COL 45-85, 10 | 0 | 0 | 0 | 3230 | 1336 | 4566 | 19 | 11 | 4 | 340 | 321 | 124
COL 45-85, 15 | 0 | 0 | 0 | 2339 | 1218 | 3558 | 16 | 14 | 5 | 327 | 309 | 119
COL 50-70, 5 | 0 | 0 | 0 | 3571 | 1276 | 4847 | 17 | 13 | 4 | 318 | 300 | 116
COL 50-70, 10 | 0 | 0 | 0 | 2337 | 1163 | 3500 | 15 | 15 | 5 | 308 | 291 | 112
COL 50-70, 15 | 0 | 0 | 0 | 1732 | 1093 | 2825 | 13 | 18 | 6 | 296 | 280 | 108
COL 50-75, 5 | 0 | 0 | 0 | 3996 | 1297 | 5293 | 18 | 12 | 4 | 320 | 301 | 117
COL 50-75, 10 | 0 | 0 | 0 | 2337 | 1163 | 3500 | 15 | 15 | 5 | 308 | 291 | 112
COL 50-75, 15 | 0 | 0 | 0 | 1732 | 1093 | 2825 | 13 | 18 | 6 | 296 | 280 | 108
COL 50-80, 5 | 0 | 0 | 0 | 4329 | 1310 | 5639 | 20 | 12 | 4 | 320 | 302 | 117
COL 50-80, 10 | 0 | 0 | 0 | 2705 | 1191 | 3896 | 18 | 14 | 5 | 310 | 293 | 113
COL 50-80, 15 | 0 | 0 | 0 | 2133 | 1139 | 3272 | 17 | 16 | 5 | 300 | 284 | 110
COL 50-85, 5 | 0 | 0 | 0 | 4560 | 1315 | 5875 | 22 | 12 | 4 | 320 | 302 | 117
COL 50-85, 10 | 0 | 0 | 0 | 2705 | 1191 | 3896 | 18 | 14 | 5 | 310 | 293 | 113
COL 50-85, 15 | 0 | 0 | 0 | 2133 | 1139 | 3272 | 17 | 16 | 5 | 300 | 284 | 110
COL 55-70, 5 | 0 | 0 | 0 | 2815 | 1121 | 3936 | 16 | 17 | 6 | 284 | 267 | 104
COL 55-70, 10 | 0 | 0 | 0 | 1668 | 1021 | 2689 | 14 | 20 | 7 | 272 | 256 | 100
COL 55-70, 15 | 0 | 0 | 0 | 1619 | 976 | 2595 | 14 | 21 | 7 | 267 | 251 | 97
COL 55-75, 5 | 0 | 0 | 0 | 3241 | 1143 | 4384 | 18 | 16 | 6 | 286 | 268 | 104
COL 55-75, 10 | 0 | 0 | 0 | 2142 | 1073 | 3216 | 16 | 18 | 6 | 278 | 261 | 101
COL 55-75, 15 | 0 | 0 | 0 | 1619 | 976 | 2595 | 14 | 21 | 7 | 267 | 251 | 97
COL 55-80, 5 | 0 | 0 | 0 | 3574 | 1155 | 4729 | 19 | 16 | 5 | 286 | 268 | 104
COL 55-80, 10 | 0 | 0 | 0 | 2142 | 1073 | 3216 | 16 | 18 | 6 | 278 | 261 | 101
COL 55-80, 15 | 0 | 0 | 0 | 1619 | 976 | 2595 | 14 | 21 | 7 | 267 | 251 | 97
COL 55-85, 5 | 0 | 0 | 0 | 3805 | 1160 | 4966 | 21 | 16 | 5 | 286 | 268 | 105
COL 55-85, 10 | 0 | 0 | 0 | 2396 | 1086 | 3482 | 18 | 18 | 6 | 278 | 261 | 102
COL 55-85, 15 | 0 | 0 | 0 | 1896 | 997 | 2893 | 17 | 20 | 7 | 268 | 252 | 98

COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.1c Estimated Outcomes for Colonoscopy Screening Strategies: MISCAN

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 81 | 81 | 2 | 81 | 34 | 0 | 0 | 0
COL 45-70, 5 | 0 | 0 | 0 | 4147 | 1479 | 5626 | 16 | 32 | 8 | 318 | 288 | 116
COL 45-70, 10 | 0 | 0 | 0 | 2428 | 1351 | 3779 | 13 | 37 | 10 | 292 | 265 | 107
COL 45-70, 15 | 0 | 0 | 0 | 1805 | 1201 | 3006 | 11 | 41 | 12 | 265 | 240 | 97
COL 45-75, 5 | 0 | 0 | 0 | 4518 | 1498 | 6016 | 17 | 31 | 7 | 321 | 291 | 117
COL 45-75, 10 | 0 | 0 | 0 | 2837 | 1395 | 4232 | 15 | 34 | 8 | 301 | 272 | 110
COL 45-75, 15 | 0 | 0 | 0 | 2256 | 1276 | 3532 | 15 | 37 | 10 | 281 | 253 | 103
COL 45-80, 5 | 0 | 0 | 0 | 4808 | 1512 | 6320 | 19 | 30 | 7 | 323 | 293 | 118
COL 45-80, 10 | 0 | 0 | 0 | 2837 | 1395 | 4232 | 15 | 34 | 8 | 301 | 272 | 110
COL 45-80, 15 | 0 | 0 | 0 | 2256 | 1276 | 3532 | 15 | 37 | 10 | 281 | 253 | 103
COL 45-85, 5 | 0 | 0 | 0 | 5001 | 1515 | 6516 | 20 | 30 | 7 | 323 | 293 | 118
COL 45-85, 10 | 0 | 0 | 0 | 3053 | 1404 | 4457 | 17 | 34 | 8 | 302 | 273 | 110
COL 45-85, 15 | 0 | 0 | 0 | 2256 | 1276 | 3532 | 15 | 37 | 10 | 281 | 253 | 103
COL 50-70, 5 | 0 | 0 | 0 | 3341 | 1357 | 4698 | 15 | 33 | 8 | 300 | 271 | 110
COL 50-70, 10 | 0 | 0 | 0 | 2224 | 1252 | 3476 | 14 | 36 | 9 | 286 | 257 | 104
COL 50-70, 15 | 0 | 0 | 0 | 1685 | 1184 | 2868 | 13 | 40 | 11 | 264 | 237 | 96
COL 50-75, 5 | 0 | 0 | 0 | 3713 | 1376 | 5089 | 17 | 32 | 8 | 304 | 274 | 111
COL 50-75, 10 | 0 | 0 | 0 | 2224 | 1252 | 3476 | 14 | 36 | 9 | 286 | 257 | 104
COL 50-75, 15 | 0 | 0 | 0 | 1685 | 1184 | 2868 | 13 | 40 | 11 | 264 | 237 | 96
COL 50-80, 5 | 0 | 0 | 0 | 4002 | 1390 | 5393 | 18 | 32 | 8 | 305 | 275 | 112
COL 50-80, 10 | 0 | 0 | 0 | 2540 | 1279 | 3819 | 16 | 35 | 9 | 290 | 260 | 106
COL 50-80, 15 | 0 | 0 | 0 | 2031 | 1226 | 3257 | 16 | 38 | 10 | 271 | 242 | 99
COL 50-85, 5 | 0 | 0 | 0 | 4196 | 1393 | 5589 | 20 | 32 | 7 | 306 | 275 | 112
COL 50-85, 10 | 0 | 0 | 0 | 2540 | 1279 | 3819 | 16 | 35 | 9 | 290 | 260 | 106
COL 50-85, 15 | 0 | 0 | 0 | 2031 | 1226 | 3257 | 16 | 38 | 10 | 271 | 242 | 99
COL 55-70, 5 | 0 | 0 | 0 | 2618 | 1204 | 3822 | 15 | 36 | 9 | 274 | 245 | 100
COL 55-70, 10 | 0 | 0 | 0 | 1602 | 1122 | 2724 | 13 | 40 | 11 | 255 | 228 | 93
COL 55-70, 15 | 0 | 0 | 0 | 1556 | 1074 | 2630 | 13 | 40 | 11 | 250 | 223 | 91
COL 55-75, 5 | 0 | 0 | 0 | 2990 | 1223 | 4213 | 16 | 35 | 9 | 277 | 248 | 101
COL 55-75, 10 | 0 | 0 | 0 | 2014 | 1167 | 3180 | 15 | 37 | 10 | 264 | 235 | 96
COL 55-75, 15 | 0 | 0 | 0 | 1556 | 1074 | 2630 | 13 | 40 | 11 | 250 | 223 | 91
COL 55-80, 5 | 0 | 0 | 0 | 3279 | 1238 | 4517 | 18 | 34 | 8 | 279 | 249 | 102
COL 55-80, 10 | 0 | 0 | 0 | 2014 | 1167 | 3180 | 15 | 37 | 10 | 264 | 235 | 96
COL 55-80, 15 | 0 | 0 | 0 | 1556 | 1074 | 2630 | 13 | 40 | 11 | 250 | 223 | 91
COL 55-85, 5 | 0 | 0 | 0 | 3473 | 1240 | 4713 | 19 | 34 | 8 | 279 | 250 | 102
COL 55-85, 10 | 0 | 0 | 0 | 2229 | 1176 | 3406 | 17 | 37 | 10 | 265 | 236 | 97
COL 55-85, 15 | 0 | 0 | 0 | 1791 | 1090 | 2881 | 16 | 40 | 11 | 252 | 224 | 92

COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.2a Estimated Outcomes for FIT Strategies: SimCRC

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 85 | 85 | 2 | 85 | 34 | 0 | 0 | 0
FIT 45-70, 1 | 17539 | 0 | 0 | 0 | 1453 | 1453 | 8 | 30 | 8 | 336 | 310 | 123
FIT 45-70, 2 | 10148 | 0 | 0 | 0 | 1006 | 1006 | 6 | 42 | 11 | 297 | 271 | 108
FIT 45-70, 3 | 7435 | 0 | 0 | 0 | 810 | 810 | 6 | 49 | 14 | 266 | 241 | 97
FIT 45-75, 1 | 19680 | 0 | 0 | 0 | 1602 | 1602 | 10 | 26 | 6 | 348 | 321 | 127
FIT 45-75, 2 | 11731 | 0 | 0 | 0 | 1147 | 1147 | 8 | 38 | 9 | 318 | 289 | 116
FIT 45-75, 3 | 8475 | 0 | 0 | 0 | 917 | 917 | 7 | 46 | 11 | 286 | 258 | 104
FIT 45-80, 1 | 21368 | 0 | 0 | 0 | 1715 | 1715 | 11 | 25 | 5 | 355 | 326 | 129
FIT 45-80, 2 | 12576 | 0 | 0 | 0 | 1220 | 1220 | 9 | 36 | 7 | 325 | 295 | 119
FIT 45-80, 3 | 9043 | 0 | 0 | 0 | 971 | 971 | 8 | 44 | 10 | 293 | 264 | 107
FIT 45-85, 1 | 22567 | 0 | 0 | 0 | 1790 | 1790 | 12 | 24 | 4 | 356 | 328 | 130
FIT 45-85, 2 | 13487 | 0 | 0 | 0 | 1294 | 1294 | 10 | 36 | 6 | 329 | 298 | 120
FIT 45-85, 3 | 9734 | 0 | 0 | 0 | 1037 | 1037 | 9 | 44 | 9 | 298 | 267 | 109
FIT 50-70, 1 | 14004 | 0 | 0 | 0 | 1271 | 1271 | 8 | 34 | 9 | 302 | 277 | 110
FIT 50-70, 2 | 8382 | 0 | 0 | 0 | 909 | 909 | 6 | 45 | 12 | 268 | 244 | 98
FIT 50-70, 3 | 5757 | 0 | 0 | 0 | 691 | 691 | 5 | 53 | 16 | 231 | 208 | 84
FIT 50-75, 1 | 16160 | 0 | 0 | 0 | 1423 | 1423 | 9 | 30 | 7 | 316 | 289 | 115
FIT 50-75, 2 | 9446 | 0 | 0 | 0 | 1006 | 1006 | 7 | 42 | 10 | 283 | 256 | 103
FIT 50-75, 3 | 6945 | 0 | 0 | 0 | 814 | 814 | 6 | 49 | 13 | 256 | 230 | 94
FIT 50-80, 1 | 17856 | 0 | 0 | 0 | 1538 | 1538 | 11 | 28 | 6 | 322 | 294 | 118
FIT 50-80, 2 | 10719 | 0 | 0 | 0 | 1116 | 1116 | 9 | 40 | 8 | 294 | 265 | 107
FIT 50-80, 3 | 7785 | 0 | 0 | 0 | 900 | 900 | 8 | 47 | 11 | 267 | 238 | 98
FIT 50-85, 1 | 19059 | 0 | 0 | 0 | 1613 | 1613 | 12 | 28 | 5 | 324 | 296 | 118
FIT 50-85, 2 | 11329 | 0 | 0 | 0 | 1166 | 1166 | 10 | 39 | 8 | 296 | 267 | 108
FIT 50-85, 3 | 8199 | 0 | 0 | 0 | 939 | 939 | 8 | 47 | 10 | 270 | 240 | 99
FIT 55-70, 1 | 10601 | 0 | 0 | 0 | 1072 | 1072 | 8 | 40 | 11 | 260 | 236 | 95
FIT 55-70, 2 | 6100 | 0 | 0 | 0 | 742 | 742 | 6 | 51 | 15 | 223 | 201 | 82
FIT 55-70, 3 | 4710 | 0 | 0 | 0 | 624 | 624 | 5 | 56 | 17 | 203 | 181 | 74
FIT 55-75, 1 | 12790 | 0 | 0 | 0 | 1232 | 1232 | 9 | 36 | 9 | 275 | 249 | 100
FIT 55-75, 2 | 7715 | 0 | 0 | 0 | 893 | 893 | 7 | 46 | 12 | 247 | 221 | 90
FIT 55-75, 3 | 5351 | 0 | 0 | 0 | 691 | 691 | 6 | 54 | 15 | 216 | 192 | 79
FIT 55-80, 1 | 14502 | 0 | 0 | 0 | 1349 | 1349 | 11 | 34 | 8 | 281 | 255 | 103
FIT 55-80, 2 | 8573 | 0 | 0 | 0 | 970 | 970 | 8 | 45 | 10 | 255 | 228 | 93
FIT 55-80, 3 | 6324 | 0 | 0 | 0 | 791 | 791 | 7 | 52 | 13 | 231 | 204 | 84
FIT 55-85, 1 | 15711 | 0 | 0 | 0 | 1426 | 1426 | 12 | 33 | 7 | 283 | 256 | 103
FIT 55-85, 2 | 9494 | 0 | 0 | 0 | 1046 | 1046 | 10 | 44 | 9 | 259 | 231 | 95
FIT 55-85, 3 | 6931 | 0 | 0 | 0 | 851 | 851 | 9 | 52 | 12 | 235 | 207 | 86

COL – colonoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.2b Estimated Outcomes for FIT Strategies: CRC-SPIN

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 77 | 77 | 2 | 77 | 32 | 0 | 0 | 0
FIT 45-70, 1 | 16882 | 0 | 0 | 0 | 1692 | 1692 | 12 | 22 | 7 | 306 | 286 | 112
FIT 45-70, 2 | 9891 | 0 | 0 | 0 | 1230 | 1230 | 9 | 32 | 11 | 267 | 249 | 98
FIT 45-70, 3 | 7299 | 0 | 0 | 0 | 1007 | 1007 | 8 | 38 | 13 | 235 | 218 | 86
FIT 45-75, 1 | 18950 | 0 | 0 | 0 | 1824 | 1824 | 13 | 20 | 6 | 314 | 293 | 115
FIT 45-75, 2 | 11420 | 0 | 0 | 0 | 1361 | 1361 | 11 | 29 | 9 | 281 | 262 | 103
FIT 45-75, 3 | 8300 | 0 | 0 | 0 | 1110 | 1110 | 9 | 36 | 11 | 248 | 230 | 91
FIT 45-80, 1 | 20622 | 0 | 0 | 0 | 1923 | 1923 | 14 | 19 | 5 | 318 | 296 | 116
FIT 45-80, 2 | 12249 | 0 | 0 | 0 | 1426 | 1426 | 12 | 28 | 8 | 287 | 266 | 105
FIT 45-80, 3 | 8866 | 0 | 0 | 0 | 1163 | 1163 | 10 | 35 | 11 | 253 | 235 | 93
FIT 45-85, 1 | 21850 | 0 | 0 | 0 | 1990 | 1990 | 15 | 19 | 5 | 319 | 298 | 117
FIT 45-85, 2 | 13160 | 0 | 0 | 0 | 1492 | 1492 | 13 | 27 | 7 | 289 | 268 | 106
FIT 45-85, 3 | 9551 | 0 | 0 | 0 | 1222 | 1222 | 11 | 34 | 10 | 257 | 238 | 94
FIT 50-70, 1 | 13481 | 0 | 0 | 0 | 1483 | 1483 | 11 | 26 | 8 | 276 | 258 | 101
FIT 50-70, 2 | 8177 | 0 | 0 | 0 | 1102 | 1102 | 9 | 35 | 12 | 239 | 222 | 87
FIT 50-70, 3 | 5663 | 0 | 0 | 0 | 858 | 858 | 7 | 43 | 15 | 202 | 188 | 74
FIT 50-75, 1 | 15562 | 0 | 0 | 0 | 1619 | 1619 | 12 | 23 | 7 | 285 | 266 | 104
FIT 50-75, 2 | 9206 | 0 | 0 | 0 | 1194 | 1194 | 10 | 33 | 10 | 248 | 231 | 91
FIT 50-75, 3 | 6818 | 0 | 0 | 0 | 981 | 981 | 9 | 39 | 13 | 220 | 203 | 80
FIT 50-80, 1 | 17240 | 0 | 0 | 0 | 1721 | 1721 | 13 | 22 | 7 | 288 | 268 | 105
FIT 50-80, 2 | 10454 | 0 | 0 | 0 | 1294 | 1294 | 11 | 31 | 9 | 257 | 238 | 94
FIT 50-80, 3 | 7634 | 0 | 0 | 0 | 1059 | 1059 | 10 | 38 | 12 | 228 | 210 | 83
FIT 50-85, 1 | 18471 | 0 | 0 | 0 | 1788 | 1788 | 14 | 22 | 6 | 290 | 270 | 106
FIT 50-85, 2 | 11065 | 0 | 0 | 0 | 1339 | 1339 | 12 | 30 | 9 | 258 | 239 | 94
FIT 50-85, 3 | 8055 | 0 | 0 | 0 | 1096 | 1096 | 11 | 37 | 11 | 230 | 212 | 84
FIT 55-70, 1 | 10229 | 0 | 0 | 0 | 1249 | 1249 | 10 | 31 | 10 | 240 | 222 | 88
FIT 55-70, 2 | 5974 | 0 | 0 | 0 | 896 | 896 | 8 | 41 | 14 | 202 | 186 | 74
FIT 55-70, 3 | 4637 | 0 | 0 | 0 | 754 | 754 | 7 | 47 | 17 | 175 | 161 | 64
FIT 55-75, 1 | 12342 | 0 | 0 | 0 | 1394 | 1394 | 12 | 28 | 9 | 250 | 231 | 91
FIT 55-75, 2 | 7539 | 0 | 0 | 0 | 1043 | 1043 | 10 | 37 | 12 | 219 | 201 | 80
FIT 55-75, 3 | 5270 | 0 | 0 | 0 | 824 | 824 | 8 | 45 | 15 | 185 | 170 | 67
FIT 55-80, 1 | 14032 | 0 | 0 | 0 | 1499 | 1499 | 13 | 27 | 8 | 254 | 235 | 93
FIT 55-80, 2 | 8381 | 0 | 0 | 0 | 1114 | 1114 | 11 | 36 | 11 | 225 | 206 | 82
FIT 55-80, 3 | 6226 | 0 | 0 | 0 | 920 | 920 | 9 | 42 | 14 | 195 | 179 | 71
FIT 55-85, 1 | 15273 | 0 | 0 | 0 | 1568 | 1568 | 14 | 27 | 8 | 256 | 236 | 93
FIT 55-85, 2 | 9304 | 0 | 0 | 0 | 1182 | 1182 | 12 | 36 | 10 | 227 | 208 | 83
FIT 55-85, 3 | 6824 | 0 | 0 | 0 | 973 | 973 | 10 | 42 | 13 | 199 | 181 | 73

COL – colonoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.2c Estimated Outcomes for FIT Strategies: MISCAN

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 81 | 81 | 2 | 81 | 34 | 0 | 0 | 0
FIT 45-70, 1 | 17494 | 0 | 0 | 0 | 1498 | 1498 | 9 | 49 | 13 | 274 | 242 | 100
FIT 45-70, 2 | 10116 | 0 | 0 | 0 | 1052 | 1052 | 7 | 58 | 16 | 232 | 201 | 85
FIT 45-70, 3 | 7409 | 0 | 0 | 0 | 852 | 852 | 6 | 62 | 18 | 205 | 175 | 75
FIT 45-75, 1 | 19607 | 0 | 0 | 0 | 1620 | 1620 | 10 | 46 | 10 | 291 | 256 | 106
FIT 45-75, 2 | 11672 | 0 | 0 | 0 | 1172 | 1172 | 8 | 55 | 13 | 256 | 221 | 93
FIT 45-75, 3 | 8437 | 0 | 0 | 0 | 948 | 948 | 7 | 60 | 16 | 226 | 192 | 82
FIT 45-80, 1 | 21300 | 0 | 0 | 0 | 1710 | 1710 | 11 | 45 | 9 | 300 | 263 | 110
FIT 45-80, 2 | 12509 | 0 | 0 | 0 | 1230 | 1230 | 9 | 54 | 12 | 264 | 227 | 96
FIT 45-80, 3 | 8991 | 0 | 0 | 0 | 991 | 991 | 8 | 60 | 14 | 233 | 198 | 85
FIT 45-85, 1 | 22527 | 0 | 0 | 0 | 1769 | 1769 | 12 | 44 | 8 | 303 | 266 | 111
FIT 45-85, 2 | 13423 | 0 | 0 | 0 | 1288 | 1288 | 10 | 54 | 11 | 269 | 231 | 98
FIT 45-85, 3 | 9679 | 0 | 0 | 0 | 1043 | 1043 | 9 | 60 | 13 | 239 | 202 | 87
FIT 50-70, 1 | 13963 | 0 | 0 | 0 | 1319 | 1319 | 9 | 50 | 13 | 257 | 225 | 94
FIT 50-70, 2 | 8347 | 0 | 0 | 0 | 956 | 956 | 7 | 58 | 16 | 222 | 191 | 81
FIT 50-70, 3 | 5736 | 0 | 0 | 0 | 737 | 737 | 6 | 64 | 20 | 184 | 156 | 67
FIT 50-75, 1 | 16097 | 0 | 0 | 0 | 1445 | 1445 | 10 | 47 | 11 | 274 | 240 | 100
FIT 50-75, 2 | 9395 | 0 | 0 | 0 | 1038 | 1038 | 8 | 56 | 14 | 238 | 204 | 87
FIT 50-75, 3 | 6905 | 0 | 0 | 0 | 847 | 847 | 7 | 61 | 17 | 209 | 177 | 76
FIT 50-80, 1 | 17802 | 0 | 0 | 0 | 1537 | 1537 | 11 | 46 | 10 | 283 | 247 | 103
FIT 50-80, 2 | 10658 | 0 | 0 | 0 | 1127 | 1127 | 9 | 55 | 12 | 251 | 214 | 92
FIT 50-80, 3 | 7740 | 0 | 0 | 0 | 919 | 919 | 8 | 61 | 15 | 221 | 186 | 81
FIT 50-85, 1 | 19037 | 0 | 0 | 0 | 1597 | 1597 | 11 | 45 | 9 | 286 | 249 | 105
FIT 50-85, 2 | 11272 | 0 | 0 | 0 | 1166 | 1166 | 10 | 55 | 11 | 254 | 216 | 93
FIT 50-85, 3 | 8148 | 0 | 0 | 0 | 948 | 948 | 8 | 61 | 14 | 224 | 188 | 82
FIT 55-70, 1 | 10580 | 0 | 0 | 0 | 1118 | 1118 | 8 | 53 | 15 | 228 | 198 | 83
FIT 55-70, 2 | 6080 | 0 | 0 | 0 | 788 | 788 | 6 | 61 | 18 | 189 | 161 | 69
FIT 55-70, 3 | 4696 | 0 | 0 | 0 | 665 | 665 | 6 | 65 | 20 | 171 | 144 | 63
FIT 55-75, 1 | 12758 | 0 | 0 | 0 | 1253 | 1253 | 9 | 50 | 12 | 247 | 214 | 90
FIT 55-75, 2 | 7677 | 0 | 0 | 0 | 921 | 921 | 8 | 58 | 15 | 215 | 182 | 78
FIT 55-75, 3 | 5325 | 0 | 0 | 0 | 725 | 725 | 6 | 63 | 18 | 184 | 154 | 67
FIT 55-80, 1 | 14485 | 0 | 0 | 0 | 1348 | 1348 | 10 | 48 | 11 | 256 | 221 | 93
FIT 55-80, 2 | 8530 | 0 | 0 | 0 | 983 | 983 | 8 | 57 | 14 | 223 | 189 | 82
FIT 55-80, 3 | 6288 | 0 | 0 | 0 | 810 | 810 | 7 | 62 | 16 | 199 | 165 | 73
FIT 55-85, 1 | 15731 | 0 | 0 | 0 | 1410 | 1410 | 11 | 48 | 10 | 259 | 224 | 95
FIT 55-85, 2 | 9459 | 0 | 0 | 0 | 1044 | 1044 | 9 | 57 | 12 | 229 | 193 | 84
FIT 55-85, 3 | 6897 | 0 | 0 | 0 | 858 | 858 | 8 | 63 | 15 | 204 | 169 | 74

COL – colonoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.3a Estimated Outcomes for sDNA-FIT Strategies: SimCRC

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 85 | 85 | 2 | 85 | 34 | 0 | 0 | 0
sDNA-FIT 45-70, 1 | 12498 | 0 | 0 | 0 | 2258 | 2258 | 10 | 22 | 6 | 354 | 329 | 129
sDNA-FIT 45-70, 2 | 8354 | 0 | 0 | 0 | 1708 | 1708 | 9 | 28 | 7 | 338 | 313 | 123
sDNA-FIT 45-70, 3 | 6548 | 0 | 0 | 0 | 1442 | 1442 | 8 | 33 | 9 | 322 | 297 | 118
sDNA-FIT 45-75, 1 | 13888 | 0 | 0 | 0 | 2462 | 2462 | 12 | 19 | 4 | 363 | 337 | 133
sDNA-FIT 45-75, 2 | 9543 | 0 | 0 | 0 | 1910 | 1910 | 10 | 24 | 5 | 352 | 325 | 129
sDNA-FIT 45-75, 3 | 7274 | 0 | 0 | 0 | 1582 | 1582 | 9 | 30 | 7 | 335 | 308 | 122
sDNA-FIT 45-80, 1 | 14966 | 0 | 0 | 0 | 2614 | 2614 | 13 | 17 | 4 | 367 | 340 | 134
sDNA-FIT 45-80, 2 | 10167 | 0 | 0 | 0 | 2012 | 2012 | 11 | 23 | 5 | 356 | 329 | 130
sDNA-FIT 45-80, 3 | 7852 | 0 | 0 | 0 | 1684 | 1684 | 10 | 28 | 6 | 342 | 313 | 125
sDNA-FIT 45-85, 1 | 15721 | 0 | 0 | 0 | 2713 | 2713 | 14 | 17 | 3 | 368 | 341 | 134
sDNA-FIT 45-85, 2 | 10828 | 0 | 0 | 0 | 2114 | 2114 | 13 | 22 | 4 | 358 | 330 | 131
sDNA-FIT 45-85, 3 | 8347 | 0 | 0 | 0 | 1770 | 1770 | 12 | 28 | 5 | 344 | 315 | 126
sDNA-FIT 50-70, 1 | 10087 | 0 | 0 | 0 | 1953 | 1953 | 10 | 25 | 7 | 321 | 298 | 117
sDNA-FIT 50-70, 2 | 6929 | 0 | 0 | 0 | 1520 | 1520 | 9 | 31 | 8 | 307 | 283 | 112
sDNA-FIT 50-70, 3 | 5122 | 0 | 0 | 0 | 1221 | 1221 | 7 | 38 | 11 | 286 | 262 | 104
sDNA-FIT 50-75, 1 | 11463 | 0 | 0 | 0 | 2156 | 2156 | 11 | 22 | 6 | 330 | 305 | 121
sDNA-FIT 50-75, 2 | 7728 | 0 | 0 | 0 | 1659 | 1659 | 10 | 29 | 7 | 317 | 292 | 116
sDNA-FIT 50-75, 3 | 6074 | 0 | 0 | 0 | 1405 | 1405 | 9 | 34 | 8 | 304 | 278 | 111
sDNA-FIT 50-80, 1 | 12548 | 0 | 0 | 0 | 2310 | 2310 | 13 | 21 | 5 | 334 | 308 | 122
sDNA-FIT 50-80, 2 | 8668 | 0 | 0 | 0 | 1813 | 1813 | 12 | 26 | 6 | 324 | 297 | 118
sDNA-FIT 50-80, 3 | 6652 | 0 | 0 | 0 | 1513 | 1513 | 10 | 32 | 7 | 311 | 283 | 113
sDNA-FIT 50-85, 1 | 13305 | 0 | 0 | 0 | 2410 | 2410 | 14 | 20 | 4 | 335 | 309 | 122
sDNA-FIT 50-85, 2 | 9110 | 0 | 0 | 0 | 1881 | 1881 | 13 | 26 | 5 | 325 | 298 | 119
sDNA-FIT 50-85, 3 | 7066 | 0 | 0 | 0 | 1582 | 1582 | 11 | 32 | 6 | 313 | 285 | 114
sDNA-FIT 55-70, 1 | 7737 | 0 | 0 | 0 | 1633 | 1633 | 10 | 31 | 9 | 280 | 257 | 102
sDNA-FIT 55-70, 2 | 5122 | 0 | 0 | 0 | 1237 | 1237 | 8 | 38 | 11 | 262 | 240 | 96
sDNA-FIT 55-70, 3 | 4121 | 0 | 0 | 0 | 1070 | 1070 | 7 | 42 | 12 | 250 | 227 | 91
sDNA-FIT 55-75, 1 | 9171 | 0 | 0 | 0 | 1849 | 1849 | 11 | 28 | 7 | 289 | 265 | 106
sDNA-FIT 55-75, 2 | 6340 | 0 | 0 | 0 | 1452 | 1452 | 10 | 33 | 8 | 278 | 254 | 102
sDNA-FIT 55-75, 3 | 4730 | 0 | 0 | 0 | 1187 | 1187 | 8 | 39 | 10 | 262 | 237 | 96
sDNA-FIT 55-80, 1 | 10246 | 0 | 0 | 0 | 2002 | 2002 | 13 | 26 | 7 | 293 | 269 | 107
sDNA-FIT 55-80, 2 | 6973 | 0 | 0 | 0 | 1558 | 1558 | 11 | 32 | 8 | 283 | 258 | 103
sDNA-FIT 55-80, 3 | 5493 | 0 | 0 | 0 | 1331 | 1331 | 10 | 37 | 9 | 271 | 245 | 99
sDNA-FIT 55-85, 1 | 11009 | 0 | 0 | 0 | 2104 | 2104 | 14 | 26 | 6 | 294 | 269 | 107
sDNA-FIT 55-85, 2 | 7641 | 0 | 0 | 0 | 1662 | 1662 | 13 | 31 | 7 | 285 | 259 | 104
sDNA-FIT 55-85, 3 | 5905 | 0 | 0 | 0 | 1403 | 1403 | 11 | 37 | 8 | 273 | 247 | 100

COL – colonoscopy; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.3b Estimated Outcomes for sDNA-FIT Strategies: CRC-SPIN

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 77 | 77 | 2 | 77 | 32 | 0 | 0 | 0
sDNA-FIT 45-70, 1 | 12107 | 0 | 0 | 0 | 2433 | 2433 | 13 | 17 | 5 | 326 | 305 | 119
sDNA-FIT 45-70, 2 | 8128 | 0 | 0 | 0 | 1908 | 1908 | 12 | 21 | 7 | 310 | 290 | 113
sDNA-FIT 45-70, 3 | 6400 | 0 | 0 | 0 | 1647 | 1647 | 11 | 25 | 8 | 293 | 274 | 107
sDNA-FIT 45-75, 1 | 13494 | 0 | 0 | 0 | 2617 | 2617 | 14 | 15 | 5 | 331 | 309 | 121
sDNA-FIT 45-75, 2 | 9298 | 0 | 0 | 0 | 2089 | 2089 | 13 | 19 | 6 | 319 | 298 | 116
sDNA-FIT 45-75, 3 | 7105 | 0 | 0 | 0 | 1772 | 1772 | 12 | 23 | 7 | 301 | 281 | 110
sDNA-FIT 45-80, 1 | 14608 | 0 | 0 | 0 | 2758 | 2758 | 15 | 14 | 4 | 333 | 311 | 122
sDNA-FIT 45-80, 2 | 9928 | 0 | 0 | 0 | 2181 | 2181 | 14 | 18 | 5 | 322 | 300 | 118
sDNA-FIT 45-80, 3 | 7688 | 0 | 0 | 0 | 1866 | 1866 | 13 | 21 | 6 | 305 | 285 | 111
sDNA-FIT 45-85, 1 | 15424 | 0 | 0 | 0 | 2856 | 2856 | 16 | 14 | 4 | 334 | 312 | 122
sDNA-FIT 45-85, 2 | 10620 | 0 | 0 | 0 | 2275 | 2275 | 15 | 17 | 5 | 323 | 301 | 118
sDNA-FIT 45-85, 3 | 8193 | 0 | 0 | 0 | 1944 | 1944 | 14 | 21 | 6 | 307 | 286 | 112
sDNA-FIT 50-70, 1 | 9760 | 0 | 0 | 0 | 2111 | 2111 | 13 | 19 | 7 | 296 | 277 | 108
sDNA-FIT 50-70, 2 | 6740 | 0 | 0 | 0 | 1698 | 1698 | 12 | 24 | 8 | 281 | 262 | 102
sDNA-FIT 50-70, 3 | 5011 | 0 | 0 | 0 | 1407 | 1407 | 10 | 29 | 10 | 260 | 243 | 95
sDNA-FIT 50-75, 1 | 11132 | 0 | 0 | 0 | 2295 | 2295 | 14 | 18 | 6 | 301 | 281 | 110
sDNA-FIT 50-75, 2 | 7525 | 0 | 0 | 0 | 1822 | 1822 | 13 | 22 | 7 | 287 | 268 | 105
sDNA-FIT 50-75, 3 | 5939 | 0 | 0 | 0 | 1576 | 1576 | 12 | 26 | 8 | 271 | 253 | 99
sDNA-FIT 50-80, 1 | 12255 | 0 | 0 | 0 | 2438 | 2438 | 15 | 17 | 5 | 303 | 283 | 111
sDNA-FIT 50-80, 2 | 8474 | 0 | 0 | 0 | 1961 | 1961 | 14 | 21 | 6 | 290 | 271 | 106
sDNA-FIT 50-80, 3 | 6510 | 0 | 0 | 0 | 1672 | 1672 | 13 | 25 | 8 | 276 | 257 | 101
sDNA-FIT 50-85, 1 | 13073 | 0 | 0 | 0 | 2537 | 2537 | 16 | 17 | 5 | 304 | 284 | 111
sDNA-FIT 50-85, 2 | 8937 | 0 | 0 | 0 | 2025 | 2025 | 15 | 20 | 6 | 291 | 272 | 106
sDNA-FIT 50-85, 3 | 6941 | 0 | 0 | 0 | 1737 | 1737 | 14 | 24 | 7 | 278 | 258 | 101
sDNA-FIT 55-70, 1 | 7485 | 0 | 0 | 0 | 1769 | 1769 | 12 | 24 | 8 | 262 | 244 | 96
sDNA-FIT 55-70, 2 | 4987 | 0 | 0 | 0 | 1390 | 1390 | 11 | 30 | 10 | 244 | 227 | 89
sDNA-FIT 55-70, 3 | 4029 | 0 | 0 | 0 | 1219 | 1219 | 10 | 33 | 11 | 229 | 212 | 83
sDNA-FIT 55-75, 1 | 8911 | 0 | 0 | 0 | 1964 | 1964 | 13 | 22 | 7 | 268 | 249 | 98
sDNA-FIT 55-75, 2 | 6183 | 0 | 0 | 0 | 1587 | 1587 | 12 | 27 | 8 | 255 | 236 | 93
sDNA-FIT 55-75, 3 | 4633 | 0 | 0 | 0 | 1332 | 1332 | 11 | 31 | 10 | 237 | 219 | 87
sDNA-FIT 55-80, 1 | 10021 | 0 | 0 | 0 | 2107 | 2107 | 15 | 21 | 7 | 270 | 251 | 99
sDNA-FIT 55-80, 2 | 6820 | 0 | 0 | 0 | 1683 | 1683 | 13 | 26 | 8 | 258 | 239 | 94
sDNA-FIT 55-80, 3 | 5391 | 0 | 0 | 0 | 1463 | 1463 | 12 | 29 | 9 | 243 | 225 | 89
sDNA-FIT 55-85, 1 | 10845 | 0 | 0 | 0 | 2207 | 2207 | 16 | 21 | 7 | 271 | 251 | 99
sDNA-FIT 55-85, 2 | 7517 | 0 | 0 | 0 | 1779 | 1779 | 14 | 25 | 8 | 260 | 240 | 95
sDNA-FIT 55-85, 3 | 5809 | 0 | 0 | 0 | 1529 | 1529 | 13 | 29 | 9 | 245 | 226 | 89

COL – colonoscopy; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.3c Estimated Outcomes for sDNA-FIT Strategies: MISCAN

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 81 | 81 | 2 | 81 | 34 | 0 | 0 | 0
sDNA-FIT 45-70, 1 | 12364 | 0 | 0 | 0 | 2346 | 2346 | 11 | 41 | 10 | 295 | 263 | 108
sDNA-FIT 45-70, 2 | 8285 | 0 | 0 | 0 | 1785 | 1785 | 9 | 47 | 13 | 274 | 243 | 100
sDNA-FIT 45-70, 3 | 6493 | 0 | 0 | 0 | 1507 | 1507 | 9 | 51 | 14 | 257 | 225 | 94
sDNA-FIT 45-75, 1 | 13698 | 0 | 0 | 0 | 2515 | 2515 | 12 | 38 | 9 | 306 | 272 | 112
sDNA-FIT 45-75, 2 | 9435 | 0 | 0 | 0 | 1954 | 1954 | 11 | 44 | 10 | 292 | 258 | 107
sDNA-FIT 45-75, 3 | 7204 | 0 | 0 | 0 | 1629 | 1629 | 10 | 49 | 12 | 273 | 239 | 100
sDNA-FIT 45-80, 1 | 14753 | 0 | 0 | 0 | 2641 | 2641 | 13 | 37 | 8 | 311 | 277 | 114
sDNA-FIT 45-80, 2 | 10046 | 0 | 0 | 0 | 2037 | 2037 | 12 | 43 | 9 | 298 | 262 | 109
sDNA-FIT 45-80, 3 | 7760 | 0 | 0 | 0 | 1709 | 1709 | 10 | 48 | 10 | 280 | 244 | 102
sDNA-FIT 45-85, 1 | 15513 | 0 | 0 | 0 | 2727 | 2727 | 14 | 36 | 8 | 313 | 278 | 114
sDNA-FIT 45-85, 2 | 10707 | 0 | 0 | 0 | 2121 | 2121 | 13 | 42 | 8 | 301 | 265 | 110
sDNA-FIT 45-85, 3 | 8255 | 0 | 0 | 0 | 1780 | 1780 | 11 | 47 | 10 | 284 | 247 | 104
sDNA-FIT 50-70, 1 | 9988 | 0 | 0 | 0 | 2040 | 2040 | 11 | 42 | 11 | 279 | 247 | 102
sDNA-FIT 50-70, 2 | 6868 | 0 | 0 | 0 | 1592 | 1592 | 9 | 48 | 13 | 262 | 230 | 96
sDNA-FIT 50-70, 3 | 5080 | 0 | 0 | 0 | 1291 | 1291 | 8 | 53 | 15 | 235 | 205 | 86
sDNA-FIT 50-75, 1 | 11315 | 0 | 0 | 0 | 2211 | 2211 | 12 | 39 | 9 | 290 | 257 | 106
sDNA-FIT 50-75, 2 | 7642 | 0 | 0 | 0 | 1708 | 1708 | 10 | 46 | 11 | 274 | 241 | 100
sDNA-FIT 50-75, 3 | 6006 | 0 | 0 | 0 | 1449 | 1449 | 9 | 50 | 12 | 257 | 223 | 94
sDNA-FIT 50-80, 1 | 12379 | 0 | 0 | 0 | 2339 | 2339 | 13 | 38 | 9 | 296 | 261 | 108
sDNA-FIT 50-80, 2 | 8565 | 0 | 0 | 0 | 1836 | 1836 | 12 | 44 | 9 | 283 | 248 | 104
sDNA-FIT 50-80, 3 | 6579 | 0 | 0 | 0 | 1540 | 1540 | 10 | 49 | 11 | 265 | 230 | 97
sDNA-FIT 50-85, 1 | 13142 | 0 | 0 | 0 | 2425 | 2425 | 14 | 38 | 8 | 297 | 263 | 109
sDNA-FIT 50-85, 2 | 9009 | 0 | 0 | 0 | 1892 | 1892 | 12 | 44 | 9 | 286 | 250 | 104
sDNA-FIT 50-85, 3 | 6984 | 0 | 0 | 0 | 1595 | 1595 | 11 | 49 | 10 | 268 | 232 | 98
sDNA-FIT 55-70, 1 | 7698 | 0 | 0 | 0 | 1714 | 1714 | 11 | 45 | 12 | 251 | 221 | 92
sDNA-FIT 55-70, 2 | 5092 | 0 | 0 | 0 | 1306 | 1306 | 9 | 51 | 14 | 229 | 200 | 84
sDNA-FIT 55-70, 3 | 4099 | 0 | 0 | 0 | 1133 | 1133 | 8 | 55 | 16 | 216 | 186 | 79
sDNA-FIT 55-75, 1 | 9090 | 0 | 0 | 0 | 1897 | 1897 | 12 | 42 | 10 | 264 | 232 | 96
sDNA-FIT 55-75, 2 | 6283 | 0 | 0 | 0 | 1492 | 1492 | 10 | 48 | 12 | 249 | 217 | 91
sDNA-FIT 55-75, 3 | 4684 | 0 | 0 | 0 | 1232 | 1232 | 9 | 53 | 14 | 229 | 197 | 84
sDNA-FIT 55-80, 1 | 10153 | 0 | 0 | 0 | 2027 | 2027 | 13 | 40 | 9 | 269 | 236 | 98
sDNA-FIT 55-80, 2 | 6907 | 0 | 0 | 0 | 1580 | 1580 | 11 | 46 | 11 | 255 | 222 | 93
sDNA-FIT 55-80, 3 | 5436 | 0 | 0 | 0 | 1352 | 1352 | 10 | 51 | 12 | 240 | 206 | 88
sDNA-FIT 55-85, 1 | 10924 | 0 | 0 | 0 | 2115 | 2115 | 14 | 40 | 9 | 271 | 238 | 99
sDNA-FIT 55-85, 2 | 7580 | 0 | 0 | 0 | 1667 | 1667 | 12 | 46 | 10 | 259 | 224 | 94
sDNA-FIT 55-85, 3 | 5853 | 0 | 0 | 0 | 1413 | 1413 | 11 | 51 | 11 | 243 | 209 | 89

COL – colonoscopy; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.4a Estimated Outcomes for Sigmoidoscopy Strategies: SimCRC

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 85 | 85 | 2 | 85 | 34 | 0 | 0 | 0
SIG 45-70, 5 | 0 | 4402 | 0 | 0 | 1592 | 1592 | 9 | 28 | 9 | 302 | 284 | 110
SIG 45-70, 10 | 0 | 2622 | 0 | 0 | 1155 | 1155 | 7 | 37 | 13 | 262 | 246 | 96
SIG 45-75, 5 | 0 | 4846 | 0 | 0 | 1720 | 1720 | 10 | 25 | 8 | 309 | 289 | 113
SIG 45-75, 10 | 0 | 3173 | 0 | 0 | 1360 | 1360 | 9 | 32 | 10 | 278 | 260 | 101
SIG 45-80, 5 | 0 | 5185 | 0 | 0 | 1809 | 1809 | 11 | 24 | 7 | 311 | 291 | 114
SIG 45-80, 10 | 0 | 3173 | 0 | 0 | 1360 | 1360 | 9 | 32 | 10 | 278 | 260 | 101
SIG 45-85, 5 | 0 | 5414 | 0 | 0 | 1864 | 1864 | 12 | 24 | 7 | 312 | 292 | 114
SIG 45-85, 10 | 0 | 3463 | 0 | 0 | 1449 | 1449 | 11 | 32 | 10 | 279 | 261 | 102
SIG 50-70, 5 | 0 | 3611 | 0 | 0 | 1414 | 1414 | 9 | 31 | 10 | 272 | 254 | 99
SIG 50-70, 10 | 0 | 2465 | 0 | 0 | 1138 | 1138 | 8 | 37 | 13 | 247 | 230 | 90
SIG 50-75, 5 | 0 | 4058 | 0 | 0 | 1544 | 1544 | 10 | 29 | 9 | 279 | 260 | 102
SIG 50-75, 10 | 0 | 2465 | 0 | 0 | 1138 | 1138 | 8 | 37 | 13 | 247 | 230 | 90
SIG 50-80, 5 | 0 | 4399 | 0 | 0 | 1634 | 1634 | 11 | 28 | 9 | 282 | 262 | 103
SIG 50-80, 10 | 0 | 2894 | 0 | 0 | 1282 | 1282 | 10 | 34 | 11 | 253 | 235 | 92
SIG 50-85, 5 | 0 | 4629 | 0 | 0 | 1690 | 1690 | 12 | 28 | 8 | 282 | 263 | 103
SIG 50-85, 10 | 0 | 2894 | 0 | 0 | 1282 | 1282 | 10 | 34 | 11 | 253 | 235 | 92
SIG 55-70, 5 | 0 | 2851 | 0 | 0 | 1224 | 1224 | 8 | 36 | 12 | 235 | 218 | 86
SIG 55-70, 10 | 0 | 1708 | 0 | 0 | 907 | 907 | 7 | 45 | 16 | 204 | 189 | 74
SIG 55-75, 5 | 0 | 3302 | 0 | 0 | 1357 | 1357 | 10 | 34 | 11 | 242 | 224 | 88
SIG 55-75, 10 | 0 | 2267 | 0 | 0 | 1118 | 1118 | 9 | 39 | 13 | 220 | 203 | 80
SIG 55-80, 5 | 0 | 3647 | 0 | 0 | 1449 | 1449 | 11 | 33 | 10 | 244 | 226 | 89
SIG 55-80, 10 | 0 | 2267 | 0 | 0 | 1118 | 1118 | 9 | 39 | 13 | 220 | 203 | 80
SIG 55-85, 5 | 0 | 3878 | 0 | 0 | 1505 | 1505 | 12 | 32 | 10 | 245 | 227 | 90
SIG 55-85, 10 | 0 | 2559 | 0 | 0 | 1208 | 1208 | 11 | 39 | 13 | 221 | 205 | 81

COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.4b Estimated Outcomes for Sigmoidoscopy Strategies: CRC-SPIN

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 77 | 77 | 2 | 77 | 32 | 0 | 0 | 0
SIG 45-70, 5 | 0 | 4446 | 0 | 0 | 1586 | 1586 | 11 | 25 | 9 | 277 | 261 | 101
SIG 45-70, 10 | 0 | 2604 | 0 | 0 | 1260 | 1260 | 9 | 29 | 11 | 259 | 245 | 95
SIG 45-75, 5 | 0 | 4935 | 0 | 0 | 1680 | 1680 | 12 | 24 | 9 | 280 | 264 | 102
SIG 45-75, 10 | 0 | 3169 | 0 | 0 | 1411 | 1411 | 11 | 26 | 9 | 268 | 252 | 98
SIG 45-80, 5 | 0 | 5326 | 0 | 0 | 1749 | 1749 | 12 | 23 | 8 | 281 | 265 | 103
SIG 45-80, 10 | 0 | 3169 | 0 | 0 | 1411 | 1411 | 11 | 26 | 9 | 268 | 252 | 98
SIG 45-85, 5 | 0 | 5602 | 0 | 0 | 1793 | 1793 | 13 | 23 | 8 | 282 | 265 | 103
SIG 45-85, 10 | 0 | 3487 | 0 | 0 | 1479 | 1479 | 12 | 26 | 9 | 269 | 253 | 98
SIG 50-70, 5 | 0 | 3644 | 0 | 0 | 1415 | 1415 | 10 | 27 | 10 | 253 | 238 | 92
SIG 50-70, 10 | 0 | 2454 | 0 | 0 | 1217 | 1217 | 10 | 29 | 11 | 240 | 227 | 88
SIG 50-75, 5 | 0 | 4134 | 0 | 0 | 1510 | 1510 | 11 | 26 | 9 | 256 | 241 | 94
SIG 50-75, 10 | 0 | 2454 | 0 | 0 | 1217 | 1217 | 10 | 29 | 11 | 240 | 227 | 88
SIG 50-80, 5 | 0 | 4525 | 0 | 0 | 1579 | 1579 | 12 | 25 | 9 | 258 | 243 | 94
SIG 50-80, 10 | 0 | 2906 | 0 | 0 | 1324 | 1324 | 12 | 28 | 10 | 243 | 230 | 89
SIG 50-85, 5 | 0 | 4801 | 0 | 0 | 1624 | 1624 | 13 | 25 | 9 | 258 | 243 | 94
SIG 50-85, 10 | 0 | 2906 | 0 | 0 | 1324 | 1324 | 12 | 28 | 10 | 243 | 230 | 89
SIG 55-70, 5 | 0 | 2873 | 0 | 0 | 1228 | 1228 | 10 | 31 | 11 | 225 | 211 | 82
SIG 55-70, 10 | 0 | 1699 | 0 | 0 | 995 | 995 | 9 | 35 | 13 | 210 | 197 | 77
SIG 55-75, 5 | 0 | 3364 | 0 | 0 | 1325 | 1325 | 11 | 29 | 11 | 229 | 214 | 84
SIG 55-75, 10 | 0 | 2268 | 0 | 0 | 1153 | 1153 | 11 | 31 | 11 | 219 | 206 | 80
SIG 55-80, 5 | 0 | 3756 | 0 | 0 | 1395 | 1395 | 12 | 29 | 10 | 230 | 216 | 84
SIG 55-80, 10 | 0 | 2268 | 0 | 0 | 1153 | 1153 | 11 | 31 | 11 | 219 | 206 | 80
SIG 55-85, 5 | 0 | 4032 | 0 | 0 | 1439 | 1439 | 13 | 28 | 10 | 231 | 216 | 84
SIG 55-85, 10 | 0 | 2587 | 0 | 0 | 1221 | 1221 | 12 | 31 | 11 | 221 | 207 | 81

COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.4c Estimated Outcomes for Sigmoidoscopy Strategies: MISCAN

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 81 | 81 | 2 | 81 | 34 | 0 | 0 | 0
SIG 45-70, 5 | 0 | 4013 | 0 | 0 | 2020 | 2020 | 11 | 40 | 12 | 263 | 237 | 96
SIG 45-70, 10 | 0 | 2480 | 0 | 0 | 1635 | 1635 | 10 | 45 | 14 | 234 | 210 | 85
SIG 45-75, 5 | 0 | 4389 | 0 | 0 | 2119 | 2119 | 12 | 39 | 11 | 269 | 241 | 98
SIG 45-75, 10 | 0 | 2946 | 0 | 0 | 1800 | 1800 | 12 | 43 | 12 | 245 | 220 | 90
SIG 45-80, 5 | 0 | 4681 | 0 | 0 | 2196 | 2196 | 13 | 38 | 10 | 271 | 244 | 99
SIG 45-80, 10 | 0 | 2946 | 0 | 0 | 1800 | 1800 | 12 | 43 | 12 | 245 | 220 | 90
SIG 45-85, 5 | 0 | 4877 | 0 | 0 | 2235 | 2235 | 13 | 38 | 10 | 272 | 244 | 99
SIG 45-85, 10 | 0 | 3193 | 0 | 0 | 1869 | 1869 | 13 | 42 | 12 | 247 | 221 | 90
SIG 50-70, 5 | 0 | 3268 | 0 | 0 | 1826 | 1826 | 11 | 41 | 12 | 251 | 225 | 92
SIG 50-70, 10 | 0 | 2297 | 0 | 0 | 1581 | 1581 | 10 | 44 | 14 | 233 | 208 | 85
SIG 50-75, 5 | 0 | 3646 | 0 | 0 | 1927 | 1927 | 12 | 40 | 11 | 256 | 229 | 93
SIG 50-75, 10 | 0 | 2297 | 0 | 0 | 1581 | 1581 | 10 | 44 | 14 | 233 | 208 | 85
SIG 50-80, 5 | 0 | 3939 | 0 | 0 | 2004 | 2004 | 13 | 39 | 11 | 259 | 231 | 94
SIG 50-80, 10 | 0 | 2660 | 0 | 0 | 1704 | 1704 | 12 | 43 | 12 | 238 | 212 | 87
SIG 50-85, 5 | 0 | 4136 | 0 | 0 | 2044 | 2044 | 13 | 39 | 11 | 259 | 231 | 95
SIG 50-85, 10 | 0 | 2660 | 0 | 0 | 1704 | 1704 | 12 | 43 | 12 | 238 | 212 | 87
SIG 55-70, 5 | 0 | 2578 | 0 | 0 | 1608 | 1608 | 11 | 43 | 13 | 228 | 203 | 83
SIG 55-70, 10 | 0 | 1623 | 0 | 0 | 1340 | 1340 | 10 | 48 | 16 | 204 | 182 | 75
SIG 55-75, 5 | 0 | 2960 | 0 | 0 | 1711 | 1711 | 12 | 42 | 12 | 234 | 208 | 85
SIG 55-75, 10 | 0 | 2094 | 0 | 0 | 1513 | 1513 | 11 | 45 | 14 | 217 | 192 | 79
SIG 55-80, 5 | 0 | 3255 | 0 | 0 | 1790 | 1790 | 13 | 41 | 12 | 237 | 210 | 86
SIG 55-80, 10 | 0 | 2094 | 0 | 0 | 1513 | 1513 | 11 | 45 | 14 | 217 | 192 | 79
SIG 55-85, 5 | 0 | 3453 | 0 | 0 | 1831 | 1831 | 13 | 41 | 12 | 237 | 210 | 87
SIG 55-85, 10 | 0 | 2343 | 0 | 0 | 1583 | 1583 | 13 | 45 | 13 | 218 | 193 | 80

COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.5a Estimated Outcomes for 10-Yearly Sigmoidoscopy Plus Interval FIT Strategies: SimCRC

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 85 | 85 | 2 | 85 | 34 | 0 | 0 | 0
SIG+FIT 45-70, 10_1 | 14876 | 2264 | 0 | 0 | 1903 | 1903 | 10 | 22 | 6 | 353 | 329 | 129
SIG+FIT 45-70, 10_2 | 8643 | 2362 | 0 | 0 | 1617 | 1617 | 9 | 26 | 7 | 340 | 316 | 124
SIG+FIT 45-75, 10_1 | 16648 | 2568 | 0 | 0 | 2102 | 2102 | 11 | 18 | 4 | 363 | 338 | 133
SIG+FIT 45-75, 10_2 | 9936 | 2757 | 0 | 0 | 1835 | 1835 | 11 | 22 | 5 | 354 | 329 | 129
SIG+FIT 45-80, 10_1 | 17986 | 2664 | 0 | 0 | 2203 | 2203 | 12 | 17 | 4 | 366 | 340 | 134
SIG+FIT 45-80, 10_2 | 10569 | 2806 | 0 | 0 | 1889 | 1889 | 11 | 21 | 4 | 357 | 331 | 130
SIG+FIT 45-85, 10_1 | 18952 | 2812 | 0 | 0 | 2293 | 2293 | 14 | 17 | 3 | 367 | 341 | 134
SIG+FIT 45-85, 10_2 | 11283 | 3003 | 0 | 0 | 1988 | 1988 | 13 | 20 | 4 | 358 | 332 | 131
SIG+FIT 50-70, 10_1 | 11821 | 2005 | 0 | 0 | 1714 | 1714 | 10 | 24 | 7 | 324 | 301 | 118
SIG+FIT 50-70, 10_2 | 7125 | 2152 | 0 | 0 | 1512 | 1512 | 9 | 27 | 7 | 314 | 291 | 115
SIG+FIT 50-75, 10_1 | 13537 | 2099 | 0 | 0 | 1840 | 1840 | 11 | 22 | 6 | 330 | 306 | 121
SIG+FIT 50-75, 10_2 | 7932 | 2196 | 0 | 0 | 1579 | 1579 | 10 | 26 | 7 | 320 | 296 | 117
SIG+FIT 50-80, 10_1 | 14921 | 2331 | 0 | 0 | 1986 | 1986 | 13 | 21 | 5 | 335 | 310 | 122
SIG+FIT 50-80, 10_2 | 8949 | 2498 | 0 | 0 | 1738 | 1738 | 12 | 24 | 5 | 326 | 301 | 119
SIG+FIT 50-85, 10_1 | 15864 | 2398 | 0 | 0 | 2052 | 2052 | 13 | 20 | 5 | 335 | 310 | 122
SIG+FIT 50-85, 10_2 | 9398 | 2532 | 0 | 0 | 1774 | 1774 | 12 | 24 | 5 | 327 | 301 | 119
SIG+FIT 55-70, 10_1 | 8842 | 1498 | 0 | 0 | 1432 | 1432 | 9 | 31 | 9 | 278 | 257 | 102
SIG+FIT 55-70, 10_2 | 5139 | 1547 | 0 | 0 | 1230 | 1230 | 8 | 35 | 10 | 266 | 245 | 97
SIG+FIT 55-75, 10_1 | 10651 | 1830 | 0 | 0 | 1650 | 1650 | 11 | 27 | 7 | 290 | 267 | 106
SIG+FIT 55-75, 10_2 | 6459 | 1962 | 0 | 0 | 1465 | 1465 | 11 | 30 | 8 | 282 | 259 | 103
SIG+FIT 55-80, 10_1 | 11994 | 1903 | 0 | 0 | 1745 | 1745 | 12 | 26 | 7 | 293 | 269 | 107
SIG+FIT 55-80, 10_2 | 7095 | 1997 | 0 | 0 | 1516 | 1516 | 11 | 29 | 7 | 285 | 261 | 104
SIG+FIT 55-85, 10_1 | 12970 | 2060 | 0 | 0 | 1838 | 1838 | 14 | 26 | 6 | 294 | 270 | 107
SIG+FIT 55-85, 10_2 | 7817 | 2200 | 0 | 0 | 1617 | 1617 | 13 | 29 | 7 | 287 | 262 | 105

COL – colonoscopy; SIG – sigmoidoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.5b Estimated Outcomes for 10-Yearly Sigmoidoscopy Plus Interval FIT Strategies: CRC-SPIN

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 77 | 77 | 2 | 77 | 32 | 0 | 0 | 0
SIG+FIT 45-70, 10_1 | 14529 | 2219 | 0 | 0 | 2072 | 2072 | 13 | 17 | 6 | 324 | 304 | 118
SIG+FIT 45-70, 10_2 | 8503 | 2318 | 0 | 0 | 1779 | 1779 | 12 | 20 | 7 | 313 | 294 | 114
SIG+FIT 45-75, 10_1 | 16322 | 2525 | 0 | 0 | 2237 | 2237 | 14 | 15 | 5 | 330 | 309 | 120
SIG+FIT 45-75, 10_2 | 9813 | 2717 | 0 | 0 | 1955 | 1955 | 13 | 18 | 5 | 321 | 301 | 117
SIG+FIT 45-80, 10_1 | 17752 | 2628 | 0 | 0 | 2331 | 2331 | 15 | 15 | 4 | 332 | 311 | 121
SIG+FIT 45-80, 10_2 | 10493 | 2770 | 0 | 0 | 2008 | 2008 | 14 | 17 | 5 | 323 | 303 | 118
SIG+FIT 45-85, 10_1 | 18818 | 2791 | 0 | 0 | 2413 | 2413 | 16 | 14 | 4 | 333 | 312 | 122
SIG+FIT 45-85, 10_2 | 11272 | 2985 | 0 | 0 | 2094 | 2094 | 15 | 17 | 5 | 324 | 304 | 118
SIG+FIT 50-70, 10_1 | 11534 | 1967 | 0 | 0 | 1854 | 1854 | 13 | 19 | 7 | 296 | 278 | 108
SIG+FIT 50-70, 10_2 | 7006 | 2115 | 0 | 0 | 1643 | 1643 | 12 | 22 | 7 | 287 | 269 | 105
SIG+FIT 50-75, 10_1 | 13305 | 2067 | 0 | 0 | 1973 | 1973 | 13 | 18 | 6 | 301 | 282 | 110
SIG+FIT 50-75, 10_2 | 7842 | 2163 | 0 | 0 | 1708 | 1708 | 12 | 21 | 7 | 290 | 272 | 106
SIG+FIT 50-80, 10_1 | 14761 | 2310 | 0 | 0 | 2098 | 2098 | 15 | 17 | 5 | 304 | 284 | 111
SIG+FIT 50-80, 10_2 | 8909 | 2479 | 0 | 0 | 1840 | 1840 | 14 | 19 | 6 | 294 | 276 | 108
SIG+FIT 50-85, 10_1 | 15814 | 2386 | 0 | 0 | 2163 | 2163 | 15 | 17 | 5 | 304 | 285 | 111
SIG+FIT 50-85, 10_2 | 9411 | 2518 | 0 | 0 | 1877 | 1877 | 14 | 19 | 6 | 295 | 277 | 108
SIG+FIT 55-70, 10_1 | 8652 | 1475 | 0 | 0 | 1561 | 1561 | 12 | 24 | 8 | 262 | 245 | 96
SIG+FIT 55-70, 10_2 | 5065 | 1523 | 0 | 0 | 1357 | 1357 | 11 | 27 | 9 | 252 | 236 | 92
SIG+FIT 55-75, 10_1 | 10476 | 1809 | 0 | 0 | 1741 | 1741 | 13 | 22 | 7 | 269 | 251 | 98
SIG+FIT 55-75, 10_2 | 6396 | 1942 | 0 | 0 | 1548 | 1548 | 13 | 24 | 8 | 262 | 244 | 96
SIG+FIT 55-80, 10_1 | 11917 | 1891 | 0 | 0 | 1833 | 1833 | 14 | 21 | 7 | 272 | 253 | 99
SIG+FIT 55-80, 10_2 | 7079 | 1981 | 0 | 0 | 1599 | 1599 | 13 | 24 | 8 | 264 | 246 | 96
SIG+FIT 55-85, 10_1 | 12987 | 2062 | 0 | 0 | 1918 | 1918 | 15 | 21 | 7 | 272 | 253 | 99
SIG+FIT 55-85, 10_2 | 7866 | 2202 | 0 | 0 | 1687 | 1687 | 14 | 23 | 7 | 265 | 246 | 97

COL – colonoscopy; SIG – sigmoidoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.5c Estimated Outcomes for 10-Yearly Sigmoidoscopy Plus Interval FIT Strategies: MISCAN

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 81 | 81 | 2 | 81 | 34 | 0 | 0 | 0
SIG+FIT 45-70, 10_1 | 13812 | 2055 | 0 | 0 | 2148 | 2148 | 11 | 40 | 10 | 292 | 261 | 107
SIG+FIT 45-70, 10_2 | 7965 | 2209 | 0 | 0 | 1947 | 1947 | 11 | 42 | 11 | 280 | 250 | 102
SIG+FIT 45-75, 10_1 | 15466 | 2393 | 0 | 0 | 2331 | 2331 | 13 | 37 | 9 | 304 | 272 | 111
SIG+FIT 45-75, 10_2 | 9117 | 2593 | 0 | 0 | 2130 | 2130 | 12 | 39 | 9 | 294 | 262 | 108
SIG+FIT 45-80, 10_1 | 16683 | 2393 | 0 | 0 | 2379 | 2379 | 13 | 37 | 8 | 307 | 274 | 112
SIG+FIT 45-80, 10_2 | 9673 | 2593 | 0 | 0 | 2154 | 2154 | 12 | 39 | 9 | 296 | 264 | 108
SIG+FIT 45-85, 10_1 | 17634 | 2570 | 0 | 0 | 2463 | 2463 | 14 | 37 | 8 | 309 | 275 | 113
SIG+FIT 45-85, 10_2 | 10336 | 2795 | 0 | 0 | 2235 | 2235 | 14 | 39 | 8 | 298 | 265 | 109
SIG+FIT 50-70, 10_1 | 10831 | 1900 | 0 | 0 | 1984 | 1984 | 11 | 40 | 10 | 282 | 251 | 103
SIG+FIT 50-70, 10_2 | 6482 | 2038 | 0 | 0 | 1835 | 1835 | 11 | 42 | 11 | 274 | 243 | 100
SIG+FIT 50-75, 10_1 | 12357 | 1900 | 0 | 0 | 2048 | 2048 | 12 | 39 | 10 | 287 | 255 | 105
SIG+FIT 50-75, 10_2 | 7177 | 2038 | 0 | 0 | 1867 | 1867 | 11 | 41 | 10 | 277 | 246 | 101
SIG+FIT 50-80, 10_1 | 13676 | 2161 | 0 | 0 | 2185 | 2185 | 13 | 38 | 8 | 293 | 260 | 107
SIG+FIT 50-80, 10_2 | 8098 | 2335 | 0 | 0 | 2005 | 2005 | 13 | 40 | 9 | 284 | 251 | 104
SIG+FIT 50-85, 10_1 | 14548 | 2161 | 0 | 0 | 2218 | 2218 | 14 | 38 | 8 | 294 | 260 | 107
SIG+FIT 50-85, 10_2 | 8496 | 2335 | 0 | 0 | 2021 | 2021 | 13 | 40 | 9 | 284 | 251 | 104
SIG+FIT 55-70, 10_1 | 7944 | 1389 | 0 | 0 | 1680 | 1680 | 11 | 43 | 12 | 250 | 222 | 91
SIG+FIT 55-70, 10_2 | 4622 | 1462 | 0 | 0 | 1547 | 1547 | 10 | 45 | 13 | 241 | 213 | 88
SIG+FIT 55-75, 10_1 | 9625 | 1730 | 0 | 0 | 1871 | 1871 | 12 | 40 | 10 | 263 | 233 | 96
SIG+FIT 55-75, 10_2 | 5792 | 1851 | 0 | 0 | 1739 | 1739 | 12 | 42 | 11 | 256 | 225 | 93
SIG+FIT 55-80, 10_1 | 10851 | 1730 | 0 | 0 | 1920 | 1920 | 13 | 40 | 10 | 266 | 235 | 97
SIG+FIT 55-80, 10_2 | 6351 | 1851 | 0 | 0 | 1764 | 1764 | 12 | 42 | 10 | 258 | 227 | 94
SIG+FIT 55-85, 10_1 | 11807 | 1908 | 0 | 0 | 2004 | 2004 | 14 | 40 | 9 | 268 | 236 | 98
SIG+FIT 55-85, 10_2 | 7018 | 2054 | 0 | 0 | 1847 | 1847 | 14 | 42 | 10 | 260 | 228 | 95

COL – colonoscopy; SIG – sigmoidoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.6a Estimated Outcomes for Computed Tomographic Colonography Strategies: SimCRC

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 85 | 85 | 2 | 85 | 34 | 0 | 0 | 0
CTC 45-70, 5 | 0 | 0 | 4372 | 0 | 1653 | 1653 | 9 | 21 | 6 | 348 | 326 | 127
CTC 45-70, 10 | 0 | 0 | 2605 | 0 | 1233 | 1233 | 8 | 31 | 9 | 310 | 290 | 113
CTC 45-75, 5 | 0 | 0 | 4804 | 0 | 1788 | 1788 | 11 | 18 | 5 | 355 | 332 | 130
CTC 45-75, 10 | 0 | 0 | 3141 | 0 | 1459 | 1459 | 10 | 24 | 6 | 328 | 306 | 120
CTC 45-80, 5 | 0 | 0 | 5131 | 0 | 1882 | 1882 | 12 | 17 | 4 | 358 | 335 | 131
CTC 45-80, 10 | 0 | 0 | 3141 | 0 | 1459 | 1459 | 10 | 24 | 6 | 328 | 306 | 120
CTC 45-85, 5 | 0 | 0 | 5348 | 0 | 1939 | 1939 | 13 | 17 | 4 | 359 | 335 | 131
CTC 45-85, 10 | 0 | 0 | 3416 | 0 | 1559 | 1559 | 12 | 24 | 6 | 330 | 307 | 120
CTC 50-70, 5 | 0 | 0 | 3573 | 0 | 1488 | 1488 | 9 | 24 | 7 | 318 | 296 | 116
CTC 50-70, 10 | 0 | 0 | 2440 | 0 | 1229 | 1229 | 8 | 29 | 9 | 295 | 274 | 108
CTC 50-75, 5 | 0 | 0 | 4006 | 0 | 1624 | 1624 | 11 | 21 | 6 | 325 | 302 | 119
CTC 50-75, 10 | 0 | 0 | 2440 | 0 | 1229 | 1229 | 8 | 29 | 9 | 295 | 274 | 108
CTC 50-80, 5 | 0 | 0 | 4334 | 0 | 1719 | 1719 | 12 | 20 | 5 | 327 | 304 | 119
CTC 50-80, 10 | 0 | 0 | 2852 | 0 | 1390 | 1390 | 11 | 27 | 7 | 302 | 280 | 110
CTC 50-85, 5 | 0 | 0 | 4551 | 0 | 1776 | 1776 | 13 | 20 | 5 | 328 | 305 | 120
CTC 50-85, 10 | 0 | 0 | 2852 | 0 | 1390 | 1390 | 11 | 27 | 7 | 302 | 280 | 110
CTC 55-70, 5 | 0 | 0 | 2810 | 0 | 1309 | 1309 | 9 | 29 | 9 | 276 | 256 | 101
CTC 55-70, 10 | 0 | 0 | 1695 | 0 | 995 | 995 | 7 | 38 | 12 | 245 | 227 | 90
CTC 55-75, 5 | 0 | 0 | 3246 | 0 | 1447 | 1447 | 11 | 26 | 7 | 284 | 263 | 104
CTC 55-75, 10 | 0 | 0 | 2235 | 0 | 1228 | 1228 | 10 | 31 | 9 | 264 | 243 | 96
CTC 55-80, 5 | 0 | 0 | 3574 | 0 | 1543 | 1543 | 12 | 25 | 7 | 286 | 265 | 105
CTC 55-80, 10 | 0 | 0 | 2235 | 0 | 1228 | 1228 | 10 | 31 | 9 | 264 | 243 | 96
CTC 55-85, 5 | 0 | 0 | 3792 | 0 | 1601 | 1601 | 13 | 25 | 7 | 287 | 265 | 105
CTC 55-85, 10 | 0 | 0 | 2512 | 0 | 1329 | 1329 | 12 | 31 | 9 | 266 | 245 | 97

COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.6b Estimated Outcomes for Computed Tomographic Colonography Strategies: CRC-SPIN

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 77 | 77 | 2 | 77 | 32 | 0 | 0 | 0
CTC 45-70, 5 | 0 | 0 | 4432 | 0 | 1677 | 1677 | 11 | 20 | 7 | 308 | 289 | 112
CTC 45-70, 10 | 0 | 0 | 2621 | 0 | 1273 | 1273 | 10 | 27 | 10 | 276 | 260 | 101
CTC 45-75, 5 | 0 | 0 | 4893 | 0 | 1791 | 1791 | 13 | 18 | 6 | 313 | 294 | 114
CTC 45-75, 10 | 0 | 0 | 3179 | 0 | 1465 | 1465 | 12 | 22 | 7 | 289 | 272 | 106
CTC 45-80, 5 | 0 | 0 | 5254 | 0 | 1874 | 1874 | 14 | 17 | 5 | 315 | 296 | 115
CTC 45-80, 10 | 0 | 0 | 3179 | 0 | 1465 | 1465 | 12 | 22 | 7 | 289 | 272 | 106
CTC 45-85, 5 | 0 | 0 | 5504 | 0 | 1927 | 1927 | 15 | 17 | 5 | 316 | 296 | 115
CTC 45-85, 10 | 0 | 0 | 3483 | 0 | 1551 | 1551 | 14 | 21 | 7 | 291 | 273 | 106
CTC 50-70, 5 | 0 | 0 | 3625 | 0 | 1510 | 1510 | 11 | 22 | 8 | 281 | 265 | 103
CTC 50-70, 10 | 0 | 0 | 2462 | 0 | 1259 | 1259 | 10 | 26 | 9 | 259 | 244 | 95
CTC 50-75, 5 | 0 | 0 | 4088 | 0 | 1626 | 1626 | 12 | 20 | 7 | 287 | 270 | 105
CTC 50-75, 10 | 0 | 0 | 2462 | 0 | 1259 | 1259 | 10 | 26 | 9 | 259 | 244 | 95
CTC 50-80, 5 | 0 | 0 | 4450 | 0 | 1709 | 1709 | 13 | 19 | 6 | 289 | 272 | 106
CTC 50-80, 10 | 0 | 0 | 2903 | 0 | 1397 | 1397 | 12 | 23 | 8 | 265 | 250 | 97
CTC 50-85, 5 | 0 | 0 | 4700 | 0 | 1763 | 1763 | 14 | 19 | 6 | 290 | 272 | 106
CTC 50-85, 10 | 0 | 0 | 2903 | 0 | 1397 | 1397 | 12 | 23 | 8 | 265 | 250 | 97
CTC 55-70, 5 | 0 | 0 | 2854 | 0 | 1321 | 1321 | 11 | 26 | 9 | 251 | 235 | 92
CTC 55-70, 10 | 0 | 0 | 1705 | 0 | 1029 | 1029 | 9 | 32 | 12 | 227 | 213 | 83
CTC 55-75, 5 | 0 | 0 | 3320 | 0 | 1440 | 1440 | 12 | 24 | 8 | 257 | 240 | 94
CTC 55-75, 10 | 0 | 0 | 2267 | 0 | 1227 | 1227 | 11 | 27 | 10 | 241 | 225 | 88
CTC 55-80, 5 | 0 | 0 | 3683 | 0 | 1525 | 1525 | 13 | 23 | 8 | 259 | 242 | 95
CTC 55-80, 10 | 0 | 0 | 2267 | 0 | 1227 | 1227 | 11 | 27 | 10 | 241 | 225 | 88
CTC 55-85, 5 | 0 | 0 | 3934 | 0 | 1579 | 1579 | 14 | 23 | 8 | 260 | 242 | 95
CTC 55-85, 10 | 0 | 0 | 2572 | 0 | 1315 | 1315 | 13 | 27 | 9 | 242 | 226 | 88

COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 9.6c Estimated Outcomes for Computed Tomographic Colonography Strategies: MISCAN

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 81 | 81 | 2 | 81 | 34 | 0 | 0 | 0
CTC 45-70, 5 | 0 | 0 | 4436 | 0 | 1569 | 1569 | 9 | 45 | 12 | 271 | 241 | 99
CTC 45-70, 10 | 0 | 0 | 2622 | 0 | 1149 | 1149 | 7 | 55 | 18 | 210 | 185 | 77
CTC 45-75, 5 | 0 | 0 | 4881 | 0 | 1672 | 1672 | 10 | 42 | 11 | 283 | 251 | 103
CTC 45-75, 10 | 0 | 0 | 3164 | 0 | 1316 | 1316 | 9 | 50 | 14 | 234 | 205 | 86
CTC 45-80, 5 | 0 | 0 | 5227 | 0 | 1744 | 1744 | 11 | 40 | 9 | 288 | 256 | 105
CTC 45-80, 10 | 0 | 0 | 3164 | 0 | 1316 | 1316 | 9 | 50 | 14 | 234 | 205 | 86
CTC 45-85, 5 | 0 | 0 | 5464 | 0 | 1790 | 1790 | 12 | 40 | 9 | 290 | 257 | 106
CTC 45-85, 10 | 0 | 0 | 3455 | 0 | 1389 | 1389 | 11 | 50 | 13 | 238 | 208 | 87
CTC 50-70, 5 | 0 | 0 | 3627 | 0 | 1414 | 1414 | 9 | 46 | 13 | 257 | 227 | 94
CTC 50-70, 10 | 0 | 0 | 2453 | 0 | 1137 | 1137 | 8 | 52 | 15 | 220 | 192 | 80
CTC 50-75, 5 | 0 | 0 | 4075 | 0 | 1519 | 1519 | 10 | 43 | 11 | 268 | 238 | 98
CTC 50-75, 10 | 0 | 0 | 2453 | 0 | 1137 | 1137 | 8 | 52 | 15 | 220 | 192 | 80
CTC 50-80, 5 | 0 | 0 | 4422 | 0 | 1592 | 1592 | 11 | 42 | 10 | 274 | 242 | 100
CTC 50-80, 10 | 0 | 0 | 2878 | 0 | 1253 | 1253 | 10 | 50 | 13 | 232 | 202 | 85
CTC 50-85, 5 | 0 | 0 | 4660 | 0 | 1638 | 1638 | 12 | 41 | 10 | 276 | 243 | 101
CTC 50-85, 10 | 0 | 0 | 2878 | 0 | 1253 | 1253 | 10 | 50 | 13 | 232 | 202 | 85
CTC 55-70, 5 | 0 | 0 | 2857 | 0 | 1242 | 1242 | 9 | 48 | 14 | 232 | 204 | 85
CTC 55-70, 10 | 0 | 0 | 1701 | 0 | 939 | 939 | 7 | 57 | 19 | 181 | 159 | 66
CTC 55-75, 5 | 0 | 0 | 3309 | 0 | 1350 | 1350 | 10 | 45 | 12 | 244 | 215 | 89
CTC 55-75, 10 | 0 | 0 | 2250 | 0 | 1113 | 1113 | 9 | 52 | 15 | 207 | 180 | 76
CTC 55-80, 5 | 0 | 0 | 3660 | 0 | 1425 | 1425 | 11 | 43 | 11 | 250 | 220 | 91
CTC 55-80, 10 | 0 | 0 | 2250 | 0 | 1113 | 1113 | 9 | 52 | 15 | 207 | 180 | 76
CTC 55-85, 5 | 0 | 0 | 3899 | 0 | 1472 | 1472 | 12 | 43 | 10 | 252 | 221 | 92
CTC 55-85, 10 | 0 | 0 | 2543 | 0 | 1187 | 1187 | 10 | 51 | 14 | 211 | 182 | 77

COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.