# Appendix 8 Model-Estimated Outcomes With Strategies With Once-only Colonoscopy, Followed by Annual FIT

Appendix Table 8.1 Estimated Outcomes for Once-Only Colonoscopy Followed by Annual FIT Screening Strategies, by Model

Model/Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Model/Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
SimCRC
No screening | 0 | 0 | 0 | 0 | 85 | 85 | 2 | 85 | 34 | 0 | 0 | 0
COL at 45 followed by
FIT 55-70, 1 | 9554 | 0 | 0 | 1037 | 1274 | 2311 | 9 | 26 | 7 | 345 | 323 | 126
FIT 55-75, 1 | 11649 | 0 | 0 | 1037 | 1413 | 2451 | 10 | 22 | 5 | 357 | 333 | 130
FIT 55-80, 1 | 13309 | 0 | 0 | 1037 | 1521 | 2559 | 11 | 21 | 4 | 362 | 338 | 132
FIT 55-85, 1 | 14491 | 0 | 0 | 1037 | 1593 | 2631 | 13 | 20 | 4 | 364 | 339 | 133
COL at 50, followed by
FIT 60-70, 1 | 6319 | 0 | 0 | 1019 | 1109 | 2128 | 9 | 28 | 8 | 316 | 295 | 115
FIT 60-75, 1 | 8372 | 0 | 0 | 1019 | 1243 | 2262 | 10 | 25 | 6 | 327 | 304 | 119
FIT 60-80, 1 | 10021 | 0 | 0 | 1019 | 1348 | 2367 | 11 | 23 | 5 | 332 | 309 | 121
FIT 60-85, 1 | 11196 | 0 | 0 | 1019 | 1420 | 2439 | 13 | 23 | 5 | 334 | 310 | 122
CRC-SPIN
No screening | 0 | 0 | 0 | 0 | 77 | 77 | 2 | 77 | 32 | 0 | 0 | 0
COL at 45, followed by
FIT 55-70, 1 | 9192 | 0 | 0 | 1038 | 1481 | 2518 | 12 | 19 | 6 | 322 | 304 | 118
FIT 55-75, 1 | 11233 | 0 | 0 | 1038 | 1603 | 2641 | 13 | 17 | 5 | 329 | 309 | 120
FIT 55-80, 1 | 12888 | 0 | 0 | 1038 | 1698 | 2736 | 14 | 16 | 5 | 332 | 312 | 121
FIT 55-85, 1 | 14106 | 0 | 0 | 1038 | 1763 | 2801 | 15 | 15 | 4 | 334 | 313 | 122
COL at 50, followed by
FIT 60-70, 1 | 6143 | 0 | 0 | 1020 | 1279 | 2299 | 12 | 20 | 7 | 294 | 278 | 107
FIT 60-75, 1 | 8153 | 0 | 0 | 1020 | 1398 | 2418 | 13 | 19 | 6 | 301 | 283 | 110
FIT 60-80, 1 | 9805 | 0 | 0 | 1020 | 1491 | 2511 | 14 | 18 | 6 | 304 | 286 | 111
FIT 60-85, 1 | 11020 | 0 | 0 | 1020 | 1556 | 2576 | 15 | 17 | 5 | 305 | 287 | 111
MISCAN
No screening | 0 | 0 | 0 | 0 | 81 | 81 | 2 | 81 | 34 | 0 | 0 | 0
COL at 45, followed by
FIT 55-70, 1 | 8674 | 0 | 0 | 1038 | 1368 | 2406 | 9 | 46 | 13 | 272 | 242 | 99
FIT 55-75, 1 | 10765 | 0 | 0 | 1038 | 1480 | 2518 | 10 | 44 | 11 | 288 | 256 | 105
FIT 55-80, 1 | 12481 | 0 | 0 | 1038 | 1566 | 2603 | 11 | 42 | 9 | 297 | 263 | 108
FIT 55-85, 1 | 13768 | 0 | 0 | 1038 | 1626 | 2664 | 12 | 42 | 9 | 301 | 266 | 110
COL at 50, followed by
FIT 60-70, 1 | 5459 | 0 | 0 | 1020 | 1235 | 2255 | 10 | 46 | 13 | 259 | 231 | 95
FIT 60-75, 1 | 7462 | 0 | 0 | 1020 | 1337 | 2357 | 11 | 44 | 11 | 274 | 243 | 100
FIT 60-80, 1 | 9140 | 0 | 0 | 1020 | 1418 | 2438 | 11 | 42 | 10 | 282 | 250 | 103
FIT 60-85, 1 | 10404 | 0 | 0 | 1020 | 1475 | 2495 | 12 | 42 | 9 | 285 | 252 | 104

COL – colonoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 8.2 Efficient Once-Only Colonoscopy Followed by Annual FIT Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by Model

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | SimCRC | CRC-SPIN | MISCAN
COL at 50; FIT 60-70, 1 | -- | -- | --
COL at 50; FIT 60-75, 1 | Dominated | Dominated | 7
COL at 45; FIT 55-70, 1 | 6 | 8 | 12^*^
COL at 50; FIT 60-80, 1 | Dominated | Dominated | 10
COL at 50; FIT 60-85, 1 | Dominated | Dominated | 16^*^
COL at 45; FIT 55-75, 1 | 12 | 18 | 12^*^
COL at 45; FIT 55-80, 1 | 19 | 28 | 11
COL at 45; FIT 55-85, 1 | 41 | 46 | 16

COL – colonoscopy; LYG – life-years gained compared with no screening; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all 3 models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 8.1 Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for Screening Strategies With Once-Only Colonoscopy Followed by Annual FIT, by Model

Estimated colonoscopies vs life-years gained for screening strategies with once-only colonoscopy followed by annual FIT

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.