# Appendix 7 Model-Estimated Outcomes With Strategies With Annual FIT, Followed by 10-Yearly Colonoscopy

Appendix Table 7.1 Estimated Outcomes for 5 Years of Annual FIT Followed by 10-Yearly Colonoscopy Screening Strategies, by Model

Model/Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Model/Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
SimCRC
No screening | 0 | 0 | 0 | 0 | 85 | 85 | 2 | 85 | 34 | 0 | 0 | 0
Annual FIT from 45 to 49, followed by
COL 50-70, 10 | 4541 | 0 | 0 | 2177 | 1281 | 3458 | 13 | 17 | 4 | 361 | 338 | 132
COL 50-80, 10 | 4541 | 0 | 0 | 2521 | 1329 | 3850 | 16 | 15 | 3 | 365 | 341 | 133
Annual FIT from 50 to 54, followed by
COL 55-75, 10 | 4411 | 0 | 0 | 1945 | 1252 | 3197 | 15 | 20 | 5 | 331 | 307 | 121
COL 55-85, 10 | 4411 | 0 | 0 | 2174 | 1273 | 3447 | 18 | 19 | 5 | 331 | 308 | 121
CRC-SPIN
No screening | 0 | 0 | 0 | 0 | 77 | 77 | 2 | 77 | 32 | 0 | 0 | 0
Annual FIT from 45 to 49, followed by
COL 50-70, 10 | 4492 | 0 | 0 | 2143 | 1418 | 3561 | 15 | 14 | 4 | 330 | 311 | 121
COL 50-80, 10 | 4492 | 0 | 0 | 2519 | 1447 | 3967 | 18 | 13 | 4 | 332 | 313 | 121
Annual FIT from 50 to 54, followed by
COL 55-75, 10 | 4352 | 0 | 0 | 1936 | 1346 | 3282 | 16 | 16 | 5 | 302 | 283 | 110
COL 55-85, 10 | 4352 | 0 | 0 | 2200 | 1359 | 3559 | 18 | 16 | 5 | 302 | 284 | 110
MISCAN
No screening | 0 | 0 | 0 | 0 | 81 | 81 | 2 | 81 | 34 | 0 | 0 | 0
Annual FIT from 45 to 49, followed by
COL 50-70, 10 | 4555 | 0 | 0 | 2063 | 1454 | 3517 | 14 | 36 | 9 | 300 | 270 | 110
COL 50-80, 10 | 4555 | 0 | 0 | 2387 | 1483 | 3870 | 16 | 34 | 8 | 305 | 274 | 111
Annual FIT from 50 to 54, followed by
COL 55-75, 10 | 4419 | 0 | 0 | 1840 | 1385 | 3224 | 15 | 36 | 9 | 288 | 257 | 105
COL 55-85, 10 | 4419 | 0 | 0 | 2064 | 1396 | 3460 | 17 | 36 | 9 | 289 | 258 | 106

COL – colonoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 7.2 Efficient Strategies With 5 Years of Annual FIT Followed by 10-Yearly Colonoscopy With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by Model

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | SimCRC | CRC-SPIN | MISCAN
FIT 50-54, 1; COL 55-75, 10 | -- | -- | --
FIT 45-49, 1; COL 50-70, 10 | 8 | 10 | 23
FIT 45-49, 1; COL 50-80, 10 | 123 | 216 | 81

COL – colonoscopy; LYG – life-years gained compared with no screening; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all 3 models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 7.1 Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds for Screening Strategies With 5 Years of Annual FIT Followed by 10-Yearly Colonoscopy, by Model

Estimated colonoscopies vs life-years gained for screening strategies with 5 years of annual FIT followed by colonoscopy every 10 years

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.