# Appendix 6 Model-Estimated Outcomes With Once-only Sigmoidoscopy Strategies

Appendix Table 6.1 Estimated Outcomes for Once-Only Sigmoidoscopy Strategies by Model

Model/Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Model/Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
SimCRC
No screening | 0 | 0 | 0 | 0 | 85 | 85 | 2 | 85 | 34 | 0 | 0 | 0
SIG at 45 | 0 | 988 | 0 | 0 | 500 | 500 | 3 | 64 | 25 | 138 | 131 | 51
SIG at 50 | 0 | 971 | 0 | 0 | 543 | 543 | 4 | 61 | 23 | 150 | 141 | 55
SIG at 55 | 0 | 944 | 0 | 0 | 579 | 579 | 4 | 58 | 22 | 151 | 141 | 55
SIG at 60 | 0 | 905 | 0 | 0 | 587 | 587 | 5 | 57 | 21 | 140 | 129 | 51
SIG at 65 | 0 | 851 | 0 | 0 | 588 | 588 | 6 | 58 | 21 | 117 | 107 | 43
CRC-SPIN
No screening | 0 | 0 | 0 | 0 | 77 | 77 | 2 | 77 | 32 | 0 | 0 | 0
SIG at 45 | 0 | 988 | 0 | 0 | 651 | 651 | 5 | 51 | 20 | 165 | 157 | 60
SIG at 50 | 0 | 971 | 0 | 0 | 695 | 695 | 6 | 47 | 18 | 174 | 165 | 63
SIG at 55 | 0 | 945 | 0 | 0 | 711 | 711 | 7 | 44 | 17 | 174 | 164 | 64
SIG at 60 | 0 | 906 | 0 | 0 | 690 | 690 | 7 | 44 | 17 | 151 | 142 | 55
SIG at 65 | 0 | 852 | 0 | 0 | 646 | 646 | 7 | 47 | 18 | 126 | 117 | 46
MISCAN
No screening | 0 | 0 | 0 | 0 | 81 | 81 | 2 | 81 | 34 | 0 | 0 | 0
SIG at 45 | 0 | 988 | 0 | 0 | 769 | 769 | 5 | 66 | 26 | 107 | 97 | 39
SIG at 50 | 0 | 971 | 0 | 0 | 896 | 896 | 6 | 61 | 23 | 137 | 124 | 50
SIG at 55 | 0 | 945 | 0 | 0 | 966 | 966 | 7 | 57 | 21 | 155 | 138 | 56
SIG at 60 | 0 | 906 | 0 | 0 | 955 | 955 | 8 | 55 | 20 | 156 | 138 | 57
SIG at 65 | 0 | 852 | 0 | 0 | 906 | 906 | 9 | 56 | 20 | 136 | 117 | 50

COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 6.2 Efficient Once-Only Sigmoidoscopy Screening Strategies, by Model

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | SimCRC | CRC-SPIN | MISCAN
SIG at 45 | -- | <1 | --
SIG at 50 | 4 | 5 | 4^*^
SIG at 55 | 21 | 34 | Dominated
SIG at 60 | Dominated | Dominated | 4
SIG at 65 | Dominated | -- | 5^*^

COL – colonoscopy; LYG – life-years gained compared with no screening; SIG – sigmoidoscopy; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 6.3 Efficient Sigmoidoscopy Screening Strategies Including Once-Only Strategies, by Model

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | SimCRC | CRC-SPIN | MISCAN
SIG at 45 | -- | <1 | --
SIG at 50 | 4 | 5 | 4^*^
SIG at 55 | 21^*^ | 34^*^ | 4^*^
SIG at 60 | Dominated | Dominated | 4
SIG at 65 | Dominated | -- | 5^*^
SIG 55-70, 10 | Dominated | Dominated | 8
SIG 50-70, 10 | Dominated | Dominated | 8
SIG 45-70, 10 | 5 | 7 | 73^*^
SIG 55-70, 5 | Dominated | Dominated | 11^*^
SIG 50-80, 10 | Dominated | Dominated | 22^*^
SIG 45-75, 10 | 13^*^ | 18 | 18^*^
SIG 50-70, 5 | Dominated | Dominated | 14
SIG 45-85, 10 | Dominated | 68^*^ | 21^*^
SIG 50-75, 5 | Dominated | Dominated | 19^*^
SIG 45-70, 5 | 11 | 20 | 15
SIG 50-80, 5 | Dominated | Dominated | 23^*^
SIG 50-85, 5 | Dominated | Dominated | 26^*^
SIG 45-75, 5 | 20 | 27 | 19
SIG 45-80, 5 | 38 | 49 | 29
SIG 45-85, 5 | 89 | 98 | 78

COL – colonoscopy; LYG – life-years gained compared with no screening; SIG – sigmoidoscopy; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all 3 models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 6.1 Estimated Colonoscopies and Life-Years Gained (Compared With No Screening) for a Cohort of 40-Year-Olds for Once-Only Sigmoidoscopy Strategies, by Model

Estimated colonoscopies vs life-years gained for once-only sigmoidoscopy screening strategies.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 6.2 Estimated Colonoscopies and Life-Years Gained (Compared With No Screening) for a Cohort of 40-Year-Olds for Sigmoidoscopy Screening Including Once-Only Strategies, by Model

Estimated colonoscopies vs life-years gained for sigmoidoscopy screening strategies including once-only sigmoidoscopy strategies.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.