# Appendix 5 Model-Estimated Outcomes With Once-only Colonoscopy Screening Strategies

Appendix Table 5.1 Estimated Outcomes for Once-Only Colonoscopy Screening Strategies by Model

Model/Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Model/Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
SimCRC
No screening | 0 | 0 | 0 | 0 | 85 | 85 | 2 | 85 | 34 | 0 | 0 | 0
COL at 45 | 0 | 0 | 0 | 1037 | 649 | 1686 | 6 | 45 | 17 | 246 | 233 | 90
COL at 50 | 0 | 0 | 0 | 1019 | 700 | 1720 | 7 | 40 | 14 | 256 | 241 | 94
COL at 55 | 0 | 0 | 0 | 991 | 730 | 1721 | 8 | 37 | 13 | 248 | 232 | 91
COL at 60 | 0 | 0 | 0 | 950 | 691 | 1640 | 9 | 38 | 13 | 219 | 203 | 80
COL at 65 | 0 | 0 | 0 | 893 | 654 | 1547 | 11 | 43 | 14 | 177 | 161 | 64
CRC-SPIN
No screening | 0 | 0 | 0 | 0 | 77 | 77 | 2 | 77 | 32 | 0 | 0 | 0
COL at 45 | 0 | 0 | 0 | 1038 | 845 | 1882 | 8 | 33 | 13 | 255 | 242 | 93
COL at 50 | 0 | 0 | 0 | 1020 | 859 | 1879 | 9 | 30 | 11 | 254 | 241 | 93
COL at 55 | 0 | 0 | 0 | 992 | 838 | 1830 | 10 | 29 | 11 | 243 | 229 | 89
COL at 60 | 0 | 0 | 0 | 951 | 751 | 1702 | 11 | 31 | 12 | 206 | 194 | 75
COL at 65 | 0 | 0 | 0 | 895 | 663 | 1557 | 11 | 36 | 13 | 167 | 155 | 61
MISCAN
No screening | 0 | 0 | 0 | 0 | 81 | 81 | 2 | 81 | 34 | 0 | 0 | 0
COL at 45 | 0 | 0 | 0 | 1038 | 822 | 1860 | 7 | 58 | 22 | 168 | 153 | 61
COL at 50 | 0 | 0 | 0 | 1020 | 921 | 1941 | 8 | 52 | 18 | 199 | 180 | 73
COL at 55 | 0 | 0 | 0 | 992 | 941 | 1933 | 10 | 48 | 16 | 212 | 190 | 77
COL at 60 | 0 | 0 | 0 | 951 | 855 | 1806 | 11 | 47 | 15 | 204 | 180 | 74
COL at 65 | 0 | 0 | 0 | 895 | 758 | 1653 | 12 | 49 | 16 | 171 | 149 | 62

COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 5.2 Efficient Once-Only Colonoscopy Screening Strategies, by Model

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | SimCRC | CRC-SPIN | MISCAN
COL at 65 | -- | -- | --
COL at 60 | 2^*^ | 4^*^ | 5
COL at 45 | 2 | 4 | Dominated
COL at 50 | 3 | 4^*^ | Dominated
COL at 55 | Dominated | 4 | 15

COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 5.3 Efficient Colonoscopy Screening Strategies Including Once-Only Strategies, by Model

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | SimCRC | CRC-SPIN | MISCAN
COL at 65 | -- | -- | --
COL at 60 | 2^*^ | 4^*^ | 5
COL at 45 | 2 | 4 | Dominated
COL at 50 | 3 | 4^*^ | Dominated
COL at 55 | Dominated | 4 | 15
COL 55-70, 15 | Dominated | Dominated | 18^*^
COL 55-70, 10 | Dominated | Dominated | 19^*^
COL 50-70, 15 | Dominated | Dominated | 18
COL 45-70, 15 | 14 | 18 | 85^*^
COL 50-80, 15 | Dominated | Dominated | 56^*^
COL 50-70, 10 | Dominated | Dominated | 28
COL 45-75, 15 | 39^*^ | 59^*^ | 38^*^
COL 45-70, 10 | 34 | 44 | 45
COL 50-80, 10 | Dominated | Dominated | 86^*^
COL 45-75, 10 | 64 | 112 | 52
COL 45-85, 10 | 394^*^ | 828^*^ | 227^*^
COL 50-70, 5 | Dominated | Dominated | 120^*^
COL 50-75, 5 | Dominated | Dominated | 367^*^
COL 45-70, 5 | 180^*^ | 179 | 84
COL 45-75, 5 | 178 | 344 | 116
COL 45-80, 5 | 428 | 736 | 169
COL 45-85, 5 | 1445 | 2190 | 926

COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all 3 models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 5.1 Estimated Colonoscopies and Life-Years Gained (Compared With No Screening) for a Cohort of 40-Year-Olds for Once-Only Colonoscopy Screening Strategies, by Model

Estimated colonoscopies vs life-years gained for once-only colonoscopy screening strategies

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 5.2 Estimated Colonoscopies and Life-Years Gained (Compared With No Screening) for a Cohort of 40-Year-Olds for Colonoscopy Screening Strategies Including Once-Only Strategies, by Model

Estimated colonoscopies vs life-years gained for colonoscopy screening strategies including once-only colonoscopy strategies.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.