# Appendix 4 Model-Estimated Outcomes With HSgFOBT Screening Strategies

As noted in the section “Model Input Parameters” there is considerable uncertainty in the diagnostic accuracy of the HSgFOBT Hemoccult SENSA.82,83 As a result, model outcomes for HSgFOBT should be interpreted with caution and decisions about this test should not be informed by modeling. Outcomes for HSgFOBT strategies using the pooled estimates of test sensitivity and specificity from Lin et al.17 are presented in Appendix Table 4.1. Colonoscopies and life-years gained for stool-based modalities are in Appendix Figure 4.1 and efficient stool-based strategies with inclusion of HSgFOBT strategies are in Appendix Table 4.2.

When HSgFOBT is evaluated together with FIT and sDNA-FIT, all 3 models find that HSgFOBT strategies with a 3-year interval are efficient but they are estimated to provide the lowest LYG relative to the other efficient stool-based modalities (Appendix Figure 4.1). With MISCAN, a small number of HSgFOBT strategies with shorter screening intervals are also efficient.

Appendix Table 4.1a Estimated Outcomes for HSgFOBT Strategies: SimCRC

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 85 | 85 | 2 | 85 | 34 | 0 | 0 | 0
HSgFOBT 45-70, 1 | 18001 | 0 | 0 | 0 | 1321 | 1321 | 8 | 40 | 10 | 314 | 285 | 115
HSgFOBT 45-70, 2 | 10362 | 0 | 0 | 0 | 857 | 857 | 6 | 54 | 15 | 262 | 234 | 96
HSgFOBT 45-70, 3 | 7560 | 0 | 0 | 0 | 668 | 668 | 5 | 61 | 18 | 225 | 200 | 82
HSgFOBT 45-75, 1 | 20251 | 0 | 0 | 0 | 1464 | 1464 | 9 | 36 | 8 | 330 | 299 | 121
HSgFOBT 45-75, 2 | 12025 | 0 | 0 | 0 | 982 | 982 | 7 | 51 | 12 | 286 | 255 | 105
HSgFOBT 45-75, 3 | 8651 | 0 | 0 | 0 | 758 | 758 | 6 | 58 | 15 | 248 | 218 | 91
HSgFOBT 45-80, 1 | 22037 | 0 | 0 | 0 | 1573 | 1573 | 10 | 35 | 6 | 338 | 306 | 124
HSgFOBT 45-80, 2 | 12922 | 0 | 0 | 0 | 1047 | 1047 | 8 | 50 | 10 | 296 | 262 | 108
HSgFOBT 45-80, 3 | 9247 | 0 | 0 | 0 | 803 | 803 | 6 | 58 | 13 | 256 | 225 | 94
HSgFOBT 45-85, 1 | 23312 | 0 | 0 | 0 | 1646 | 1646 | 11 | 35 | 5 | 341 | 308 | 125
HSgFOBT 45-85, 2 | 13898 | 0 | 0 | 0 | 1116 | 1116 | 9 | 50 | 9 | 301 | 266 | 110
HSgFOBT 45-85, 3 | 9983 | 0 | 0 | 0 | 860 | 860 | 7 | 59 | 12 | 263 | 229 | 96
HSgFOBT 50-70, 1 | 14431 | 0 | 0 | 0 | 1138 | 1138 | 7 | 44 | 11 | 280 | 253 | 102
HSgFOBT 50-70, 2 | 8582 | 0 | 0 | 0 | 762 | 762 | 6 | 57 | 16 | 235 | 209 | 86
HSgFOBT 50-70, 3 | 5855 | 0 | 0 | 0 | 560 | 560 | 4 | 64 | 20 | 193 | 170 | 71
HSgFOBT 50-75, 1 | 16703 | 0 | 0 | 0 | 1285 | 1285 | 9 | 41 | 9 | 297 | 268 | 109
HSgFOBT 50-75, 2 | 9702 | 0 | 0 | 0 | 848 | 848 | 6 | 54 | 13 | 252 | 223 | 92
HSgFOBT 50-75, 3 | 7096 | 0 | 0 | 0 | 662 | 662 | 5 | 61 | 16 | 220 | 193 | 81
HSgFOBT 50-80, 1 | 18502 | 0 | 0 | 0 | 1397 | 1397 | 10 | 39 | 7 | 306 | 274 | 112
HSgFOBT 50-80, 2 | 11055 | 0 | 0 | 0 | 947 | 947 | 8 | 53 | 11 | 266 | 234 | 97
HSgFOBT 50-80, 3 | 7988 | 0 | 0 | 0 | 736 | 736 | 6 | 61 | 14 | 234 | 203 | 85
HSgFOBT 50-85, 1 | 19784 | 0 | 0 | 0 | 1471 | 1471 | 11 | 39 | 7 | 309 | 276 | 113
HSgFOBT 50-85, 2 | 11710 | 0 | 0 | 0 | 994 | 994 | 9 | 53 | 10 | 270 | 237 | 99
HSgFOBT 50-85, 3 | 8426 | 0 | 0 | 0 | 769 | 769 | 7 | 61 | 13 | 237 | 205 | 87
HSgFOBT 55-70, 1 | 10967 | 0 | 0 | 0 | 940 | 940 | 7 | 50 | 14 | 238 | 212 | 87
HSgFOBT 55-70, 2 | 6246 | 0 | 0 | 0 | 608 | 608 | 5 | 62 | 18 | 192 | 169 | 70
HSgFOBT 55-70, 3 | 4800 | 0 | 0 | 0 | 498 | 498 | 4 | 67 | 20 | 170 | 148 | 62
HSgFOBT 55-75, 1 | 13284 | 0 | 0 | 0 | 1095 | 1095 | 8 | 46 | 11 | 257 | 229 | 94
HSgFOBT 55-75, 2 | 7949 | 0 | 0 | 0 | 741 | 741 | 6 | 58 | 15 | 220 | 193 | 80
HSgFOBT 55-75, 3 | 5468 | 0 | 0 | 0 | 553 | 553 | 5 | 65 | 19 | 184 | 159 | 67
HSgFOBT 55-80, 1 | 15106 | 0 | 0 | 0 | 1210 | 1210 | 10 | 45 | 9 | 266 | 236 | 97
HSgFOBT 55-80, 2 | 8862 | 0 | 0 | 0 | 810 | 810 | 7 | 57 | 13 | 231 | 200 | 84
HSgFOBT 55-80, 3 | 6495 | 0 | 0 | 0 | 638 | 638 | 6 | 64 | 16 | 201 | 173 | 73
HSgFOBT 55-85, 1 | 16399 | 0 | 0 | 0 | 1286 | 1286 | 11 | 44 | 9 | 269 | 239 | 98
HSgFOBT 55-85, 2 | 9852 | 0 | 0 | 0 | 880 | 880 | 8 | 58 | 12 | 236 | 205 | 86
HSgFOBT 55-85, 3 | 7147 | 0 | 0 | 0 | 689 | 689 | 7 | 65 | 15 | 207 | 177 | 75

HSgFOBT – high sensitivity guaiac-based fecal occult blood test; COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 4.1b Estimated Outcomes for HSgFOBT Strategies: CRC-SPIN

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 77 | 77 | 2 | 77 | 32 | 0 | 0 | 0
HSgFOBT 45-70, 1 | 17621 | 0 | 0 | 0 | 1505 | 1505 | 10 | 30 | 10 | 280 | 260 | 102
HSgFOBT 45-70, 2 | 10237 | 0 | 0 | 0 | 1002 | 1002 | 8 | 43 | 15 | 224 | 206 | 82
HSgFOBT 45-70, 3 | 7501 | 0 | 0 | 0 | 782 | 782 | 6 | 50 | 18 | 183 | 168 | 67
HSgFOBT 45-75, 1 | 19829 | 0 | 0 | 0 | 1637 | 1637 | 11 | 28 | 8 | 290 | 269 | 106
HSgFOBT 45-75, 2 | 11876 | 0 | 0 | 0 | 1122 | 1122 | 9 | 40 | 12 | 242 | 222 | 88
HSgFOBT 45-75, 3 | 8576 | 0 | 0 | 0 | 871 | 871 | 7 | 48 | 16 | 199 | 182 | 73
HSgFOBT 45-80, 1 | 21617 | 0 | 0 | 0 | 1736 | 1736 | 12 | 26 | 7 | 296 | 274 | 108
HSgFOBT 45-80, 2 | 12769 | 0 | 0 | 0 | 1184 | 1184 | 10 | 39 | 11 | 248 | 227 | 91
HSgFOBT 45-80, 3 | 9175 | 0 | 0 | 0 | 915 | 915 | 8 | 47 | 15 | 206 | 188 | 75
HSgFOBT 45-85, 1 | 22930 | 0 | 0 | 0 | 1803 | 1803 | 13 | 26 | 7 | 299 | 276 | 109
HSgFOBT 45-85, 2 | 13757 | 0 | 0 | 0 | 1246 | 1246 | 11 | 39 | 11 | 253 | 231 | 92
HSgFOBT 45-85, 3 | 9918 | 0 | 0 | 0 | 967 | 967 | 9 | 47 | 14 | 211 | 192 | 77
HSgFOBT 50-70, 1 | 14154 | 0 | 0 | 0 | 1293 | 1293 | 10 | 34 | 11 | 249 | 230 | 91
HSgFOBT 50-70, 2 | 8495 | 0 | 0 | 0 | 878 | 878 | 7 | 47 | 16 | 195 | 179 | 71
HSgFOBT 50-70, 3 | 5820 | 0 | 0 | 0 | 649 | 649 | 6 | 55 | 20 | 155 | 142 | 57
HSgFOBT 50-75, 1 | 16386 | 0 | 0 | 0 | 1431 | 1431 | 11 | 32 | 10 | 261 | 241 | 95
HSgFOBT 50-75, 2 | 9601 | 0 | 0 | 0 | 962 | 962 | 8 | 44 | 14 | 208 | 191 | 76
HSgFOBT 50-75, 3 | 7051 | 0 | 0 | 0 | 752 | 752 | 7 | 52 | 17 | 175 | 159 | 64
HSgFOBT 50-80, 1 | 18188 | 0 | 0 | 0 | 1532 | 1532 | 12 | 30 | 9 | 267 | 246 | 98
HSgFOBT 50-80, 2 | 10952 | 0 | 0 | 0 | 1056 | 1056 | 9 | 43 | 13 | 219 | 200 | 80
HSgFOBT 50-80, 3 | 7937 | 0 | 0 | 0 | 821 | 821 | 8 | 50 | 16 | 185 | 168 | 68
HSgFOBT 50-85, 1 | 19508 | 0 | 0 | 0 | 1601 | 1601 | 13 | 30 | 8 | 270 | 248 | 99
HSgFOBT 50-85, 2 | 11616 | 0 | 0 | 0 | 1099 | 1099 | 10 | 43 | 12 | 222 | 202 | 81
HSgFOBT 50-85, 3 | 8386 | 0 | 0 | 0 | 852 | 852 | 8 | 50 | 15 | 188 | 170 | 69
HSgFOBT 55-70, 1 | 10797 | 0 | 0 | 0 | 1058 | 1058 | 9 | 41 | 13 | 211 | 194 | 77
HSgFOBT 55-70, 2 | 6202 | 0 | 0 | 0 | 689 | 689 | 6 | 53 | 18 | 161 | 146 | 59
HSgFOBT 55-70, 3 | 4779 | 0 | 0 | 0 | 561 | 561 | 5 | 58 | 21 | 133 | 120 | 48
HSgFOBT 55-75, 1 | 13077 | 0 | 0 | 0 | 1206 | 1206 | 10 | 37 | 11 | 226 | 207 | 83
HSgFOBT 55-75, 2 | 7890 | 0 | 0 | 0 | 824 | 824 | 8 | 49 | 16 | 183 | 165 | 67
HSgFOBT 55-75, 3 | 5447 | 0 | 0 | 0 | 617 | 617 | 6 | 56 | 19 | 143 | 130 | 52
HSgFOBT 55-80, 1 | 14902 | 0 | 0 | 0 | 1314 | 1314 | 11 | 36 | 10 | 233 | 213 | 85
HSgFOBT 55-80, 2 | 8803 | 0 | 0 | 0 | 890 | 890 | 9 | 48 | 14 | 191 | 172 | 70
HSgFOBT 55-80, 3 | 6476 | 0 | 0 | 0 | 699 | 699 | 7 | 55 | 18 | 156 | 140 | 57
HSgFOBT 55-85, 1 | 16233 | 0 | 0 | 0 | 1384 | 1384 | 12 | 36 | 10 | 236 | 215 | 86
HSgFOBT 55-85, 2 | 9809 | 0 | 0 | 0 | 956 | 956 | 10 | 48 | 13 | 196 | 176 | 72
HSgFOBT 55-85, 3 | 7132 | 0 | 0 | 0 | 747 | 747 | 8 | 54 | 17 | 161 | 144 | 59

HSgFOBT – high sensitivity guaiac-based fecal occult blood test; COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 4.1c Estimated Outcomes for HSgFOBT Strategies: MISCAN

Strategy | Outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | | | DLG
Strategy | Stool tests | SIGs | CTCs | Screening COLs | Other COLs^*^ | Total COLs | Complications | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
No screening | 0 | 0 | 0 | 0 | 81 | 81 | 2 | 81 | 34 | 0 | 0 | 0
HSgFOBT 45-70, 1 | 17953 | 0 | 0 | 0 | 1380 | 1380 | 8 | 55 | 14 | 257 | 222 | 94
HSgFOBT 45-70, 2 | 10347 | 0 | 0 | 0 | 900 | 900 | 6 | 64 | 19 | 206 | 175 | 75
HSgFOBT 45-70, 3 | 7548 | 0 | 0 | 0 | 699 | 699 | 5 | 68 | 21 | 176 | 147 | 64
HSgFOBT 45-75, 1 | 20153 | 0 | 0 | 0 | 1505 | 1505 | 9 | 53 | 12 | 275 | 238 | 100
HSgFOBT 45-75, 2 | 11984 | 0 | 0 | 0 | 1014 | 1014 | 7 | 62 | 15 | 230 | 194 | 84
HSgFOBT 45-75, 3 | 8632 | 0 | 0 | 0 | 785 | 785 | 6 | 67 | 18 | 197 | 163 | 72
HSgFOBT 45-80, 1 | 21913 | 0 | 0 | 0 | 1596 | 1596 | 10 | 52 | 10 | 285 | 245 | 104
HSgFOBT 45-80, 2 | 12868 | 0 | 0 | 0 | 1071 | 1071 | 8 | 62 | 14 | 239 | 201 | 87
HSgFOBT 45-80, 3 | 9212 | 0 | 0 | 0 | 823 | 823 | 6 | 67 | 17 | 204 | 168 | 75
HSgFOBT 45-85, 1 | 23187 | 0 | 0 | 0 | 1656 | 1656 | 11 | 52 | 9 | 288 | 248 | 105
HSgFOBT 45-85, 2 | 13836 | 0 | 0 | 0 | 1128 | 1128 | 9 | 63 | 13 | 245 | 205 | 89
HSgFOBT 45-85, 3 | 9944 | 0 | 0 | 0 | 872 | 872 | 7 | 68 | 16 | 211 | 173 | 77
HSgFOBT 50-70, 1 | 14409 | 0 | 0 | 0 | 1194 | 1194 | 8 | 56 | 15 | 238 | 205 | 87
HSgFOBT 50-70, 2 | 8571 | 0 | 0 | 0 | 801 | 801 | 6 | 65 | 19 | 195 | 164 | 71
HSgFOBT 50-70, 3 | 5849 | 0 | 0 | 0 | 590 | 590 | 5 | 70 | 22 | 156 | 129 | 57
HSgFOBT 50-75, 1 | 16641 | 0 | 0 | 0 | 1324 | 1324 | 9 | 54 | 12 | 258 | 221 | 94
HSgFOBT 50-75, 2 | 9677 | 0 | 0 | 0 | 880 | 880 | 7 | 64 | 16 | 212 | 177 | 78
HSgFOBT 50-75, 3 | 7077 | 0 | 0 | 0 | 687 | 687 | 6 | 68 | 19 | 181 | 148 | 66
HSgFOBT 50-80, 1 | 18420 | 0 | 0 | 0 | 1418 | 1418 | 10 | 53 | 11 | 268 | 229 | 98
HSgFOBT 50-80, 2 | 11015 | 0 | 0 | 0 | 967 | 967 | 8 | 63 | 14 | 226 | 188 | 83
HSgFOBT 50-80, 3 | 7965 | 0 | 0 | 0 | 753 | 753 | 7 | 69 | 17 | 194 | 158 | 71
HSgFOBT 50-85, 1 | 19705 | 0 | 0 | 0 | 1480 | 1480 | 11 | 53 | 10 | 271 | 231 | 99
HSgFOBT 50-85, 2 | 11666 | 0 | 0 | 0 | 1005 | 1005 | 8 | 64 | 13 | 230 | 190 | 84
HSgFOBT 50-85, 3 | 8395 | 0 | 0 | 0 | 780 | 780 | 7 | 69 | 16 | 197 | 160 | 72
HSgFOBT 55-70, 1 | 10977 | 0 | 0 | 0 | 986 | 986 | 7 | 59 | 16 | 209 | 178 | 76
HSgFOBT 55-70, 2 | 6249 | 0 | 0 | 0 | 639 | 639 | 5 | 68 | 21 | 163 | 135 | 60
HSgFOBT 55-70, 3 | 4802 | 0 | 0 | 0 | 522 | 522 | 5 | 71 | 22 | 144 | 118 | 53
HSgFOBT 55-75, 1 | 13269 | 0 | 0 | 0 | 1126 | 1126 | 9 | 57 | 14 | 230 | 195 | 84
HSgFOBT 55-75, 2 | 7938 | 0 | 0 | 0 | 764 | 764 | 7 | 66 | 17 | 190 | 157 | 69
HSgFOBT 55-75, 3 | 5460 | 0 | 0 | 0 | 574 | 574 | 5 | 70 | 21 | 158 | 128 | 58
HSgFOBT 55-80, 1 | 15081 | 0 | 0 | 0 | 1225 | 1225 | 10 | 56 | 12 | 241 | 203 | 88
HSgFOBT 55-80, 2 | 8846 | 0 | 0 | 0 | 825 | 825 | 7 | 66 | 16 | 200 | 164 | 73
HSgFOBT 55-80, 3 | 6481 | 0 | 0 | 0 | 650 | 650 | 6 | 70 | 18 | 173 | 139 | 63
HSgFOBT 55-85, 1 | 16384 | 0 | 0 | 0 | 1289 | 1289 | 11 | 56 | 11 | 245 | 206 | 89
HSgFOBT 55-85, 2 | 9835 | 0 | 0 | 0 | 886 | 886 | 8 | 66 | 14 | 206 | 168 | 75
HSgFOBT 55-85, 3 | 7134 | 0 | 0 | 0 | 696 | 696 | 7 | 71 | 17 | 178 | 142 | 65

HSgFOBT – high sensitivity guaiac-based fecal occult blood test; COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening

* Colonoscopies for follow-up, surveillance, and symptom diagnosis

† Includes deaths from complications of screening

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 4.2 Efficient Stool-Based Screening Strategies (FIT, sDNA-FIT, HSgFOBT), by Model

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | SimCRC | CRC-SPIN | MISCAN
HSgFOBT 55-70, 3 | -- | -- | --
HSgFOBT 55-75, 3 | 4^*^ | 5^*^ | 4
HSgFOBT 50-70, 3 | 3 | 4 | 6^*^
HSgFOBT 55-70, 2 | Dominated | 7^*^ | 12^*^
FIT 55-70, 3 | Dominated | 5^*^ | 7^*^
HSgFOBT 55-80, 3 | Dominated | Dominated | 5^*^
HSgFOBT 50-75, 3 | 4^*^ | 5^*^ | 5
HSgFOBT 45-70, 3 | 3 | 5^*^ | 7^*^
HSgFOBT 55-85, 3 | Dominated | Dominated | 6^*^
FIT 55-75, 3 | Dominated | Dominated | 11^*^
FIT 50-70, 3 | 4^*^ | 4 | 15^*^
HSgFOBT 50-80, 3 | Dominated | Dominated | 5
HSgFOBT 55-75, 2 | Dominated | Dominated | 8^*^
HSgFOBT 45-75, 3 | 4^*^ | 5^*^ | 10^*^
HSgFOBT 50-70, 2 | Dominated | Dominated | 27^*^
HSgFOBT 50-85, 3 | Dominated | Dominated | 8^*^
FIT 55-80, 3 | Dominated | Dominated | 11^*^
HSgFOBT 45-80, 3 | 4^*^ | Dominated | 7^*^
FIT 45-70, 3 | 3 | 5 | 9^*^
HSgFOBT 55-80, 2 | Dominated | Dominated | 11^*^
FIT 50-75, 3 | Dominated | Dominated | 6^*^
HSgFOBT 50-75, 2 | Dominated | Dominated | 7^*^
FIT 55-85, 3 | Dominated | Dominated | 11^*^
HSgFOBT 45-85, 3 | Dominated | Dominated | 7^*^
FIT 55-75, 2 | Dominated | Dominated | 8^*^
FIT 50-80, 3 | Dominated | Dominated | 6
FIT 50-70, 2 | Dominated | Dominated | 94^*^
FIT 45-75, 3 | 5 | 7^*^ | 7^*^
FIT 50-85, 3 | Dominated | Dominated | 10^*^
HSgFOBT 50-80, 2 | Dominated | Dominated | 9^*^
FIT 45-80, 3 | 7^*^ | 8^*^ | 6
HSgFOBT 45-75, 2 | Dominated | Dominated | 11^*^
HSgFOBT 50-85, 2 | Dominated | Dominated | 10^*^
FIT 45-70, 2 | 8^*^ | 7 | Dominated
FIT 50-75, 2 | Dominated | Dominated | 10^*^
FIT 45-85, 3 | 10^*^ | Dominated | 9^*^
HSgFOBT 45-80, 2 | Dominated | Dominated | 13^*^
HSgFOBT 45-85, 2 | Dominated | Dominated | 11^*^
FIT 50-80, 2 | Dominated | Dominated | 8
FIT 45-75, 2 | 7 | 9 | 9^*^
FIT 50-85, 2 | Dominated | Dominated | 12^*^
FIT 45-80, 2 | 10 | 12 | 8
FIT 45-85, 2 | 19^*^ | 25^*^ | 12
FIT 50-75, 1 | Dominated | Dominated | 29^*^
FIT 45-70, 1 | 21^*^ | 14 | Dominated
FIT 50-80, 1 | Dominated | Dominated | 18^*^
HSgFOBT 45-80, 1 | Dominated | Dominated | 19^*^
FIT 45-75, 1 | 16 | 16 | 15^*^
FIT 50-85, 1 | Dominated | Dominated | 18^*^
HSgFOBT 45-85, 1 | Dominated | Dominated | 19^*^
sDNA-FIT 45-70, 2 | Dominated | 52^*^ | Dominated
FIT 45-80, 1 | 19 | 27 | 14
FIT 45-85, 1 | 39 | 43 | 19
sDNA-FIT 45-75, 2 | 91^*^ | 135^*^ | Dominated
sDNA-FIT 45-80, 2 | 176^*^ | 75^*^ | 26^*^
sDNA-FIT 45-85, 2 | 175^*^ | 69^*^ | 375^*^
sDNA-FIT 45-70, 1 | 116^*^ | 62^*^ | Dominated
sDNA-FIT 45-75, 1 | 103^*^ | 53 | 251^*^
sDNA-FIT 45-80, 1 | 81 | 62 | 104^*^
sDNA-FIT 45-85, 1 | 95 | 111 | 94

Note: Strategies that were dominated in all 3 models are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 4.1 Estimated Colonoscopies and Life-Years Gained (Compared With No Screening) for a Cohort of 40-Year-Olds for Stool-Based Screening Strategies (FIT, sDNA-FIT, and HSgFOBT), by Model

Estimated colonoscopies vs life-years gained for FIT, sDNA-FIT, and HSgFOBT screening strategies

Note: Color indicates modality; screening interval (1, 2, or 3y) is noted on each symbol. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.