# Appendix 3 Inputs for Calculation of Quality-Adjusted Life-Years

To calculate quality-adjusted life-years (QALYs), we assign quality-of-life weights for each year of life that accounts for population health by age, as well as utility losses associated with specific events (e.g. colonoscopy) or health states (e.g., time with colorectal cancer). The approach is similar to that used by the breast cancer CISNET group in their 2016 analysis for the USPSTF.^90^

## Utilities Associated With Aging

We obtained estimates of the age-related utility weights from Hanmer et al.,^91^ who reported mean EQ-5D US values for men and women in deciles of age from age 20 to age 89 years. To extrapolate utilities within each 10-year age group (for ages 40 and older) we used data from the 2017 US life table on the mean age by sex and 10-year age group. We then fit a line to predict weights at each age within the age groups and smoothed it to eliminate discontinuities. We extrapolated to estimate risk from age 90 to 99. Finally, we calculated a weighted-average age-specific weight using data from the 2017 US life table on the proportion of the population that is female. This step was necessary because the output template did not stratify by sex. Appendix Table 3.1 contains the resulting age-specific weights used in the analysis.

## Utility Losses Associated With Screening, Complications, and Cancer Care

Appendix Table 3.2 contains the assumptions for the utility losses associated with each test. Estimates on the disutility of the screening test included those associated with the test itself, and those related to fear or anxiety while waiting for the test result and while waiting for a follow-up colonoscopy after a positive test. A study by Jonas et al.^93^ was used to derive estimates of the time spent on the different procedures. As this study only captures colonoscopy, time estimates for the other tests were adjusted based on patient information sheets and expert opinion. A study by Swan et al.^92^ was used for the disutility of a colonoscopy. Due to the lack of data, we assumed that, apart from the shorter procedure times of CTC and SIG, the disutility values of CTC and SIG are equal to those of colonoscopy. For the stool-based tests, we assumed no disutility for performing the test itself. A study by Kirkegaard et al.^150^ and the 2016 USPSTF analysis from the breast cancer CISNET group,^90^ were used to derive estimates for the disutility related to fear or anxiety while waiting for test results. Additional details on the derivation of these utility losses are in the section “Additional details on the disutility of the screening tests” below.

Appendix Table 3.3 contains the assumptions for the utility loss associated with complications. Appendix Table 3.4 contains the assumptions for the utility losses associated with cancer care by stage at diagnosis and phase of care.

## Calculation of QALYs

Using the values in Appendix Tables 3.1–3.4, we calculate QALYs as follows:

QALY = sum_i_ ( ly _ po p_i_ * age _ w t_i_ − sum_j , k_ ( ly _ cr c_i , j , k_ * age _ w t_i_ * utility _ loss _ cr c_j , k_ ) − sum_l_ ( n _ fi t_i , l_ * age _ w t_i_ * utility _ loss _ fi t_l_ ) − sum_l_ ( n _ se n_i , l_ * age _ w t_i_ * utility _ loss _ se n_l_ ) − sum_l_ ( n _ pos _ sdnafi t_i , l_ * age _ w t_i_ * utility _ loss _ sdnafi t_l_ ) − sum_l_ ( n _ pos _ si g_i , l_ * age _ w t_i_ * utility _ loss _ si g_l_ ) − sum_l_ ( n _ ct c_i , l_ * age _ w t_i_ * utility _ loss _ ct c_l_ ) − sum_l_ ( ( n _ screenco l_i , l_ + n _ followupco l_i , l_ + n _ survco l_i , l_ ) * age _ w t_i_ * utility _ loss _ co l_l_ ) − sum_i , j_ ( n _ clin _ cr c_i , j_ * age _ w t_i_ * utility _ loss _ symptom _ diagnosis ) − n _ col _ complication _ cardi o_i_ * age _ w t_i_ * utility _ loss _ complication _ cardio − n _ col _ complication _ seriousG I_i_ * age _ w t_i_ * utility _ loss _ complication _ seriousGI − n _ col _ complication _ otherG I_i_ * age _ w t_i_ * utility _ loss _ complication _ otherGI )

where i is age, j is stage at diagnosis, k is phase of care, and l is test result (positive vs negative).

## Additional Details on the Disutility of the Screening Tests

Estimates on the disutility of the screening test included those associated with the test itself, and those related to fear or anxiety while waiting for the test result and while waiting for a follow-up colonoscopy after a positive test.

### Assumptions for Utility Losses Associated With the Screening Tests Themselves

The disutility associated with a screening test depends on the time spent on a screening test and the disutility experienced during this time. Appendix Tables 3.5–3.9 contain the assumptions for time spent on the screening tests. Appendix Table 3.10 contains the disutility experienced while undergoing the screening test and the total utility losses associated with the screening tests themselves.

Data from the Centers for Medicare and Medicaid Services suggest that 22% of SIG claims are accompanied by a claim for anesthesia services provided by an anesthesiology professional. We therefore assumed the total time spent on sigmoidoscopy (Appendix Table 3.9) is the weighted average of the procedures with (22%, Appendix Table 3.8) and without (78%, Appendix Table 3.7) sedation.

### Assumptions for Utility Losses Associated With Fear or Anxiety

Appendix Table 3.11 and Appendix Table 3.12 contain the utility losses associated with fear or anxiety while waiting for the test result and while waiting for a follow-up colonoscopy after a positive test, respectively.

Appendix Table 3.1 General Health Utility Weights by Age

Age | Utility | Age | Utility | Age | Utility
40 | 0.888522 | 60 | 0.835435 | 80 | 0.763673
41 | 0.885463 | 61 | 0.833031 | 81 | 0.759805
42 | 0.882405 | 62 | 0.830623 | 82 | 0.755897
43 | 0.879346 | 63 | 0.828212 | 83 | 0.751944
44 | 0.876288 | 64 | 0.825797 | 84 | 0.747941
45 | 0.873460 | 65 | 0.822419 | 85 | 0.743880
46 | 0.870845 | 66 | 0.818415 | 86 | 0.739750
47 | 0.868229 | 67 | 0.814408 | 87 | 0.735546
48 | 0.865613 | 68 | 0.810398 | 88 | 0.731258
49 | 0.862996 | 69 | 0.806386 | 89 | 0.726879
50 | 0.860377 | 70 | 0.802370 | 90 | 0.722403
51 | 0.857758 | 71 | 0.798351 | 91 | 0.717824
52 | 0.855138 | 72 | 0.794328 | 92 | 0.713137
53 | 0.852516 | 73 | 0.790300 | 93 | 0.708341
54 | 0.849893 | 74 | 0.786267 | 94 | 0.703433
55 | 0.847402 | 75 | 0.782535 | 95 | 0.698415
56 | 0.845015 | 76 | 0.778817 | 96 | 0.693291
57 | 0.842624 | 77 | 0.775075 | 97 | 0.688068
58 | 0.840231 | 78 | 0.771305 | 98 | 0.682755
59 | 0.837835 | 79 | 0.767506 | 99 | 0.677363

Appendix Table 3.2 Assumptions for Utility Losses Associated With Each Screening Test

Test type | Utility loss when abnormal | Utility loss when normal
FIT | 0.001330 | 0.000063
sDNA-FIT | 0.001394 | 0.000127
HSgFOBT | 0.001330 | 0.000063
SIG | 0.001415 | 0.000147
CTC | 0.001559 | 0.000292
COL with adenoma polypectomy | 0.001401
COL without adenoma polypectomy | 0.000496
COL for symptomatic cancer diagnosis | 0.001401

COL – colonoscopy; CTC – computed tomography colonography; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; HSgFOBT – high sensitivity guaiac-based fecal occult blood test; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); SIG – sigmoidoscopy

Appendix Table 3.3 Assumptions for Utility Losses Associated With Complications

Complications | Utility loss | Rationale [expert opinion]
Fatal perforation | 0 | Patient dies
Serious gastrointestinal event | 0.005479 | 4 days at 0.5 utility
Other gastrointestinal event | 0.002740 | 2 days at 0.5 utility
Cardiovascular event | 0.004795 | 3.5 days at 0.5 utility

Appendix Table 3.4 Utility Losses Associated With Cancer Care by Stage at Diagnosis and Phase of Care

Phase of cancer care | Utility loss [source: Ness et al.^151^]
Phase of cancer care | Stage I | Stage II | Stage III | Stage IV
Initial phase | 0.12 | 0.18 | 0.24 | 0.70
Continuing phase | 0.05 | 0.05 | 0.24 | 0.70
Terminal phase, death CRC | 0.70 | 0.70 | 0.70 | 0.70
Terminal phase, death other causes | 0.05 | 0.05 | 0.24 | 0.70

CRC – colorectal cancer

Appendix Table 3.5 Time Spent on Colonoscopy, Based on Jonas et al^91^

Colonoscopy component | Patient time (in hours) | Assumptions
Bowel preparation | 16.70
Travel to | 0.42
Waiting/preparing | 1.40
Sedation | 0.20 | Assume always used
Procedure | 0.33
Onsite recovery | 0.78
Travel home | 0.58
Recovery to routine | 15.80
Total | 36.22

Appendix Table 3.6 Time Spent on Computed Tomography Colonography (CTC)

CTC component | Patient time (in hours) | Assumptions
Bowel preparation | 16.70 | Same as colonoscopy
Travel to | 0.42 | Same as colonoscopy
Waiting/preparing | 1.40 | Same as colonoscopy
Sedation | 0.00 | No sedation
Procedure | 0.25 | 75% of colonoscopy (generally ~15 min^152^)
Onsite recovery | 0.00 | No on-site recovery
Travel home | 0.58 | Same as colonoscopy
Recovery to routine | 0.00 | Immediately back to routine
Total | 19.35

Appendix Table 3.7 Time Spent on Sigmoidoscopy Without Sedation

Sigmoidoscopy component | Patient time (in hours) | Assumptions
Bowel preparation | 1.50 | 2 hrs. according to Capital Digestive Group,^153^ 1 h according to Forest Canyon Endoscopy^154^
Travel to | 0.42 | Same as colonoscopy
Waiting/preparing | 0.70 | 50% of colonoscopy
Sedation | 0.00 | No sedation
Procedure | 0.33 | 20 minutes according to Walter Reed’s info
Onsite recovery | 0.39 | 50% of colonoscopy, due to no sedation
Travel home | 0.58 | Same as colonoscopy
Recovery to routine | 3.95 | 25% of colonoscopy, due to no sedation
Total | 7.88

Appendix Table 3.8 Time Spent on Sigmoidoscopy With Sedation

Sigmoidoscopy component | Patient time (in hours) | Assumptions
Bowel preparation | 1.50 | 2 hrs. according to Capital Digestive Group,^153^ 1 h according to Forest Canyon Endoscopy^154^
Travel to | 0.42 | Same as colonoscopy
Waiting/preparing | 1.40 | Same as colonoscopy
Sedation | 0.20 | Same as colonoscopy
Procedure | 0.33 | 20 minutes according to Walter Reed’s info
Onsite recovery | 0.78 | Same as colonoscopy, due to sedation
Travel home | 0.58 | Same as colonoscopy
Recovery to routine | 15.80 | Same as colonoscopy
Total | 21.02

Appendix Table 3.9 Time Spent on Sigmoidoscopy, Averaged Over Procedures With and Without Sedation

Sigmoidoscopy component | Patient time (in hours)
Bowel preparation | 1.50
Travel to | 0.42
Waiting/preparing | 0.85
Sedation | 0.04
Procedure | 0.33
Onsite recovery | 0.48
Travel home | 0.58
Recovery to routine | 6.56
Total | 10.77

Appendix Table 3.10 Assumptions for Utility Losses Associated With the Screening Tests Themselves

Screening modality | Disutility | Source | Time the disutility applies in hours^*^ | Utility loss per event
Colonoscopy (regardless of type) | 0.12 | Swan et al.^92^ | 36.22 | 0.000496
CTC | 0.12 | Same as colonoscopy | 19.4 | 0.000265
SIG | 0.12 | Same as colonoscopy | 10.8 | 0.000147
FIT | 0 | Expert opinion | -- | 0
sDNA-FIT | 0 | Expert opinion | -- | 0
HSgFOBT | 0 | Expert opinion | -- | 0

COL – colonoscopy; CTC – computed tomography colonography; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; HSgFOBT – high sensitivity guaiac-based fecal occult blood test; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); SIG – sigmoidoscopy

* See Appendix Tables 3.5–3.9.

Appendix Table 3.11 Assumptions for Utility Losses Associated With Waiting for the Test Result

Screening modality | Disutility | Source | Time the disutility applies in days^*^ | Utility loss per event
COL without polypectomy | 0 | Immediate results | 0 | 0
COL with polypectomy | 0.033036 | Expert opinion, same as waiting for follow-up COL after a positive FIT | 10 | 0.000905
SIG | 0 | Immediate results (no biopsy or polypectomy) | 0 | 0
CTC | 0.003304 | Expert opinion, 10% of waiting for a follow-up COL after a positive FIT | 3 | 0.000027
FIT | 0.003304 | Expert opinion, 10% of waiting for a follow-up COL after a positive FIT | 7 | 0.000063
sDNA-FIT | 0.003304 | Expert opinion, 10% of waiting for a follow-up COL after a positive FIT | 14 | 0.000127
HSgFOBT | 0.003304 | Expert opinion, 10% of waiting for a follow-up COL after a positive FIT | 7 | 0.000063

COL – colonoscopy; CTC – computed tomography colonography; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; HSgFOBT – high sensitivity guaiac-based fecal occult blood test; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); SIG – sigmoidoscopy

* Time estimates are based on expert opinion.

Appendix Table 3.12 Assumptions for Utility Losses Associated With Waiting for a Follow-Up Colonoscopy

Screening modality | Disutility | Source | Time the disutility applies in days^*^ | Utility loss per event
CTC | 0.033036 | 12.5% are very worried.^150^ Assuming they experience half of the utility decrement as for a positive mammography as reported by Mandelblatt^90^ | 14 | 0.001267
SIG | 0.033036 | 12.5% are very worried.^150^ Assuming they experience half of the utility decrement as for a positive mammography as reported by Mandelblatt^90^ | 14 | 0.001267
FIT | 0.033036 | 12.5% are very worried.^150^ Assuming they experience half of the utility decrement as for a positive mammography as reported by Mandelblatt^90^ | 14 | 0.001267
sDNA-FIT | 0.033036 | 12.5% are very worried.^150^ Assuming they experience half of the utility decrement as for a positive mammography as reported by Mandelblatt^90^ | 14 | 0.001267
HSgFOBT | 0.033036 | 12.5% are very worried.^150^ Assuming they experience half of the utility decrement as for a positive mammography as reported by Mandelblatt^90^ | 14 | 0.001267

COL – colonoscopy; CTC – computed tomography colonography; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; HSgFOBT – high sensitivity guaiac-based fecal occult blood test; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); SIG – sigmoidoscopy

* Time estimates are based on expert opinion.