# Appendix 2 Additional Information on Test Characteristics

As noted in the section “Model Input Parameters”, test characteristics are based primarily on estimates from a systematic evidence review conducted by Lin et al.^17^ for the USPSTF. Below we provide additional information on the inputs for each screening modality.

## Colonoscopy

The EPC identified no new studies reporting test performance characteristics for colonoscopy.^17^ We therefore used the same test characteristics as in the 2016 decision analysis^16^ (Table 7); per-lesion colonoscopy sensitivity for adenomas by size category was based on a meta-analysis of tandem colonoscopy studies.^142^ Test specificity was based a screening study of colonoscopy in the Boston University catchment area.^141^

## Sigmoidoscopy

The EPC found no studies evaluating the test performance of sigmoidoscopy.^17^ As in the 2016 decision analysis,^16^ we assumed that sigmoidoscopy had the same sensitivity as colonoscopy within the reach of the endoscope (Table 7). We assumed that neither biopsies nor polypectomy would be performed during sigmoidoscopy and that persons with any lesion visualized at sigmoidoscopy were deemed positive and referred for follow-up colonoscopy. This is similar to the sigmoidoscopy approach used in the Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial in which biopsy and polypectomy were not routinely performed.^143^ Test specificity was based on data from the PLCO Trial.^143^

## CTC

The systematic evidence review reported pooled estimates of the per-person sensitivity and specificity of CTC for adenomas by size (adenomas ≥10 mm; adenomas ≥6 mm). However, the models require lesion-based sensitivity separately for adenomas 6 to <10 mm and for adenomas ≥10 mm. We therefore used the same test characteristics as in the 2016 decision analysis, which were based on test performance data from the American College of Radiology Imaging Network National CT Colonography Trial.^144^ (Table 7).

## Stool Tests

The EPC provided pooled estimates of the per-person test sensitivity and specificity for each of the 3 stool tests (FIT, sDNA-FIT, HSgFOBT).^17^ We assumed that sensitivity for adenomas ≥10 mm was equal to the sensitivity for advanced adenomas, a category that includes any adenoma ≥10 mm in size, an adenoma containing high-grade dysplasia or villous histology, and, depending on the study, sessile serrated lesions. Similarly, we assumed that the sensitivity for 1 to <10 mm adenomas was equal to the sensitivity for non-advanced adenomas. In all models, specificity is for any adenoma or cancer.

All 3 models made adjustments to the pooled person-based sensitivity estimates from the EPC. SimCRC and MISCAN derived lesion-based sensitivities that match the pooled person-based sensitivity estimates. Doing so allowed the probability of a positive test to increase with the number of adenomas a person has. For preclinical cancers and for adenomas ≥10 mm, SimCRC and MISCAN simulated stool tests (and follow-up colonoscopies) under different values for lesion-based sensitivity for the size category of interest to identify the value at which the person-based sensitivity generated by the model matched the corresponding person-based sensitivity from the EPC’s pooled analysis. These models assumed that 1 to <6 mm adenomas do not bleed, which implies that the sensitivity of the stool tests for adenomas of this size is 0 (individuals with 1 to <6 mm adenomas are allowed to have a positive test via the sensitivity for co-occurring adenomas ≥6 mm, or by the test’s false-positive rate). They then derived the person-based sensitivity for a 6 to <10 mm adenoma such that the person-based sensitivity for lesions 1 to <10 mm was equal to the pooled person-based sensitivity for 1 to <10 mm adenomas from the EPC. The resulting lesion-based sensitivity estimates are in Appendix Table 2.1.

CRC-SPIN applied person-based sensitivity estimates. Unlike SimCRC and MISCAN, CRC-SPIN allows 1 to <6 mm adenomas to bleed, assuming that the overall sensitivity for persons with these adenomas as the most-advanced finding is 1 to 2 percentage points higher than the test’s false positive rate. CRC-SPIN then determined the sensitivity for persons with 6 to <10 mm adenomas as the most advanced finding such that the weighted-average sensitivity for 1 to <6 mm adenomas and 6 to <10 mm adenomas was equal to that of 1 to <10 mm adenomas, with weights based on CRC-SPIN’s underlying distribution of the size of the most advanced adenoma across these categories. The resulting person-based sensitivity estimates are in Appendix Table 2.2.

Additional information for each of the 3 stool tests is provided below.

[underlined: FIT]: Test characteristics for FIT are for the OC-Sensor family of FITs at a cutoff of 20 µg of hemoglobin per g of feces.

[underlined: sDNA-FIT]: Test characteristics for sDNA-FIT are for Cologuard.

[underlined: HSgFOBT]: Test characteristics for HSgFOBT are for Hemoccult SENSA. As noted in the section “Model input parameters”, there is considerable uncertainty in test performance characteristics for Hemoccult SENSA and therefore in model outcomes for strategies using this modality. Decisions about this test should not be informed by the models. We include model findings for HSgFOBT strategies in Appendix 4, rather than with the main results.

Appendix Table 2.1 Per-Lesion Test Sensitivity for Stool Tests Used in the SimCRC and MISCAN Models

Model/stool test | Per-lesion sensitivity^*^
Model/stool test | Adenoma 1 to <6 mm^†^ | Adenoma 6 to <10 mm | Adenoma ≥10 mm | Preclinical colorectal cancer^‡^
SimCRC
HSgFOBT | 0 | 0.035 | 0.061 | 0.658
FIT | 0 | 0.060 | 0.161 | 0.710
sDNA-FIT | 0 | 0.103 | 0.307 | 0.922
MISCAN
HSgFOBT | 0 | 0.056 | 0.056 | 0.569 / 0.860
FIT | 0 | 0.113 | 0.147 | 0.630 / 0.888
sDNA-FIT | 0 | 0.183 | 0.295 | 0.895 / 0.975

FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; HSgFOBT – high sensitivity guaiac-based fecal occult blood test; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test)

* Estimates were derived by calibrating to the person-based sensitivities in Table 7.

† SimCRC and MISCAN assume 1 to <6 mm adenomas do not bleed and therefore cannot cause a positive stool test.

‡ For SimCRC, the value is the sensitivity for any preclinical cancer. For MISCAN, the first value is the sensitivity for a preclinical cancer while at an earlier stage than it would have been diagnosed in the absence of screening, and the second value is the sensitivity at the stage it would have been diagnosed in the absence of screening.

Appendix Table 2.2 Per-Person Test Sensitivity for Stool Tests Used in the CRC-SPIN Model

Stool test | Per-person sensitivity^*^
Stool test | Adenoma 1 to <6 mm^†^ | Adenoma 6 to <10 mm | Adenoma ≥10 mm | Preclinical colorectal cancer^‡^
HSgFOBT | 0.04 | 0.09 | 0.11 | 0.68
FIT | 0.05 | 0.15 | 0.22 | 0.74
sDNA-FIT | 0.11 | 0.31 | 0.42 | 0.94

FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; HSgFOBT – high sensitivity guaiac-based fecal occult blood test; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test)

* Estimates were derived by calibrating model outcomes to the per-person sensitivities given in Table 7.

† CRC-SPIN assumes that the overall sensitivity for detecting persons with at most 1 to <6 mm adenoma(s) is 1 (HSgFOBT) to 2 (FIT, sDNA-FIT) percentage points higher than the false-positive rate of the test.