# Appendix 17 Comparison of CISNET Decision Analyses of Colorectal Cancer Screening for the USPSTF and ACS

Appendix Table 17.1 Summary of Differences Between Base-Case Analyses for the 2021 Decision Analysis for the USPSTF and for the 2018 Decision Analyses for the ACS^27,28^

Characteristics | 2021 USPSTF analysis | 2018 ACS analysis I^22^ | 2018 ACS analysis II^23^
Simulation models | MISCAN, SimCRC and CRC-SPIN | MISCAN | MISCAN and SimCRC
Cohort of interest | All 40-year-old adults at average risk of CRC | All 40-year-old adults at average risk of CRC | Race- and sex-specific 40-year-old adults at average risk of CRC
US life table (for other-cause mortality rates) | 2017 | 2013 | 2013
CRC incidence | Models calibrated to incidence rate ratio from SEER for 20- to 44-year-olds in 2012-2016 vs 1975-1979 (IRR = 1.19) | Models calibrated to results from age-period-cohort modeling (IRR = 1.59) | 1. Models calibrated to race- and sex-specific incidence in SEER 1975-1979 (SimCRC) and SEER 1990-1994 (MISCAN); 2. Race- and sex-specific results from age-period-cohort modeling
CRC localization | Models calibrated to localization in SEER 1975-1979 | Models calibrated to localization in SEER 1975 birth cohort | 1. Models calibrated to same sources as CRC risk; 2. Models calibrated to localization in SEER 1975 birth cohort
Evaluated screening modalities | Single, hybrid and once-only test strategies | Single test strategies only | Single test strategies only
Age to begin screening (y) | 45, 50, 55 | 40, 45, 50 | 45, 50, 55
Age to end screening (y) | 70, 75, 80, 85 | 75, 80, 85 | 75, 80, 85
Selection of model-recommendable strategies (Yes/No) | No | Yes | Yes